# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as a hundredfold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop E-29, Atlanta, Georgia 30333.

## Atrazine Acute Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | Atrazine
CAS Number: | 1912–24-9
Date: | September 2003
Profile Status: | Draft 3 Post-Public
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 23
Species: | Rabbit

[underlined: Minimal Risk Level]: 0.01 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Infurna R, Levy B, Meng C, 1988. Teratological evaluations of atrazine technical, atrazine herbicide, in rats and rabbits. J Toxicol Environ Health 24:307–319.3398074

[underlined: Experimental design]: Groups of 19 female New Zealand White rabbits were artificially inseminated (gestation day 0) and administered 0, 1, 5, or 75 mg/kg/day atrazine (Aatrex) in 3% aqueous corn starch containing 0.5% Tween 80 by gavage on gestational days 7–19. Rabbits were observed twice daily for changes in appearance and behavior. Feed consumption and body weight changes were monitored throughout gestation. Dams were necropsied on gestational day 29. Ovaries were examined, corpora lutea were counted, uteri and contents were weighed, live fetuses and resorptions were counted, and liver weights were recorded. Fetuses were weighed, sexed, and examined for external, visceral, skeletal, and soft tissue abnormalities.

[underlined: Effects noted in study and corresponding doses]: Clinical signs related to treatment were increased incidence of stool variations (little, no, or soft stool) and bloody vulva. Absolute, but not relative, liver weight was decreased in the 75 mg/kg/day group. Food consumption and body weight gain were severely reduced during the treatment period in the high dose group, but rebounded after cessation of treatment; however, overall body weight gain corrected for weight of the uterus, placentas, and fetuses was significantly reduced. Slight, but statistically significant, reductions in food consumption and body weight gain were noted in the 5 mg/kg/day group.

[underlined: Dose and end point used for MRL derivation]:

[ X ] NOAEL [ ] LOAEL 1 mg/kg/day in pregnant rabbits, decreased body weight gain at ≥5 mg/kg/day

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ X ] 10 for extrapolation from animals to humans
- [ X ] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? If so, explain: None needed.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: N/A

[underlined: Other additional studies or pertinent information which lend support to this MRL]: The MRL is supported by a number of studies showing decreased body weight gain in rats (Cantemir et al. 1997; Cooper et al. 1996b, 2000; Cummings et al. 2000b; Dési 1983; Eldridge et al. 1994a, 1999a; EPA 1984f, 1987d, 1987e; Infurna et al. 1988; Kniewald et al. 2000; Pinter et al. 1990; Santa Maria et al. 1987; Šimić et al. 1994; Suschetet et al. 1974; Tennant et al. 1994b; Ugazio et al. 1991a; Vos et al. 1983; Wetzel et al. 1994) and dogs (EPA 1987f). Other effects noted in rabbits in the Infurna et al. (1988) study occurred only in the high-dose group (75 mg/kg/day) and included increased incidence of stool variations (little, no, or soft stool), bloody vulva, absolute, but not relative, liver weight decrease, and severely reduced food consumption and body weight gain. Slight, but statistically significant, decreases in body weight gain occurred in the 5 mg/kg/day group. Other NOAELs and LOAELs for acute-duration exposures include: a NOAEL of 12.5 mg/kg/day for increased inflammation of the lateral prostate in adult male offspring of atrazine-treated rat dams (Stoker et al. 1999); a NOAEL of 5 mg/kg/day for increased resorptions/litter and decreased live fetuses/litter in rabbits exposed on gestational days 7–19 (Infurna et al. 1988); and a NOAEL of 1 mg/kg/day for developmental effects (decreased fetal body weight; increased incidence of nonossification of foot bones and patellae) in offspring of treated rabbit dams (Infurna et al. 1988); and a NOAEL of 10 mg/kg/day for developmental effects (incomplete ossification of skull, hyoid bone, teeth, forepaw metacarpals, and hindpaw distal phalanges) in rat offspring of dams exposed to 70 mg/kg/day (Infurna et al. 1988). The developmental effects were attributed to severe maternal toxicity related to severe decreases in food intake and body weight. Changes in serum and pituitary hormone levels have been seen at exposures of ≥50 mg/kg/day (Cooper et al. 2000; Stoker et al. 1999).

[underlined: Agency Contact (Chemical Manager)]: Alfred S. Dorsey Jr., DVM

## Atrazine Intermediate Oral

MINIMAL RISK LEVEL WORKSHEET

Chemical Name: | Atrazine
CAS Number: | 1912–24-9
Date: | September 2003
Profile Status: | Draft 3 Post-Public
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 74
Species: | Pig

[underlined: Minimal Risk Level]: 0.003 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Gojmerac T, Uremovic M, Uremovic S, 1999. Reproduction disturbance caused by an s-triazine herbicide in pigs. Acta Veterinaria Hungarica 47(1):129–135.10213938

[underlined: Experimental design]: Groups of nine female Swedish Landrace/Large Yorkshire cross pigs (6–7-month-old gilts) were administered 0 or 1 mg/kg/day atrazine in the feed for 19 days beginning with the onset of estrus (day 0). Blood samples were drawn 3 times daily at 3-hour intervals on the 5 days immediately following the final day of atrazine administration (this corresponded to the expected day of the next estrus [day 0] and 2 days before [days −1 and −2] and 2 days [days 1 and 2] after the expected estrus). Serum 17β-estradiol (E_2_) concentrations in the blood samples were determined. Histopathological examination of the uterus was performed.

[underlined: Effects noted in study and corresponding doses]: E_2_ concentrations were statistically significantly different (p<0.001) from controls on all 5 days measured. In controls, E_2_ concentrations were high on days −2 and −1, then dropped on day 0 (beginning of estrus) and remained low on days 1 and 2. In treated animals, E_2_ concentrations were lower than controls on days −2 and −1, and higher than controls on days 0 through 2. Treated pigs failed to exhibit overt signs of estrus onset and uterine histopathology indicated a state of uterine rest (diestrus) at the end of the observation period. A slight, but steady increase of E_2_ hormone level was seen in the treated animals on day 24 of the estrus cycle (day 2). The study authors suggested that the balance of the E_2_ hormone level was being gradually restored, which is the pattern that would be anticipated if the animals were about to go into estrus.

[underlined: Dose and end point used for MRL derivation]:

[ ] NOAEL [ X ] LOAEL 1 mg/kg/day in pigs, delayed onset of estrus

[underlined: Uncertainty Factors used in MRL derivation]:

- [ X ] 10 for use of a LOAEL
- [ X ] 10 for extrapolation from animals to humans
- [ X ] 3 for human variability

An uncertainty factor of 3 for human variability was used instead of 10 because the critical effect was identified in a sensitive population (young, developing female pigs).

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]? If so, explain: N/A

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]: N/A

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Other systemic and reproductive effects have been observed in animals exposed to atrazine for 15–365 days. Decreased body weight gain was seen in rats at LOAELs of 2.7 mg/kg/day and above (Cantemir et al. 1997; Cooper et al. 1996b, 2000; Dési 1983; Eldridge et al. 1994a, 1999a; Kniewald et al. 2000; Laws et al. 2000; Suschetet et al. 1974; Trentacoste et al. 2001; Wetzel et al. 1994). Endocrine gland weights and serum and pituitary gland hormone levels were altered in rats at LOAELs as low as 6.9 mg/kg/day for 1 month (Cooper et al. 1996b, 2000; Eldridge et al. 1994a; Friedmann 2002; Laws et al. 2000; Trentacoste et al. 2001; Wetzel et al. 1994). Disrupted estrus cyclicity was seen in rats at the lowest LOAEL of 6.9 mg/kg/day (Wetzel et al. 1994). Other NOAELs and LOAELs observed included: a LOAEL of 50 mg/kg/day (NOAEL of 5 mg/kg/day) for increased relative liver weights in Sprague-Dawley and Donryu rats (Aso et al. 2000); a LOAEL of 2 mg/kg/day for degeneration of a small number of myocardial fibers, mild degeneration and inflammation and mild chronic interstitial hepatitis and subacute glomerulitis, degeneration and desquamation of proximal tubules, a 350% increase in serum gamma-glutamyl-transferase, and mild liver histological changes in pigs (Ćurić et al. 1999; Gojmerac et al. 1995); a LOAEL of 33 mg/kg/day (NOAEL of 4.6 mg/kg/day) for abnormal estrus cycle in Sprague-Dawley rats (Eldridge et al. 1999a); and a LOAEL of 2 mg/kg/day for ovarian histopathology, disrupted estrogen and progesterone levels, and delayed onset of estrus (Gojmerac et al. 1996), and ovarian cysts and disruption of estrus cyclicity (Ćurić et al. 1999).

[underlined: Agency Contact (Chemical Manager)]: Alfred S. Dorsey Jr., DVM