# 9 REFERENCES

*Cited in text

*Aberle DR, Gamsu G, Ray CS, . 1988a. Asbestos-related pleural and parenchymal fibrosis: Detection with high-resolution CT. Radiology 166:729–734.3340770
*Aberle DR, Gamsu G, Ray CS. 1988b. High-resolution CT of benign asbestos-related diseases: Clinical and radiographic correlation. Am J Radiol 151:883–891.
*Abidi P, Afaq F, Arif JM, . 1999. Chrysotile-mediated imbalance in the glutathione redox system in the development of pulmonary injury. Toxicol Lett 106:31–39.10378448
ACGIH. 1986. Documentation of the threshold limit values and biological exposure indices. 5th ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1991. Documentation of the threshold limit values and biological exposure indices 6th ed American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1992. 1992-1993 Threshold limit values for chemical substances in the work environment. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
ACGIH. 1993. 1993-1994 Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 1998. Documentation of the threshold limit values and biological exposure indices. 6th Ed. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*ACGIH. 2000. 2000 TLVs and BEIs. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists. Cincinnati, OH.
*Acheson ED, Gardner MJ, Pippard EC, . 1982. Mortality of two groups of women who manufactured gas masks from chrysotile and crocidolite asbestos: A 40-year follow-up. Br J Ind Med 39:344–348.6291580
Adachi S, Kawamura K, Kimura K, . 1992b. Tumor incidence was not related to the thickness of visceral pleural in female Syrian hamsters intratracheally administered amphibole asbestos or manmade fibers. Environ Res 58:55–65.1317792
*Adachi S, Kawamura K, Yoshida S, . 1992a. Oxidative damage on DNA induced by asbestos and man-made fibers in vitro. Int Arch Occup Environ Health 63:553–557.1587631
Adachi S, Yoshida S, Kawamura K, . 1994. Inductions of oxidative DNA damage and mesothelioma by crocidolite, with special reference to the presence of iron inside and outside of asbestos fiber. Carcinogenesis 15(4):753–758.8149491
Adamson IYR. 1997. Early mesothelial cell proliferation after asbestos exposure: In vivo and in vitro studies. Environ Health Perspect Suppl 5:1205–1208.9400724
*Adamson IY, Bowden DH. 1987a. Response of mouse lung to crocidolite asbestos. 1. Minimal fibrotic reaction to short fibres. J Pathol 152:99–107.3040953
*Adamson IY, Bowden DH. 1987b. Response of mouse lung to crocidolite asbestos. 2. Pulmonary fibrosis after long fibres. J Pathol 152:109–117.3040951
Adamson IYR, Bowden DH. 1990. Pulmonary reaction to long and short asbestos fibers is independent of fibroblast growth factor production by alveolar macrophages. Am J Pathol 137:523–529 2399932
Addison J, Browne K, Davis JM, . 1993. Asbestos fibers in parenteral medication. Regul Toxicol Pharmacol 18(3):371–380.8127999
*ADEQ. 2001. List of HAPs research compounds. Arizona Department of Environmental Quality. Http://www.adeq.state.az.us/comm/download/air.html. January 19,2001.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
*Afaq F, Abidi P, Matin R, . 1998. Activation of alveolar macrophages and peripheral red blood cells in rats exposed to fibers/particles. Toxicol Lett 99:175–182.9862283
Ahmad I, Krishnamurthi K, Arif JM, . 1995. Augmentation of chrysotile-induced oxidative stress by BHA in mice lungs. Food Chem Toxicol 33:209–215.7896231
Ahrens W, Joeckel K-H, Patzak W, . 1991. Alcohol smoking and occupational factors in cancer of the larynx: A case-control study. Am J Ind Med 20(4):477–493.1785612
Aisner J. 1989. Therapeutic approach to malignant mesothelioma. Chest 96(Suppl 1):95S–97S 2661172
*Akira M, Yokoyama K, Yamamoto S, . 1991. Early asbestosis: Evaluation with high resolution CT. Thoracic Radiology 409–416.
Albin M, Engholm G, Hallin N, . 1998. Impact of exposure to insulation wool on lung function and cough in Swedish construction workers. Occup Environ Med 55:661–667.9930086
*Albin M, Horstmann V, Jakobsson K, . 1996. Survival in cohorts of asbestos cement workers and controls. Occup Environ Med 53:87–93.8777456
*Albin M, Jakobsson K, Attewell R, . 1990a. Mortality and cancer morbidity in cohorts of asbestos cement workers and referents. Br J Ind Med 47:602–610.2207031
*Albin M, Johansson L, Pooley FD, . 1990b. Mineral fibres, fibrosis, and asbestos bodies in lung tissue from deceased asbestos cement workers. Br J Ind Med 47:767–774.2173948
*Albin M, Pooley FD, Stromberg U, . 1994. Retention patterns of asbestos fibres in lung tissue among asbestos cement workers. Occup Environ Med 51:205–211.8130851
*Alden HS, Howell WM. 1944. The asbestos corn. Archives of Dermatology and Syphilology 49:312–314.
Alderisio M, Giovagnoli MR, Cenci M, . 1996. Asbestos bodies in the sputum of workers exposed to environmental pollution. Anticancer Res 16:2965–2968.8917414
Al Jarad N, Carroll MP, Laroche C, . 1994. Respiratory muscle function in patients with asbestos-related pleural disease. Resp Med 88:115–120.
*Al Jarad N, Macey M, Uthayakumar S, . 1992. Lymphocyte subsets in subjects exposed to asbestos: Changes in circulating natural killer cells. Br J Ind Med 49(11) 811–814.1463684
Al Jarad N, Poulakis N, Pearson MC, . 1991. Assessment of asbestos-induced pleural disease by computer tomography - correlation with chest radiograph and lung function. Resp Med 85:203–208.
*Al Jarad N, Strickland B, Bothamley G, . 1993. Diagnosis of asbestosis by a time expanded wave form analysis, auscultation and high resolution computed tomography: A comparative study. Thorax 48(4)347–353.8511731
*Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III, 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Amandus HE, Wheeler R. 1987. The morbidity and mortality of vermiculite miners and millers exposed to tremolite-actimolite: Part II. Mortality. Am J Med 11:15–26.
*Amandus HE, Althouse R, Morgan WKC, . 1987. The morbidity and mortality of vermiculite miners and millers exposed to tremolite-actinolite: Part III. Radiographic findings. Am J Ind Med 11:27–37.3028137
*American Thoracic Society. 1986. The diagnosis of nonmalignant diseases related to asbestos. Am Rev Resp Dis 134:363–368.3740660
*American Thoracic Society. 1990. Health effects of tremolite. Am Rev Respir Dis 142(6):1453–1458.2252267
*Andersen A, Glattre E, Johansen BV. 1993. Incidence of cancer among lighthouse keepers exposed to asbestos in drinking water. Am J Epidemiol 138(9):682–687.8237983
*Andersen ME, Kirshnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ 3rd, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
*Anderson HA, Lilis R, Daum SM, . 1976. Household-contact asbestos neoplastic risk. Ann NY Acad Sci 271:311–323.1069520
*Anderson HA, Lilis R, Daum SM, . 1979. Asbestosis among household contacts of asbestos factory workers. Ann NY Acad Sci 271:387–399.
Andersson E, Toren K. 1995. Pleural mesotheliomas are underreported as occupational cancer in Sweden. Am J Ind Med 27:577–580.7793428
*Andrion A, Bosia S, Paoletti L, . 1994. Malignant peritoneal mesothelioma in a 17-year-old boy with evidence of previous exposure to chrysotile and tremolite asbestos. Hum Pathol 25(6):617–622.8013954
Anjilvel S, Asgharian B. 1995. A multiple-path model of particle deposition in the rat lung. Fundam Appl Toxicol 28:41–50.8566482
Anonymous. 1997. Asbestos, asbestosis, and cancer: The Helsinki criteria for diagnosis and attribution. Scand J Work Environ Health 23:311–316.9322824
*Anonymous. 2000. The WTO speaks: Chrysotile is bad for you! British Asbestos Newsletter. Issue 39. Http://www.1kaz.demon.co.uk/ban39.htm. April 19, 2001.
*Anton-Culver H, Culver BD, Kurosaki T. 1988. Immune response in shipyard workers with x-ray abnormalities consistent with asbestos exposure. Br J Ind Med 45:464–468.3260800
*Anton-Culver H, Culver BD, Kurosaki T. 1989. An epidemiologic study of asbestos-related chest x-ray changes to identify work areas of high risk in a shipyard population. Appl Ind Hyg 4:110–118.
Anttila S, Luostarinen L, Hirvonen A, . 1995. Pulmonary expression of glutathione S-transferase M3 in lung cancer patients: Association with GSTM1 polymorphism, smoking, and asbestos exposure. Cancer Res 55:3305–3309.7614465
Apostolou S, De Rienzo A, Murthy SS, . 1999. Absence of BCL10 mutations in human malignant mesothelioma. Cell 97:684–686.10380921
Appel JD, Fasy TM, Kohtz JD, . 1988. Asbestos fibers mediate transformation of monkey cells by exogenous plasmid DNA. Proc Natl Acad Sci USA 85:7670–7674.2845418
Arden MG, Adamson IYR. 1992. Collagen synthesis and degradation during the development of asbestos-induced pulmonary fibrosis. Exp Lung Res 18:9–20.1572328
Arenas-Huertero FJ, Salazar-Flores M, Osornio-Vargas AR. 1994. Ferruginous bodies as markers of environmental exposure to inorganic particles: Experience with 270 autopsy cases in Mexico. Environ Res 64:10–17.8287838
Arif JM, Khan SG, Ahmad I, . 1997. Effect of kerosene and its soot on the chrysotile-mediated toxicity to the rat alveolar macrophages. Environ Res 72:151–161.9177657
Arif JM, Khan SG, Aslam M, . 1992. Diminution in kerosene-mediated induction of drug metabolizing enzymes by asbestos in rat lungs. Pharmacol Toxicol 71:37–40.1326107
Arif JM, Khan SG, Mahmood N, . 1994. Effect of coexposure to asbestos and kerosene soot on pulmonary drug-metabolizing enzyme system. Environ Health Perspect Suppl 102:181–183.
*Armstrong BK, DeKlerk NH, Musk AW, . 1988. Mortality in miners and millers of crocidolite in Western Australia. Br J Ind Med 45:5–13.2829959
Ascoli V, Facciolo F, Rahimi S, . 1996. Concomitant malignant mesothelioma of the pleura, peritoneum, and tunica vaginalis testis. Diagn Cytopathol 14:243–248.8732655
Ascoli V, Scalxo CC, Facciolo F, . 1996. Malignant mesothelioma in Rome, Italy 1980-1995. A retrospective study of 79 patients. Tumori 82:526–532.9061058
*Asgharian B, Anjilvel S. 1998. A multiple-path model of fiber deposition in the rat lung. Toxicol Sci 44:80–86.9720144
*Asgharian B, Wood R, Schlesinger RB. 1995. Empirical modeling of particle deposition in the alveolar region of the lungs: A basis for interspecies extrapolation. Fundam Appl Toxicol 27:232–238.8529818
Ashcroft T, Heppleston AG. 1973. The optical and electron microscopic determination of pulmonary asbestos fibre concentration and its relation to the human pathological reaction. J Clin Pathol 26:224–234.4573359
*ASTM. 1988. Standard test method for airborne asbestos concentration in workplace atmosphere - method D 4240-83. In: 1988 annual book of ASTM standards. Vol 11.03. Atmospheric analysis, occupational safety and health. Philadelphia, PA: American Society for Testing and Materials, 300–308.
*ATSDR. 1989. Agency for Toxic Substances and Disease Registry. Federal Register 54:37619–37633.
Attanoos RL, Gibbs AR. 1997. Pathology of malignant mesothelioma. Histopathology 30:403–417.9181361
Auerbach O, Conston AS, Garfinkel L, . 1980. Presence of asbestos bodies in organs other than the lung. Chest 77:133–137.7353405
Aufderheide M, Knebel JW, Schulte P. 1996. Differences in the sensitivity of hamster and rat lung cells exposed in vitro to natural and man-made fibres. Exp Toxicol Pathol 48:505–507.8954333
*Ault JG, Cole RW, Jensen CG, . 1995. Behavior of crocidolite asbestos during mitosis in living vertebrate lung epithelial cells. Cancer Res 55:792–798.7850791
*Awadalla FT, Habashi F, Page M. 1990. Reaction of chrysotile asbestos with phosphate ion in relation to toxicity. J Chem Tech Biotechnol 49:183–196.
*Babu KA, Lakkad BC, Nigam SK, . 1980. In vitro cytological and cytogenetic effects of an Indian variety of chrysotile asbestos. Environ Res 21:416–422.7408813
*Baker EL, Dagg T, Greene RE. 1985. Respiratory illness in the construction trades. I. The significance of asbestos-associated pleural disease among sheet metal workers. J Occup Med 27:483–489.4032084
Balmes JR, Daponte A, Cone JE. 1991. Asbestos-related disease in custodial and building maintenance workers from a large municipal school district. Ann NY Acad Sci 540–549.
*Balsara BR, Bell DW, Sonoda G, . 1999. Comparative genomic hybridization and loss of heterozygosity analyses identify a common region of deletion at 15q11.1-15 in human malignant mesothelioma. Cancer Res 59:450–454.9927061
Band PR, Le ND, Fang R, . 1997. Cohort mortality study of pulp and paper mill workers in British Columbia, Canada. Am J Epidemiol 146:186–194.9230781
Barbers RG, Abraham JL. 1989. Asbestosis occurring after brief inhalation exposure: Usefulness of bronchoalveolar lavage in diagnosis. Br J Ind Med 46:106–110.2538140
Barbers RG, Oishi J. 1987. Effects of in vitro asbestos exposure on natural killer and antibody-dependent cellular cytotoxicity. Environ Res 43:217–226.3034562
*Barchowsky A, Roussel RR, Krieser RJ, . 1998. Expression and activity of urokinase and its receptor in endothelial and pulmonary epithelial cells exposed to asbestos. Toxicol Appl Pharmacol 152:388–396.9853007
Baris I, Simonato L, Artivinli M, . 1987. Epidemiological and environmental evidence of the health effects of exposure to erionite fibres: A four-year study in the Cappadocian region of Turkey. Int J Cancer 39:10–17.3025107
*Bariş YI, Artvinli M, Sahin AA, . 1988a. Non-occupational asbestos related chest diseases in a small Anatolian village. Br J Ind Med 45:841–842.3219308
*Baris YI, Bilir N, Artvinli M, . 1988b. An epidemiological study in an Anatolian village environmentally exposed to tremolite asbestos. Brit J Ind Med 45:838–840.2851315
Barnes GD, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
*Barnes PJ. 1997. Nuclear factor-kappa B. Int J Biochem Cell Biol 29:867–870.9304801
Barnhart S, Keogh J, Cullen MR, . 1997. The CARET asbestos-exposed cohort: Baseline characteristics and comparison to other asbestos-exposed cohorts. Am J Ind Med 32:573–581.9358912
Barnhart S, Thornquist M, Omenn GS, . 1990. The degree of roentgenographic parenchymal opacities attributable to smoking among asbestos-exposed subjects. Am Rev Respir Dis 141:1102–1106.2339831
Barrett JC. 1993. Mechanisms of multistep carcinogenesis and carcinogen risk assessment. Environ Health Perspect 100(4):9–20, 109.8354184
*Barrett JC, Lam PW, Wiseman RW. 1989. Multiple mechanisms for the carcinogenic effects of asbestos and other mineral fibers. Environ Health Perspect 81:81–89.2667990
Barrett JC, Thomassen DG, Hesterberg TW. 1983. Role of gene and chromosomal mutations in cell transformation. Ann NY Acad Sci 407:291–300.6349481
Barroetavena MC, Teschke K, Bates DV. 1996. Unrecognized asbestos-induced disease. Am J Ind Med 29:183–185.8821361
Bateman ED, Benatar SR. 1987. Asbestos-induced diseases: Clinical perspectives. Q J Med 62:183–194.3310070
Bayeux MC, Letourneux M, Brochard P, . 1998. Round atelectasis and asbestos: A review of 26 patients. Rev Mal Resp 15:281–286.
Becklake MR. 1976. Asbestos-related disease of the lung and other organs: Their epidemiology and implications for clinical practice. Am Rev Resp Dis 114:187–227.779552
*Becklake MR, Case BW. 1994. Fiber burden and asbestos-related lung disease: Determinants of dose-response relationships. Am J Respir Crit Care Med 150:1488–1492.7952604
Beer TW. 1998. Cancer among spouses: Review of 195 couples. [Letter]. Cancer 83:591–592.9690555
*Begin R, Boileau R, Peloquin S. 1987a. Asbestos exposure, cigarette smoking, and airflow limitation in long-term Canadian chrysotile miners and millers. Am J Ind Med 11:55–66.3028138
Begin R, Cantin A, Masse S. . 1988. Effects of cyclophosphamide treatment in experimental asbestosis. Exp Lung Res 14:823–836.3208722
Begin R, Cantin A, Masse S. 1991. Influence of continued asbestos exposure on the outcome of asbestosis in sheep. Exp Lung Res 17:971–984.1959506
Begin R, Cantin A, Sebastien P. 1990. Chrysotile asbestos exposures can produce an alveolitis with limited fibrosing activity in a subset of high fibre retainer sheep. Eur Respir J 3:81–90.2155816
Begin R, Filion R, Ostiguy G. 1995. Emphysema in silica- and asbestos-exposed workers seeking compensation. Chest 108:647–655.7656611
*Begin R, Martel M, Desmarais Y, . 1986. Fibronectin and procollagen 3 levels in bronchoalveolar lavage of asbestos-exposed human subjects and sheep. Chest 89:237–243.3943384
Begin R, Masse S, Rola-Pleszczynski M, . 1987b. Asbestos exposure dose-bronchoalveolar milieu response in asbestos workers and the sheep model: Evidences of a threshold for chrysotile-induced fibrosis. Drug Chem Toxicol 10:87–107.2824168
Begin R, Ostiguy G, Filion R, . 1992. Recent advances in the early diagnosis of asbestosis. Semin Roentgenol 27:121–139.1609300
Bekkelund SI, Aasebo U, Pierre-Jerome C, . 1998. Magnetic resonance imaging of the thorax in the evaluation of asbestosis. Eur Resp J 11:194–197.
Beland FA, Poirier MC. 1991. Biomarkers of human exposure to carcinogens: An overview. Biomed Environ Sci 4(1–2):69–72.1910602
*Bell DW, Jhanwar SC, Testa JR. 1997. Multiple regions of allelic loss from chromosome arm 6q in malignant mesothelioma. Cancer Res 57:4057–4062.9307293
Belli S, Bruno C, Combat P, . 1998. [Cause-specific mortality of asbestos-cement workers compensated for asbestosis in the city of Bari.] Epidemiol Prev 22:8–11. (Italian).9621499
Bellmann B, Muhle H. 1994. Investigation of the biodurability of wollastonite and xonotlite. Environ Health Perspect Suppl 102:191–195.
*Bellmann B, Muhle H, Kamstrup O, . 1994. Investigation on the durability of man-made vitreous fibers in rat lungs. Environ Health Perspect Suppl 102:185–189.
*Bellmann B, Muhle H, Pott F, . 1987. Persistence of man-made mineral fibres (MMMF) and asbestos in rat lungs. Ann Occup Hyg 31:693–709.2835923
*Berger G. 1994. Epidemiology of endometriosis. In: Modern surgical management of endometriosis. New York: Springer-Verlag.
Berger M, de Hazen M, Nejjari M, . 1993. Radical oxidation reactions of the purine moiety of 2’-deoxyribonucleosides and DNA by iron-containing minerals. Carcinogenesis 14(1):41–46.8425270
Berkow, R, Talbott, JH. 1977. The Merck index of diagnosis and therapy. 13th ed. Rahway, N.J.: Merck & Co., Inc.
Berlin J, Frumkin H. 1988. Exposure to asbestos and the risk of gastrointestinal cancer [Letter]. Br J Ind Med 45:575.
Berman DW, Crump KS. 1989. Relative potency of asbestos fibers of different lengths. Toxicol Pathol 17:841–842.
*Berman DW, Crump KS, Chatfield EJ, . 1995. The sizes, shapes, and mineralogy of asbestos structures that induce lung tumors or mesothelioma in AF/HAN rats following inhalation. (Errata attached). Risk Anal 15:181–195.7597255
Berman J. 1984. Beshada v. Johns-Manville Products Corp.: The function of state of the art evidence in strict products liability. Am J Law Med 10:93–114.6391160
Bermudez E, Everitt J, Walker C. 1990. Expression of growth factor and growth factor receptor RNA in rat pleural mesothelial cells in culture. Exp Cell Res 190:91–98.1974862
Berry G. 1994. Mortality and cancer incidence of workers exposed to chrysotile asbestos in the friction-products industry. Ann Occup Hyg 38:539–546.7978976
Berry G. 1999. Models for mesothelioma incidence following exposure to fibers in terms of timing and duration of exposure and the biopersistence of the fibers. Inhal Toxicol 11:111–130.10380162
*Berry G, Newhouse ML. 1983. Mortality of workers manufacturing friction materials using asbestos. Br J Ind Med 40:1–7.6297532
*Berry G, Gilson JC, Holmes S, . 1979. Asbestosis: A study of dose-response relationships in an asbestos textile factory. Br J Ind Med 36:98–112.465379
*Berry G, Newhouse ML, Antonis P. 1985. Combined effect of asbestos and smoking on mortality from lung cancer and mesothelioma in factory workers. Br J Ind Med 42:12–18.3965010
Berry G, Rogers AJ, Pooley FD. 1989. Mesotheliomas - asbestos exposure and lung burden. IARC Sci Pub 90:486–496.
*Berry M. 1997. Mesothelioma incidence and community asbestos exposure. Environ Res 75:34–40.9356192
Bertrand R, Pezerat H. 1980. Fibrous glass: Carcinogenicity and dimensional characteristics. IARC Sci Publ 30:901–911.
*Berube KA, Quinlan TR, Moulton G, . 1996. Comparative proliferative and histopathologic changes in rat lungs after inhalation of chrysotile or crocidolite asbestos. Toxicol Appl Pharmacol 137:67–74.8607143
Bevan DR, Ulman MR. 1991. Examination of factors that may influence disposition of benzo[a]pyrene in vivo: Vehicles and asbestos. Cancer Lett 57:173–179.2025889
Bianchi AB, Mitsunaga S-I, Cheng JQ, . 1995. High frequency of inactivating mutations in the neurofibromatosis type 2 gene (NF2) in primary malignant mesotheliomas. Proc Natl Acad Sci U S A 92:10854–10858.7479897
Bianchi C, Bittesini L, Brollo A. 1986. Asbestos exposure and Alzheimer disease. Ital J Neurol Sci 7:145–151.3957626
Bianchi C, Brollo A, Ramani L, . 1993a. Asbestos-related mesothelioma in Monfalcone, Italy. Am J Ind Med 24(2):149–160.8213843
Bianchi C, Brollo A, Ramani L, . 1997. Pleural plaques as risk indicators for malignant pleural mesothelioma: A necropsy-based study. Am J Ind Med 32:445–449.9327067
Bianchi C, Brollo A, Zuch C. 1993b. Asbestos-related familial mesothelioma. Eur J Cancer Prev 2(3):247–250.8490544
*Bianchi C, Giarelli L, Grandi G, . 1997. Latency periods in asbestos-related mesothelioma of the pleura. Eur J Cancer Prev 6:162–166.9237066
*Bignon J, Jaurand MC. 1983. Biological in vitro and in vivo responses of chrysotile versus amphiboles. Environ Health Perspect 51:73–80.6315385
*Bignon J, Sebastien P, DiMenza L, . 1979. French mesothelioma registry. Ann NY Acad Sci 330:455–466.294196
*Bisson G, Lamoureuz G, Begin R. 1987. Quantitative gallium 67 lung scan to assess the inflammatory activity in the pneumoconioses. Semin Nucl Med 17:72–80.3547665
*Bissonnette E, Bubois C, Rola-Pleszczynski M. 1989. Changes in lymphocyte function and lung histology during the development of asbestosis and silicosis in the mouse. Res Commun Chem Pathol Pharmacol 65:211–227.2587839
*Bissonnette E, Carre B, Dubois C, . 1990. Inhibition of alveolar macrophage cytotoxicity by asbestos: Possible role of prostaglandins. J Leukoc Biol 47:129–134.2154523
*Blackwell TS, Christman JW. 1997. The role of nuclear factor-kappa B in cytokine gene regulation. Am J Respir Cell Mol Biol 17:3–9.9224203
Blanc P. 1991. Cigarette smoking, asbestos, and parenchymal opacities revisited. Ann NY Acad Sci 133–141.
*Blanc PD, Golden JA, Gamsu G, . 1988. Asbestos exposure-cigarette smoking interactions among shipyard workers. JAMA 259:370–373.3336160
Blot WJ, Harrington JM, Toledo A, . 1978. Lung cancer after employment in shipyards during World War II. N Engl J Med 299:620–624.683235
*BNA. 2001. Environmental and Safety Library on the Web States and Territories. Bureau of National Affairs, Inc. Washington, D.C. Http//www.esweb.bna.com/ (http://www.esweb.bna.com/). June 6, 2001.
*Boatman ES, Merrill T, O’Neill A, . 1983. Use of quantitative analysis of urine to assess exposure to asbestos fibers in drinking water in the Puget Sound region. Environ Health Perspect 53:131–141.6662083
Boehme DS, Maples KR, Henderson RF. 1992. Glutathione release by pulmonary alveolar macrophages in response to particles in vitro. Toxicol Lett 60:53–60.1311468
Boffetta P, Burdorf A, Goldberg M, . 1998. Towards the coordination of European research on the carcinogenic effects of asbestos. Scand J Work Environ Health 24:312–317.9754864
*BOHS. 1968. Hygiene standards for chrysotile asbestos dust. British Occupational Hygiene Society. Ann Occup Hyg 11:47–69.5654330
*BOHS. 1983. A study of the health experience in two U. K. asbestos factories. British Occupational Hygiene Society. Ann Occup Hyg 27:1–13.6847041
Boltin WR, Clark BH, Detter-Hoskin L, . 1989. Alternative instrumentation in the analysis for asbestos in various media. American Laboratory (April):15–25.
*Bolton RE, Davis JM, Donaldson K, . 1982b. Variations in the carcinogenicity of mineral fibres. Ann Occup Hyg 26:569–582.6295247
*Bolton RE, Davis JM, Lamb D. 1982a. The pathological effects of prolonged asbestos ingestion in rats. Environ Res 29:134–150.6291927
*Bolton RE, Vincent JH, Jones AD, . 1983. An overload hypothesis for pulmonary clearance of UICC amosite fibres inhaled by rats. Br J Ind Med 40:264–272.6307338
*Bonneau L, Malard C, Pezerat H. 1986. Studies on surface properties of asbestos: II. Role of dimensional characteristics and surface properties of mineral fibers in the induction of pleural tumors. Environ Res 41:268–275.3757974
Bonner JC, Goodell AL, Coin PG, . 1993. Chrysotile asbestos upregulates gene expression and production of alpha-receptors for platelet-derived growth factor (PDGF-AA) on rat lung fibroblasts. J Clin Invest 92(1):425–430.8392089
Booth SJ, Weaver EJ. 1986. Malignant pleural mesothelioma five years after domestic exposure to blue asbestos [Letter]. Lancet 1:435.
*Boraschi P, Neri S, Braccini G, . 1999. Magnetic resonance appearance of asbestos-related benign and malignant pleural diseases. Scand J Work Environ Health 25:18–23.10204666
Borron SW, Forman SA, Lockey JE, . 1997. An early study of pulmonary asbestosis among manufacturing workers: Original data and reconstruction of the 1932 cohort. Am J Ind Med 31:324–334.9055956
*Both K, Henderson DW, Turner DR. 1994. Asbestos and erionite fibres can induce mutations in human lymphocytes that result in loss of heterozygosity. Int J Cancer 59:538–542.7960224
*Both K, Turner DR, Henderson DW. 1995. Loss of heterozygosity in asbestos-induced mutations in a human mesothelioma cell line. Environ Mol Mutagen 26:67–71.7641709
Botta M, Magnani C, Terracini B, . 1991. Mortality from respiratory and digestive cancers among asbestos cement workers in Italy. Cancer Detect Prev 15:445–447.1782632
Bourbeau J, Ernst P, Chrome J, . 1988. Relationship between respiratory impairment and asbestos related pleural disease in an active workforce [Abstract]. Am Rev Respir Dis 137 (Suppl): 92.
*Bourbeau J, Ernst P, Chrome J, . 1990. The relationship between respiratory impairment and asbestos-related pleural abnormality in an active work force. Am Rev Respir Dis 142:837–842.2221591
*Boutin C, Dumortier P, Rey F, . 1996. Black spots concentrate oncogenic asbestos fibers in the parietal pleura. Am J Resp Crit Care Med 153:444–449.8542156
*Boutin G, Viallat JR, Steinbauer J, . 1989. Bilateral pleural plaques in Corsica: A marker of non-occupational asbestos exposure. IARC Sci Publ 90:406–410.
*Boylan AM, Ruegg C, Kim JK, . 1992. Evidence of a role for mesothelial cell-derived interleukin 8 in the pathogenesis of asbestos-induced pleurisy in rabbits. J Clin Invest 89:1257–1267.1556187
*Brackett KA, Clark PJ, Millette JR. 1992. Method for the analysis of asbestos fibers in water using MCE filters. Microscope 40(3):159–163.
*Branchaud RM, Garant LJ, Kane AB. 1993. Pathogenesis of mesothelial reactions to asbestos fibers. Monocyte recruitment and macrophage activation. Pathobiology 61(3–4):154–163.8216837
Branchaud RM, MacDonald JL, Kane AB. 1989. Induction of angiogenesis by intraperitoneal injection of asbestos fibers. FASEB J 3:1747–1752.2467835
Brass DM, Hoyle G, Liu JY, . 1997. Asbestos-induced lung fibrosis and expression of TNF-alpha in two strains of mice. FASEB J 11:A227.
*Brass DM, Hoyle GW, Poovey HG, . 1999. Reduced tumor necrosis factor-α and transforming growth factor-β1 expression in the lungs of inbred mice that fail to develop fibroproliferative lesions consequent to asbestos exposure. Am J Pathol 154:853–862.10079263
*Bravo MP, Del Rey-Calero J, Conde M. 1988. Bladder cancer and asbestos in Spain. Rev Epidemol Med Soc Sante Publique 36:10–14.
*Bresnitz EA, Gilman MJ, Gracely EJ, . 1993. Asbestos-related radiographic abnormalities in elevator construction workers. Am Rev Respir Dis 147(6):1341–1344.8503542
*Britton MG. 1982. Asbestos pleural disease. Br J Dis Chest 76:1–10.7059482
*Broaddus VC, Yang L, Scavo LM, . 1996. Asbestos induces apoptosis of human and rabbit pleural mesothelial cells via reactive oxygen species. J Clin Invest 98:2050–2059.8903324
*Broaddus VC, Yang L, Scavo LM, . 1997. Crocidolite asbestos induces apoptosis of pleural mesothelial cells: Role of reactive oxygen species and poly (ADP-ribosyl) polymerase. Environ Health Perspect Suppl 105:1147–1152.9400715
Brodkin CA, McCullough J, Stover B, . 1997. Lobe of origin and histologic type of lung cancer associated with asbestos exposure in the carotene and retinol efficacy trial (CARET). Am J Ind Med 32:582–591.9358913
*Brody AR. 1986. Pulmonary cell interactions with asbestos fibers in vivo and in vitro. Chest 89(Suppl 3):155S–159S.3004834
*Brody AR. 1993. Asbestos-induced lung disease. Environ Health Perspect 100(4):21–30.8354168
Brody AR, Hill LH. 1982. Interstitial accumulation of inhaled chrysotile asbestos fibers and consequent formation of microcalcifications. Am J Pathol 109:107–114.7124904
Brody AR, Hill LH, Adkins B, . 1981. Chrysotile asbestos inhalation in rats: Deposition pattern and reaction of alveolar epithelium and pulmonary macrophages. Am Rev Respir Dis 123:670–679.6267971
Brody AR, Hoyle G, Liu J-Y, . 1999. Reduced growth factor expression in mice resistant to developing fibroproliferative lesions after lung injury. Chest 116(1)(Suppl.):97.10424510
Brody AR, Liu J-Y, Brass D, . 1997. Analyzing the genes and peptide growth factors expressed in lung cells in vivo consequent to asbestos exposure in vitro. Environ Health Perspect Suppl 105:1165–1171.9400718
Broser M, Zhang Y, Aston C, . 1996. Elevated interleukin-8 in the alveolitis of individuals with asbestos exposure. Int Arch Occup Environ Health 68:109–114.8720280
Brown A. 1974. Lymphohematogenous spread of asbestos [Commentary]. Environ Health Perspect 9:203–204.4470937
*Brown DM, Fisher C, Donaldson K. 1998. Free radical activity of synthetic vitreous fibers: Iron chelation inhibits hydroxy radical generation by refractory ceramic fiber. J Toxicol Environ Health 53:545–561.
*Brown DP, Dement JM, Okun A. 1994. Mortality patterns among female and male chrysotile asbestos textile workers. J Occup Med 36:882–888.7807269
*Brown RC, Carthew P, Hoskins JA, . 1990. Surface modification can affect the carcinogenicity of asbestos. Carcinogenesis 11:1883–1885.2170048
*Brown RC, Poole A, Fleming GTA. 1983. The influence of asbestos dust on the oncogenic transformation of C3HlOT1/2 cells. Cancer Letters 18:221–227.6299520
*Brown RC, Sara EA, Hoskins JA, . 1991. Factors affecting the interaction of asbestos fibres with mammalian cells: a study using cells in suspension. Ann Occup Hyg 35:25–34.2035951
Browne K. 1983. Asbestos-related mesothelioma: Epidemiological evidence for asbestos as a promoter. Arch Environ Health 38:261–266.6651349
*Browne K. 1986a. A threshold for asbestos related lung cancer. Br J Ind Med 43:556–558.3730306
*Browne K. 1986b. Is asbestos or asbestosis the cause of increased risk of lung cancer in asbestos workers [Editorial]? Br J Ind Med 43:145–149.3511951
*Browne K, Gee JBL. 2000. Asbestos exposure and laryngeal cancer. Ann Occup Hyg 44(4):239–250.10831728
Browne KA. 1991. Asbestos related malignancy and the Cairns hypothesis [Letter]. Br J Ind Med 48:73–76.1998610
Brownson RC, Alavanja MCR, Chang JC. 1993. Occupational risk factors for lung cancer among nonsmoking women a case-control study in Missouri, United States. Cancer Causes Control 4(5):449–454.8218877
Brownson RD. 1998. Current and historical American asbestos regulations. Monaldi Arch Chest Dis 53:181–185.9689805
Buckley SE, Aust AE. 1997. Role of vitronectin in regulation of intracellular glutathione concentrations in human lung epithelial cells. FASEB J 11:A1335.
Burdett G. 1998. A comparison of historic asbestos measurements using a thermal precipitator with the membrane filter-phase contrast microscopy method. Ann Occup Hyg 42:21–31.9566112
Burdett GJ, Jaffrey SAMT, Rood AP. 1989. Airborne asbestos fibre levels in buildings: A summary of UK measurements. IARC Sci Pub 90:277–290.
*California DHS. 1999. California drinking water standards, action levels, and unregulated chemicals requiring monitoring. California Department of Health Services. Http://www.dhs.cahwnet.gov/ps/ddwem/chemicals/mcl/mclindex.htm. May 7, 1999.
Callahan KS, Griffith DE, Garcia JGN. 1990. Asbestos exposure results in increased lung procoagulant activity in vivo and in vitro. Chest 98:112–119.2361375
*Camus M, Siematycki J, Meek B. 1998. Nonoccupational exposure to chrysotile asbestos and the risk of lung cancer. N Engl J Med 338:1565–1571.9603793
*Cantin A, Dubois F, Begin R. 1988. Lung exposure to mineral dusts enhances the capacity of lung inflammatory cells to release superoxide. J Leukoc Biol 43:299–303.2832495
*Cantin AM, Larivee P, Martel M, . 1992. Hyaluronan (hyaluronic acid) in lung lavage of asbestos-exposed humans and sheep. Lung 170:211–220.1522741
*Cantor KP. 1997. Drinking water and cancer. Cancer Causes Control 8:292–308.9498894
Capellaro E, Chiesa A, Villari S, . 1996. Asbestos bodies in bronchoalveolar lavage fluid and sputum. Med Lav 88:99–107.
*Carbone M. 1999. Simian virus 40 and human tumors: It is time to study mechanisms. J Cell Biochem 76:189–193.10618636
*Carbone M, Rizzo P, Pass H. 2000. Simian virus 40: The link with human malignant mesothelioma is well established. Anticancer Res 20:875–878.10810369
*Carter RE, Taylor WF. 1980. Identification of a particular amphibole asbestos fiber in tissues of persons exposed to a high oral intake of the mineral. Environ Res 21:85–93.7389707
Carthew P, Edwards RE, Dorman BM, . 1993. A reappraisal of the carcinogenicity of surface modified asbestos fibers. Carcinogenesis 14(11):2413–2414.8242873
Carthew P, Hill RJ, Edwards RE, . 1992. Intrapleural administration of fibers induces mesothelioma in rats in the same relative order of hazard as occurs in man after exposure. Hum Exp Toxicol 11(6):530–534.1361144
*Case BW. 1991. Health effects of tremolite. Now and in the future. Ann NY Acad Sci 491–504.
*Case BW. 1994. Biological indicators of chrysotile exposure. Ann Occup Hyg 38:503–518.7978972
Case BW. 1998. [Letter]. N Engl J Med 339:1001.
*Case BW, Dufresne A. 1997. Asbestos, asbestosis, and lung cancer: Observations in Quebec chrysotile workers. Environ Health Perspect Suppl 105:1113–1119.9400709
Case BW, Oliver LC. 1992. Asbestos bodies are absent from sputum of school custodial workers [Abstract]. Am Rev Respir Dis 145:332.1736737
*Case BW, Sebastien P. 1987. Environmental and occupational exposures to chrysotile asbestos: A comparative microanalytic study. Arch Environ Health 42(4):185–191.2821933
*Case BW, Sebastien P. 1989. Fibre levels in lung and correlation with air samples. In: Bignon J, Peto J, Saracci R, eds. Non-occupational exposure to mineral fibres, 207–218.
*Case BW, Dufresne A, McDonald AD, . 2000. Asbestos fiber type and length in lungs of chrysotile textile and production workers: Fibers longer than 18 µm. Inhal Toxicol 12:411–418.26368643
*Case BW, Ip MPC, Padilla M, . 1986. Asbestos effects on superoxide production: An in vitro study of hamster alveolar macrophages. Environ Res 39:299–306.3007104
*Case BW, Kuhar M, Harrigan M, . 1994. Lung fibre content of American children aged 8-15 years: Preliminary findings. Ann Occup Hyg 38:639–645.7978987
Case BW, Monaghan LA, Giguère M. 1991. Sputum asbestos bodies in female residents of two chrysotile mining towns [Abstract]. Am Rev Respir Dis 143:266.
*Case BW, Sebastien P, McDonald JC. 1988. Lung fiber analysis in accident victims: A biological assessment of general environmental exposure. Arch Environ Health 43:178–179.3377553
*Casey G. 1983. Sister-chromatid exchange and cell kinetics in CHO-Kl cells, human fibroblasts and lymphoblastoid cells exposed in vitro to asbestos and glass fibre. Mutat Res 116:369–377.6300672
Castellan RM, Sanderson WT, Petersen MR. 1985. Prevalence of radiographic appearance of pneumoconiosis in an unexposed blue collar population. Am Rev Respir Dis 131:684–686.4003914
*Cavalleri A, Gobba F, Bacchella L, . 1991. Evaluation of serum aminoterminal propeptide of type III procollagen as an early marker of the active fibrotic process in asbestos-exposed workers. Scand J Work Environ Health 17:139–144.2047816
Cazzadori A, Malesani F, Romeo L. 1992. Malignant pleural mesothelioma caused by non-occupational childhood exposure to asbestos. Br J Ind Med 49:599 1515354
CCRIS. 1992. Chemical Carcinogenesis Research Information System. National Library of Medicine, Bethesda, MD. November 2, 1992.
CCTTE. 1988. Computerized Listing of Chemicals Being Tested for Toxic Effects. United Nations Environment Programme, International Programme on Chemical Safety, International Register of Potentially Toxic Chemicals. Geneva, Switzerland.
*CDC. 1999. Centers for Disease Control and Prevention. Http://search.cdc.gov/shd/search2.html. May 25, 1999.
CDC/ATSDR. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary and immune systems. Atlanta, GA: CDC/ATSDR Subcommittee on Biomarkers of Organ Damage and Dysfunction, Centers for Disease Control, Agency for Toxic Substances and Disease Registry. Summary report, August 27, 1990.
*CELDS. 1994. Computer-Environmental Legislative Data Systems. University of Illinois, Urbana, IL. August 1994.
Chailleux E, Pioche D, Chopra S, . 1995. [The epidemiology of malignant pleural mesothelioma in the Nantes-Saint-Nazaire region. Evolution between 1956 and 1992]. Rev Mal Resp 12:353–357. (French)
Chamberlain M, Brown RC. 1978. The cytotoxic effects of asbestos and other mineral dust in tissue culture cell lines. Br J Exp Pathol 59:183–189.656318
*Chamberlain M, Tarmy EM. 1977. Asbestos and glass fibres in bacterial mutation tests. Mutat Res 43:159–164.194149
Chan CK, Gee JB. 1988. Asbestos exposure and laryngeal cancer: An analysis of the epidemiologic evidence. J Occup Med 30:23–27.3280756
*Chang H-Y, Chen C-R, Wang J-D. 1999. Risk assessment of lung cancer and mesothelioma in people living near asbestos-related factories in Taiwan. Arch Environ Health 54(3):194–201.10444041
*Chang L-Y, Overby LH, Brody AR, . 1988. Progressive lung cell reactions and extracellular matrix production after a brief exposure to asbestos. Am J Pathol 131:156–170.2833103
*Chang MJ, Joseph LB, Stephens RE, . 1990. Modulation of biological processes by mineral fiber adsorption of macromolecules in vitro. JEPTO 10:89–93.1700100
*Chao CC, Aust AE. 1994. Effect of long-term removal of iron from asbestos by desferrioxamine B on subsequent mobilization by other chelators and induction of DNA single-strand breaks. Arch Biochem Biophys 308(1):64–69.8311475
*Chao C-C, Park S-H, Aust AE. 1996. Participation of nitric oxide and iron in the oxidation of DNA in asbestos-treated human lung epithelial cells. Arch Biochem Biophys 326:152–157.8579364
Chen CR, Chang HY, Suo J, . 1992. Occupational exposure and respiratory morbidity among asbestos workers in Taiwan. J Formos Med Assoc 91(12):1138–1142.1363633
*Cheng JQ, Jhanwar SC, Klein WM, . 1994. p16 alterations and deletion mapping of 9p21-p22 in malignant mesothelioma. Cancer Res 54:5547–5551.7923195
*Cheng JQ, Jhanwar SC, Lu YY, . 1993. Homozygous deletions within 9p21-p22 identify a small critical region of chromosomal loss in human malignant mesotheliomas. Cancer Res 53:4761–4763.8402655
Cheng JQ, Lee W-C, Klein MA, . 1999a. Frequent mutations of NF2 and allelic loss from chromosome band 22q12 in malignant mesothelioma: Evidence for a two-hit mechanism of NF2 inactivation. Genes Chromosomes Cancer 24:238–242.10451704
*Cheng N, Shi X, Ye J, . 1999b. Role of transcription factor NF-κB in asbestos-induced TNFα response from macrophages. Exp Mol Pathol 66:201–210.10486238
Cheng WN, Kong J. 1992. A retrospective mortality cohort study of chrysotile asbestos products workers in Tianjin 1972-1987. Environ Res 59(1):271–278.1425517
*Cherubini M, Fornaciai G, Mantelli F, . 1998. Results of survey on asbestos fibre contamination of drinking water in Tuscany, Italy. J Wat SRT 47:1–8.
*Chesson J, Hatfield J, Schultz B, . 1990. Airborne asbestos in public buildings. Environ Res 51:100–107.2298180
*Chissick SS. 1985. Asbestos. In: Gerhartz W, Yamamoto YS, Campbell FT, ., ed. Ullmann’s encyclopedia of industrial chemistry. Weinheim: VCH, 151–167.
Choe N, Tanaka S, Kagan E. 1998. Asbestos fibers and interleukin-1 upregulate the formation of reactive nitrogen species in rat pleural mesothelial cells. Am J Respir Cell Mol Biol 19:226–236.9698594
Choe N, Tanaka S, Xia W, . 1997. Pleural macrophage recruitment and activation in asbestos-induced pleural injury. Environ Health Perspect Suppl 105:1257–1260.9400734
Choe N, Zhang J, Iwagaki A, . 1999. Asbestos exposure upregulates the adhesion of pleural leukocytes to pleural mesothelial cells via VCAM-1. Am J Physiol 277(2):292–300.
*Choi I, Smith RW. 1972. Kinetic study of dissolution of asbestos fibers in water. J Colloid Interface Sci 40:253–262.
Choudhary G. 1996. Human health perspectives on environmental exposure to benzidine: A review. Chemosphere 32:267–291.8581430
Chouroulinkov I. 1989. Experimental studies on ingested fibres. IARC Sci Publ 90:112–126.
*Churg A. 1982. Fiber counting and analysis in the diagnosis of asbestos-related disease. Hum Pathol 13(4):381–392.6281166
*Churg A. 1986a. Nonneoplastic asbestos-induced disease. Mt Sinai J Med (NY) 53:409–415.
*Churg A. 1986b. Lung asbestos content in long-term residents of a chrysotile mining town. Am Rev Respir Dis 134:125–127.3014932
*Churg A. 1988. Chrysotile, tremolite, and malignant mesothelioma in man. Chest 93:621–628.2830081
*Churg A. 1989. The diagnosis of asbestosis. Hum Pathol 20(2):97–99.2914704
*Churg A. 1993. Asbestos-related disease in the workplace and the environment: Controversial issues. Monogr Pathol 36:54–77.
*Churg A. 1994. Deposition and clearance of chrysotile asbestos. Ann Occup Hyg 38:625–633.7978985
*Churg A. 1998. Nonoccupational exposure to chrysotile asbestos and the risk of lung cancer [Letter]. N Engl J Med 339:999.
*Churg A, DePaoli L. 1988. Environmental pleural plaques in residents of a Quebec chrysotile mining town. Chest 94(1):58–60.2838224
Churg A, Stevens B. 1993. Absence of amosite asbestos in airway mucosa of non-smoking long term workers with occupational exposure to asbestos. Br J Ind Med 50(4):355–359.8388242
*Churg A, Stevens B. 1995. Enhanced retention of asbestos fibers in the airways of human smokers. Am J Resp Crit Care Med 151:1409–1413.7735593
*Churg AM, Warnock ML. 1981. Asbestos and other ferruginous bodies: Their formation and clinical significance. Am J Pathol 102:447–456.6101235
Churg A, Wiggs B. 1986. Fiber size and number in workers exposed to processed chrysotile asbestos, chrysotile miners, and the general population. Am J Ind Med 9:143–152.3008552
*Churg A, Wright JL. 1989. Fibre content of lung in amphibole- and chrysotile-induced mesothelioma: Implications for environmental exposure. IARC Sci Pub 90:314–318.
*Churg A, Wright JL. 1994. Persistence of natural mineral fibers in human lungs: An overview. Environ Health Perspect 102(Suppl. 5):229–233.
*Churg A, Brauer M, Keeling B. 1996. Ozone enhances the uptake of mineral particles by tracheobronchial epithelial cells in organ culture. Am J Resp Crit Care Med 153:1230–1233.8616546
*Churg A, Sun J-P, Zay K. 1998. Cigarette smoke increases amosite asbestos fiber binding to the surface of tracheal epithelial cells. Am J Physiol 275(19):L502–L508.9728044
*Churg A, Wright JL, Depaoli L, . 1989a. Mineralogic correlates of fibrosis in chrysotile miners and millers. Am Rev Respir Dis 139:891–896.2539033
*Churg A, Wright JL, Gilks B, . 1989b. Rapid short-term clearance of chrysotile compared with amosite asbestos in the guinea pig. Am Rev Respir Dis 139:885–890.2539032
*Churg A, Wright JL, Hobson J, . 1992. Effects of cigarette smoke on the clearance of short asbestos fibres from the lung and a comparison with the clearance of long asbestos fibres. Int J Exp Path 73:287–297.1320393
*Churg A, Wright JL, Vedal S. 1993. Fiber burden and patterns of asbestos-related disease in chrysotile miners and millers. Am Rev Respir Dis 148:25–31.8391235
*Churg A, Wright JL, Wiggs B, . 1990. Mineralogic parameters related to amosite asbestos-induced fibrosis in humans. Am Rev Respir Dis 142:1331–1336.2174656
*Chuwers P, Barnhart S, Blanc P, . 1997. The protective effect of beta-carotene and retinol on ventilatory function in an asbestos-exposed cohort. Am J Resp Crit Care Med 155:1066–1071.9116988
Cicioni C, London SJ, Garabrant DH, . 1991. Occupational asbestos exposure and mesothelioma risk in Los Angeles county: Application of an occupational hazard survey job-exposure matrix. Am J Ind Med 20:371–379.1928113
Clansky KB, ed. 1986. Chemical guide to the OSHA hazard communication standard. Burlingame, CA: Roytech Publications, Inc., 100, B-3, C-3, E-3.
CLC. 1988. Coordinated List of Chemicals. Washington, DC: U. S. Environmental Protection Agency, Office of Research and Development.
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
Clouter A, Houghton CE, Bowskill CA, . 1996. An in vitro/in vivo study into the short term effects of exposure to mineral fibres. Exp Toxicol Pathol 48:484–486.8954327
Cocco P, Dosemeci M. 1999. Peritoneal cancer and occupational exposure to asbestos: Results from the application of a job-exposure matrix. Am J Ind Med 35:9–14.9884740
Cocco P, Palli D, Buiatti E, . 1994. Occupational exposures as risk factors for gastric cancer in Italy. Cancer Causes Control 5:241–248.8061172
*Cocco P, Ward MH, Buiatti E. 1996. Occupational risk factors for gastric cancer: An overview. Epidemiol Rev 18:218–234.9021314
Cocco P, Ward MH, Dosemeci M. 1998. Occupational risk factors for cancer of the gastric cardia. J Occup Environ Med 40:855–861.9800169
*Coin PG, Osornio-Vargas AR, Roggli VL, . 1996. Pulmonary fibrogenesis after three consecutive inhalation exposures to chrysotile asbestos. Am J Resp Crit Care Med 154:1511–1519.8912773
*Coin PG, Roggli VL, Brody AR. 1992. Deposition, clearance and translocation of chrysotile asbestos from peripheral and central regions of the rat lung. Environ Res 58:97–116.1317793
*Coin PC, Roggli VL, Brody AR. 1994. Persistence of long, thin chrysotile asbestos fibers in the lungs of rats. Environ Health Perspect Suppl 102:197–199.7882930
*Cole RW, Ault JG, Hayden JH, . 1991. Crocidolite asbestos fibers undergo size-dependent microtubule-mediated transport after endocytosis in vertebrate lung epithelial cells. Cancer Res 51:4942–4947.1893384
Collegium Ramazzini. 1999a. Call for an international ban on asbestos. Am J Ind Med 36:227–229.10398930
Collegium Ramazzini. 1999b. Call for an international ban on asbestos. Int J Occup Med Environ Health 12(3):285–288.10581869
Collegium Ramazzini. 1999c. Call for an international ban on asbestos. J Occup Environ Med 41(10):830–832.10529938
Colt HG. 1997. Mesothelioma: Epidemiology, presentation, and diagnosis. Am J Resp Crit Care Med 18:353–361.
Comba P, Di Paola M, Martuzzi M, . 1997. Asbestos-related mortality in Italy: A geographical approach. Med Lav 88:293–301.9396214
Conforti PM. 1983. Effect of population density on the results of the study of water supplies in five California counties. Environ Health Perspect 53:69–78.6319119
*Conforti PM, Kanarek MS, Jackson LA, . 1981. Asbestos in drinking water and cancer in the San Francisco Bay Area: 1969-1974 incidence. J Chronic Dis 34:211–224.7240361
Constantini AS, Chellini E. 1997. The experience of the mesothelioma registry of Tuscany in assessing health hazard associated with asbestos exposure. Med Lav 88:310–315.9396216
*Constantinidis K. 1977. Pneumoconiosis and rheumatoid arthritis (Caplan’s syndrome). Br J Clin Pract 31:25–31.326283
Constantopoulos SH, Dalavanga YA, Sakellariou K, . 1992. Lymphocytic alveolitis and pleural calcifications in nonoccupational asbestos exposure: Protection against neoplasia? Am Rev Respir Dis 146(6):1565–1570.1456576
*Constantopoulos SH, Goudevenos JA, Saratzis N, . 1985. Metsovo lung: Pleural calcification and restrictive lung function in northwestern Greece. Environmental exposure to mineral fiber as etiology. Environ Res 38:319–331.4065080
*Constantopoulos SH, Malamou-Mitsi VD, Goudevenos JA, . 1987a. High incidence of malignant pleural mesothelioma in neighbouring villages of northwestern Greece. Respiration 51:266–271.3659577
*Constantopoulos SH, Saratzis NA, Kontogiannis D, . 1987b. Tremolite whitewashing and pleural calcifications. Chest 92(4):709–712.2820656
Cook PM. 1983. Review of published studies on gut penetration by ingested asbestos fibers. Environ Health Perspect 53:121–130.6662082
*Cook PM, Olson GF. 1979. Ingested mineral fibers: Elimination in human urine. Science 204:195–198.219478
*Cook PM, Palekar LD, Coffin DL. 1982. Interpretation of the carcinogenicity of amosite asbestos and ferroactinolite on the basis of retained fiber dose and characteristics in vivo. Toxicol Lett 13:151–158.6293119
Cooper M, Johnson K, Delany DJ. 1996. Case report: Asbestos related pericardial disease. Clin Radiol 51:656–657.8810699
*Çöplü L, Dumortier P, Demir AU, . 1996. An epidemiological study in an Anatolian village in Turkey environmentally exposed to tremolite asbestos. J Environ Pathol Toxicol Oncol 15:177–182.9216803
*Cordier S, Lazar P, Brochard P, . 1987. Epidemiologic investigation of respiratory effects related to environmental exposure to asbestos inside insulated buildings. Arch Environ Health 42:303–309.3452298
Corhay JL, Delavignette JP, Bury T, . 1990. Occult exposure to asbestos in steel workers revealed by bronchoalveolar lavage. Arch Environ Health 45:278–282.2175167
*Corn M. 1994. Airborne concentrations of asbestos in non-occupational environments. Ann Occup Hyg 38:495–502.7978971
*Corn M, McArthur B, Dellarco M. 1994. Asbestos exposures of building maintenance personnel. Appl Occup Environ Hyg 9(11):845–852.
*Corpet DE, Pirot V, Goubet I. 1993. Asbestos induces aberrant crypt foci in the colon of rats. Cancer Letters 74(3):183–187.8174102
*Corsini E, Luster MI, Mahler J, . 1994. A protective role for T lymphocytes in asbestos-induced pulmonary inflammation and collagen deposition. Am J Respir Cell Mol Biol 11:531–539.7946383
Cote RJ, Jhanwar SC, Novick S, . 1991. Genetic alterations of the p53 gene are a feature of malignant mesotheliomas. Cancer Res 51(19):5410–5416.1913660
*CPSC. 2001a. CPSC release test results on crayons. Consumer Product Safety Commission. Http://cpsc.gov/cpscpub/prerel/prhtml100/00123.html. May 01, 2001.
*CPSC. 2001b. CPSC testing finds no asbestos fibers in children’s chalk. Consumer Product Safety Commission. Http://cpsc.gov/cpscpub/prerel/prhtml100/00123.html. May 01, 2001.
Craighead JE. 1987. Current pathogenetic concepts of diffuse malignant mesothelioma. Hum Pathol 18:544–557.3036684
Craighead JE, Mossman BT. 1982. The pathogenesis of asbestos-associated diseases. N Engl J Med 306:1446–1455.7043267
*Craighead JE, Abraham JL, Churg A, . 1982. The pathology of asbestos-associated diseases of the lungs and pleural cavities: Diagnostic criteria and proposed grading schema. Arch Pathol Lab Med 106:544–597.6897166
Craighead JE, Mossman BT, Bradley BJ. 1980. Comparative studies on the cytotoxicity of amphibole and serpentine asbestos. Environ Health Perspect 34:37–46.6993203
*Craun GF, Millette JR, Woodhull RS, . 1977. Exposure to asbestos fibers in water distribution systems. In: Proceedings of the 97th Annual Conference of the American Waterworks Association, Anaheim, California, May 8-13, 1–13.
CRISP Database. 1994. Computer Retrieval of Information on Scientific Projects. Washington, DC: National Institutes of Health, Public Health Service, U.S. Department of Health and Human Services. December 1992.
Crosignani P, Forastiere F, Petrelli G, . 1995. Malignant mesothelioma in thermoelectric power plant workers in Italy. Am J Ind Med 27:573–576.7793427
Crotty TB, Myers JL, Katzenstein A-L, . 1994. Localized malignant mesothelioma: A clinicopathologic and flow cytometric study. Am J Surg Pathol 18(4):357–363.7511353
*Cullen MR, Baloyi RS. 1991. Chrysotile asbestos and health in Zimbabwe. I. Analysis of miners and millers compensated for asbestos-related diseases since independence (1980). Am J Ind Med 19(2):161–169.1847001
Cullen RT, Miller BG, Davis JMG, . 1997. Short-term inhalation and in vitro tests as predictors of fiber pathogenicity. Environ Health Perspect Suppl 105:1235–1240.9400730
Cullen RT, Searl A, Miller BG, . 2000. Pulmonary and intraperitoneal inflammation induced by cellulose fibres. J Appl Toxicol 20:49–60.10641016
Cunningham HM, Pontefract R. 1971. Asbestos fibres in beverages and drinking water. Nature 232:332–333.5094836
*Cunningham HM, Pontefract RD. 1973. Asbestos fibers in beverages, drinking water, and tissues: Their passage through the intestinal wall and movement through the body. J AOAC 56:976–981.
*Cunningham HM, Pontefract RD. 1974. Placental transfer of asbestos. Nature 249:177–178.4833523
*Cunningham HM, Moodie CA, Lawrence GA, . 1977. Chronic effects of ingested asbestos in rats. Arch Environ Contam Toxicol 6:507–513.318538
*Cunningham HM, Pontefract RD, O’Brien RC. 1976. Quantitative relationship of fecal asbestos to asbestos exposure. J Toxicol Environ Health 1:377–379.1246083
Curin K, Saric M. 1995. Cancer of the lung, pleura, larynx, and pharynx in an area with an asbestos-cement plant. Arh Hig Rada Toksikol 46:289–300.8645115
Dai J, Gilks B, Price K, . 1998. Mineral dusts directly induce epithelial and interstitial fibrogenic mediators and matrix components in the airway wall. Am J Respir Crit Care Med 158:1907–1913.9847285
Daniel FB. 1983. In vitro assessment of asbestos genotoxicity. Environ Health Perspect 53:163–167.6363052
Dave SK, Bhagia LJ, Mazumdar PK, . 1996. The correlation of chest radiograph and pulmonary function tests in asbestos miners and millers. Indian J Chest Dis Allied Sci 38:81–89.8822641
*Dave SK, Ghodasara NB, Mohanrao N, . 1997. The relation of exposure to asbestos and smoking habit with pulmonary function tests and chest radiograph. Indian J Public Health 41:16–24.9567522
Dave SK, Ghodasara NB, Patel GC, . 1995. Correlation of asbestos exposure and cigarette smoking with pulmonary function tests and chest radiography. Indian J Ind Med 41:106–115.
*Davies D, Andrews MI, Jones JS. 1991. Asbestos induced pericardial effusion and constrictive pericarditis. Thorax 46(6):429–432.1858081
*Davis JM. 1970. The long term fibrogenic effects of chrysotile and crocidolite asbestos dust injected into the pleural cavity of experimental animals. Br J Exp Pathol 5:617–627.
*Davis JM. 1972. The fibrogenic effects of mineral dusts injected into the pleural cavity of mice. Br. J Exp Pathol 53:190–201.4338060
Davis JM. 1975. The use of animal experiments in the study of asbestos bioeffects. Hefte Unfallheilkd (Iss 126):564–574.1234271
Davis JM. 1979. The use of animal models for studies on asbestos bioeffects. Ann NY Acad Sci 330:795–798.294224
Davis JM. 1981. The biological effect of mineral fibres. Ann Occup Hyg 24:227–234.7032390
Davis JM. 1984. The pathology of asbestos related disease. Thorax 39:801–808.6390772
*Davis JMG. 1989. Mineral fibre carcinogenesis: Experimental data relating to the importance of fibre type, size, deposition, dissolution and migration. IARC Sci Publ 90:33–45.
Davis JMG. 1994. Other diseases in animals. Ann Occup Hyg 38:581–587.7978981
Davis JM, Coniam SW. 1973. Experimental studies on the effects of heated chrysotile asbestos and automobile brake lining dust injected into the body cavities of mice. Exp Mol Pathol 19:339–353.4763634
*Davis JM, Cowie HA. 1990. The relationship between fibrosis and cancer in experimental animals exposed to asbestos and other fibers. Environ Health Perspect 88:305–309.2272327
*Davis JM, Jones AD. 1988. Comparisons of the pathogenicity of long and short fibres of chrysotile asbestos in rats. Br J Exp Pathol 69:717–737.2848570
*Davis JM, Addison J, Bolton RE, . 1985. Inhalation studies on the effects of tremolite and brucite dust in rats. Carcinogenesis 6:667–674.2988806
*Davis JM, Addison J, Bolton RE, . 1986a. The pathogenicity of long versus short fibre samples of amosite asbestos administered to rats by inhalation and intraperitoneal injection. Br J Exp Pathol 67:415–430.2872911
*Davis JM, Beckett ST, Bolton RE, . 1980a. The effects of intermittent high asbestos exposure (peak dose levels) on the lungs of rats. Br J Exp Pathol 61:272–280.7426382
*Davis JM, Beckett ST, Bolton RE, . 1980b. A comparison of the pathological effects in rats of the UICC reference samples of amosite and chrysotile with those of amosite and chrysotile collected from the factory environment. IARC Sci Publ 30:285–292.
Davis JMG, Beckett ST, Boulton RE, . 1978. Mass and number of fibres in the pathogenesis of asbestos-related lung disease in rats. Br J Cancer 37:673–688.656299
Davis JM, Bolton RE, Brown D, . 1986b. Experimental lesions in rats corresponding to advanced human asbestosis. Exp Mol Pathol 44:207–221.3699139
*Davis JM, Bolton RE, Douglas AN, . 1988. Effects of electrostatic charge on the pathogenicity of chrysotile asbestos. Br J Ind Med 45:292–299.2837270
*Davis JM, Bolton BG, Niven K. 1991a. Mesothelioma dose response following intraperitoneal injection of mineral fibres. Int J Exp Path 72:263–274.1843255
*Davis JM, Gylseth B, Morgan A. 1986c. Assessment of mineral fibres from human lung tissue. Thorax 41:167–175.3520934
Davis JM, Jones AD, Miller BG. 1991b. Experimental studies in rats on the effects of asbestos inhalation coupled with the inhalation of titanium dioxide or quartz. Int J Exp Path 72:501–525.1742204
Dawson A, Gibbs A, Browne K, . 1992. Familial mesothelioma details of 17 cases with histopathologic findings and mineral analysis. Cancer 70(5):1183–1187.1515995
Dawson A, Gibbs AR, Pooley FD, . 1993. Malignant mesothelioma in women. Thorax 48(3):269–274.8497827
*de Klerk NH, Armstrong BK, Musk AW, . 1989. Cancer mortality in relation to measures of occupational exposure to crocidolite at Wittenoom Gorge in Western Australia. Br J Ind Med 46:529–536.2550048
*de Klerk NH, Musk AW, Ambrosini GL, . 1998. Vitamin A and cancer prevention II: Comparison of the effects of retinol and beta-carotene. Int J Cancer 75:362–367.9455794
*de Klerk NH, Musk AW, Armstrong BK, . 1991. Smoking, exposure to crocidolite, and the incidence of lung cancer and asbestosis. Br J Ind Med 48:412–417.1648376
de Klerk NH, Musk AW, Armstrong BK, . 1994. Diseases in miners and millers of crocidolite from Wittenoom, Western Australia: A further follow-up to December 1986. Ann Occup Hyg 38:647–655.
de Klerk NH, Musk AW, Cookson WO, . 1993. Radiographic abnormalities and mortality in subjects with exposure to crocidolite. Br J Ind Med 50(10):902–906.8217849
*de Klerk NH, Musk AW, Williams V, . 1996. Comparison of measures of exposure to asbestos in former crocidolite workers from Wittenoon Gorge, W. Australia. Am J Ind Med 30:579–587.8909606
*Delahunty TJ, Hollander D. 1987. Toxic effect on the rat small intestine of chronic administration of asbestos in drinking water. Toxicol Lett 39:205–209.3120357
Delfino RJ, Anton-Culver H, Saltzstein SL. 1995. Gender-related differences in the distribution of throacic versus abdominal malignant mesothelioma. Cancer Detect Prev 19:301–307.7553671
Dell L, Teta MJ. 1995. Mortality among workers at a plastics manufacturing and research and development facility: 1946-1988. Am J Ind Med 28:373–384.7485191
Dement JM. 1991. Carcinogenicity of chrysotile asbestos: A case control study of textile workers. Cell Biol Toxicol 7:59–65.1647260
*Dement JM, Brown DP. 1994. Lung cancer mortality among asbestos textile workers: A review and update. Ann Occup Hyg 38:525–532.7978974
*Dement JM, Brown DP, Okun A. 1994. Follow-up study of chrysotile asbestos textile workers: Cohort mortality and case-control analyses. Am J Ind Med 26:431–447.7810543
*Dement JM, Harris RL, Symons MJ, . 1983. Exposures and mortality among chrysotile asbestos workers. Part II: Mortality. Am J Ind Med 4:421–433.6846339
*Dement JM, Hensley L, Kieding S, . 1998. Proportionate mortality among union members employed at three Texas refineries. Am J Ind Med 33:327–340.9513640
*Demers PA, Stellman SD, Colin D, . 1998. Nonmalignant respiratory disease mortality among woodworkers participating in the American Cancer Society cancer prevention study-II (CPS-II). Am J Ind Med 34:238–243.9698992
Demers RY, Burns PB, Swanson GM. 1994. Construction occupations, asbestos exposure, and cancer of the colon and rectum. J Occup Med 36:1027–1031.7823215
*Demyanek ML, Lee RJ, Allison KA, . 1994. Air, surface, and passive measurements in a building during spray-buffing of vinyl-asbestos floor tile. Appl Occup Environ Hyg 9:869–875.
*deShazo RD, Morgan J, Bozelka B, . 1988. Natural killer cell activity in asbestos workers: Interactive effects of smoking and asbestos exposure. Chest 94:482–485.3409724
De Stafani E, Kogevinas M, Boffetta P, . 1996. Occupation and the risk of lung cancer in Uruguay. Scand J Work Environ Health 22:346–352.8923607
*De Vuyst P, Dumortier P, Gevenois PA. 1997. Analysis of asbestos bodies in BAL from subjects with particular exposure. Am J Ind Med 31:699–704.9131224
De Vuyst P, Dumortier P, Jacobovitz D, . 1994. Environmental asbestosis complicated by lung cancer. Chest 105:1593–1595.8181367
*De Vuyst P, Dumortier P, Moulin E, . 1988. Asbestos bodies in bronchoalveolar lavage reflect lung asbestos body concentration. Eur Resp J 1:362–367.
*De Vuyst P, Jedwab J, Dumortier P, . 1982. Asbestos bodies in bronchoalveolar lavage. Am Rev Resp Dis 126:972–976.7181238
*De Vuyst P, Karjalainen A, Dumortier P, . 1998. Guidelines for mineral fibre analyses in biological samples: Report of the ERS Working Group. Eur Resp J 11:1416–1426.
*DHHS. 1985. The health consequences of smoking: Cancer and chronic lung disease in the workplace. U.S. Department of Health and Human Services. Office on Smoking and Health, Rockville, MD, 13–14.
DHHS. 1986. Report on cancer risks associated with the ingestion of asbestos. U.S. Department of Health and Human Services. NTIS No. PB90-B0527.
Di Bonito L, Giarelli L, Stanta G, . 1997. [Lung cancer in the Trieste area]. G Ital Med Lav 19:42–43. (Italian).
*Di Lorenzo L, Mele M, Pegorari MM, . 1996. Lung cinescintigraphy in the dynamic assessment of ventilation and mucociliary clearance of asbestos cement workers. Occup Environ Med 53:628–635.8882120
*Dion C, Perrault G. 1994. Comparison of four methods for the determination of asbestos fiber concentrations in workplace atmospheres by phase contrast microscopy. Appl Occup Environ Hyg 9(10):707–711.
*DiPaolo JA, DeMarinis AJ, Doniger J. 1983. Asbestos and benzo(a)pyrene synergism in the transformation of Syrian hamster embryo cells. Pharmacology 27:65–73.
Dixon D, Bowser AD, Badgett A, . 1995. Incorporation of bromodeoxyuridine (BrdU) in the bronchiolar-alveolar regions of the lungs following two inhalation exposures to chyrsotile asbestos in strain A/J mice. J Environ Pathol Toxicol Oncol 14:205–213.9003699
Dodoli D, Del Nevo M, Fiumalbi C, . 1992. Environmental household exposures to asbestos and occurrence of pleural mesothelioma. Am J Ind Med 21:681–687.1609814
Dodson RF, Ford JO. 1991. Tissue reaction following a second exposure to amosite asbestos. Cytobios 68:53–62.1778092
Dodson RF, Hurst GA, Williams MG, . 1988. Comparison of light and electron microscopy for defining occupational asbestos exposure in transbronchial lung biopsies. Chest 94:366–370.3396416
Dodson RF, O’Sullivan M, Corn C. 1993. Technique dependent variations in asbestos burden as illustrated in a case of nonoccupational exposed mesothelioma. Am J Ind Med 24(2):235–40.8213850
Dodson RF, O’Sullivan M, Corn CJ, . 1995. Quantitative comparison of asbestos and talc bodies in an individual with mixed exposure. Am J Ind Med 27:207–215.7755011
Dodson RF, O’Sullivan M, Corn CJ. 1996. Relationships between ferruginous bodies and uncoated asbestos fibers in lung tissue. Arch Environ Health 51:462–466.9012326
Dodson RF, O’Sullivan M, Corn CJ, . 1997. Analysis of asbestos fiber burden in lung tissue from mesothelioma patients. Ultrastruct Pathol 21:321–336.9205997
*Dodson RF, Williams MG, Huang J, . 1999. Tissue burden of asbestos in nonoccupationally exposed individuals from east Texas. Am J Ind Med 35:281–286.9987561
*DOL. 1980. Asbestiform and/or fibrous minerals in mines, mills, and quarries. Mine Safety and Health Administration, U.S. Department of Labor.
*Doll R. 1955. Mortality from lung cancer in asbestos workers. Br J Ind Med 12:81–86.14363586
Doll R. 1987. The quantitative significance of asbestos fibres in the ambient air. Experientia (Supp) 51:213–219.
*Doll R. 1989. Mineral fibres in the nonoccupational environment: Concluding remarks. IARC Sci Pub 90:511–518.
*Doll R, Peto J. 1985. Asbestos: Effects on health of exposure to asbestos. A report to the Health and Safety Commission. London, England, Her Majesty’s Stationery Office.
*Doll R, Peto J. 1987. Other asbestos-related neoplasms. In: Antman K, Aisner J, ed. Asbestos-related malignancy. New York: Grune & Stratton, Inc., 81–96.
*Donaldson K, Golyasnya N. 1995. Cytogenetic and pathogenic effects of long and short amosite asbestos. J Pathol 177:303–307.8551393
*Donaldson K, Bolton RE, Jones A, . 1988a. Kinetics of the bronchoalveolar leucocyte response in rates during exposure to equal airborne mass concentrations of quartz, chrysolite asbestos, or titanium dioxide. Thorax 43:525–533.2850638
Donaldson K, Brown GM, Brown DM, . 1989. Inflammation generating potential of long and short fibre amosite asbestos samples. Br J Ind Med 46:271–276.2540793
Donaldson K, Brown RC, Brown GM. 1993. Respirable industrial fibers: Mechanisms of pathogenicity. Thorax 48(4):390–395.8511739
Donaldson K, Slight J, Bolton RE. 1988b. Oxidant production by control and inflammatory bronchoalveolar leukocyte populations treated with mineral dusts in vitro. Inflammation 12:231–243.2843464
*Dong H, Saint-Etienne L, Renier A, . 1994. Air samples from a building with asbestos-containing material: Asbestos content and in vitro toxicity on rat pleural mesothelial cells. Fundam Appl Toxicol 22:178–185.8005370
*Donham KJ, Berg JW, Will LA, . 1980. The effects of long-term ingestion of asbestos on the colon of F344 rats. Cancer (March Suppl) 45:1073–1084.6244076
*Donmez H, Ozkul Y, Ucak R. 1996. Sister chromatid exchange frequency in inhabitants exposed to asbestos in Turkey. Mutat Res 361:129–132.8980698
*Dopp E, Schiffmann D. 1998. Analysis of chromosomal alteration induced by asbestos and ceramic fibers. Toxicol Lett 96:155–162.9820661
*Dopp E, Jonas L, Nebe B, . 2000. Dielectric changes in membrane properties and cell interiors of human mesothelial cells in vitro after crocidolite asbestos exposure. Environ Health Perspect 108(2):153–158.10656856
*Dopp E, Nebe B, Hahnel C, . 1995a. Mineral fibers induce apoptosis in Syrian hamster embryo fibroblasts. Pathobiology 63:213–221.8866793
*Dopp E, Saedler J, Stopper H, . 1995b. Mitotic disturbances and micronucleus induction in Syrian hamster embryo fibroblast cells caused by asbestos fibers. Environ Health Perspect 103:268–271.7768228
*Dopp E, Schuler M, Schiffmann D, . 1997. Induction of micronucleai, hyperdiploidy and chromosomal breakage affecting the centri/pericentric regions of chromosomes 1 and 9 in human amniotic fluid cells after treatment with asbestos and ceramic fibers. Mutat Res 377:77–87.9219582
Dossing M, Groth S, Vestbo J, . 1990. Small-airways dysfunction in never smoking asbestos exposed Danish plumbers. Int Arch Occup Environ Health 62:209–212.2189832
*Driscoll KE, Carter JM, Hassenbein DG, . 1997. Cytokines and particle-induced inflammatory cell recruitment. Environ Health Perspect Suppl 105:1159–1164.9400717
*Driscoll KE, Carter JM, Howard BW, . 1998. Crocidolite activates NF-kB and MIP-2 gene expression in rat alveolar epithelial cells. Role of mitochrondrial-derived oxidants. Environ Health Perspect 106(Suppl. 5):1171–1174.9788893
Drumm K, Buhl R, Kienast K. 1999. Additional NO2 exposure induces a decrease in cytokine specific mRNA expression and cytokine release of particle and fibre exposed human alveolar macrophages. Eur J Med Res 4:59–66.10066641
Dubes GR, Mack LR. 1988. Asbestos-mediated transfection of mammalian cell cultures. In Vitro Cellular Devel Biol 24:175–181.2832359
*Dubois CM, Bissonnette E, Rola-Pleszczynski M. 1989. Asbestos fibers and silica particles stimulate rat alveolar macrophages to release tumor necrosis factor. Am Rev Respir Dis 139:1257–1264.2540688
*Dufresne A, Begin R, Churg A, . 1996a. Mineral fiber content of lungs in patients with mesothelioma seeking compensation in Quebec. Am J Respir Crit Care Med 153:711–718.8564122
*Dufresne A, Begin R, Masse S, . 1996b. Retention of asbestos fibres in lungs of workers with asbestosis, asbestosis and lung cancer, and mesothelioma in Asbestos township. Occup Environ Med 53:801–807.8994398
*Dufresne A, Harrigan M, Masse S, . 1995. Fibers in lung tissues of mesothelioma cases among miners and millers of the township of Asbestos, Quebec. Am J Ind Med 27:581–592.7793429
Dujic Z, Eterovic D, Tocilj J. 1993. Association between asbestos-related pleural plaques and resting hyperventilation. Scand J Work Environ Health 19(5):346–351.8296184
*Dujic Z, Tocilj J, Boshi S, . 1992. Biphasic lung diffusing capacity: Detection of early asbestos induced changes in lung function. Br J Ind Med 49:260–267.1315153
Dujic Z, Tocilj J, Saric M. 1991. Early detection of interstitial lung disease in asbestos exposed non-smoking workers by mid-expiratory flow rate and high resolution computed tomography. Br J Ind Med 48(10):663–664.1657109
Dumortier P, Rey F. 1998. RE main asbestos type in pleural mesothelioma [Letter]. Am J Ind Med 33:94–95.9408534
*Dumortier P, Cöplü L, de Maertelaer V, . 1998. Assessment of environmental asbestos exposure in Turkey by bronchoalveolar lavage. Am J Respir Crit Care Med 158:1815–1824.9847273
*Dumotier P, De Vuyst P, Strauss P, . 1990. Asbestos bodies in bronchoalveolar lavage fluids of brake lining and asbestos cement workers. Br J Ind Med 47:91–98.2155652
*Dupre JS, Mustard JF, Uffen RJ, . 1984. Report of the Royal Commission on matters of health and safety arising from the use of asbestos in Ontario. Ontario, Canada: Ontario Ministry of the Attorney General, Publ., 73–112.
Eastes W, Hadley JG. 1995. Dissolution of fibers inhaled by rats. Inhal Toxicol 7:179–196.
*Eastes W, Hadley JG. 1996. A mathematical model of fiber carcinogenicity and fibrosis in inhalation and intraperitoneal experiments in rats. Inhal Toxicol 8:323–343.
*Edelman DA. 1988a. Exposure to asbestos and the risk of gastrointestinal cancer: A reassessment. Br J Ind Med 45:75–82.3342198
Edelman DA. 1988b. Exposure to asbestos and the risk of gastrointestinal cancer [Letter]. Br J Ind Med 45:574–576.
*Edelman DA. 1988c. Asbestos exposure, pleural plaques and the risk lung cancer. Int Arch Occup Environ Health 60:389–393.3045007
*Edelman DA. 1989. Laryngeal cancer and occupational exposure to asbestos. Int Arch Occup Environ Health 61:223–227.2656525
Edelman DA. 1992. Does asbestos exposure increase the risk of urogenital cancer? Int Arch Occup Environ Health 63:469–475.1577526
*Edward AT, Whitaker D, Browne K, . 1996. Mesothelioma in a community in the north of England. Occup Environ Med 53:547–552.8983466
Egilman D, Reinert A. 1996. Lung cancer and asbestos exposure: Asbestosis is not necessary. Am J Ind Med 30:398–406.8892544
Egilman DS, Reinert A. 2000. Corruption of previously published asbestos research. Arch Environ Health 55(1):75–76.10735525
Egilman DA, Goldin AS, Golding GA. 1996. Mesothelioma: An unwarranted causal model. J Occup Environ Med 38:239–240.8882093
Ehrenreich T, Selikoff IJ. 1981. Asbestos fibers in human lung: Forensic significance. Am J Forensic Med Pathol 2:67–74.6458205
Ehrlich A, Gordon RE, Dikman SH. 1991. Carcinoma of the colon in asbestos-exposed workers: Analysis of asbestos content in colon tissue. Am J Ind Med 19:629–636.1647135
*Ehrlich R, Lilis R, Chan E, . 1992. Long term radiological effects of short term exposure to amosite asbestos among factory workers. Br J Ind Med 49:268–275.1315154
Elferink JGR. 1989. Chrysotile asbestos-induced cytotoxicity and calcium-dependent exocytosis in polymorphonuclear leukocytes. Res Commun Chem Pathol Pharmacol 65:361–372.2554437
Elferink JGR, Kelters I. 1991. Chrysotile asbestos-induced membrane damage in human erythrocytes. Res Commun Chem Pathol Pharmacol 73:355–365.1719594
*Ellenhorn MJ, Schonwald S, Ordog G ., eds. 1997. Ellenhorn’s medical toxicology: Diagnosis and treatment of human poisoning. 2^nd^ ed. Baltimore, MD: Williams & Wilkins.
Elmes P. 1994. Mesotheliomas and chrysotile. Ann Occup Hyg 38:547–553.7978977
Elmes P, Browne K. 1986. Mesothelioma shortly after brief exposure to asbestos [Letter]. Lancet 1:746.2870260
Elstner EF, Schueltz W, Vogl G. 1988. Cooperative stimulation by sulfite and crocidolite asbestos fibres of enzyme catalyzed production of reactive oxygen species. Arch Toxicol 62:424–427.2854963
*Emerit I, Jaurand MC, Saint-Etienne L, . 1991. Formation of a clastogenic factor by asbestos-treated rat pleural mesothelial cells. Agents Actions 34(3–4):410–415.1667247
*EMMIWIN. 1997. Environmental monitoring methods index, Ver 1.1 Environ Dynamics, Inc. McLean, VA.
*Enarson DA, Embree V, MacLean L, . 1988. Respiratory health in chrysotile asbestos miners in British Columbia: A longitudinal study. Br J Ind Med 45:459–463.2840111
Englund A. 1995. Recent data on cancer due to asbestos in Sweden. Med Lav 86:435–439.8684293
*Enterline PE, Henderson VL. 1987. Geographic patterns for pleural mesothelioma deaths in the United States, 1968-81. J Natl Cancer Inst 79:31–37.3474447
Enterline PE, Kendrick MA. 1967. Asbestos-dust exposures at various levels and mortality. Arch Environ Health 15:181–186.4951708
*Enterline PE, Hartley J, Henderson V. 1987. Asbestos and cancer: A cohort followed up to death. Br J Ind Med 44:396–401.3606968
*Environmental Defense. 2001. Asbestos. CalEPA Air Resources Board Toxic Air Contaminant Summary, Environmental Defense. Http://www.scorecard.org/chemical-profiles/html/asbesots.html. January 19, 2001.
*EPA. 1976. Asbestos fibers in natural runoff and discharges from sources manufacturing asbestos products. Pt II Non-point sources and point sources manufacturing asbestos products. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA-560/6-76-020. NTIS No. PB-263746.
*EPA. 1977. Movement of selected metals, asbestos, and cyanide in soil: Applications to waste disposal problems. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2-77-020. NTIS No. PB-266905.
EPA. 1978a. Development of a rapid analytical method for determining asbestos in water. Report to U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory, Athens, GA, by Battelle Columbus Laboratories. EPA-600/4-78-066.
EPA. 1978b. Fate of ingested chrysotile asbestos fiber in the newborn baboon. Report to U.S. Environmental Protection Agency, Office of Research and Development, Health Effects Research Laboratory, Cincinnati, OH, by University of Illinois, School of Public Health. EPA-600/1-78-069. NTIS PB 291686.
EPA. 1979a. Effects of selected asbestos fibers on cellular and molecular parameters. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/1-79-021. NTIS No. PB-299199.
*EPA. 1979b. Exposure to asbestos from drinking water in the United States. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/1-79-028. NTIS No. PB-300444.
*EPA. 1979c. Water-related environmental fate of 129 priority pollutants. Vol I. Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standards. EPA-440/4-79-029a. NTIS No. PB80-204373.
*EPA. 1980a. Ambient water quality criteria for asbestos. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA 440/5-80-022. PB81-117335.
EPA. 1980b. Interim method for determining asbestos in water. Atlanta, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/4-80-005.
EPA. 1980c. Chemical contaminants in nonoccupationally exposed U.S. residents. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/1-80-001. NTIS No. PB80-192339.
EPA. 1982. Intermedia priority pollutant guidance documents. Washington, DC: U.S. Environmental Protection Agency, Office of Toxics Integration, Office of Pesticides and Toxic Substances.
EPA. 1983. Treatability manual. Vol I. Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/2-82-001a.
EPA. 1984a. Health effects for asbestos. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA 540/1-86/049.
EPA. 1984b. Final report: Asbestos in buildings: National survey of asbestos-containing friable materials. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
EPA. 1984c. Evaluation of turbidometric methods for monitoring of asbestos fibers in water. Athens, GA: U.S. Environmental Protection Agency, Office of Research and Development. EPA-600/4-84-071. NTIS PB84-232511.
*EPA. 1985a. Drinking water criteria document for asbestos. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Criteria and Assessment office. EPA 600/X-84-199-1.
*EPA. 1985b. U.S. Environmental Protection Agency. Federal Register 50:13456–13522.
EPA. 1985c. U.S. Environmental Protection Agency. Federal Register 50:46936–47022.
EPA. 1985d. Environmental release of asbestos from commercial product shaping. Cincinnati, OH: U.S. Environmental Protection Agency, Water Engineering Research Laboratory. EPA/600/S2-85/044.
*EPA. 1986a. Airborne asbestos health assessment update. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environment Assessment. EPA/600/8-84/003F.
EPA. 1986b. U.S. Environmental Protection Agency. Federal Register 51:3738–3759.
EPA. 1986c. Reference values for risk assessment. Final draft. Cincinnati OH: U.S. Environmental Protection Agency, Office of Solid Waste. ECAO-CIN-477.
EPA. 1986d. U.S. Environmental Protection Agency. Federal Register 51:15722–15733.
EPA. 1987a. U.S. Environmental Protection Agency. Federal Register 52:8140–8171.
EPA. 1987b. U.S. Environmental Protection Agency. Federal Register 52:41826–41835.
EPA. 1987c. Toxic air pollutant/source crosswalk: A screening tool for locating possible sources emitting toxic air pollutants. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA-450/4-87-023a.
*EPA. 1987d. Asbestos-containing materials in schools. U.S. Environmental Protection Agency. Federal Register 40CFR 763.
EPA. 1987e. Reference dose (RfD): Description and use in health risk assessments. Vol. I. Appendix A: Integrated risk information system supportive documentation. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-86/032a.
EPA. 1988a. U.S. Environmental Protection Agency. Federal Register 53:38642–38654.
EPA. 1988b. U.S. Environmental Protection Agency. Federal Register 53:4500–4539.
*EPA. 1988c. EPA study of asbestos-containing materials in public buildings: A report to Congress. Washington, DC: U.S. Environmental Protection Agency.
EPA. 1988d. Assessing asbestos exposure in public buildings. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA 560/5-88-002.
EPA. 1988e. U.S. Environmental Protection Agency. Federal Register 53:40615.
EPA. 1988f. Comparative mesothelioma induction in rats by asbestos and nonasbestos mineral fibers: possible correlation with human exposure data. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory. NTIS No. PB88-250246.
EPA. 1988g. Additional analysis of EPA’s 1984 asbestos survey data. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA 560/5-88-010.
EPA. 1988h. General pretreatment regulations for existing and new sources of pollution. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 403 (plus Appendix B).
*EPA. 1988i. Asbestos exposure assessment. Revised report. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1988j. Chromosomal changes associated with tumorigenic mineral fibers. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory, Office of Research and Development. EPA/600/D-88/222. NTIS No. PB89-124739.
EPA. 1989a. Exposure factors handbook. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-89/043.
EPA. 1989b. Interim methods for development of inhalation references doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA 600/8-88/066F.
*EPA. 1989c. U.S. Environmental Protection Agency. Federal Register 54:36315–36316, 38436.
EPA. 1989d. U.S. Environmental Protection Agency. Federal Register 54:912–937.
*EPA. 1989e. U.S. Environmental Protection Agency. Federal Register 54:22062–22160.
*EPA. 1989f. U.S. Environmental Protection Agency. Federal Register 54:29460–29513.
EPA. 1989g. U.S. Environmental Protection Agency. Federal Register 54:32430, 33449–33450.
EPA. 1989h. Guidelines for conducting the AHERA TEM clearance test to determine completion of an asbestos abatement project. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances, NTIS No. PB90-171778.
EPA. 1989i. U.S. Environmental Protection Agency. Federal Register 54:15622–15627.
*EPA. 1990a. U.S. Environmental Protection Agency. Federal Register 55:48406–48433.
EPA. 1990b. U.S. Environmental Protection Agency. Federal Register 55:5144–5162, 20522–20523.
*EPA. 1990c. Environmental asbestos assessment manual: Superfund method for the determination of asbestos in ambient air: Part 2: Technical background document. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA-540/2-90/005b.
*EPA. 1990d. Environmental asbestos assessment manual: Method for the Determination of Asbestos in Ambient Air, Part 1: Method. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA/540/2-90/005a. NTIS No. PB90-274283.
EPA. 1991a. U.S. Environmental Protection Agency. Federal Register 56:3526–3528, 3536, 3548, 3565, 11421–11422.
*EPA. 1991b. Indoor-air assessment: Indoor concentrations of environmental carcinogens. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA/600/8-90/042. NTIS No. PB91-193847.
*EPA. 1992a. U.S. Environmental Protection Agency. Federal Register 57:11364–11365.
*EPA. 1992b. U.S. Environmental Protection Agency. Federal Register 57:31576–31592.
*EPA. 1992c. Asbestos concentrations two years after abatement in seventeen schools. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development. EPA 600/R-92/027.
EPA. 1992d. U.S. Environmental Protection Agency. Federal Register 57:11412–11413.
EPA. 1993a. Test method for the determination of asbestos in bulk building materials. Washington, DC: U.S. Environmental Protection Agency. EPA 600/R-93/116.
EPA. 1993b. Quantitative evaluation of HEPA filtration systems at asbestos abatement sites. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Risk Reduction Engineering Laboratory. EPA/600/J-93/498. NTIS PB94-136116.
EPA. 1994. Drinking water regulations and health advisories. Washington, DC: U.S. Environmental Protection Agency. May 1994.
EPA. 1995. Final decision not to issue new regulations for asbestos processing facilities under the air toxics provision of the Clean Air Act Amendments of 1990. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Http://www.epa.gov/ttnuatw1/fsasbes.html. May 11, 1999.
EPA. 1996. Drinking water regulations and health advisories. Washington DC: U.S. Environmental Protection Agency, Office of Water. EPA 822-B-96-002.
*EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency. EPA/630/R-96/012.
*EPA. 1998a. Technical drinking water and health contaminant specific fact sheets. Washington, DC: U.S. Environmental Protection Agency, Office of Water. Http://www.epa.gov/ogwdw000/dwh/t-ioc/asbestos.htm. April 29, 1999.
*EPA. 1998b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1998c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 763 Subpart G.
EPA. 1998d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
EPA. 1998e. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.30.
*EPA. 1999a. National recommended water quality criteria - Correction. Washington, DC: U. S. Environmental Protection Agency, Office of Water. EPA 822-Z-99-001.
*EPA. 1999b. Toxic chemical release inventory reporting forms and instructions. U. S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. EPA 745-K-99-001.
EPA. 1999c. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations, National Archives and Records Administration. 40 CFR 302.4. Http:www.access.gpo.gov.nara/cfr/cfr-table-search.html (http://www.access.gpo.gov.nara/cfr/cfr-table-search.html). January 15, 2001.
*EPA. 2000a. Asbestos-containing materials in schools. U.S. Environmental Protection Agency. Code of Federal Regulations, National Archives and Records Administration. 40 CFR 763. Http://www.access.gpo.gov/nara/cfr/cfr-table-search.html. January 23, 2001.
*EPA. 2000b. Drinking water standards and health advisories. Washington, DC: U. S. Environmental Protection Agency, Office of Water. Http://www.epa.gov/ow/search.html. January 18, 2001.
*EPA. 2000c. National emission standards for hazardous air pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations, National Archives and Records Administration. 40 CFR 61.01. Http://www.access.gpo.gov/nara/cfr/cfr-table-search.html. January 23,2001.
*EPA. 2000d. Sampling and analysis of consumer garden products that contain vermiculite. Washington, DC: U.S. Environmental Protection Agency, Office of Prevention, Pesticides and Toxic Substances. EPA 744-R-00-010.
*EPA. 2001a. Asbestos: Hazard summary. Washington, DC: U. S. Environmental Protection Agency, Office of Air and Radiation. Http://www.epa.gov/ttnuatw1/hlthef/asbestos.html. January 18,2001.
*EPA. 2001b. Technical drinking water and health: Contaminant specific fact sheets for consumers. Washington, DC: U. S. Environmental Protection Agency, Office of Water. Http;//www.epa.gov/safewater/dwh/c-ioc/asbestos.html (http://www.epa.gov/safewater/dwh/c-ioc/asbestos.html). January 18, 2001.
*EPA. 2001c. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. Http://www.access.gpo.gov/nara/cfr/cfrhtml_00/Title_40/40cfr20_00.html. May 01, 2001.
Epstein PE. 1992. Asbestos inhalation and nonmalignant abnormalities of the chest. Semin Roentgenol 27:85–93.1609304
Erdogdu G, Hasirci V. 1998. An overview of the role of mineral solubility in silicosis and asbestosis. Environ Res 78:38–42.9630443
Erdreich LS. 1983. Comparing epidemiologic studies of ingested asbestos for use in risk assessment. Environ Health Perspect 53:99–104.6662098
*Ernst P, Dales RE, Nunes F, . 1989. Relation of airway responsiveness to duration of work in a dusty environment. Thorax 44:116–120.2648647
Erren TC, Jacobsen M, Piekarski C. 1999. Synergy between asbestos and smoking on lung cancer risks. Epidemiology 10(4):405–411.10401875
*Erzen C, Eryilmaz M, Kalyoncu F, . 1991. CT findings in malignant pleural mesothelioma related to nonoccupational exposure to asbestos and fibrous zeolite (erionite). J Comput Assist Tomogr 15:256–260.1848247
*Esmen NA, Corn M. 1998. Airborne fiber concentrations during splitting open and boxing bags of asbestos. Toxicol Ind Health 14(6):843–856.9891915
*Evans JC, Evans RJ, Holmes A, . 1973. Studies on the deposition of inhaled fibrous material in the respiratory tract of the rat and its subsequent clearance using radioactive tracer techniques. 1. UICC crocidolite asbestos. Environ Res 6:180–201.4576668
EXICHEM Data Base. 1989. Organization for Economic Cooperation and Development.
*Fasske E. 1988. Experimental lung tumors following specific intrabronchial application of chrysotile asbestos. Longitudinal light and electron microscopic investigations in rats. Respir 53:111–127.
Fasy TM. 1991. Asbestos fibers are mutagenic after all: New signs of orthodoxy for a paradoxical group of carcinogens. Ann NY Acad Sci 271–279.1809140
*Fatma N, Jain AK, Rahman Q. 1991. Frequency of sister chromatid exchange and chromosomal aberrations in asbestos cement workers. Br J Ind Med 48:103–105.1998603
*Fatma N, Khan SG, Aslam M, . 1992. Induction of chromosomal aberrations in bone marrow cells of asbestotic rats. Environ Res 57:175–180.1314734
*Faux SP, Howden PJ. 1997. Possible role of lipid peroxidation in the induction of NF-KB and AP-1 in RFL-6 cells by crocidolite asbestos: Evidence following protection by vitamin E. Environ Health Perspect Suppl 105:1127–1130.9400711
*Faux SP, Howden PJ, Levy LS. 1994. Iron-dependent formation of 8-hydroxydeoxyguanosine in isolated DNA and mutagenicity in salmonella typhimurium TA102 induced by crocidolite. Carcinogenesis 15:1749–1751.8055658
FDA. 1994. Indirect food additives: Adhesives and components of coatings. U.S. Department of Health and Human Services, U.S. Food and Drug Administration. Code of Federal Regulations 21 CFR 175.
FDA. 1998. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 175.105.
*FDA. 2000a. Food and drugs: Indirect food additives: Adhesives and components of coatings. U.S. Food and Drug Administration. Code of Federal Regulations, National Archives and Records Administration. 21 CFR 175.105. Http://frwebgate.access.gpo.gov/cgi…175&SECTION=105&YEAR=2000&TYPE=TEXT. January 18, 2001.
*FDA. 2000b. Food and drugs: Indirect food additives: Polymers. U.S. Food and Drug Administration. Code of Federal Regulations, National Archives and Records Administration. 21 CFR 177.2410. Http://frwebgate.access.gpo.gov/cgi…77&SECTION=2410&YEAR=2000&TYPE=TEXT. January 23, 2001.
*FDA. 2000c. Food and drugs: Indirect food additives: Polymers. U.S. Food and Drug Administration. Code of Federal Regulations, National Archives and Records Administration. 21 CFR 177.2420. Http://frwebgate.access.gpo.gov/cgi…77&SECTION=2420&YEAR=2000&TYPE=TEXT. January 23, 2001.
Fear NT, Roman E, Carpenter LM, . 1996. Cancer in electrical workers: An analysis of cancer registrations in England, 1981-87. Br J Cancer 73:935–939.8611410
FEDRIP. 1994. Federal Research in Progress [database]. Dialog Information Retrieval System, CA.
FEDRIP. 1999. Federal Research in Progress [database]. Dialog Information Retrieval System, CA.
*FEDRIP. 2000. Federal Research in Progress [database]. Dialog Information Retrieval System, CA.
*FEDRIP. 2001. Federal Research in Progress [database]. Dialog Information Retrieval System, CA.
Feige MA, Clark PJ, Brackett KA. 1993. Guidance and clarification for the current U.S. EPA test method for asbestos in drinking water. Environmental Choices Technical Supplement Fall 1993. Cincinnati, OH: IT Corp. NTIS publication no. PB94-126108.
Felton JS, Sargent EN, Gordonson JS. 1980. Radiographic changes following asbestos exposure: Experience with 7,500 workers. J Occup Med 22(1):15–20.7354408
*Finkelstein M. 1986. Pulmonary function in asbestos cement workers: A dose-response study. Br J Ind Med 43:406–413.3718885
*Finkelstein MM. 1983. Mortality among long-term employees of an Ontario asbestos-cement factory. Br J Ind Med 40:138–144.6830709
Finkelstein MM. 1989. Mortality among employees of an Ontario factory that manufactured construction materials using chrysotile asbestos and coal tar pitch. Am J Ind Med 16:281–287.2782316
Finkelstein MM. 1991. Analysis of the exposure-response relationship for mesothelioma among asbestos-cement factory workers. Ann NY Acad Sci 85–89.
*Finkelstein MM. 1995. Potential pitfall in using cumulative exposure in exposure-response relationships: Demonstration and discussion. Am J Ind Med 28:41–47.7573074
Finkelstein MM. 1996. Asbestos-associated cancer in the Ontario refinery and petrochemical sector. Am J Ind Med 30:610–615.8909610
*Finkelstein MM, Dufresne A. 1999. Inferences on the kinetics of asbestos deposition and clearance among chrysotile miners and millers. Am J Ind Med 35:401–412.10086201
Finkelstein MM, Vingilis JJ. 1984. Radiographic abnormalities among asbestos-cement workers: An exposure-response study. Am Rev Respir Dis 129:17–22.6703476
*Finn MB, Hallenbeck WH. 1984. Detection of chrysotile asbestos in workers’ urine. Am Ind Hyg Assoc J 45:752–759.6095633
Fischbein A, Luo J-C, Lacher M, . 1993. Respiratory findings among millwright and machinery erectors: Identification of health hazards from asbestos in place at work. Environ Res 61(1):25–35.8472674
Fischbein A, Luo J-C, Pinkston GR. 1991a. Asbestosis, laryngeal carcinoma, and malignant peritoneal mesothelioma in an insulation worker. Br J Ind Med 48(5):338–341.2039746
Fischbein A, Luo J-C, Rosenfeld S, . 1991b. Respiratory findings among ironworkers: Results from a clinical survey in the New York metropolitan area and identification of health hazards from asbestos in place at work. Br J Ind Med 48(6):404–411.2064979
Fisher CE, Brown DM, Shae J, . 1998. Respirable fibres: Surfactant coated fibres release more Fe3+ than native fibres at both pH 4.5 and 7.2. Ann Occup Hyg 42:337–345.9729922
Fisher CE, Rossi AG, Shaw J, . 2000. Release of TNFα in response to SiC fibres: Differential effects in rodent and human primary macrophages, and in macrophage-like cell lines. Toxicol in Vitro 14:25–31.10754660
Fisher GL, Mossman BT, McFarland AR, . 1987. A possible mechanism of chrysotile asbestos toxicity. Drug Chem Toxicol 10:109–131.2824165
Fitzgerald EF, Stark AD, Vianna N, . 1991. Exposure to asbestiform minerals and radiographic chest abnormalities in a talc mining region of upstate New York. Arch Environ Health 46:151–154.2039269
*Flejter WL, Li FP, Antman KH, . 1989. Recurring loss involving chromosomes 1, 3, and 22 in malignant mesothelioma: Possible sites of tumor suppressor genes. Genes Chromosomes Cancer 1:148–154.2487155
*Fligiel Z, Kaneko M. 1976. Malignant mesothelioma of the tunica vaginalis propria testis in a patient with asbestos exposure. Cancer 37:1478–1484.1260666
Fogel P, Morsheidt C, Hanton D, . 1998. A formula for predicting the tumor incidence in intraperitoneal experiments with mineral fibers. Inhal Toxicol 10:875–893.
*Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Fontecave M, Jaouen M, Mansuy D, . 1990. Microsomal lipid peroxidation and oxy-radicals formation are induced by insoluble iron-containing minerals. Biochem Biophys Res Commun 173:912–918.2176494
*Fowler DP. 2000. Exposures to asbestos arising from bandsawing gasket material. Appl Occup Environ Hyg 15(5):404–408.10808262
*Fraire AE, Cooper S, Greenberg SD, . 1988. Mesothelioma of childhood. Cancer 62:838–847.3293765
Frank AL. 1982. The epidemiology and etiology of lung cancer. Clin Chest Med 3:219–228.7047057
*Frank AL, Dodson RF, Williams MG. 1998. Carcinogenic implications of the lack of tremolite in UICC reference chrysotile. Am J Ind Med 34:314–317.9750936
Freed JA, Miller A, Gordon RE, . 1991. Desquamative interstitial pneumonia associated with chrysotile asbestos fibers. Br J Ind Med 48(5):332–337.1645584
*Friedman AC, Fiel SB, Fisher MS, . 1988. Asbestos-related pleural disease and asbestosis: A comparison of CT and chest radiography. Am J Roentgenol 150:269–275.3257311
Friemann J, Mueller KM, Pott F. 1990. Mesothelial proliferation due to asbestos and man-made fibres. Path Res Pract 186:117–123.2156241
*Froom P, Lahat N, Kristal-Boneh E, . 2000. Circulating natural killer cells in retired asbestos cement workers. J Occup Environ Med 42:19–24.10652684
*Frumkin H, Berlin J. 1988. Asbestos exposure and gastrointestinal malignancy review and meta-analysis. Am J Ind Med 14:79–95 3044065
FSTRAC. 1990. Summary of state and federal drinking water standards and guidelines. Washington, DC: Federal-State Toxicology and Regulatory Alliance Committee, Chemical Communication Subcommittee.
*FSTRAC. 1999. Federal-State Toxicology and Risk Analysis Committee. U. S. Environmental Protection Agency, Office of Water. May 20, 1999. Http://www.epa.gov/ostwater/fstrac/states.html. May 20, 1999.
Fubini B. 1997. Surface reactivity in the pathogenic response to particulates. Environ Health Perspect Suppl 105:1013–1020.9400693
*Fung H, Kow YW, Van Houten B, . 1997a. Patterns of 8-hydroxydeoxyguanosine formation in DNA and indications of oxidative stress in rat and human pleural mesothelial cells after exposure to crocidolite asbestos. Carcinogenesis 18:825–832.9111221
Fung H, Kow YW, Van Houten B, . 1998. Asbestos increases mammalian AP-endonuclease gene expression, protein levels, and enzyme activity in mesothelial cells. Cancer Res 58:189–194.9443389
*Fung H, Quinlan TR, Janssen YMW, . 1997b. Inhibition of protein kinase C prevents asbestos-induced c-fos and c-jun proto-oncogene expression in mesothelial cells. Cancer Res 57:3101–3105.9242432
Gabrielson EW, Rosen GM, Grafstrom RC, . 1986. Studies on the role of oxygen radicals in asbestos-induced cytopathology of cultured human lung mesothelial cells. Carcinogenesis 7:1161–1164.2872977
Gabrielson EW, Van der Meeren A, Reddel RR, . 1992. Human mesothelioma cells and asbestos-exposed mesothelial cells are selectively resistant to amosite toxicity: A possible mechanism for tumor promotion by asbestos. Carcinogenesis 13:1359–1363.1323425
Gaensler EA. 1992. Asbestos exposure in buildings. Occup Lung Diseases 13:231–242.
Gaensler EA, Jederlinic PJ, Churg A. 1991. Idiopathic pulmonary fibrosis in asbestos-exposed workers. Am Rev Respir Dis 144(3):689–696.1892312
*Gamble JF. 1994. Asbestos and colon cancer: A weight-of-the-evidence review. Environ Health Perspect 102:1038–1050.7713017
*Gamsu G, Aberle DR, Lynch D. 1989. Computed tomography in the diagnosis of asbestos-related thoracic disease. J Thorac Imag 4:61–67.
*Garabrant DH, Peters RK, Homa DM. 1992. Asbestos and colon cancer: Lack of association in a large case-control study. Am J Epidemiol 135:843–853.1585897
*Garcia JGN, Gray LD, Dodson RF, . 1988. Asbestos-induced endothelial cell activation and injury. Demonstration of fiber phagocytosis and oxidant-dependent toxicity. Am Rev Respir Dis 138:958–964.3202471
*Garcia JGN, Griffith DE, Cohen AB, . 1989. Alveolar macrophages from patients with asbestos exposure release increased levels of leukotriene B_4_. Am Rev Respir Dis 139:1494–1501.2543249
Garcia-Closas M, Christiano DC. 1995. Asbestos-related diseases in construction carpenters. Am J Ind Med 27:115–125.7900729
Gardner MJ, Powell CA, Gardner AW, . 1988. Continuing high lung cancer mortality among ex-amosite asbestos factory workers and a pilot study of individual anti-smoking advice. J Soc Occup Med 38:69–72.2902246
*Gaumer HR, Doll NJ, Kaimal J, . 1981. Diminished suppressor cell function in patients with asbestosis. Clin Exp Immunol 44:108–116.6455225
*Gefter WB, Conant EF. 1988. Issues and controversies in the plain-film diagnosis of asbestos-related disorders in the chest. J Thorac Imaging 3:11–28.3054135
Geisler O. 1991. Occupational health and hygiene following a fire in a warehouse with an asbestos cement roof [Letter; Comment]. J Soc Occup Med 41(3):143.1656144
Geist LJ, Powers LS, Monick MM, . 2000. Asbestos stimulation triggers differential cytokine release from human monocytes and alveolar macrophages. Exp Lung Res 26:41–56.10660835
*Gendek EG, Brody AR. 1990. Changes in lipid ordering of model phospholipid membranes treated with chrysotile and crocidolite asbestos. Environ Res 53:152–167.2174769
Gennaro V, Ceppi M, Boffetta P, . 1994. Pleural mesothelioma and asbestos exposure among Italian oil refinery workers. Scand J Work Environ Health 20:213–215.7973494
*Gerhardsson de Verdier M, Plato N, Steineck G, . 1992. Occupational exposures and cancer of the colon and rectum. Am J Ind Med 22(3):291–303.1519614
Gevenous PA, de Maertelaer V, Madani A, . 1998. Asbestosis, pleural plaques and diffuse pleural thickening: Three distinct benign responses to asbestosis exposure. Eur Resp J 11:1021–1027.
Ghio AJ, Crumbliss AL. 1992. Surface complexation of Fe^3+^ by silica and silicate dusts increases in vitro oxidant generation but diminishes in vitro cytotoxicity. Durham, NC: Duke University Medical Center, Division of Allergy, Critical Care, and Respiratory Medicine, Department of Medicine.
*Ghio AJ, Kadiiska MB, Xiang QH, . 1998. In vivo evidence of free radical formation after asbestos instillation: An ESR spin trapping investigation. Free Radic Biol Med 24:11–17.9436609
Ghio AJ, Kennedy TP, Schapira RM, . 1990. Hypothesis: Is lung disease after silicate inhalation caused by oxidant generation? Lancet 336:967–969.1977006
*Ghio AJ, LeFrugey A, Roggli VL. 1997. In vivo accumulation of iron on crocidolite is associated with decrements in oxidant generation by the fiber. J Toxicol Environ Health 50:125–142.9048957
Giarelli L, Bianchi C, Grandi G. 1992. Malignant mesothelioma of the pleura in Trieste, Italy. Am J Ind Med 22(4):521–530.1442787
Giaroli C, Bruno C, Candela S, . 1994. Mortality study of asbestos cement workers. Int Arch Occup Environ Health 66(1):7–11.7927845
Gibbs AR, Gardner MJ, Pooley FD, . 1994. Fiber levels and disease in workers from a factory predominantly using amosite. Environ Health Perspect Suppl 102:261–263.7882947
Gibbs AR, Griffiths DM, Pooley FD, . 1990. Comparison of fibre types and size distributions in lung tissues of paraoccupational and occupational cases of malignant mesothelioma. Br J Ind Med 47:621–626.2207033
Gibbs AR, Jasani B, Pepper C, . 1998. SV40 DNA sequences in mesotheliomas. In: Brown F, Lewis AM, ed. Simian virus 40 (SV40): A possible human polyomavirus. Basel: Karger, 41–45.
Gibbs AR, Stephens M, Griffiths DM, . 1991. Fibre distribution in the lungs and pleura of subjects with asbestos related diffuse pleural fibrosis. Br J Ind Med 48:762–770.1659443
*Gibbs GW. 1979. Etiology of pleural calcification: A study of Quebec chrysotile asbestos miners and millers. Arch Environ Health 34:76–83.434935
Gibbs GW. 1994. The assessment of exposure in terms of fibres. Ann Occup Hyg 38(4):477–487.7978969
Gillam JD, Dement JM, Lemen RA, . 1976. Mortality patterns among hard rock gold miners exposed to an asbestiform mineral. Ann NY Acad Sci 271:336–344.1069522
Gilmour PS, Brown DM, Beswick PH, . 1997. Free radical activity of industrial fibers: Role of iron in oxidative stress and activation of transcription factors. Environ Health Perspect Suppl 105:1313–1317.9400744
Gilson JC. 1971. Asbestos. In: Encyclopedia of occupational health and safety. New York, NY: McGraw Hill, 120–124.
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101:65–71.
Glass W, Kawachi I, Pearce N. 1991. Lung cancer, smoking and exposure to asbestos in New Zealand. Journal of Occupational Health and Safety of Australia and New Zealand 7(1):43–47.
*Glencross PM, Weinberg JM, Ibrahaim JG, . 1997. Loss of lung function among sheet metal workers: Ten-year study. Am J Ind Med 32:460–466.9327069
Gold J, Amandusson H, Krozer A, . 1997. Chemical characterization and reactivity of iron chelator-treated amphibole asbestos. Environ Health Perspect Suppl 5:1021–1030.9400694
Goldberg P, Luce D, Billon-Galland MA, . 1995. Potential role of environmental and domestic exposure to tremolite in pleural cancer in New Caledonia. Rev Epidemiol Sante Publique 43:444–450.7501891
*Goldfrank LR, Flomenbaum NE, Lewin NA ., eds. 1998. Goldfrank’s toxicologic emergencies. 6^th^ ed. Stanford, CT: Appleton & Lange.
*Goldstein B, Coetzee FSJ. 1990. Experimental malignant mesothelioma in baboons. South Africa J Sci 86:89–93.
Gonzalez S, Friemann J, Mueller KM, . 1991. Ultrastructure of mesothelial regeneration after intraperitoneal injection of asbestos fibres on rat omentum. Path Res Pract 187:931–935.1665227
*Goodglick LA, Kane AB. 1990. Cytotoxicity of long and short crocidolite asbestos fibers in vitro and in vivo. Cancer Res 50:5153–5163.2165857
*Goodglick LA, Pietras LA, Kane AB. 1989. Evaluation of the causal relationship between crocidolite asbestos-induced lipid peroxidation and toxicity to macrophages. Am Rev Respir Dis 139:1265–1273.2540689
Goodman GE, Omenn GS. 1992. Carotene and retinol efficacy trial: Lung cancer chemoprevention trial in heavy cigarette smokers and asbestos-exposed workers. CARET Coinvestigators and Staff. Adv Exp Med Biol 320:137–40.1442278
*Goodman M, Morgan RW, Ray R, . 1999. Cancer in asbestos-exposed occupational cohorts: a meta-analysis. Cancer Causes Control 10:453–465.10530617
Gormley IP, Bolton RE, Brown GM, . 1983. Some observations on the in vitro cytotoxicity of chrysotile prepared by the wet dispersion process. Environ Health Perspect 51:35–39.6315378
Gosselin RE, Smith RP, Hodge HC. 1984. Toxicity information about selected ingredients. In: Clinical toxicology of commercial products. 5th ed. Baltimore, MD: Williams and Wilkins, II–94.
Governa M, Amati M, Fontana S, . 1999. Role of iron in asbestos-body-induced oxidant radical generation. J Toxicol Environ Health A 58:279–287.10598953
Governa M, Amati M, Valentino M, . 2000. In vitro cleavage by asbestos fibers of the fifth component of human complement through free-radical generation and kallikrein activation. J Toxicol Environ Health A 59:539–552.10777245
*Graceffa P, Weitzman SA. 1987. Asbestos catalyzes the formation of the 6-oxobenzo[a]pyrene radical from 6-hydroxybenzo[a]pyrene. Arch Biochem Biophysics 257:481–484.
*Greaves IA. 1979. Rheumatoid “pneumoconiosis” (Caplan’s syndrome) in an asbestos worker: A 17 years’ follow-up. Thorax 34:404–405.483218
*Green FH, Harley R, Vallyathan V, . 1986. Pulmonary fibrosis and asbestos exposure in chrysotile asbestos textile workers: Preliminary results. In: Accomplishments in oncology. The biological effects of chrysotile. Vol. 1, No. 2, 59–68.
*Green FHY, Harley R, Vallyathan V, . 1997. Exposure and mineralogical correlates of pulmonary fibrosis in chrysotile asbestos workers. Occup Environ Med 54:549–559.9326158
Greenberg M. 1994. Dust exposure and mortality in chrysotile mining, 1910-76. Occup Environ Med 51:431.
Greenberg M. 1997. History of mesothelioma. Eur Resp J 10:2690–2691.
Greenberg M. 1998. The priority for recognizing asbestos as a multicentre carcinogen, and problems in categorizing asbestos tumours. Eur Resp J 11:996.
Greenberg M. 1999. A study of lung cancer mortality in asbestos workers: Doll, 1955. Am J Ind Med 36:331–347.10469998
Greenblatt J. 1984. Evaluation of the EPA asbestos-in-schools identification and notification rule. Report to Battelle Columbus Laboratories, Washington, DC, by Westat, Inc., Rockville, MD.
Greene R, Boggis C, Jantsch H. 1982. Asbestos-related pleural thickening: Effect of threshold criteria on interpretation. Radiology 152:569–573.
Greene R, Schaefer CM, Oliver LC. 1991. Improved detection of asbestos-related pleural plaques with digital radiography. Ann NY Acad Sci 643(12):90–96.1809179
*Griffis LG, Pickrell JA, Carpenter PR, . 1983. Deposition of crocidolite asbestos and glass microfibers inhaled by the beagle dog. Amer Ind Hyg Assoc J 44(3):216–222.6303099
*Griffith DE, Miller EJ, Gray LD, . 1994. Interleukin-1-mediated release of interleukin-8 by asbestos-stimulated human pleural mesothelial cells. Am J Respir Cell Mol Biol 10(3):245–52.8117443
Grimson RC. 1987. Apportionment of risk among environmental exposures: Application to asbestos exposure and cigarette smoking. J Occup Med 29:253–255.3559770
Gross P, Harley RA. 1988. Asbestos-induced intrathoracic tissue reactions. Pittsburgh, PA: Industrial Health Foundation, Inc. PB88-248380.
*Gross P, deTreville RT, Tolker EB, . 1967. Experimental asbestosis: The development of lung cancer in rats with pulmonary deposits of chrysotile asbestos dust. Arch Environ Health 15:343–355.6035084
*Gross P, Harley RA, Swinburne LM, . 1974. Ingested mineral fibers: Do they penetrate tissue or cause cancer? Arch Environ Health 29:341–347.4429402
Guillemin B, Zhang Y, Lee TC, . 1991. Role of peptide growth factors in asbestos-related human lung cancer. Ann NY Acad Sci 245–257.
Guillemin MP, Madelaine P, Litzistorf G, . 1989. Asbestos in buildings. Aerosol Sci Technol 11:221–243.
*Guinee DGJ, Travis WD, Trivers GE, . 1995. Gender comparisons in human lung cancer: Analysis of p53 mutations, anti-p53 serum antibodies and C-erB-2 expression. Carcinogenesis 16:993–1002.7767998
Gulumian M. 1999. The role of oxidative stress in diseases caused by mineral dusts and fibres: Current status and future of prophylaxis and treatment. Mol Cell Biochem 196:69–77.10448904
Gulumian M, Bhoolia DJ, Du Toit RS, . 1993. Activation of UICC crocidolite: The effect of conversion of some ferric ions to ferrous ions. Environ Res 60(2):193–206.8386081
Gun RT. 1995. Mesothelioma: Is asbestos exposure the only cause? Med J Aust 162:429–432.7746179
Gustavsson P, Jakobsson R, Johansson H, . 1998. Occupational exposures and squamous cell carcinoma of the oral cavity, pharynx, larynx, and oesophagus: A case-control study in Sweden. Occup Environ Med 55:393–400.9764099
Guthrie GD. 1997. Mineral properties and their contributions to particle toxicity. Environ Health Perspect Suppl 5:1003–1011.9400692
*Guzelian PS, Henry CJ, Olin SS. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Gylseth B, Skaug V. 1986. Relation between pathological grading and lung fibre concentration in a patient with asbestosis. Br J Ind Med 43:754–759.3539176
*Gylseth B, Churg A, Davis JM, . 1985. Analysis of asbestos fibers and asbestos bodies in tissue samples from human lung: An international interlaboratory trial. Scand J Work Environ Health 11:107–110.4001898
*Habashi F, Awadalla FT, Page M. 1991. Surface modification of chrysotile asbestos with organic reagents: A preliminary in vitro toxicological study. CIM Bulletin 84:67–79.
Hahon N, Booth JA, Flowers L. 1990. Coinhibition of viral interferon induction by benzo[a]pyrene in association with occupation-related particles. Environ Res 52:83–98.2351130
Hall EJ, Hei TK. 1985. Oncogenic transformation with radiation and chemicals. Int J Radiat Biol 48:1–18.
Hall NEL, Rosenmann KD. 1991. Cancer by industry: Analysis of a population-based cancer registry with an emphasis on blue-collar workers. Am J Ind Med 19(2):145–159.1992675
Hallenbeck WH. 1983. Asbestos penetration of the gastrointestinal tract [Commentary]. Environ Health Perspect 53:153–154.6662085
Hallenbeck WH. 1988. Can we really evaluate the health risks due to exposure to airborne asbestos? The Environmental Professional 10:333–340.
*Hallenbeck WH, Patel-Mandlik KJ. 1979. Presence of fibers in the urine of a baboon gavaged with chrysotile asbestos. Environ Res 20:335–340.121078
*Hallenbeck WH, Chen EH, Hesse CS. 1978. Is chrysotile asbestos released from asbestos-cement pipe into drinking water? J AWWA (February):97–102.
Hammar SP. 1992. Controversies and uncertainties concerning the pathologic features and pathologic diagnosis of asbestosis. Sem Diag Path 9:102–109.
*Hammond EC, Selikoff IJ, Seidman H. 1979. Asbestos exposure, cigarette smoking and death rates. Ann NY Acad Sci 330:473–490.294198
Hansen J, de Klerk NH, Eccles JL, . 1993. Malignant mesothelioma after environmental exposure to blue asbestos. Int J Cancer 54(4):578–581.8390408
*Hansen J, de Klerk NH, Musk AW, . 1998. Environmental exposure to crocidolite and mesothelioma: Exposure-response relationships. Am J Respir Crit Care Med 157:69–75.9445280
*Hansen K, Mossman BT. 1987. Generation of superoxide (O_2_^.^-) from alveolar macrophages exposed to asbestiform and nonfibrous particles. Cancer Res 47:1681–1686.3028612
*Hansteen I-L, Hilt B, Lien JT, . 1993. Karyotypic changes in the preclinical and subsequent stages of malignant mesothelioma: A case report. Cancer Genet Cytogenet 70(2):94–98.7694791
*Haque AK, Kanz, MF. 1988. Asbestos bodies in children’s lungs. Arch Pathol Lab Med 112:514–518.3358652
*Haque AK, Vrazel DM. 1998. Transplacental transfer of asbestos in pregnant mice. Bull Environ Contam Toxicol 60:620–625.9557202
*Haque AK, Kanz MF, Mancuso MG, . 1991. Asbestos in the lungs of children. Ann NY Acad Sci 419–429.
*Haque AK, Mancugo MG, Williams MG, . 1992. Asbestos in organs and placenta of 5 stillborn infants suggests transplacental transfer. Environ Res 58(2):163–175.1511671
*Haque AK, Vrazel DM, Burau KD, . 1996. Is there transplacental transfer of asbestos? A study of 40 stillborn infants. Pediatr Pathol Lab Med 16:877–892.9025886
*Haque AK, Vrazel DM, Uchida T. 1998. Assessment of asbestos burden in the placenta and tissue digets of stillborn infants in South Texas. Arch Environ Contam Toxicol 35:532–538.9732488
*Hardy RJ, Highsmith VR, Costa DL, . 1992. Indoor asbestos concentrations associated with the use of asbestos-contaminated tap water in portable home humidifiers. Environ Sci Technol 26:680–689.
Harington JS. 1981. Fiber carcinogenesis: Epidemiologic observations and the Stanton hypothesis. J Natl Cancer Inst 67:977–989.7029102
Harington JS. 1991. The carcinogenicity of chrysotile asbestos. Ann NY Acad Sci 465–472.
Harkin TJ, McGuinness G, Goldring R, . 1996. Differentiation of the ILO boundary chest roentgenograph (0/1 to 1/0) in asbestosis by high-resolution computed tomography scan, alveolitis, and respiratory impairment. J Occup Environ Med 38:46–52.8871331
Harrington JM, Craun GF, Meigs JW, . 1978. An investigation of the use of asbestos cement pipe for public water supply and the incidence of gastrointestinal cancer in Connecticut, 1935-1973. Am J Epidemiol 107:96–103.623099
Harrison PT, Health JC. 1988. Apparent synergy between chrysotile asbestos and N-nitrosoheptamethyleneimine in the induction of pulmonary tumours in rats. Carcinogenesis 9:2165–2171.2847878
Harrison PTC, Levy LS, Patrick G, . 1999. Comparative hazards of chrysotile asbestos and its substitutes: A European perspective. Environ Health Perspect 107(8):607–611.10417355
Hatch GE, Boykin E, Graham JA, . 1985. Inhalable particles and pulmonary host defense: In vivo and in vitro effects of ambient air and combustion particles. Environ Res 36:67–80.3967645
*Hayashi I, Konishi N, Matsuda H, . 1996. Comparative analysis of p16/CDKN2, p53 and ras gene alterations in human non-small cell lung cancers, with and without associated pulmonary asbestosis. Int J Oncol 8:85–90.21544334
*Hayes AA, Mullan B, Lovegrove FT, . 1989. Gallium lung scanning and bronchoalveolar lavage in crocidolite-exposed workers. Chest 96:22–26.2544351
*Hayes AA, Venaille TJ, Rose AH, . 1990. Asbestos-induced release of a human alveolar macrophage-derived neutrophil chemotactic factor. Exp Lung Res 16:121–130.2184026
HazDat. 1994. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA.
HazDat. 1999. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. May 1999.
HazDat. 2000. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. May 2000.
*HazDat. 2001. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. Http://atsdr.cdc.gov/hazdat.html. June 13, 2001.
*HEI. 1991. Health Effects Institute. Asbestos in public and commercial buildings: A literature review and synthesis of current knowledge. Report of the asbestos literature review panel. Cambridge, MA: Health Effects Institute.
*HEI. 1992. Health Effects Institute. Asbestos in public and commercial buildings: Supplementary analyses of selected data previously considered by the literature review panel. Cambridge, MA: Health Effects Institute.
*Hei TK, Hall EJ, Osmak RS. 1984. Asbestos, radiation, and oncogenic transformation. Br J Cancer 50:717–720.6498070
*Hei TK, Piao CQ, He ZY, . 1992. Chrysotile fiber is a strong mutagen in mammalian cells. Cancer Res 52:6305–6309.1330290
Heineman EF, Bernstein L, Stark AD, . 1996. Mesothelioma, asbestos, and reported history of cancer in first-degree relatives. Cancer 77:549–554.8630964
*Heintz NH, Janssen YM, Mossman BT. 1993. Persistent induction of c-fos and c-jun expression by asbestos. Proc Natl Acad Sci U S A 90:3299–3303.8386370
Heler DS, Gordon RE, Turnnir R, . 1998. Presence of asbestos in peritoneal mesothelioma [Abstract]. Lab Invest 78:104A.
Heller DS, Gordon RE, Westhoff C, . 1996. Asbestos exposure and ovarian fiber burden. Am J Ind Med 29:435–439.
Henderson DW, Attwood HD, Constance TJ, . 1988. Lymphohistiocytoid mesothelioma: A rare lymphomatoid variant of predominantly sarcomatoid mesothelioma. Ultrastruct Pathol 12:367–384.2458647
*Henderson VL, Enterline PE. 1979. Asbestos exposure: Factors associated with excess cancer and respiratory disease mortality. Ann NY Acad Sci 330:117–126.294162
Hessel PA, Sluis-Cremer GK. 1989. X-ray findings, lung function, and respiratory symptoms in black South African vermiculite workers. Am J Ind Med 15:21–29.2784625
*Hesterberg TW, Barrett JC. 1984. Dependence of asbestos- and mineral dust-induced transformation of mammalian cells in culture on fiber dimension. Cancer Res 44:2170–2180.6324999
*Hesterberg TW, Axten C, McConnell EE, . 1997. Chronic inhalation study of fiber glass and amosite asbestos in hamsters: Twelve-month preliminary results. Environ Health Perspect Suppl 105:1223–1229.9400728
Hesterberg TW, Butterick CJ, Oshimura M, . 1986. Role of phagocytosis in Syrian hamster cell transformation and cytogenetic effects induced by asbestos and short and long glass fibers. Cancer Res 46:5795–5802.3756923
*Hesterberg TW, Chase G, Axten C, . 1998a. Biopersistence of synthetic vitreous fibers and amosite asbestos in the rat lung following inhalation. Toxicol Appl Pharmacol 151:262–275.9707503
*Hesterberg TW, Hart GA, Chevalier J, . 1998b. The importance of fiber biopersistence and lung dose in determining the chronic inhalation effects of X607, RCF1, and chrysotile asbestos in rats. Toxicol Appl Pharmacol 153:68–82.9875301
*Hesterberg TW, Miller WC, Musselman RP, . 1996. Biopersistence of man-made vitreous fibers and crocidolite asbestos in the rat lung following inhalation. Fundam Appl Toxicol 29:267–279.
*Hesterberg TW, Miller WC, Thevenaz P, . 1995. Chronic inhalation studies of man-made vitreous fibres: Characterization of fibres in the exposure aerosol and lungs. Ann Occup Hyg 39:637–653.8526395
*Higashi T, Hori H, Sakurai H, . 1994. Work environment of plants manufacturing asbestos-containing products in Japan. Ann Occup Hyg 38:489–494.7978970
Hill RJ, Edwards RE, Carthew P. 1990. Early changes in the pleural mesothelium following intrapleural inoculation of the mineral fibre erionite and the subsequent development of mesotheliomas. J Exp Path 71:105–118.
Hillerdal G. 1978. Pleural plaques in a health survey material: Frequency, development and exposure to asbestos. Scand J Respir Dis 59:257–263.734385
*Hillerdal G. 1980. The pathogenesis of pleural plaques and pulmonary asbestosis: Possibilities and impossibilities. Eur J Respir Dis 61:129–138.7002573
Hillerdal G. 1983. Malignant mesothelioma 1982: Review of 4710 published cases. Br J Dis Chest 77:321–343.6357260
Hillerdal G. 1991. Pleural plaques in the general population. Ann NY Acad Sci 430–437.
*Hillerdal G. 1994. Pleural plaques and risk for bronchial carcinoma and mesothelioma: A prospective study. Chest 105(1):144–150.8275722
*Hillerdal G, Henderson DW. 1997. Asbestos, asbestosis, pleural plaques and lung cancer. Scand J Work Environ Health 23:93–103.9167232
Hillerdal G, Musk AW. 1990. Pleural lesions in crocidolite workers from Western Australia. Br J Ind Med 47:782–783.2173949
Hillerdal G, Lee J, Blomkvist A, . 1997. Pleural disease during treatment with bromocriptine in patients previously exposed to asbestos. Eur Resp J 10:2711–2715.
Hilt B, Andersen A, Rosenber J, . 1991. Cancer incidence among asbestos-exposed chemical industry workers: An extended observation period. Am J Ind Med 20:261–264.1951372
Hilt B, Lien JT, Lund-Larsen PG, . 1986. Asbestos-related findings in chest radiographs of the male population of the county of Telemark, Norway - a cross-sectional study. Scand J Work Environ Health 12:567–573.3493527
Hirano S, Ono M, Aimoto A. 1988. Functional and biochemical effects on rat lung following instillation of crocidolite and chrysotile asbestos. J Toxicol Environ Health 24:27–39.2453678
Hiraoka K, Horie A, Kido M. 1990. Study of asbestos bodies in Japanese urban patients. Am J Ind Med 18:547–554.2173890
Hiraoka T, Ohkura M, Morinaga K, . 1998. Anthophyllite exposure and endemic pleural plaques in Kumamoto, Japan. Scand J Work Environ Health 24:392–397.9869311
Hiroshima K, Murai Y, Suzuki Y, . 1993. Characterization of asbestos fibers in lungs and mesotheliomatous tissues of baboons following long-term inhalation. Am J Ind Med 23(6):883–901.8328475
Hirvone A, Saarikoski ST, Linnainmaa K, . 1996. Glutathion S-transferase and N-acetyltransferase genotypes and asbestos-associated pulmonary disorders. J Natl Cancer Inst 88:1853–1856.8961976
*Hirvonen A. 1997. Combinations of susceptible genotypes and individual responses to toxicants. Environ Health Perspect Suppl 105:755–758.9255557
Hirvonen A, Mattson K, Karjalainen A, . 1999. Simian virus 40 (SV40)-like DNA sequences not detectable in Finnish mesothelioma patients not exposed to SV40-contaminated polio vaccines. Mol Carcinog 26:93–99.10506753
*Hirvonen A, Pelin K, Tammilehto L, . 1995. Inherited GSTM1 and NAT2 defects as concurrent risk modifiers in asbestos-related human malignant mesothelioma. Cancer Res 55:2981–2983.7606714
*Hirvonen A, Saarikoski ST, Linnainmaa K, . 1996. Glutathione-S-transferase and N-acetyltransferase genotypes and asbestos-associated pulmonary disorders. J Natl Cancer Inst 88:1853–1856.8961976
*Hnizdo E, Sluis-Cremer GK. 1988. Effect of tobacco-smoking on the presence of asbestosis at postmortem and on the reading of irregular opacities on roentgenograms in asbestos-exposed workers. Am Rev Respir Dis 138:1207–1212.3202481
*Hobson J, Gilks B, Wright J, . 1988. Direct enhancement by cigarette smoke of asbestos fiber penetration and asbestos-induced epithelial proliferation in rat tracheal explants. J Natl Cancer Inst 80:518–521.3367389
*Hobson J, Wright JL, Churg A. 1990. Active oxygen species mediate asbestos fiber uptake by tracheal epithelial cells. FASEB J 4:3135–3139.2170219
*Hodgson JT, Darnton A. 2000. The quantitative risks of mesothelioma and lung cancer in relation to asbestos exposure. Ann Occup Hyg 44(8):565–601.11108782
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84:313–320.1738181
*Hofmann W, Koblinger L, Martonen TB. 1989. Structural differences between human and rat lungs: Implications for Monte Carlo modeling of aerosol deposition. Health Phys 57:41–47.2606700
*Holian A, Uthman MO, Goltsova T, . 1997. Asbestos and silica-induced changes in human alveolar macrophage phenotype. Environ Health Perspect Suppl 105:1139–1142.9400713
*Holt PF. 1974. Small animals in the study of pathological effects of asbestos. Environ Health Perspect 9:205–211.4377872
*Holt PF. 1983. Translocation of inhaled dust to the pleura. Environ Res 31:212–220.6303774
Holtz G, Bresnick E. 1988. Ascorbic acid inhibits the squamous metaplasia that results from treatment of tracheal explants with asbestos or benzo[a]pyrene-coated asbestos. Cancer Lett 42:23–28.3180035
*Homa DM, Garabrant DH, Gillespie BW. 1994. A meta-analysis of colorectal cancer and asbestos exposure. Am J Epidemiol 139:1210–1222.8209879
Hooper K, Ladou J, Resenbaum JS, . 1992. Regulation of priority carcinogens and reproductive or developmental toxicants. Am J Ind Med 22(6):793–808.1463026
Horii H, Nagasaka Y, Yamada Y. 1992. Asbestos-related pleural thickenings in Japanese sake brewers. Int Arch Occup Environ Health 64(5):315–319.
*Howe HL, Wolfgang PE, Burnett WS, . 1989. Cancer incidence following exposure to drinking water with asbestos leachate. Public Health Reports 104:251–256.2498974
Howel D, Arblaster L, Swinburne L, . 1997. Routes of asbestos exposure and the development of mesothelioma in an English region. Occup Environ Med 54:403–409.9245946
HSDB. 1994. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
HSDB. 1999a. Asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. June 16, 1999.
HSDB. 1999b. Tremolite asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. June 16, 1999.
HSDB. 1999c. Chrysotile asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. June 16, 1999.
HSDB. 1999d. Amosite asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. June 16, 1999.
*HSDB. 2001a. Asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. January 23, 2001.
*HSDB. 2001b. Tremolite asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. January 23, 2001.
*HSDB. 2001c. Chrysotile asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. January 23, 2001.
*HSDB. 2001d. Amosite asbestos. Hazardous Substances Data Bank. National Library of Medicine, National Toxicology Information Program, Bethesda, MD. January 23, 2001.
*Hsiao TM, Ho CK, Su WP, . 1993. Asbestos related pleural plaques in retired boiler room workers. Kao Hsiung I Hsueh Ko Hsueh Tsa Chih 9(2):74–79.8492355
*Huang SL. 1979. Amosite, chrysotile and crocidolite asbestos are mutagenic in Chinese hamster lung cells. Mutat Res 68:265–274.514306
Hubbard R. 1997. The aetiology of mesothelioma: Are risk factors other than asbestos exposure important? [Letter]. Thorax 52:496–497.9227712
*Hughes JM. 1994. Human evidence: Lung cancer mortality risk from chrysotile exposure. Ann Occup Hyg 38(4):555–560.7978978
*Hughes J, Weill H. 1980. Lung cancer risk associated with manufacture of asbestos-cement products. IARC Sci Publ 30:627–635.
Hughes JM, Weill H. 1991. Asbestosis as a precursor of asbestos related lung cancer: Results of a prospective mortality study. Br J Ind Med 48(4):229–233.2025587
*Hughes JM, Weill H, Hammad YY. 1987. Mortality of workers employed in two asbestos cement manufacturing plants. Br J Ind Med 44:161–174.3828242
*Huilan Z, Zhiming W. 1993. Study of occupational lung cancer in asbestos factories in China. Br J Ind Med 50(11):1039–1042.8280629
Huncharek M. 1986. The biomedical and epidemiological characteristics of asbestos-related diseases: A review. Yale J Biol Med 59:435–451.3532578
Huncharek M. 1994. Asbestos and cancer: Epidemiological and public health controversies. Cancer Invest 12(2):214–222.8131096
Huncharek M, Muscat J. 1991. Metastatic laryngeal carcinoma mimicking pleural mesothelioma. Respiration 58(3–4):204–206.1745856
*Huncharek M, Kelsey K, Muscat J, . 1996. Parental cancer and genetic predisposition in malignant pleural mesothelioma: A case-control study. Cancer Lett 102:205–208.8603371
*Huncharek M, Klassen M, Christian D. 1995. Mesothelioma of the tunica vaginalis testis with possible occupational asbestos exposure. Br J Urol 75:673–685.7613808
Hunting KL, Welch LS. 1993. Occupational exposure to dust and lung disease among sheet metal workers. Br J Ind Med 50(5):432–442.8507596
Hurbankova M. 1994. One-year follow-up of the phagocytic activity of leukocytes after exposure of rats to asbestos and basalt fibers. Environ Health Perspect Suppl 102:201–203.
*Hurbankova M, Kaiglova A. 1993. The changes of some immunological parameters in subjects exposed to asbestos in dependence on age, duration of exposure, radiological findings, and smoking habits. Zentralbl Hyg Umweltmed 195(1):55–65.8117391
Hurbankova M, Kaiglova A. 1997. Some bronchoalveolar lavage parameters and leukocyte cytokine release in response to intratracheal instillation of short and long asbestos and wollastonite fibres in rats. Physiol Res 46:459–466.9730053
*Hurlbut CS Jr, Klein C. 1977. Manual of mineralogy. 19th ed. New York, NY: John Wiley and Sons, 338–339.
Husgafvel-Pursiainen K, Kannio A, Oksa P, . 1997. Mutations, tissue accumulations, and serum levels of p53 in patients with occupational cancers from asbestos and silica exposure. Environ Mol Mutagen 30:224–230.9329647
Husgafvel-Pursiainen K, Ridanpaa M, Anttila S, . 1995. p53 and ras Gene mutations in lung cancer: Implications for smoking and occupational exposures. J Occup Environ Med 37:69–76.7620945
*IARC. 1977. IARC monographs on the evaluation of the carcinogenic risk of chemicals to man: Asbestos. Vol 14. World Health Organization, Lyon, France, 33–35.
IARC. 1982. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol 1–29 (Supplement 4): Chemicals, industrial processes and industries associated with cancer in humans. World Health Organization, Lyon, France, 33–35.
*IARC. 1987. Asbestos and certain asbestos compounds. In: IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Chemicals, industrial processes and industries associated with cancer in humans. IARC monographs, Vol 1 to 42. IARC monographs supplement 7. Lyon, France: World Health Organization, International Agency for Research on Cancer, 29–33,56–58.
*IARC. 2001. Asbestos. IARC Monographs Database on Carcinogenic Risks to Humans, International Agency for Research on Cancer. Http://www.iarc.fr/pageroot/top1.html. January 17, 2001.
*IARC Expert Panel. 1996. Consensus Report. In: Kane AB, Boffetta P, Saracci R ., eds. Mechanisms of fibre carcinogenesis. Lyon: International Agency for Research on Cancer. IARC Scientific Publications No. 140, 1–9.
*ICRP. 1994. Human respiratory tract model for radiological protection. ICRP Publ.66:1–482.
*IDEM. 2001a. Demolition and renovation: Asbestos. Indiana Department of Environmental Management. Http://www.state.in.us/idem/ctap/asbestos.pdf. January 19, 2001.
*IDEM. 2001b. Water pollution control board: Proposed rule as preliminarily adopted. Indiana Department of Environmental Management. Http://www.state.in.us/idem/owm/planbr/rules/dwspropr.pdf. January 23, 2001.
*Iguchi H, Kojo S. 1989. Possible generation of hydrogen peroxide and lipid peroxidation of erythrocyte membrane by asbestos: Cytotoxic mechanism of asbestos. Biochem Int 18:981–990.2783149
*Iguchi H, Kojo S, Ikeda M. 1993. Lipid peroxidation and disintegration of the cell membrane structure in cultures of rat lung fibroblasts treated with asbestos. J Appl Toxicol 13(4):269–275.8376727
Ilg AGS, Bignon J, Valleron AJ. 1998. Estimation of the past and future burden of mortality from mesothelioma in France. Occup Environ Med 55:760–765.9924453
Ilgren EB, Browne K. 1991. Asbestos-related mesothelioma: Evidence for a threshold in animals and humans. Regul Toxicol Pharmacol 13:116–132.1852925
ILO. 1980. International Labour Office. Guidelines for the use of the ILO international classification of radiographs of pneumoconiosis, revised edition. Geneva, Switzerland: ILO Occupational Safety and Health Series. No. 22.
Imbernon E, Goldberg M, Bonenfant S, . 1995. Occupational respiratory cancer and exposure to asbestos: A case-control study in a cohort of workers in the electricity and gas industry. Am J Ind Med 28:339–352.7485188
*Inase N, Takayama S, Nakayama M, . 1991. Pleural mesothelioma after neighborhood exposure to asbestos during childhood. Jpn J Med 30(4):343–345.1942646
*International Expert Meeting on Asbestos. 1997. Asbestos, asbestosis, and cancer: The Helsinki criteria for diagnosis and attribution. Scand J Work Environ Health 23:311–316.9322824
IRIS. 1993. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. July 1, 1993.
IRIS. 1999. Asbestos. Integrated Risk Information System, U.S. Environmental Protection Agency.
*IRIS. 2001. Asbestos. Integrated Risk Information System, U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/0371.htm. January 23,2001.
IRPTC. 1989. IRPTC data profile: Asbestos. International Register of Potentially Toxic Chemicals, United Nations Environment Programme, Geneva, Switzerland. January 1989.
Irvine HDV. 1995. Mesotheliom. Lancet 345:1233–1234.
Irvine HD, Lemont DW, Hole DJ, . 1993. Asbestos and lung-cancer in Glasgow and the west of Scotland. BMJ 306(6891):1503–1506.8518676
*Irwig LM, du Toit RS, Sluis-Cremer GK, . 1979. Risk of asbestosis in crocidolite and amosite mines in South Africa. Ann NY Acad Sci 330:35–52.294187
Ishihara Y, Kohyama N, Kagawa J. 1998. Contribution of human pulmonary macrophage-derived cytokines to asbestos-induced lung inflammation and fibrosis. Inhal Toxicol 10:205–225.
*Ishizaki T, Yano E, Evans PH. 1997. Cellular mechanisms of reactive oxygen metabolite generation from human polymorphonuclear leukocytes induced by crocidolite asbestos. Environ Res 75:135–140.9417844
*Israbian VA, Weitman SA, Kamp DW. 1994. Dibutyryl cAMP attenuates asbestos-induced pulmonary epithelial cell cytotoxicity and decline in ATP levels. Am J Physiol 267(11):L518–L525.7977762
*Iwatsubo Y, Pairon JC, Boutin C, . 1998. Pleural mesothelioma: Dose-response relation at low levels of asbestos exposure in a French population-based case-control study. Am J Epidemiol 148:133–142.9676694
Jabbour AJ, Holian A, Scheule RK. 1991. Lung lining fluid modification of asbestos bioactivity for the alveolar macrophage. Toxicol App Pharmacol 110:283–294.
Jackson JH, Schraufstatter IU, Hyslop PA, . 1987. Role of oxidants in DNA damage: Hydroxyl radical mediates the synergistic DNA damaging effects of asbestos and cigarette smoke. J Clin Invest 80:1090–1095.2821073
*Jacobs R, Humphrys J, Dodgson KS, . 1978a. Light and electron microscope studies of the rat digestive tract following prolonged and short-term ingestion of chrysotile asbestos. Br J Exp Pathol 59:443–453.718798
*Jacobs R, Weinzweig M, Dodgson KS, . 1978b. Nucleic acid metabolism in the rat following short-term and prolonged ingestion of chrysotile asbestos or cigarette-smoke condensate. Br J Exp Pathol 59:594–600.747710
*Jaenicke R. 1980. Natural aerosols. Ann NY Acad Sci 338:317–325.
Jagirdar J, Lee TC, Reibman J, . 1997. Immunohistochemical localization of transforming growth factor beta isoforms in asbestos-related diseases. Environ Health Perspect Suppl 105:1197–1203.9400723
*Jakobsson K, Albin M, Hagmar L. 1994. Asbestos, cement, and cancer in the right part of the colon. Occup Environ Med 51(2):95–101.8111470
*Jakobsson K, Rannug A, Alexandrie AK, . 1995a. Radiographic changes and lung function in relation to activity of the glutathione transferases theta and mu among asbestos cement workers. Toxicol Lett 77:363–369.
*Jakobsson K, Stromberg U, Albin M, . 1995b. Radiological changes in asbestos cement workers. Occup Environ Med 52:20–27.7697136
*Janssen YMW, Sen CK. 1999. Nuclear factor kappa B activity in response to oxidants and antioxidants. Methods Enzymol 300:363–374.9919537
Janssen YMW, Driscoll KE, Howard B, . 1997. Asbestos causes translocation of p65 protein and increase NF-KB DNA binding activity in rat lung epithelial and pleural mesothelial cells. Am J Pathol 151:389–401.9250152
*Janssen YMW, Heintz NH, Mossman BT. 1995. Induction of c-fos and c-jun proto-oncogene expression by asbestos is ameliorated by N-acetyl-L-cysteine in mesothelial cells. Cancer Res 55:2085–2089.
*Janssen YMW, Marsh JP, Absher MP, . 1992. Expression of antioxidant enzymes in rat lungs after inhalation of asbestos or silica. J Biol Chem 267:10625–10630.1316905
Jarvholm B, Brisman J. 1988. Asbestos associated tumours in car mechanics. Br J Ind Med 45:645–646.
*Jarvholm B, Larsson S. 1988. Do pleural plaques produce symptoms? A brief report. J Occup Med 30:345–347.3379488
Jarvholm B, Sanden A. 1988. Asbestos-associated diseases in Swedish shipyard workers. Arh Hig Rada Toksikol 39:437–440.3273136
Jarvholm B, Sanden A. 1998. Lung cancer and mesothelioma in the pleura and peritoneum among Swedish insulation workers. Occup Environ Med 55:766–770.9924454
*Jarvholm B, Arvidsson, H, Bake B, . 1986. Pleural plaques -asbestos - ill-health. Eur J Respir Dis Suppl 68(Suppl 145):1–59.
Jarvholm B, Larsson S, Hagberg S, . 1993. Quantitative importance of asbestos as a cause of lung cancer in a Swedish industrial city: A case-referent study. Eur Respir J 6(9):1271–1275.8287942
Jarvholm B, Malker H, Malker B, . 1988. Pleural mesotheliomas and asbestos exposure in the pulp and paper industries: A new risk group identified by linkage of official registers. Am J Ind Med 13:561–567.3376945
Jaurand MC. 1991. Observations on the carcinogenicity of asbestos fibers. Ann NY Acad Sci 258–270.
Jaurand MC. 1997. Mechanisms of fiber-induced genotoxicity. Environ Health Perspect Suppl 105:1073–1084.9400703
*Jaurand MC, Fleury J, Monchaux G, . 1987. Pleural carcinogenic potency of mineral fibers (asbestos, attapulgite) and their cytotoxicity on cultured cells. J Natl Cancer Inst 79:797–804.
*Jaurand MC, Gaudichet A, Halpern S, . 1984. In vitro biodegradation of chrysotile fibers by alveolar macrophages and mesothelial cells in culture: Comparison with a pH effect. Br J Ind Med 41:389–395.6331496
Jaurand MC, Magne L, Bignon J. 1979. Inhibition by phospholipids of haemolytic action of asbestos. Br J Ind Med 36:113–116.465374
Jaurand MC, Renier A, Gaudichet A, . 1988. Short-term tests for the evaluation of potential cancer risk of modified asbestos fibers. Ann NY Acad Sci 741–753.2839092
*Jensen CG, Watson M. 1999. Inhibition of cytokinesis by asbestos and synthetic fibres. Cell Biol Int 23(12):829–840.10772757
Jessurun GAJ, Crijns HJGM, van Wijngaarden J. 1996. An unusual case of cardiac tamponade following electrical cardioversion. Int J Cardiol 53:317–320.8793589
Jimenez LA, Zanella C, Fung H, . 1997. Role of extracellular signal-regulated protein kinases in apoptosis by asbestos and H2O2. Am J Physiol 273(17):L1029–L1035.9374731
Jockel K-H, Ahrens W, Bolm-Audorff U. 1994. Lung cancer risk and welding-Preliminary results from an ongoing case-control study. Am J Ind Med 25:805–812.8067358
Jockel K-H, Ahrens W, Bolm-Audorff U, . 1997. Estimation of the dose-response between risk of lung cancer and cumulative dose of asbestos exposure in fibre-year [Abstract]. Eur Resp J 10:434S.
Jockel K-H, Ahrens W, Jan I, . 1998. Occupational risk factors for lung cancer: A case-control study in West Germany. Int J Epidemiol 27:549–560.9758106
Johansen C, Olsen Jorgen H. 1998. Risk of cancer among Danish utility workers-A nationwide cohort study. Am J Epidemiol 147:548–555.9521181
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johansson L, Albin M, Jakobsson K, . 1992. Histological type of lung carcinoma in asbestos cement workers and matched controls. Br J Ind Med 49(9):626–30.1390268
Johnson NF. 1994. Phagosomal pH and glass fiber dissolution in cultured nasal epithelial cells and alveolar macrophages: A preliminary study. Environ Health Perspect Suppl 102(5):97–102.
*Johnson NF, Jaramillo RJ. 1997. p53, Cip1, and Gadd153 expression following treatment of A549 cells with natural and man-made vitreous fibers. Environ Health Perspect Suppl 105:1143–1145.9400714
Johnson NF, Carpenter TR, Jaramillo RJ, . 1997. DNA damage-inducible genes as biomarkers for exposures to environmental agents. Environ Health Perspect Suppl 105:913–918.9255580
Johnson NF, Edwards RE, Munday DE, . 1984. Pluripotential nature of mesotheliomata induced by inhalation of erionite in rats. Br J Exp Pathol 65:377–388.6204669
Johnson NF, Haslam PL, Dewar A, . 1988. Identification of inorganic dust particles in bronchoalveolar lavage macrophages by energy dispersive X-ray microanalysis. Arch Environ Health 41:133–144.
Johnson NF, Hoover MD, Thomassen DG, . 1992. In vitro activity of silicon carbide whiskers in comparison to other industrial fibers using four cell culture systems. Am J Ind Med 21:807–823.1320327
Johnson NF, Wagner JC, Brown DG, . 1982. The ultrastructure of asbestos induced rat pleural mesotheliomas following transplantation into syngeneic animals [Abstract]. J Pathol 137:80.
Johnson NF, Wagner JC, Wills HA. 1980a. Endocrine cell proliferation in the rat lung following asbestos inhalation. Lung 158:221–228.7464213
Johnson NF, Wagner JC, Wills HA. 1980b. Neuroendocrine cell proliferation in the rat lung following asbestos inhalation [Abstract]. J Pathol 131:261–262.
Jolicoeur C, Poisson D. 1987. Surface physico-chemical studies of chrysotile asbestos and related minerals. Drug Chem Toxicol 10:1–47.
*Jolicoeur CR, Alary JF, Sokov A. 1992. Asbestos. In: Kroschwitz JI, Howe-Grant M, ed. Kirk-Othmer encyclopedia of chemical technology. New York: John Wiley & Sons, 659–688.
*Jones AD, McMillan CH, Johnston AM, . 1988a. Pulmonary clearance of UICC amosite fibres inhaled by rats during chronic exposure at low concentration. Br J Ind Med 45:300–304.
*Jones AD, Vincent JH, Addison J, . 1994. The fate and effect of inhaled chrysotile asbestos fibres. Ann Occup Hyg 38:619–629.
Jones AD, Vincent JH, McIntosh C, . 1989. The effect of fibre durability on the hazard potential of inhaled chrysotile asbestos fibres. Exp Pathol 37:98–102.2637179
*Jones JS, Pooley FD, Smith PG, . 1980a. The consequences of exposure to asbestos dust in a wartime gas-mask factory. IARC Sci Publ 30:637–653.
Jones RN, Diem JE, Ziskand MM, . 1984. Radiographic evidence of asbestos effects in American marine engineers. J Occup Med 26(4):281–284.6716195
*Jones JS, Pooley FD, Clark NJ, . 1980b. The pathology and mineral content of lungs in cases of mesothelioma in the United Kingdom in 1976. IARC Sci Publ 30:187–199.
Jones RN, Hughes JM, Weill H. 1996. Asbestos exposure, asbestosis, and asbestos-attributable lung cancer. Thorax 51:S9–S15.8869346
*Jones RN, McLoud T, Rockoff SD. 1988b. The radiographic pleural abnormalities in asbestos exposure: Relationship to physiologic abnormalities. J Thoracic Imaging 3:57–66.3054138
Joubert L, Seidman H, Selikoff IJ. 1991. Mortality experience of family contacts of asbestos factory workers. Ann NY Acad Sci 416–418.
Jung M, Davis WP, Taatjes DJ, . 2000. Asbestos and cigarette smoke cause increased DNA strand breaks and necrosis in bronchiolar epithelial cells in vivo. Free Radic Biol Med 28(8):1295–1299.10889460
Jung T, Burkart W. 1997. Assessment of risks from combined exposures to radiation and other agents at environmental levels. In: Wei L, Sugarhara T, Tao Z, ed. High levels of natural radiation 1996: Radiation dose and health effects. New York, NY: Elsevier Science, 167–178.
Juntunen J, Oksa P, Pukkala E, . 1997. Neurological signs in relation to cancer in patients with asbestosis. Occup Environ Med 54:746–749.9404323
Kagamimori S, Scott MP, Brown DG, . 1980. Effects of chrysotile asbestos on mononuclear cells in vitro. Br J Exp Pathol 61:55–60.7378274
*Kagan E. 1988. Current issues regarding the pathobiology of asbestosis: A chronologic perspective. J Thorac Imaging 3:1–9.
*Kagan E, Solomon A, Cochrane JC, . 1977. Immunological studies of patients with asbestosis: I. Studies of cell-mediated immunity. Clin Exp Immunol 28:261–267.872451
*Kaiglová A, Kováciková Z, Hurbánková M. 1999. Impact of acute and subchronic asbestos exposure on some parameters of antioxidant defense system and lung tissue injury. Ind Health 37:348–351.10441908
*Kamal AA, El Khafif M, Koraah S, . 1992. Blood superoxide dismutase and plasma malondialdehyde among workers exposed to asbestos. Am J Ind Med 21:353–361.1585946
*Kamal AA, Gomaa A, El Khafif M, . 1989. Plasma lipid peroxides among workers exposed to silica or asbestos dusts. Environ Res 49:173–180.2546756
*Kambic V, Radsel Z, Gale N. 1989. Alterations in the laryngeal mucosa after exposure to asbestos. Br J Ind Med 46:717–723.2489023
*Kamp DW, Weitzman SA. 1997. Asbestosis: Clinical spectrum and pathogenic mechanisms. Proc Soc Exp Biol Med 214:12–26.9012357
*Kamp DW, Weitzman SA. 1999. The molecular basis of asbestos induced lung injury. Thorax 54:638–652.10377212
Kamp DW, Dunne M, Dykewicz MS, . 1993. Asbestos-induced injury to cultured human pulmonary epithelial-like cells: Role of neutrophil elastase. J Leukoc Biol 54(1):73–80.8336081
*Kamp DW, Graceffa P, Pryor WA, . 1992. The role of free radicals in asbestos-induced diseases. Free Rad Biol Med 12:293–315.1577332
*Kamp DW, Greenberger MJ, Sbalchierro JS, . 1998. Cigarette smoke augments asbestos-induced alveolar epithelial cell injury: Role of free radicals. Free Radic Biol Med 25:728–739.9801074
Kamp DW, Israbian VA, Presusen SE, . 1995a. Asbestos causes DNA strand breaks in cultured pulmonary epithelial cells: Role of iron-catalyzed free radicals. Am J Physiol 268(12):L471–L480.7900829
Kamp DW, Israbian VA, Yeldandi AV, . 1995b. Phytic acid, an iron chelator, attenuates pulmonary inflammation and fibrosis in rats after intratracheal instillation of asbestos. Toxicol Pathol 23:689–695.8772254
Kanarek MS. 1983. The San Francisco Bay epidemiology studies on asbestos in drinking water and cancer incidence: Relationship to studies in other locations and pointers for further research [Commentary]. Environ Health Perspect 53:105–106.6662077
*Kanarek MS. 1989. Epidemiological studies on ingested mineral fibers: Gastric and other cancers. IARC Sci Pub 90:428–437.
*Kanarek MS, Conforti PM, Jackson LA, . 1980. Asbestos in drinking water and cancer incidence in the San Francisco Bay Area. Am J Epidemiol 112:54–72.7395855
*Kanarek MS, Conforti PM, Jackson LA, . 1981. Chrysotile asbestos fibers in drinking water from asbestos-cement pipe. Environ Sci Technol 15:923–925.22284002
Kanazawa K, Birbeck MS, Carter RL, . 1969. Migration of asbestos fibers from subcutaneous injection sites in mice. Br J Cancer 24:96–106.
Kane AB. 1992. Environmental pathology: The pathologist’s responsibility? Hum Pathol 23:1093–1094.1398638
Kane AB. 1996. Mechanisms of mineral fibre carcinogenesis. In: Kane AB, Bofetta P, Saracci R, ., eds. Mechanisms of fibre carcinogenesis. Lyon, France: International Agency for Research on Cancer. IARC Scientific Publications No. 140, 11–34.
Kane MJ, Chahinian AP, Holland JF. 1990. Malignant mesothelioma in young adults. Cancer 65:1449–1455.2306689
*Kang S-K, Burnett CA, Freund E, . 1997. Gastrointestinal cancer mortality of workers in occupations with high asbestos exposures. Am J Ind Med 31:713–718.9131226
Kannerstein M. 1979. Recent advances and perspectives relevant to the pathology of asbestos-related diseases in man. IARC Sci Publ 30:149–162.
Kannio A, Ridanpaa M, Koskinen H, . 1996. A molecular and epidemiological study on bladder cancer: P53 mutations, tobacco smoking, and occupational exposure to asbestos. Cancer Epidemiol Biomarkers Prev 5:33–39.8770464
*Kaplan DE. 1993. Unregulated disposal of asbestos contaminated shower water effluent: A question of public health risk. J Environ Health 55(6):6–8.
*Kaplan H, Renier A, Javrand MG, . 1980. Sister chromatid exchanges in mesothelial cells cultured with chrysotile fibers. In: Brown ., eds. The in vitro effects of mineral dusts. London, England: Acad. Press, 251.
Karjalainen A, Anttila S, Heikkila L, . 1993a. Asbestos exposure among Finnish lung cancer patients: Occupational history and fiber concentration in lung tissue. Am J Ind Med 23(3):461–471.8389099
Karjalainen A, Anttila S, Heikkila L. 1993b. Lobe of origin of lung cancer among asbestos-exposed patients with or without diffuse interstitial fibrosis. Scand J Work Environ Health 19(4):102–107.8391162
*Karjalainen A, Banhala E, Karhunen PJ, . 1994a. Asbestos exposure and pulmonary fiber concentrations of 300 Finnish urban men. Scand J Work Environ Health 20:34–41.8016597
Karjalainen A, Karhunen PJ, Lalu K, . 1951. Pleural plaques and exposure to mineral fibres in a male urban necropsy population. Occup Environ Med 51:456–460.
Karjalainen A, Meurman LO, Pukkala E. 1994b. Four cases of mesothelioma among Finnish anthophyllite miners. Occup Environ Med 51(3):212–215.8130852
*Karjalainen A, Nurminen M, Vanhala E, . 1996a. Pulmonary asbestos bodies and asbestos fibers as indicators of exposure. Scand J Work Environ Health 22:34–38.8685671
*Karjalainen A, Piipari R, Mantyla T, . 1996b. Asbestos bodies in bronchoalveolar lavage in relation to asbestos bodies and asbestos fibres in lung parenchyma. Eur Resp J 9:1000–1005.
Karjalainen A, Pukkala E, Mattson K, . 1997. Trends in mesothelioma incidence and occupational mesotheliomas in Finland in 1960-1995. Scand J Work Environ Health 23:266–270.9322817
Karjalainen A, Taikina-Aho O, Anttila S, . 1994c. Asbestos exposure among Finnish lung cancer patients. Comparison of scanning and transmission electron microscopy in the analysis of lung burden. Ann Occup Hyg 38:657–663.
Karjalainen A, Vanhala E, Karhunen PJ, . 1994d. Asbestos exposure and pulmonary fiber concentrations of 300 Finnish urban men. Scand J Work Environ Health 20(1):34–41.8016597
Karn CM, Socinski MA, Fletcher JA, . 1994. Cardiac synovial sarcoma with translocation (X;18) associated with asbestos exposure. Cancer 73(1):74–78.8275440
*Karnak Corporation. 1998. The U.S. Court of Appeals for the Fifth Circuit overturns EPA’s ban rule on asbestos. Http://www.karnakcorp.com/faq/faq-aiaruling.htm. April 19, 2001.
Kauffer E, Vigneron JC, Fabries JF, . 1996. The use of a new static device based on the collection of the thoracic fraction for the assessment of the airborne concentration of asbestos fibres by transmission electron microscopy. Ann Occup Hyg 40:311–319.8694492
Kawai A, Nagasaka Y, Muraki M, . 1997. Brain metastasis in malignant pleural mesothelioma. Intern Med 36:591–594.9260780
Kayser K, Seemann C, André S, . 2000. Association of concentration of asbestos and asbestos-like fibers with the patient’s survival and the binding capacity of lung parenchyma to galectin-1 and natural α-galactoside- and α-mannoside-binding immunoglobulin G subfractions from human serum. Pathol Res Pract 196:81–87.10707363
Kazan-Allen L. 2000. The international ban asbestos secretariat. Int J Occup Environ Health 6(2):164.10828148
*Keane MJ, Stephens JW, Zhong B-Z, . 1999. A study of the effect of chrysotile fiber surface composition on genotoxicity in vitro. J Toxicol Environ Health A 57:529–541.10515572
Kee ST, Gamsu G, Blanc P. 1996. Causes of pulmonary impairment in asbestos-exposed individuals with diffuse pleural thickening. Am J Respir Crit Care Med 154:789–793.8810620
Kehrer JP, Mossman BT, Sevanian A, . 1988. Free radical mechanisms in chemical pathogenesis. Toxicol App Pharmacol 95:349–362.
Kelley J. 1998. Occupational lung disease caused by asbestos, silica, and other silicates. In: Baum GL, Crapo JD, Celli BR, ., ed. Textbook pulmonary diseases. Philadelphia, PA: Lippincott-Raven, 659–682.
*Kelsey KT, Nelson HH, Wiencke JK, . 1997. The glutathione s-transferase theta and mu deletion polymorphisms in asbestosis. Am J Ind Med 31:274–279.9055949
*Kelsey KT, Yano E, Liber HL, . 1986. The in vitro genetic effects of fibrous erionite and crocidolite asbestos. Br J Cancer 54:107–114.3015180
*Kenne K, Ljungquist S, Ringertz NR. 1986. Effects of asbestos fibers on cell division, cell survival, and formation of thioguanine-resistant mutants in Chinese hamster ovary cells. Environ Res 39:448–464.3007106
Kennedy SM, Vedal S, Mueller N, . 1991. Lung function and chest radiograph abnormalities among construction insulators. Am J Ind Med 20:673–684.1793108
*Kennedy TP, Dodson R, Rao NV, . 1989. Communication. Dusts causing pneumoconiosis generate OH and produce hemolysis by acting as Fenton catalysts. Arch Biochem Biophys 269:359–364.2537062
Khan SG, Ali S, Rahman Q. 1990. Protective role of ascorbic acid against asbestos induced toxicity in rat lung: In vitro study. Drug Chem Toxicol 13:249–256.2177399
*Khan SG, Ali S, Rahman Q. 1992. Interaction of mineral fibres with lung cytochrome P-450 system: Impairment of drug metabolizing enzyme activities. Chemosphere 24:959–968.
*Kienast K, Kaes C, Drumm K, . 2000. Asbestos-exposed blood monocytes - deoxyribonucleic acid strand lesions in co-cultured bronchial epithelial cells. Scand J Work Environ Health 26(1):71–77.10744181
Kilanowicz A, Czerski B, Sapota A. 1999. The disposition and metabolism of naphthalene in rats. Int J Occup Med Environ Health 12(3):209–219.10581862
Kilburn KH. 2000. Prevalence and features of advanced asbestosis: (ILO profusion scores above 2/2). Arch Environ Health 55(2):104–108.10821510
Kilburn KH, Warshaw RH. 1992a. Irregular opacities in the lung, occupational asthma, and airways dysfunction in aluminum workers. Am J Ind Med 21:845–853.1621692
Kilburn KH, Warshaw RH. 1992b. Severity of pulmonary asbestosis as classified by international labour organization profusion of irregular opacities in 8749 asbestos-exposed American workers: Those who never smoked compared with those who ever smoked. Arch Intern Med 152(2):325–327.1739361
*Kilburn KH, Warshaw RH. 1994. Airways obstruction from asbestos exposure: Effects of asbestosis and smoking. Chest 106:1061–1070.7924474
*Kilburn KH, Warshaw RH, Thornton JC. 1995. Do radiographic criteria for emphysema predict physiologic impairment? Chest 107:1225–1231.7750310
Kimizuka G, Azuma M, Ishibashi M, . 1993. Co-carcinogenic effect of chrysotile and amosite asbestos with benzo(a)pyrene in the lung of hamsters. Acta Pathol Jpn 43(4):149–153.8388150
*Kimizuka G, Shinozaki K, Hayashi Y. 1992. Comparison of the pulmonary responses to chrysotile and amosite asbestos administered intratracheally. I. Early phase of cellular reactions. Acta Pathol Jpn 42(10):707–711.1334613
King JA, Wong SW. 1996. Autopsy evaluation of asbestos exposure: Retrospective study of 135 cases with quantitation of ferruginous bodies in digested lung tissue. South Med J 89:380–385.8614876
King JAC, Tucker JA, Wong SW. 1997. Mesothelioma: A study of 22 cases. South Med J 90:199–205.9042171
*Kinnula VL. 1999. Oxidant and antioxidant mechanisms of lung disease caused by asbestos fibres. Eur Resp J 14:706–716.
Kinnula VL, Linnala A, Viitala E, . 1998. Tenascin and fibronectin expression in human mesothelial cells and pleural mesothelioma cell-line cells. Am J Respir Cell Mol Biol 19:445–452.9730872
Kiritani EW. 1990. Asbestos and stomach cancer in Japan - a connection? Med Hypotheses 33:159–160.2292977
Kishimoto T. 1992a. Cancer due to asbestos exposure. Chest 101:58–63.1729111
Kishimoto T. 1992b. Coexistence of a malignant fibrous histiocytoma and asbestos exposure. Brief report. Pathobiology 60(6):332–334.1337830
Kishimoto T. 1992c. Intensity of exposure to asbestos in metropolitan Kure City as estimated by autopsied cases. Cancer 69(10):2598–2602.1568184
Kishimoto T, Ishikura M. 1991. Intensities of asbestos exposure in patients admitted to Kure Kyosai Hospital, Japan. Jpn J Chest Dis 50(8):637–641.
Kishimoto T, Okada K. 1988. The relationship between lung cancer and asbestos exposure. Chest 94:486–490.3409725
*Kishimoto T, Hashimoto H, Ono T, . 1992. Synchronous double malignancy: Adenocarcinoma of lung and malignant astrocytoma induced by asbestos exposure. Cancer Invest 10(2):129–133.1551022
Kishimoto T, Ono T, Okada K, . 1989. Relationship between number of asbestos bodies in autopsy lung and pleural plaques on chest x-ray film. Chest 95:549–552.2641666
*Kitamura F, Araki S, Tanigawa T, . 1998. Assessment of mutations of Ha and Ki-ras oncogenes and the p53 suppressor gene in seven malignant mesothelioma patients exposed to asbestos - PCR-SSCP and sequencing analyses of paraffin-embedded primary tumors. Ind Health 36:52–56.9473858
*Klaas VE. 1993. A diagnostic approach to asbestosis, utilizing clinical criteria, high resolution computed tomography, and gallium scanning. Am J Ind Med 23(5):801–809.8338599
Kleinfeld M, Messite J, Kooyman O, . 1967. Mortality among talc miners and millers in New York State. Arch Environ Health 14:663–667.6024643
*Kleinfeld M, Messite J, Zaki H. 1974. Mortality experiences among talc workers: A follow-up study. J Occup Med 16:345–349.4826349
Kleymenova EV, Bianchi AA, Kley N, . 1997. Characterization of the rat neruofibromatosis 2 gene and its involvement in asbestos-induced mesothelioma. Mol Carcinog 18:54–60.9022813
Klockars M, Savolainen H. 1992. Tumour necrosis factor enhances the asbestos-induced production of reactive oxygen metabolites by human polymorphonuclear leucocytes (PMN). Clin Exp Immunol 90(1):68–71.1395103
*Koerten HK, de Bruijn JD, Daems WT. 1990a. The formation of asbestos bodies by mouse peritoneal macrophages. Am J Pathol 137:121–134.2372038
*Koerten HK, Hazekamp J, Kroon M. . 1990b. Asbestos body formation and iron accumulation in mouse peritoneal granulomas after the introduction of crocidolite asbestos fibers. Am J Pathol 136:141–157.2153345
*Kokkola K, Huuskonen MS. 1979. Electrocardiographic signs of cor pulmonale in asbestosis. Int Arch Occup Environ Health 43:167–175.457289
*Kominsky JR, Freyberg RW, Clark PJ, . 1998a. Asbestos exposures during routine floor tile maintenance. Part 1: Spray-buffing and wet-stripping. Appl Occup Environ Hyg 13(2):101–106.
*Kominsky JR, Freyberg RW, Clark PJ, . 1998b. Asbestos exposures during routine floor tile maintenance. Part 2: Ultra high speed burnishing and wet-stripping. Appl Occup Environ Hyg 13(2):107–112.
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
*Korkina LG, Durnev AD, Suslova TB, . 1992. Oxygen radical-mediated mutagenic effect of asbestos on human lymphocytes: suppression by oxygen radical scavengers. Mutat Res 265:245–253.1370723
Koshi K, Kohyama N, Myojo, . 1991. Cell toxicity, hemolytic action and clastogenic activity of asbestos and its substitutes. Ind Health 29:37–56.1832142
Koskinen K, Rinne J-P, Zitting A, . 1996. Screening for asbestos-induced disease in Finland. Am J Ind Med 30:241–251.8876791
Koskinen K, Zitting A, Tossavainen A, . 1998. Radiographic abnormalities among Finnish construction, shipyard and asbestos industry workers. Scand J Work Environ Health 24:109–117.
*Kostyuk VA, Potapovich AI, Speransky SD, . 1996. Protective effect of natural flavonoids on rat peritoneal macrophages injury caused by asbestos fibers. Free Radic Biol Med 21:487–493.8886799
Koustas RN. 1991. Control of incidental asbestos exposure at hazardous waste sites. J Air Waste Manage Assoc 41:1004–1009.1930954
Kramer JR. 1976. Fibrous cummingtonite in Lake Superior. Can Mineral 14:91–98.
*Kraus T, Drexler H, Weber A, . 1995. The association of occupational asbestos dust exposure and laryngeal carcinoma. Isr J Med Sci 31:540–548.7558778
*Kravchenko IV, Furalyov VA, Vasylieva LA, . 1998. Spontaneous and asbestos-induced transformation of mesothelial cells in vitro. Teratog Carcinog Mutagen 18:141–151.9728798
*Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell H 3rd, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York: Academic Press, 399–437.
Kronenberg RS, Levin JL, Dodson RF, . 1991. Asbestos-related disease in employees of a steel mill and a glass bottle-manufacturing plant. Ann NY Acad Sci 397–403.
*Kubota M, Ksgamimori S, Yokoyama K, . 1985. Reduced killer cell activity of lymphocytes from patients with asbestosis. Br J Ind Med 42:276–280.3978049
Kurumatani N, Natori Y, Mizutani R, . 1999. A historical cohort mortality study of workers exposed to asbestos in a refitting shipyard. Ind Health 37:9–17.10052294
Kuwahara M, Kuwahara M, Verma K, . 1994. Asbestos exposure stimulates pleural mesothelial cells to secrete the fibroblast chemoattractant, fibronectin. Am J Respir Cell Mol Biol 10:167–176.8110473
Lakshmi VM, Zenser TV, Davis BB. 1994. Mechanism of 3-(glutathion-S-yl)-benzidine formation. Toxicol Appl Pharmacol 125:256–263.8171433
Landrigan PJ. 1991. A population of children at risk of exposure to asbestos in place. Ann NY Acad Sci 283–286.
*Landrigan PJ. 1998. Asbestos–still a carcinogen [Editorial]. New Engl. J. Med. 338:1618–1619.9603801
Landrigan PJ, Nicholson WJ, Suzuki Y, . 1999. The hazards of chrysotile asbestos: A critical review. Ind Health 37:271–280.10441898
*Lange A, Garncarek D, Tomeczko J, . 1986. Outcome of asbestos exposure (lung fibrosis and antinuclear antibodies) with respect to skin reactivity: An 8-year longitudinal study. Environ Res 41:1–13.3489613
Lange A, Karabon L, Tomeczko J. 1995. Interleukin-6- and interleukin-4-related proteins (C-reactive protein and IgE) are prognostic factors of asbestos-related cancer. Ann N Y Acad Sci 762:435–438.7668550
*Lange A, Smolik R, Zatonski W, . 1974. Autoantibodies and serum immunoglobulin levels in asbestos workers. Int Arch Arbeitsmed 32:313–325.4821458
Lange JH. 1999. A statistical evaluation of asbestos air concentrations. Indoor Built Environ 8:293–303.
*Lange JH, Thomulka KW. 2000a. Air sampling during asbestos abatement of floor tile and mastic. Bull Environ Contam 64:497–501.
*Lange JH, Thomulka KW. 2000b. An evaluation of personal airborne asbestos exposure measurements during abatement of dry wall and floor tile/mastic. Int J Environ Health Res 10:5–19.
*Lange JH, Thomulka KW. 2000c. Area and personal airborne exposure during abatement of asbestos-containing roofing material. Bull Environ Contam Toxicol 64:673–678.10857450
*Lange JH, Lange PR, Reinhard TK, . 1996. Ann Occup Hyg 40(4):449–466.8806215
Langer AM, Nolan RP. 1994. Chyrsotile biopersistence in the lungs of persons in the general population and exposed workers. Environ Health Perspect Suppl 102:235–239.7882940
Langer AM, Nolan RP. 1997. Asbestos disease in foundrymen [Letter]. J Occup Environ Med 39:699–700.9273871
*Langer AM, Nolan RP. 1998. Asbestos in the lungs of persons exposed in the USA. Monaldi Arch Chest Dis 53:168–180.9689804
Langer AM, Pooley FD. 1973. Identification of single asbestos fibres in human tissue. IARC Sci Publ 8:119–125.
*Langer AM, Nolan RP, Constantopoulos SH, . 1987. Association of Metsovo lung and pleural mesothelioma with exposure to tremolite-containing whitewash. Lancet 1(8539):965–967.2882352
*Lanphear BP, Buncher CR. 1992. Latent period for malignant mesothelioma of occupational origin. J Occup Med 34:718–721.1494965
*Lash TL, Crouch EAC, Green LC. 1997. A meta-analysis of the relation between cumulative exposure to asbestos and relative risk of lung cancer. Occup Environ Med 54:254–263.9166131
Lasky JA, Bonner JC, Brody AR. 1991. The pathobiology of asbestos-induced lung disease: A proposed role for macrophage-derived growth factors. Ann NY Acad Sci 239–244.
*Lasky JA, Bonner JC, Tonthat B, . 1996. Chrysotile asbestos induces PDGF-A chain-dependent proliferation in human and rat lung fibroblasts in vitro. Chest 109:26S–28S.
Lasky JA, Tonthat B, Liu J-Y, . 1998. Upregulation of the PDGF-alpha receptor precedes asbestos-induced lung fibrosis in rats. Am J Respir Crit Care Med 157:1652–1657.9603151
Laug EP, Nelson AA, Fitzhugh OG, . 1950. Liver cell alteration and DDT storage in the fat of the rat induced by dietary levels of 1 to 50 ppm DDT. J Pharmacol Exp Ther 98:268–273.15428986
*Lavappa KS, Fu MM, Epstein SS. 1975. Cytogenetic studies on chrysotile asbestos. Environ Res 10:165–173.811459
Le Bouffant L, Martin JC, Durif S, . 1973. Structure and composition of pleural plaques. IARC Sci Publ 8:249–257.
*Lechner JF, Haugen A, Trump BF, . 1983. Effects of asbestos and carcinogenic metals on cultured human bronchial epithelium. In: Harris CC, Autrup HN, eds. Human carcinogenesis. New York, NY: Academic Press, Inc., 561–585.
Lee BW, Wain JC, Kelsey KT, . 1998a. Association between diet and lung cancer location. Am J Respir Crit Care Med 158:1197–1203.9769282
Lee BW, Wain JC, Kelsey KT, . 1998b. Association of cigarette smoking and asbestos exposure with location and histology of lung cancer. Am J Respir Crit Care Med 157:748–755.9517586
Lee DH. 1974. Biological effects of ingested asbestos: Report and commentary. Environ Health Perspect 9:113–122.4620331
*Lee RJ, Florida RG, Stewart IM. 1995. Asbestos contamination in paraffin tissue blocks. Arch Pathol Lab Med 119:528–532.7605169
*Lee RJ, Van Orden DR, Corn M, . 1992. Exposure to airborne asbestos in buildings. Regul Toxicol Pharmacol 16:93–107.1410659
*Lee S-H, Shin M, Lee K-J, . 1999. Frequency of sister chromatid exchange in chrysotile-exposed workers. Toxicol Lett 108:315–319.10511277
Lee TC, Gold LI, Reibman J, . 1997. Immunohistochemical localization of transforming growth factor-beta and insulin-like growth factor-I in asbestosis in the sheep model. Int Arch Occup Environ Health 69:157–164.9049666
*Lee W-C, Testa JR. 1999. Somatic genetic alterations in human malignant mesothelioma (Review). Int J Oncol 14:181–188.9863027
*Lee W-C, Balsara B, Liu Z, . 1996. Loss of heterozygosity analysis defines a critical region in chromosome 1p22 commonly deleted in human malignant mesothelioma. Cancer Res 56:4297–4301.8813110
*Leeder JS, Kearns GL. 1997. Pharmcogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
Leigh J, Corvalan CF, Grimwood A, . 1991. The incidence of malignant mesothelioma in Australia 1982-1988. Am J Ind Med 20:643–655.1793106
Lemaire I. 1991. Selective differences in macrophage populations and monokine production in resolving pulmonary granuloma and fibrosis. Am J Pathol 138:487–495.1992772
Lemaire I, Gingras D, Lemaire S. 1986. Effects of chrysotile asbestos on DNA synthesis and growth of human embryonic lung fibroblasts. J Environ Pathol Toxicol Oncol 6:169–180.3783438
Le Marchadour F, Peoch M, Pasquier B, . 1994. Cardiac synovial sarcoma with translocation (X;18) associated with asbestos exposure [Letter]. Cancer 74:986.
*Lemen R, Becking GC, Cantor K, . 1987. Report on cancer risks associated with the ingestion of asbestos. Environ Health Perspect 72:253–265.3304998
*Lemen RA, Dement JM, Wagoner JK. 1980. Epidemiology of asbestos-related diseases. Environ Health Perspect 34:1–11.
*Lerman Y, Selikoff IJ, Lilis R, . 1986. Clinical findings among asbestos workers in V.S.: Influences of cigarette smoking. Am J Ind Med 10:449–458.3812489
Lesage S. 1993. Methods for the analysis of hazardous wastes. J Chromatogr 642(1–2):65–74.
Lesur O, Bernard AM, Begin RO. 1996. Clara cell protein (CC-16) and surfactant-associated protein A (SP-A) in asbestos-exposed workers. Chest 109:467–474.8620724
*Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, ed. General and applied toxicology. New York: Stockton Press, 153–164.
*Levin JL, Mclarty JW, Hurst GA, . 1998. Tyler asbestos workers: Mortality experience in a cohort exposed to amosite. Occup Environ Med 55:155–160.9624266
Levin SM, Selikoff IJ. 1991. Radiological abnormalities and asbestos exposure among custodians of the New York City board of education. Ann NY Acad Sci 530–539.
*Levy BS, Sigurdson E, Mandel J, . 1976. Investigating possible effects of asbestos in city water: Surveillance of gastrointestinal cancer incidence in Duluth, Minnesota. Am J Epidemiol 103:362–368.1258862
*Lew F, Tsang P, Holland JF, . 1986. High frequency of immune dysfunctions in asbestos workers and in patients with malignant mesothelioma. J Clin Immunol 6:225–233.2424930
Lewitus Z, Guttmann S, Anbar M. 1962. Effect of thyroid-stimulating hormone (TSH) on the accumulation of perchlorate and fluoroborate ions in the thyroid glands of rats. Endocrinology 70:295–297.14464922
*Lezon-Geyda K, Jaime CM, Godbold JH, . 1996. Chrysotile asbestos fibers mediate homologous recombination in rat2 delta fibroblasts: Implications for carcinogenesis. Mutat Res 361:113–120.8980696
Li XY, Lamb D, Donaldson K. 1992. Intratracheal injection of crocidolite asbestos depresses the secretion of tumor necrosis factor by pleural leukocytes in vitro. Exp Lung Res 18:359–372.1628568
Li XY, Lamb D, Donaldson K. 1994. Mesothelial cell injury caused by pleural leukocytes from rats treated with intratracheal instillation of crocidolite asbestos or Corynebacterium parvum. Environ Res 64(2):181–191.8306950
*Libbus BL, Illenye SA, Craighead JE. 1989. Induction of DNA strand breaks in cultured rat embryo cells by crocidolite asbestos as assessed by nick translation. Cancer Res 49:5713–5718.2790787
Liddell D. 1994. Cancer mortality in chrysotile mining and milling: Exposure-response. Ann Occup Hyg 38:519–523.7978973
Liddell FDK. 1994. Mining and milling. Ann Occup Hyg 38:412.
Liddell FD, Hanley JA. 1985. Relations between asbestos exposure and lung cancer SMRS in occupational cohort studies. Br J Ind Med 42:389–396.4005191
Liddell FDK, McDonald JC. 1980. Radiological findings as predictors of mortality in Quebec asbestos workers. Br J Ind Med 37:257–267.7426477
*Liddell FDK, McDonald AD, McDonald JC. 1997. The 1891-1920 birth cohort of Quebec chrysotile miners and millers: Development from 1904 and mortality to 1992. Ann Occup Hyg 41:13–36.9072947
*Liddell FDK, McDonald AD, McDonald JC. 1998. Dust exposure and lung cancer in Quebec chyrsotile miners and millers. Ann Occup Hyg 42:7–20.9566111
Lilienfeld DE. 1991a. Asbestos-associated pleural mesothelioma in school teachers: A discussion of four cases. Ann NY Acad Sci 643:454–486.1809159
Lilienfeld DE. 1991b. The silence: The asbestos industry and early occupational cancer research--a case study. Am J Public Health 81(6):791–800.2029056
Lilienfeld DE, Mandel JS, Coin P, . 1988. Projection of asbestos related diseases in the United States, 1985-2009 I. Cancer. Br J Ind Med 45:283–291.3378008
Lilis R, Miller A, Godbold J, . 1991. Radiographic abnormalities in asbestos insulators: Effects of duration from onset of exposure and smoking. Relationships of dyspnea with parenchymal and pleural fibrosis. Am J Ind Med 20:1–15.1867212
*Lim Y, Kim S-H, Kim K-A, . 1997. Involvement of protein kinase C, phospholipase C, and protein tyrosine kinase pathways in oxygen radical generation by asbestos-stimulated alveolar macrophage. Environ Health Perspect Suppl 105:1325–1327.9400746
Lindroos PN, Coin PG, Badgett A, . 1997. Alveolar macrophages stimulated with titanium dioxide, chrysotile asbestos, and residual oil fly ash upregulate the PDGF receptor-alpha on lung fibroblasts through an IL-1 beta-dependent mechanism. Am J Respir Cell Mol Biol 16:283–292.9070613
Linnalnmaa K, Pelin K, Vanhala E, . 1993. Gap junctional intercellular communication of primary and asbestos-associated malignant human mesothelial cells. Carcinogenesis 14(8):1597–1602.8394779
*Lippmann M. 1988. Review: Asbestos exposure indices. Environ Res 46:86–106.3286241
*Lippmann M. 1990. Effects of fiber characteristics on lung deposition, retention, and disease. Environ Health Perspect 88:311–317.2272328
*Lippmann M. 1994. Deposition and retention of inhaled fibres: Effects on incidence of lung cancer and mesothelioma. Occup Environ Med 51:793–798.7849861
Lippmann M, Schlesinger RB. 1983. Interspecies comparisons of particle deposition and mucociliary clearance in tracheobronchial airways. J Toxicol Environ Health :441–463.6655745
Lison D, Knoops B, Lauwerys R. 1989. Effect of retinoic acid on asbestos induced plasminogen activator activity of peritoneal macrophages. Br J Ind Med 46:496–497.2548565
Little DN. 1995. Children and environmental toxins. Prim Care 22:69–79.7777638
*Liu J-Y, Brass DM, Hoyle GW, . 1998. TNF-α receptor knockout mice are protected from the fibroproliferative effects of inhaled asbestos fibers. Am J Pathol 153(6):1839–1847.9846974
Liu JY, Morris GF, Lei WH, . 1997. Rapid activation of PDGF-A and -B expression at sites of lung injury in asbestos-exposed rats. Am J Respir Cell Mol Biol 17:129–140.9271299
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301.351201
*Livingston GK, Rom WN, Morris MV. 1980. Asbestos-induced sister chromatid exchanges in cultured Chinese hamster ovarian fibroblast cells. J Environ Pathol Toxicol 3:373–382.6771358
*Lockey JE, Brooks SM, Jarabek AM, . 1984. Pulmonary changes after exposure to vermiculite contaminated with fibrous tremolite. Am Rev Respir Dis 129(6):952–958.6329050
Longo WE, Rigler MW, Slade J. 1995. Crocidolite asbestos fibers in smoke from original Kent cigarettes. Cancer Res 55:2232–2235.7757969
Lotan R. 1999. Lung cancer promotion by beta-carotene and tobacco smoke: Relationship to suppression of retinoic acid receptor-beta and increased activator protein-1? J Natl Cancer Inst 91:7–9.9890162
Lozewicz S, Reznek RH, Herdman M, . 1989. Role of computed tomography in evaluating asbestos related lung disease. Br J Ind Med 46:777–781.2590642
*Lu J, Keane MJ, Ong T, . 1994a. In vitro genotoxicity studies of chrysotile asbestos fibers dispersed in simulated pulmonary surfactant. Mutat Res 320(4):253–259.7508551
*Lu YY, Jhanwar SC, Cheng JQ, . 1994b. Deletion mapping of the short arm of chromosome 3 in human malignant mesothelioma. Genes Chromosomes Cancer 9:76–80.7507705
*Luce D, Bugel I, Goldberg P, . 2000. Environmental exposure to tremolite and respiratory cancer in New Caledonia: A case-control study. Am J Epidemiol 151(3):259–265.10670550
*Lund LG, Aust AE. 1991a. Iron-catalyzed reactions may be responsible for the biochemical and biological effects of asbestos. BioFactors 3:83–89.1910455
*Lund LG, Aust AE. 1991b. Mobilization of iron from crocidolite asbestos by certain chelators results in enhanced crocidolite-dependent oxygen consumption. Arch Biochem Biophys 287:91–96.1654807
*Lund LG, Aust AE. 1992. Iron mobilization from crocidolite asbestos greatly enhances crocidolite-dependent formation of DNA single-strand breaks in X174 RFI DNA. Carcinogenesis 13:637–642.1315628
Lund LG, Williams MG, Dodson RF, . 1994. Iron associated with asbestos bodies is responsible for the formation of single strand breaks in φ X174 RFI DNA. Occup Environ Med 51(3):200–204.8130850
Luo J-C, Zehab R, Anttila S, . 1994. Detection of serum p53 protein in lung cancer patients. J Occup Med 36:155–160.8176513
*Luo SQ, Liu XZ, Wang CJ. 1992. An investigation of crocidolite contamination and experimental study in southwestern China. J Hyg Epidemiol Microbiol Immunol 36(2):223–224.
*Luster MI, Simeonova PP. 1998. Asbestos induces inflammatory cytokines in the lung through redox sensitive transcription factors. Toxicol Lett 102–103:271–275.
Lutz W, Krajewska B, Pilacic B. 1997. Determination of tissue polypeptide antigens (TPA) and carcinoembryonic antigen (CEA) in serum: Its value in the preliminary cancer risk assessment in asbestos exposed workers. Int J Occup Med Environ Health 10:259–265.9524403
MacDonald JL, Kane AB. 1997. Mesothelial cell proliferation and biopersistence of wollastonite and crocidolite asbestos fibers. Fundam Appl Toxicol 38:173–183.9299191
MacRae KD. 1988. Asbestos in drinking water and cancer. J R Coll Physicians Lond 22:7–10.3276886
*Magee F, Wright JL, Chan N, . 1986. Malignant mesothelioma caused by childhood exposure to long-fiber low aspect ratio tremolite. Am J Ind Med 9:529–533.3017103
*Magnani C, Leporati M. 1998. Mortality from lung cancer and population risk attributable to asbestos in an asbestos cement manufacturing town in Italy. Occup Environ Med 55:111–114.9614395
Magnani C, Borgo G, Betta GP, . 1991. Mesothelioma and non-occupational environmental exposure to asbestos [Letter]. Lancet 338(50):8758.
Magnani C, Ivaldi C, Botta M, . 1997. Pleural malignant mesothelioma and environmental asbestos exposure in Casale Monferrato, Piedmont. Preliminary analysis of a case-control study. Med Lav 88:302–309.9396215
Magnani C, Mollo F, Paoletti L, . 1998. Asbestos lung burden and asbestosis after occupational and environmental exposure in an asbestos cement manufacturing area: A necropsy study. Occup Environ Med 98:840–846.
*Magnani C, Terracini B, Ivaldi C, . 1993. A cohort study on mortality among wives of workers in the asbestos cement industry in Casale Monferrato, Italy. Br J Ind Med 50(9):779–784.8398870
Magnani C, Terracini B, Ivaldi C, . 1995. Pleural malignant mesothelioma and non-occupational exposure to asbestos in Casale Monferrato, Italy. Occup Environ Med 52:362–367.7627311
Maguire GP, Meggs LG, Addonizio J, . 1991. Association of asbestos exposure, retroperitoneal fibrosis, and acute renal failure. NY State J Med 91(8):357–359.
*Mahmood N, Khan SG, Ali S, . 1993. Asbestos induced oxidative injury to DNA. Ann Occup Hyg 37(3):315–319.8346877
Maier H, Tisch M. 1997. Epidemiology of laryngeal cancer. In: Kleinasser O, Glanz H, Olofsson J, ed. Advances in larynogology in Europe. Elsevier Science, 129–133.
*Malorni W, Iosi F, Falchi M, . 1990. On the mechanism of cell internalization of chrysotile fibers: An immunocytochemical and ultrastructural study. Environ Res 52:164–177.2168315
Maltoni C. 1999. Call for an international ban on asbestos. Toxicol Ind Health 15:529–531.10560131
Maltoni C, Minardi F. 1989. Recent results of carcinogenicity bioassays of fibres and other particulate materials. Bologna, Italy: Institute of Oncology, 46–53.
Maltoni C, Pinto C. 1997. Mesotheliomas in some selected Italian population groups. Med Lav 88:321–332.9396218
Maltoni C, Pinto C, Carnuccio R, . 1995. Mesotheliomas following exposure to asbestos used in railroads: 130 Italian cases. Med Lav 86:461–477.8684297
Maltoni C, Pinto C, Mobiglia A. 1991. Mesotheliomas following exposure to asbestos used in railroads: The Italian cases. Toxicol Ind Health 7:1–45.
Maltoni C, Pinto C, Valenti D, . 1994. Mesotheliomas following exposure to asbestos used in sugar refineries: Report of the eleven Italian cases. J Occup Med Toxicol 3:233–238.
Manavoglu O, Orhan B, Evrensel T, . 1996. Malignant peritoneal mesothelioma following asbestos exposure. J Environ Pathol Toxicol Oncol 15:191–194.9216805
Mandel JS, McLaughlin JK, Schlehofer B, . 1995. International renal-cell cancer study. IV. Occupation. Int J Cancer 61:601–605.7768630
Manning LS, Davis MR, Robinson BWS. 1991. Asbestos fibres inhibit the in vitro activity of lymphokine-activated killer (LAK) cells from healthy individuals and patients with malignant mesothelioma. Clin Exp Immunol 83:85–91.1846329
Manos CG, Patel-Mandlik KJ, Lisk DJ. 1992. Prevalence of asbestos in composted waste from 26 communities in the United States. Arch Environ Contam Toxicol 23 (2):266–269.
*Manos CG, Patel-Mandlik KJ, Lisk DJ. 1993. Asbestos in yard or sludge composts from the same community as a function of time-of-waste-collection. Chemosphere 26(8):1537–1540.
*Manos CG, Patel-Mandlik KJ, Ross BJ, . 1991. Prevalence of asbestos in sewage sludges from 51 large and small cities in the united states. Chemosphere 22:963–973.
Manzini VDP, Brollo A, Franceschi S, . 1993. Prognostic factors of malignant mesothelioma of the pleura. Cancer 72:410–417.8319172
Maples KR, Johnson NF. 1992. Fiber-induced hydroxyl radical formation: Correlation with mesothelioma induction in rats and humans. Carcinogenesis 13(11):2035–2039.1330349
*Marczynski B, Czuppon AB, Marek W, . 1994a. Increased incidence of DNA double-strand breaks and anti-ds DNA antibodies in blood of workers occupationally exposed to asbestos. Hum Exp Toxicol 13(1):3–9.8198827
*Marczynski B, Kerenyi T, Czuppon AB, . 1994b. Increased incidence of DNA double-strand breaks in lung and liver of rats after exposure to crocidolite asbestos fibers. Inhal Toxicol 6:395–406.
*Marczynski B, Kerenyi T, Marek W, . 1994c. Induction of DNA - damage after rats exposure to crocidolite asbestos fibers. In: Davis JMG, Jaurand MC, ed. Cellular and molecular effects of mineral and synthetic dusts and fibres. Berlin: Springer-Verlag, 227–232.
*Marczynski B, Kraus T, Rozynek P, . 2000a. Association between 8-hydroxy-2’-deoxyguanosine levels in DNA of workers highly exposed to asbestos and their clinical data, occupational and non-occupational confounding factors, and cancer. Mutat Res 468:203–212.10882897
*Marczynski B, Rozynek P, Kraus T, . 2000b. Levels of 8-hydroxy-2’-deoxyguanosine in DNA of white blood cells from workers highly exposed to asbestos in Germany. Mutat Res 468:195–202.10882896
*Markowitz SB, Morabia A, Lilis R, . 1997. Clinical predictors of mortality from asbestosis in the North American insulator cohort, 1981 to 1991. Am J Respir Crit Care Med 156:101–108.9230732
Marsella JM, Liu BL, Vaslet CA, . 1997. Susceptibility of p53-deficient mice to induction of mesothelioma by crocidolite asbestos fibers. Environ Health Perspect Suppl 105:1069–1972.9400702
*Marsh GM. 1983. Critical review of epidemiologic studies related to ingested asbestos. Environ Health Perspect 53:49–56.6662094
*Marsh JP, Mossman BT. 1991. Role of asbestos and active oxygen species in activation and expression of ornithine decarboxylase in hamster tracheal epithelial cells. Cancer Res 51:167–173.1846307
Martuzzi M, Comba P, De Santis M, . 1998. Asbestos-related lung cancer mortality in Piedmont, Italy. Am J Ind Med 33:565–570.9582948
Masson TJ, McKay FW, Miller RW. 1974. Asbestos-like fibers in Duluth water supply: Relation to cancer mortality. JAMA 228:1019–1020.4406338
*Mast RW, Hesterberg TW, Glass LR, . 1994. Chronic inhalation and biopersistence of refractory ceramic fiber in rats and hamsters. Environ Health Perspect Suppl 102:207–209.
*Mast RW, McConnell EE, Anderson R, . 1995. Studies on the chronic toxicity (inhalation) of four types of refractory ceramic fiber in male Fischer 344 rats. Inhal Toxicol 7:425–467.21539476
*Mayne ST, Redlich CA, Cullen MR. 1998. Dietary vitamin A and prevalence of bronchial metaplasia in asbestos-exposed workers. Am J Clin Nutr 68:630–635.9734740
*Mayr U, Butsch A and Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mays CW, Spiess H. 1984. Bone sarcomas in patients given radium-224. In: Boice JD Jr, Fraumeni JF Jr, eds. Radiation carcinogenesis: Epidemiology and biological significance. New York, NY: Raven Press, 241–252.
McCaughey WT. 1986. Neoplastic asbestos-induced disease. Mt Sinai J Med (NY) 53:416–420.
McClellan RO. 1997. Use of mechanistic data in assessing human risks from exposure to particles. Environ Health Perspect Suppl 105:1363–1372.9400751
*McConnell EE, Chevalier HJ, Hesterberg TW, . 1994. Comparison of the effects of chrysotile and crocidolite asbestos in rats after inhalation for 24 months. In: Mohr U, Dungworth DL, Mauderly JL, ., ed. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 461–467.
McConnell EE, Rutter HA, Ulland BM, . 1983a. Chronic effects of dietary exposure to amosite asbestos and tremolite in F344 rats. Environ Health Perspect 53:27–44.6319118
McConnell EE, Shefner AM, Rust JH, . 1983b. Chronic effects of dietary exposure to amosite and chrysotile asbestos in Syrian golden hamsters. Environ Health Perspect 53:11–25.6319115
*McConnochie K, Simonato L, Mayrides P, . 1987. Mesothelioma in Cyprus: The role of tremolite. Thorax 42:342–347.2821642
*McDonald AD, McDonald JC. 1980. Malignant mesothelioma in North America. Cancer 46:1650–1656.7417959
*McDonald AD, Case BW, Churg A, . 1997. Mesothelioma in Quebec chrysotile miners and millers: Epidemiology and aetiology. Ann Occup Hyg 41:707–719.9375529
*McDonald AD, Fry JS, Woolley AJ, . 1982. Dust exposure and mortality in an American factory using chrysotile, amosite, and crocidolite in mainly textile manufacture. Br J Ind Med 39:368–374.
*McDonald AD, Fry JS, Woolley AJ, . 1983. Dust exposure and mortality in an American chrysotile textile plant. Br J Ind Med 40:361–367.6313032
*McDonald AD, Fry JS, Wooley AJ, . 1984. Dust exposure and mortality in an American chrysotile asbestos friction products plant. Br J Ind Med 41:151–157.6326794
*McDonald JC. 1998a. Mineral fibre persistence and carcinogenicity. Ind Health 36:372–375.9810152
*McDonald JC. 1998b. Unfinished business: The asbestos textiles mystery. Ann Occup Hyg 42:3–5.9566110
*McDonald JC, McDonald AD. 1997. Chrysotile, tremolite and carcinogenicity. Ann Occup Hyg 41:699–705.9375528
*McDonald JC, Armstrong B, Case B, . 1989. Mesothelioma and asbestos fiber type. Evidence from lung tissue analysis. Cancer 63:1544–1547.2924262
*McDonald JC, Liddell FD, Dufresne A, . 1993. The 1891-1920 birth cohort of Quebec chrysotile miners and millers: Mortality 1976-88. Br J Ind Med 50(12):1073–1081.8280638
*McDonald JC, Liddell FD, Gibbs GW, . 1980. Dust exposure and mortality in chrysotile mining, 1910-75. Br J Ind Med 37:11–24.7370189
*McDonald JC, McDonald AD, Armstrong B, . 1986a. Cohort study of mortality of vermiculite miners exposed to tremolite. Br J Ind Med 43:436–444.3013278
*McDonald JC, McDonald AD, Hughes JM. 1999. Chrysotile, tremolite and fibrogenicity. Ann Occup Hyg 43(7):439–442.10582027
*McDonald JC, McDonald AD, Sebastien P, . 1988. Health of vermiculite miners exposed to trace amounts of fibrous tremolite. Br J Ind Med 45:63–634.3342189
*McDonald JC, Sebastien P, Armstrong B. 1986b. Radiological survey of past and present vermiculite miners exposed to tremolite. Br J Ind Med 43:445–449.3013279
*McDonald JC, Sebastien P, Case B. 1992. Ferruginous body counts in sputum as an index of past exposure to mineral fibers. Ann Occup Hyg 36(3):271–82.1519873
*McFadden D, Wright J, Wiggs B, . 1986. Cigarette smoke increases the penetration of asbestos fibers into airway walls. Am J Pathol 123:95–99.3963152
McGavin C, Hughes P. 1998. Finger clubbing in malignant mesotheliom and benign asbestos pleural disease. Resp Med 92:691–692.
*McGavin CR, Sheers G. 1984. Diffuse pleural thickening in asbestos workers: Disability and lung function abnormalities. Thorax 39:604–607.6474388
*McGavran PD, Butterick CJ, Brody AR. 1989. Tritiated thymidine incorporation and the development of an interstitial lesion in the bronchiolar-alveolar regions of the lungs of normal and complement deficient mice after inhalation of chrysotile asbestos. JEPTO 9:377–391.2637933
McLachlan MS, Wagner JC. 1974. Radiological diagnosis of crocidolite induced pleural mesotheliomata in the rat. Br J Exp Pathol 55:164–168.4835804
McLarty JW, Holiday DB, Girard WM, . 1995. Beta-carotene, vitamin A, and lung cancer chemoprevention: Results of an intermediate endpoint study. Am J Clin Nutr 62:1431S–14318S.7495244
McLean AN, Patel KR. 1997. Clinical features and epidemiology of malignant pleural mesothelioma in west Glasgow 1987-1992. Scott Med J 42:37–39.9507577
McMillan CH, Jones AD, Vincent JH, . 1989. Accumulation of mixed mineral dusts in the lungs of rats during chronic inhalation exposure. Environ Res 48:218–237.2538327
McMillan GHG. 1983. The risk of asbestos-related diseases occurring in welders. J Occup Med 25(10):727–730.6631557
McNeill KR, Waring S. 1992. Vitrification of contaminated soils. In: Rees JF, ed. Contamination and land treatment technology (International Public Conference), 143–159.
MDEQE. 1989. Summary of Massachusetts’ methodology for developing allowable ambient limits. Boston, MA: Massachusetts Department of Environmental Quality Engineering. Written Communication (May 8).
Meek ME. 1983. Transmigration of ingested asbestos. Environ Health Perspect 53:149–152.6662084
*Menard H, Noel L, Khorami J, . 1986. The adsorption of polyaromatic hydrocarbons on natural and chemically modified asbestos fibers. Environ Res 40:84–91.3709501
Meranger JC, Davey ABC. 1989. Non-asbestos fibre content of selected consumer products. Ottawa, Ontario, Canada: Environmental Health Directorate, Health and Welfare Canada, 347–353.
Meredith SK, McDonald JC. 1994. Work-related respiratory disease in the United Kingdom, 1989-1992: Report on the SWORD project. Occup Med 44:183–189.
Merler E. 1998. A cross-sectional study on asbestos workers carried out in Italy in 1940: A forgotten study. Am J Ind Med 33:90–93.9408533
Merler E, Buiatti E, Vainio H. 1997. Surveillance and intervention studies on respiratory cancers in asbestos-exposed workers. Scand J Work Environ Health 23:83–92.9167231
Merler E, Ricci P, Silvestri S. 1996. Crocidolite and not chrysotile was mainly used by the Italian railroad system. Med Lav 87:268–269.8858903
Metintas M, Gibbs AR, Harmanci E, . 1997. Malignant localized fibrous tumor of the pleura occurring in a person environmentally exposed to tremolite asbestos. Respiration 64:236–239.9154678
*Metintas M, Özdemir n, Hillerdal G, . 1999. Environmental asbestos exposure and malignant pleural mesothelioma. Resp Med 93:349–355.
*Meurman LO, Kiviluoto R, Hakama M. 1974. Mortality and morbidity among the working population of anthophyllite asbestos miners in Finland. Br J Ind Med 31:105–112.4830762
*Meurman LO, Pukkala E, Hakama M. 1994. Incidence of cancer among anthrophyllite asbestos miners in Finland. Occup Environ Med 51(6):421–425.8044235
Miller A, Miller JA. 1993. Diffuse thickening superimposed on circumscribed pleural thickening related to asbestos exposure. Am J Ind Med 23(6):859–871.8328474
*Miller A, Lilis R, Godbold J. 1992. Relationship of pulmonary function to radiographic interstitial fibrosis in 2,611 long-term asbestos insulators: An assessment of the International Labour Office profusion score. Am Rev Respir Dis 145(2):263–270.1736729
*Miller A, Lilis R, Godbold J, . 1994. Spirometric impairments in long-term insulators: Relationships to duration of exposure, smoking, and radiographic abnormalities. Chest 105:175–182.8275729
*Miller A, Lilis R, Godbold J, . 1996. Relation of spirometric function to radiographic interstitial fibrosis in two large workforces exposed to asbestos: An evaluation of the ILO profusion score. Occup Environ Med 53:808–812.8994399
*Miller A, Teirstein AS, Selikoff I. 1983. Ventilatory failure due to asbestos pleurisy. Am J Med 75:911–919.6650544
Miller BG, Jones AD, Searl A, . 1999a. Influence of characteristics of inhaled fibres on development of tumours in the rat lung. Ann Occup Hyg 43(3):167–179.10366898
Miller BG, Searl A, Davis JMG, . 1999b. Influence of fibre length, dissolution and biopersistence on the production of mesothelioma in the rat peritoneal cavity. Ann Occup Hyg 43(3):155–166.10366897
Miller K. 1985. Immunotoxicology. Clin Exp Immunol 61:219–223.2994925
Miller K, Brown RC. 1985. The immune system and asbestos-associated disease. In: Dean J ., eds. Immunotoxicology and immunopharmacology. New York, NY: Raven Press, 429–440.
*Miller K, Webster I, Handfield RI, . 1978. Ultrastructure of the lung in the rat following exposure to crocidolite and asbestos and quartz. J Pathol 124:39–44.214530
*Millette JR, Clark PJ, Pansing MF. 1980. Concentration and size of asbestos in water supplies. Environ Health Perspect 34:13–25.7389681
Millette JR, Clark PJ, Stober J, . 1983a. Asbestos in water supplies of the United States. Environ Health Perspect 53:45–48.6662093
Millette JR, Craun GF, Stober JA, . 1983b. Epidemiology study of the use of asbestos-cement pipe for the distribution of drinking water in Escambia County, Florida. Environ Health Perspect 53:91–98.6559131
Milosevic M, Petrovic L. 1988. Environmental exposure to chrysotile asbestos and cancer epidemiology. Arh Hig Rada Toksikol 39:489–498.3273143
Minardi F, Maltoni C. 1988. Results of recent experimental research on the carcinogenicity of natural and modified asbestos. Ann NY Acad Sci 754–761.2839093
Minowa M, Hatano S, Ashizawa, . 1991. A case-control study of lung cancer with special reference to asbestos exposure. Environ Health Perspect 94:39–42.1954937
Mishra A, Liu J-Y, Brody AR, . 1997. Inhaled asbestos fibers induce p52 expression in the rat lung. Am J Respir Cell Mol Biol 16:479–485.9115760
*Mlynarek S, Corn M, Blake C. 1996. Asbestos exposure of building maintenance personnel. Regul Toxicol Pharmacol 23:213–224.8812963
*Moatmed F, Lockey JE, Parry WT. 1986. Fiber contamination of vermiculites: A potential occupational and environmental health hazard. Environ Res 41:207–218.3019658
*Molinini R, Paoletti L, Albrizio M, . 1992. Occupational exposure to asbestos and urinary bladder cancer. Environ Res 58(2):176–183.1324833
Mollo F, Magnani C. 1995. European multicentric case control study on risk for mesothelioma after non-occupational (domestic and environmental) exposure to asbestos. Med Lav 86:496–500.8684301
Mollo F, Andrion A, Pira E, . 1983. Indicators of asbestos exposure in autopsy routine. 2. Pleural plaques and occupation. Med Lav 74:137–142.6865841
Mollo F, Piolatto G, Bellis D, . 1990. Asbestos exposure and histologic cell types of lung cancer in surgical and autopsy series. Int J Cancer 46:576–580.2170277
Mollo F, Pira E, Piolatto G, . 1995. Lung adenocarcinoma and indicators of asbestos exposure. Int J Cancer 60:289–293.7829232
Monchaux G, Chameaud J, Morlier JP, . 1989. Translocation of subcutaneously injected chrysotile fibres: potential cocarcinogenic effect on lung cancer induced in rats by inhalation of radon and its daughters. IARC Sci Pub 90:161–166.
*Mongan LC, Jones T, Patrick G. 2000. Cytokine and free radical responses of alveolar macrophages in vitro to asbestos fibres. Cytokine 12(8):1243–1247.10930305
Moniewska A, Szyba K, Jazwiec B, . 1989. Chrysotile A affects YAC-1 cytolytic activity of spleen cells. Arch Imm Et Therap 37:61–68.
Monso E, Texido A, Lopex D, . 1995. Asbestos bides in normal lung of western Mediterranean populations with no occupational exposure to inorganic dust. Arch Environ Health 50:305–311.7677431
Moran EM. 1996. Environment, cancer, and molecular epidemiology: Air pollution. J Environ Pathol Toxicol Oncol 15:97–104.9216792
Morgan A. 1994. The removal of fibres of chrysotile asbestos from lung. Ann Occup Hyg 38:643–646.7978988
Morgan A. 1995. Deposition of inhaled asbestos and man-made mineral fibers in the respiratory tract. Ann Occup Hyg 39:747–758.8526405
Morgan A, Holmes A. 1983. Distribution and characteristics of amphibole asbestos fibres, measured with the light microscope, in the left lung of an insulation worker. Br J Ind Med 40:45–50.6824599
*Morgan A, Holmes A. 1986. Solubility of asbestos and man-made mineral fibers in vitro and in vivo: Its significance in lung disease. Environ Res 39:475–484.3007107
Morgan A, Collier CG, Morris KJ, . 1993. A radioactive tracer technique to determine in vivo the number of fibers in the lungs of rats following their administration by intratracheal instillation. Environ Res 63(2):182–190.8243413
Morgan A, Davies P, Wagner JC, . 1977. The biological effects of magnesium-leached chrysotile asbestos. Br J Exp Pathol 58:465–473.588440
*Morgan A, Evans JC, Evans RJ, . 1975. Studies on the deposition of inhaled fibrous material in the respiratory tract of the rat and its subsequent clearance using radioactive tracer techniques: II. Deposition of the UICC standard reference samples of asbestos. Environ Res 10:196–207.1193032
*Morgan A, Talbot RJ, Holmes A. 1978. Significance of fiber length in the clearance of asbestos fibres from the lung. Br J Ind Med 35:146–153.656339
*Morgan RW. 1991. Re: Meta-analysis of asbestos and gastrointestinal cancer. Am J Ind Med 19:407–408.1826191
Morgan RW, Goodman M. 1998. [Letter]. N Engl J Med 339:1001.
*Morgan RW, Foliart DE, Wong O. 1985. Asbestos and gastrointestinal cancer. West J Med 143:60–65.4036114
Morimoto Y, Kido M, Tanaka I, . 1993. Synergistic effects of mineral fibers and cigarette smoke on the production of necrosis factor by alveolar macrophages of rats. Br J Ind Med 50(10):955–960.8217857
Morimoto Y, Tsuda T, Nakamura H, . 1997. Expression of matrix metalloproteinases, tissue inhibitors of metalloproteinases, and extracellular matrix mRNA following exposure to mineral fibers and cigarette smoke in vivo. Environ Health Perspect Suppl 105:1247–1251.9400732
Morris GF, Brody AR. 1999. Stressing fibrogenesis in cell culture. Am J Respir Cell Mol Biol 21:447–448.10502552
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Mossman BT. 1983. In vitro approaches for determining mechanisms of toxicity an carcinogenicity by asbestos in the gastrointestinal and respiratory tracts. Environ Health Perspect 53:155–161.6363051
Mossman BT. 1988. Carcinogenic potential of asbestos and nonasbestos fibers. J Environ Sci Health 6:151–195.
Mossman BT. 1990. In vitro studies on the biologic effects of fibers: Correlation with in vivo bioassays. Environ Health Perspect 88:319–322.2272329
*Mossman BT, Churg A. 1998. Mechanisms in the pathogenesis of asbestosis and silicosis. Am J Resp Crit Care Med 157:1666–1680.9603153
Mossman BT, Craighead JE. 1979. Use of hamster tracheal organ cultures for assessing the cocarcinogenic effects of inorganic particulates on the respiratory epithelium. Prog Exp Tumor Res 24:37–47.538256
Mossman BT, Marsh JP. 1989. Evidence supporting a role for active oxygen species in asbestos-induced toxicity and lung disease. Environ Health Perspect 81:91–94.2667992
*Mossman BT, Bignon J, Corn M, . 1990a. Asbestos: Scientific developments and implications for public policy. Science 247:294–301.2153315
*Mossman BT, Eastman A, Bresnick E. 1984. Asbestos and benzo[a]pyrene act synergistically to induce squamous metaplasia and incorporation of [^3^H]thymidine in hamster tracheal epithelium. Carcinogenesis 5:1401–1405.6488462
*Mossman BT, Eastman A, Landesman JM, . 1983a. Effects of crocidolite and chrysotile asbestos on cellular uptake and metabolism of benzo(a)pyrene in hamster epithelial cells. Environ Health Perspect 51:331–335.6315375
*Mossman BT, Faux S, Janssen Y, . 1997. Cell signaling pathways elicited by asbestos. Environ Health Perspect Suppl 105:1121–1125.9400710
*Mossman B, Light W, Wei E. 1983b. Asbestos: Mechanisms of toxicity and carcinogenicity in the respiratory tract. Ann Rev Pharmacol Toxicol 23:595–615.6347054
*Mossman BT, Marsh JP, Sesko A, . 1990b. Inhibition of lung injury, inflammation, and interstitial pulmonary fibrosis by polyethylene glycol-conjugated catalase in a rapid inhalation model of asbestosis. Am Rev Respir Dis 141:1266–1271.2160214
Moulin JJ. 1997. A meta-analysis of epidemiologic studies of lung cancer in welders. Scand J Work Environ Health 23:104–113.9167233
Mukhtar M-SR, Rao GMM. 1996. Respiratory effects of occupational exposure to asbestos. Indian J Physiol Pharmacol 40:98–102.8864781
Murai Y, Kitagawa M. 1992. Asbestos fiber analysis in 27 malignant mesothelioma cases. Am J Ind Med 22(2):193–207.1415286
Murai Y, Kitagawa M, Hiraoka T. 1995a. Asbestos body formation in the human lung: Distinctions, by type and size. Arch Environ Health 50:19–25.7717765
Murai Y, Kitagawa M, Hiraoka T. 1997. Fiber analysis in lungs of residents of a Japanese town with endemic pleural plaques. Arch Environ Health 52:263–269.9210725
Murai Y, Kitagawa M, Matsui K, . 1995b. Asbestos fiber analysis in nine lung cancer cases with high asbestos exposure. Arch Environ Health 50:320–325.7677433
Murai Y, Kitagawa M, Yasuda M, . 1994. Asbestos fiber analysis in seven asbestosis cases. Arch Environ Health 49:67–72.8117151
*Murray KA, Gamsu G, Webb WR, . 1995. High-resolution computed tomography sampling for detection of asbestos-related lung disease. Acad Radiol 2:111–115.9419533
*Murthy SS, Testa JR. 1999. Asbestos, chromosomal deletions, and tumor suppressor gene alterations in human malignant mesothelioma. J Cell Physiol 180:150–157.10395284
Murthy SS, Shen T, De Rienzo A, . 2000. Expression of GPC3, an X-linked recessive overgrowth gene, is silenced in malignant mesothelioma. Oncogene 19:410–416.10656689
*Muscat JE, Wynder EL. 1991. Cigarette smoking, asbestos exposure, and malignant mesothelioma. Cancer Res 51:2263–2267.2015590
Muscat JE, Wynder EL. 1992. Tobacco, alcohol, asbestos, and occupational risk factors for laryngeal cancer. Cancer 69:2244–2251.1562970
Muscat JE, Stellman SD, Richie JP, . 1998. Lung cancer risk and workplace exposures in black men and women. Environ Res 76:78–84.9515062
Muscat JE, Stellman SD, Wynder EL. 1995. Insulation, asbestos, smoking habits, and lung cancer cell types. Am J Ind Med 27:257–269.7755015
*Musk AW, De Klerk NH, Ambrosimi GL, . 1998. Vitamin A and cancer prevention I: Observations in workers previously exposed to asbestos at Wittenoom, western Australia. Int J Cancer 75:355–361.9455793
Musselman R, Miiller W, Eastes W, . 1994a. Biopersistence of crocidolite versus man-made vitreous fibers in rat lungs after brief exposures. In: Mohr U, Dungworth DL, Mauderly JL, ., ed. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington,DC: ILSI Press, 451–454.
Musselman RP, Miiller WC, Eastes W, . 1994b. Biopersistences of man-made vitreous fibers and crocidolite fibers in rat lungs following short-term exposures. Environ Health Perspect Suppl 102:139–143.
Mutsaers SE, Harrison NK, McAnulty RJ, . 1998. Fibroblast mitogens in bronchoalveolar lavage (BAL) fluid from asbestos-exposed subjects with and without clinical evidence of asbestosis: No evidence for the role of PDGF, TNF-alpha, IGF-1, or IL-1beta. J Pathol 185:199–203.9713348
Mutti L, De Luca A, Claudio PP, . 1998. Simian virus 40-like DNA sequences and large-T antigenretinoblastoma family protein pRb2/p130 interaction in human mesothelioma. Dev Biol 94:47–53.
Nadeau Denis, Lane DA. 1989. On the cytotoxicity of chrysotile asbestos fibers toward pulmonary alveolar macrophages. Toxicol App Pharmacol 98:144–158.
Nakadate T. 1995. Decline in annual lung function in workers exposed to asbestos with and without pre-existing fibrotic changes on chest radiography. Occup Environ Med 52:368–373.7627312
Narasimhan SR, Yang L, Gerwin BI, . 1998. Resistance of pleural mesothelioma cell lines to apoptosis: Relation to expression of Bcl-2 and Bax. Am J Physiol 275:L165–L171.9688948
*NAS. 1977. Drinking water and health. Washington, DC: National Academy of Sciences, 144–168.
*NAS. 1982. Drinking water and health. Vol 4. Washington, DC: National Academy Press, 42–61.
*NAS. 1983. Drinking water and health. Vol 5. Washington, DC: National Academy Press, 123–147.
*NAS/NRC. 1989. Biologic markers in reproductive toxicology. National Academy of Sciences/National Research Council. Washington, DC: National Academy Press, 15–35.
NATICH. 1988. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards, National Air Toxics Information Clearinghouse. EPA 450/5-88-007. NTIS No. PB89-106983.
NATICH. 1991. NATICH data base report on state, local and EPA air toxics activities. Report to U.S. Environmental Protection Agency, Office of Air Quality Planning Standards, National Air Toxics Information Clearinghouse, Research Triangle Park, NC, by Radian Corporation, Austin, TX. EPA 68/08-0065.
NATICH. 1992. NATICH data base report on state, local and EPA air toxics activities. Research Triangle Park, NC: U. S. Environmental Protection Agency, Office of Air Quality Planning and Standards, National Air Toxics Information Clearinghouse. September 1992.
*Nelson HH, Christiani DC, Wiencke JK, . 1999. k-ras mutation and occupational asbestos exposure in lung adenocarcinoma: Asbestos-related cancer without asbestosis. Cancer Res 59:4570–4573.10493509
*Nelson HH, Wiencke JK, Gunn L, . 1998. Chromosome 3p14 alterations in lung cancer: Evidence the FHIT exon deletion is a target of tobacco carcinogens and asbestos. Cancer Res 58:1804–1807.9581816
*Neri S, Antonelli A, Falaschi F, . 1994. Findings from high resolution computed tomography of the lung and pleura of symptom free workers exposed to amosite who had normal chest radiographs and pulmonary function tests. Occup Environ Med 51:239–243.8199665
*Neri S, Boraschi P, Antonelli A, . 1996. Pulmonary function, smoking habits, and high resolution computed tomography (HRCT) early abnormalities of lung and pleural fibrosis in shipyard workers exposed to asbestos. Am J Ind Med 30:588–595.8909607
Nettesheim P, Topping DC, Jamasbi R. 1981. Host and environmental factors enhancing carcinogenesis in the respiratory tract. Ann Rev Pharmacol Toxicol 21:133–163.7016003
Neuberger M, Kundi M. 1990. Individual asbestos exposure: Smoking and mortality-a cohort study in the asbestos cement industry. Br J Ind Med 47:615–620.2169860
*Neuberger M, Frank W, Golob P, . 1996. [Asbestos concentrations in drinking water: Asbestos cement pipes and geogen sources in Austria.] Zentralbl Hyg Umeweltmed 198:293–306. (German).
*Neugut AI, Murray TI, Garbowski GC, . 1991. Association of asbestos exposure with colorectal adenomatous polyps and cancer. J Natl Cancer Inst 83:1827–1828.1744926
*Newhouse ML, Berry G. 1976. Predictions of mortality from mesothelial tumours in asbestos factory workers. Br J Ind Med 33:147–151.962998
*Newhouse ML, Berry G. 1979. Patterns of mortality in asbestos factory worker in London. Ann NY Acad Sci 330:53–60.294204
*Newhouse ML, Sullivan KR. 1989. A mortality study of workers manufacturing friction materials: 1941-86. Br J Ind Med 46:176–179.2539183
Newhouse ML, Berry G, Skidmore JW. 1982. A mortality study of workers manufacturing friction materials with chrysotile asbestos. Ann Occup Hyg 26:899–909.6295251
Newhouse ML, Berry G, Wagner JC, . 1972. A study of the mortality of female asbestos workers. Br J Ind Med 29:134–141.5021993
Newhouse ML, Berry G, Wagner JC. 1985. Mortality of factory workers in east London 1933-1980. Br J Ind Med 42:4–11.3965014
Newman HA, Saat YA, Hart RW. 1980. Putative inhibitory effects of chrysotile, crocidolite, and amosite mineral fibers on the more complex surface membrane glycolipids and glycoproteins. Environ Health Perspect 34:103–111.7389680
*Ni Z, Liu Y-Q, Keshava N, . 2000. Analysis of K-ras and p53 mutations in mesotheliomas from humans and rats exposed to asbestos. Mutat Res 468:87–92.10863160
Nicholson WJ. 1971. Measurement of asbestos in ambient air. Final report. National Air Pollution Control Administration. [Unpublished study to be peer reviewed].
Nicholson WJ. 1978. Chrysotile asbestos in air samples collected in Puerto Rico. Report to the Consumer Products Safety Commission by the City University of New York. New York, NY: Mount Sinai School of Medicine, Environmental Sciences Laboratory. CPSC 77128000.
*Nicholson WJ. 1987. Airborne levels of mineral fibres in the non-occupational environment. New York, NY: City University of New York, Mount Sinai School of Medicine, Division of Environmental and Occupational Medicine.
Nicholson WJ. 1989. Airborne mineral fibre levels in the non-occupational environment. In: Bignon J, Peto J, Saracci R, eds. Lyon, France: International Agency for Research on Cancer, World Health Organization.
Nicholson WJ. 1991. Comparative dose-response relationships of asbestos fiber types: Magnitude and uncertainties. Ann NY Acad Sci 74–84.
*Nicholson WJ, Landrigan PJ. 1996. Asbestos: A status report. Curr Issues Pub Health 2:118–123.
*Nicholson WJ, Pundsack FL. 1973. Asbestos in the environment. In: Biological effects of asbestos, proceedings of a working conference held at IARC 26 October, 1972. IARC Sci Publ 8:126–132.
*Nicholson WJ, Perkel G, Selikoff IJ. 1982. Occupational exposure to asbestos: Populations at risk and projected mortality--1980-2030. Am J Ind Med 3:259–311.7171087
Nicholson WJ, Rohl AN, Weisman I. 1975. Asbestos contamination of the air in public buildings. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. EPA-450/3-76-004. NTIS No. PB-250980.
*Nicholson WJ, Selikoff IJ, Seidman H, . 1979. Long-term mortality experience of chrysotile miners and millers in Thetford Mines, Quebec. Ann NY Acad Sci 330:11–21.294161
*Nigam SK, Suthar AM, Patel MM, . 1993. Humoral immunological profile of workers exposed to asbestos in asbestos mines. Indian J Med Res 98(12):274–7.8132229
NIOSH. 1975. Asbestos exposure during servicing of motor vehicle brake and clutch assemblies. Current intelligence bulletin 5. Rockville, MD: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health.
*NIOSH. 1976. Revised recommended asbestos standard. Washington, DC: U.S. Department of Health, Education, and Welfare, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. DHEW (NIOSH) Publication No. 77-169.
NIOSH. 1984. Chrysotile asbestos - method 9000. In: NIOSH manual of analytical methods. 3rd ed. Cincinnati, OH: National Institute for Occupational Safety and Health, 9000-1 – 9000-7.
NIOSH. 1985. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, 54.
*NIOSH. 1987. Fibers - method 7400. In: NIOSH manual of analytical methods. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. Revision 2. August 15, 1987.
NIOSH. 1988a. National occupational exposure survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1988b. National occupational hazard survey. Cincinnati, OH: National Institute for Occupational Safety and Health.
NIOSH. 1988c. Asbestos-induced intrathoracic tissue reactions. Cincinnati, OH: National Institute for Occupational Safety and Health, NTIS No. PB88-248380.
*NIOSH. 1989a. Fibers - method 7400. In: NIOSH manual of analytical methods. 3rd ed. Supplement. Cincinnati, OH: National Institute for Occupational Safety and Health, 7400-1 – 7400-13.
*NIOSH. 1989b. Asbestos fibers - method 7402. In: NIOSH manual of analytical methods. 3rd ed. Supplement. Cincinnati, OH: National Institute for Occupational Safety and Health, 7402-1 – 7402-8.
*NIOSH. 1989c. Fibers - method 9002. In: NIOSH manual of analytical methods. 3rd ed. Supplement. Cincinnati, OH: National Institute for Occupational Safety and Health, 9002-1 to 9002-10.
NIOSH. 1989d. Control of asbestos exposure during brake drum service. Cincinnati, OH: National Institute for Occupational Safety and Health, NTIS no. PB90-168501.
NIOSH. 1990a. Asbestos related disease - a community epidemic in the making. Cincinnati, OH: National Institute for Occupational Safety and Health, NTIS no. PB90-155896.
NIOSH. 1990b. National Institute for Occupational Safety and Health. NIOSH pocket guide to chemical hazards. Washington, DC: U.S. Department of Health and Human Services.
NIOSH. 1990c. Testimony of the National Institute for Occupational Safety and Health on the occupational safety of proposed rulemaking on occupational exposure to asbestos, tremolite, anthrophyllite, and actinolite. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health. 2 CFR 1910 and 1926. May 9, 1990. NTIS no. PB91-152-439.
NIOSH. 1992. NIOSH recommendations for occupational safety and health. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, iv–vi, 51, 140.
*NIOSH. 1994a. Asbestos and other fibres by PCM. In: Manual of analytical methods, 4th edition. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 1994b. Asbestos by TEM. In: Manual of analytical methods, 4th ed. Cincinnati, OH: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 1999. Pocket guide to chemical hazards. Washington D.C.: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health.
*NIOSH. 2001. Pocket guide to chemical hazards. Washington D.C.: U.S. Department of Health and Human Services, National Institute for Occupational Safety and Health. Http://www.cdc.gov/niosh/nioshsrch.html. January 17,2001.
Nishimura SL, Broaddus VC. 1998. Asbestos-induced pleural disease. Clin Chest Med 19:311–329.9646983
NLM. 1988. Chemline. National Library of Medicine, Bethesda, MD. December 1988.
Nokso-Koivisto P, Pukkala E. 1994. Past exposure to asbestos and combustion products and incidence of cancer among Finnish locomotive drivers. Occup Environ Med 51:330–334.8199683
Nolan RP, Langer AM, Addison J. 1994. Lung content analysis of cases occupationally exposed to chrysotile asbestos. Environ Health Perspect Suppl 102:245–250.
Nolan RP, Langer AM, Wilson R. 1999. A risk assessment for exposure to grunerite asbestos (amosite) in an iron ore mine. Proc Natl Acad Sci U S A 96:3412–3419.10097051
*NRC. 1984. National Research Council. Asbestiform fibers: Nonoccupational health risks. Washington, DC: National Academy Press.
*NRC. 1993. National Research Council. Pesticides in the diets of infants and children. Washington, DC: National Academy Press.
*NTP. 1983. National Toxicology Program. Technical report series no. 249. Lifetime carcinogenesis studies of amosite asbestos (CAS no. 121-72-73-5) in Syrian golden hamsters (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 84-2505.
*NTP. 1985. National Toxicology Program. Technical report series no. 295. Toxicology and carcinogenesis studies of chrysotile asbestos (CAS no. 12001-29-5) in F344/N rats (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 86-2551.
*NTP. 1988. National Toxicology Program. Technical report on the toxicology and carcinogenesis studies of crocidolite asbestos (CAS no. 12001-28-4) in F344/N rats (feed studies). Research Triangle Park, NC: U. S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 88-2536.
*NTP. 1990a. National Toxicology Program. Technical report on the carcinogenesis lifetime studies of chrysotile asbestos (CAS no. 12001-29-5) in Syrian golden hamsters (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 90-2502.
*NTP. 1990b. National Toxicology Program. Technical report series no. 279. Toxicology and carcinogenesis studies of amosite asbestos F344/N rats. Report to National Institute of Environmental Health Sciences, Research Triangle Park, NC, by Technical Resources, Inc., Rockville, MD. NTP 91-2535.
*NTP. 1990c. National Toxicology Program. Technical report on the toxicology and carcinogenesis studies of tremolite (CAS no. 14567-73-8) in Fischer 344 rats (feed study). Research Triangle Park, NC: U. S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NIH Publication No. 90-2531.
NTP. 1991. National Toxicology Program. Sixth annual report on carcinogens 1991 summary. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. 27–33.
NTP. 1994. National Toxicology Program. Management status report. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, Division of Toxicology Research and Testing.
*NTP. 2001. National Toxicology Program. Ninth annual report on carcinogens. U.S. Department of Health and Human Services, Public Health Service.
*Nuorva K, Makitaro R, Huhti E, . 1994. p53 Protein accumulation in lung carcinomas of patients exposed to asbestos and tobacco smoke. Am J Respir Crit Care Med 150:528–533.8049841
*Nurminen M, Tossavainen A. 1994. Is there an association between pleural plaques and lung cancer without asbestos? Scand J Work Environ Health 20:62–64.8016601
*Nyberg P, Klockars M. 1991. Interferon-γ and immunoglobulin enhance mineral dust-induced production of reactive oxygen metabolites by human macrophages. Clin Immunol Immunopathol 60:128–136.1646088
Nyberg P, Klockars M. 1994. Bacillus Calmette-Guerin (BCG) and immunoglobulins synergistically enhance mineral dust-induced production of reactive oxygen metabolites by human monocytes. Clin Exp Immunol 97:334–337.8050185
Nyberg PW, Nordman SAS, Klockars MLG. 1994. Increased mineral dust-induced production of reactive oxygen species by blood monocytes from patients with malignant diseases. Apmis 102:765–770.7826606
Oehlert GW. 1991. A reanalysis of the Stanton et al. pleural sarcoma data. Environ Res 54:194–205.2029879
*Oettinger R, Drumm K, Knorst M, . 1999. Production of reactive oxygen intermediates by human macrophages exposed to soot particles and asbestos fibers and increase in NF-kappa B p50/p105 mRNA. Lung 177:343–354.10541885
*Ogino S, Fukumori N, Yasuno T, . 1988. Asbestos fibers in sake. J Food Protection 51:737–739.
*Ohio EPA. 2001. Toxic release inventory rules: Air pollution regulations. Division of Air Pollution Control, Ohio Environmental Protection Agency. Http://www.epa.state.oh.us/cgi-bin/htsearch. January 19, 2001.
*Ohlson C-G, Bodin L, Rydman T, . 1985. Ventilatory decrements in former asbestos cement workers: A four year follow up. Br J Ind Med 42:612–616.3849974
*Ohlson C-G, Rydman T, Sundell L, . 1984. Decreased lung function in long-term asbestos cement workers: A cross-sectional study. Am J Ind Med 5:359–366.6609639
*Okayasu R, Takahashi S, Yamada S, . 1999a. Asbestos and DNA double strand breaks. Cancer Res 59:298–300.9927035
Okayasu R, Wu L, Hei TK. 1999b. Biological effects of naturally occurring and man-made fibres: in vitro cytotoxicity and mutagenesis in mammalian cells. Br J Cancer 79(9/10):1319–1324.10188871
Oksa P, Huuskonen MS, Jarvisalo J, . 1998a. Follow-up of asbestosis patients and predictors for radiographic progression. Int Arch Occup Environ Health 71:465–471.9826079
Oksa P, Klockers M, Karjalainen A, . 1998b. Progression of asbestosis predicts lung cancer. Chest 113:1517–1521.9631787
Oksa P, Koskinen H, Rinne JP, . 1992. Parenchymal and pleural fibrosis in construction workers. Am J Ind Med 21:561–567.1580260
Oksa P, Pukkala E, Karjalainen A, . 1997. Cancer incidence and mortality among Finnish asbestos sprayers and in asbestosis and silicosis patients. Am J Ind Med 31:693–698.9131223
*Oksa P, Suoranto H, Koshinen H, . 1994. High resolution computed tomography in the early detection of asbestosis. Int Arch Occup Environ Health 65(5):299–304.8175184
Oliver LC, Sprince NL, Greene R. 1991. Asbestos-related abnormalities in school maintenance personnel. Ann NY Acad Sci 521–529.
*Ollikainen T, Linnainmaa K, Kinnula VL. 1999. DNA single strand breaks induced by asbestos fibers in human pleural mesothelial cells in vitro. Environ Mol Mutagen 33:153–160.10217069
*Olofsson K, Mark J. 1989. Specificity of asbestos-induced chromosomal aberrations in short-term cultured human mesothelial cells. Cancer Genet Cytogenet 41:33–39.2766251
Omenn GS. 1991/92. CARET, the beta-carotene and retinal efficacy trial to prevent lung cancer in high-risk populations. Public Health Rev 19(1–4):205–208.1844268
Omenn GS, Goodman G, Grizzle J, . 1992. Recruitment for the β-carotene and retino efficacy trial (caret) to prevent lung cancer in smokers and asbestos-exposed workers. West J Med 156:540–544.1595284
Omenn GS, Goodman GE, Thornquist MD, . 1993. The carotene and reinol efficacy trial (CARET) to prevent lung-cancer in high risk populations--pilot study with asbestos-exposed workers. Cancer Epidemiol Biomarkers Prev 2(4):381–387.8348062
Omenn GS, Goodman G, Thornquist M, . 1994. The beta-carotene and retinol efficacy trial (CARET) for chemoprevention of lung cancer in high risk populations: Smokers and asbestos-exposed workers. Cancer Res 54(Suppl 7):2038s–2043s.8137335
*Omenn GS, Goodman GE, Thornquist MD, . 1996a. Effects of a combination of beta carotene and vitamin A on lung cancer and cardiovascular disease. N Engl J Med 334:1150–1155.8602180
*Omenn GS, Goodman GE, Thornquist MD, . 1996b. Risk factors for lung cancer and for intervention effects in CARET, the beta-carotene and retinol efficacy trial. J Natl Cancer Inst 88:1550–1559.8901853
Orlowski E, Pairon JC, Ameille J, . 1994. Pleural plaques, asbestos exposure, and asbestos bodies in bronchoalveolar lavage fluid. Am J Ind Med 26:349–358.7977408
*Osgood C, Sterling D. 1991. Chrysotile and amosite asbestos induce germ-line aneuploidy in Drosophila. Mutat Res 261:9–13.1881411
*OSHA. 1986. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 51:22612–22790.
OSHA. 1988. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 53:35610–35629.
*OSHA. 1990. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 55:29712–29753.
*OSHA. 1992. U.S. Department of Labor, Occupational Safety and Health Administration. 57:7877–7878, 24310–24331, 49657–49661.
*OSHA. 1994. Occupational exposure to asbestos. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 59(153):40964–41162.
OSHA. 1995. Occupational exposure to asbestos; corrections; final rule. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 60(125):33973–34002.
OSHA. 1996. Occupational exposure to asbestos, tremolite, anthophyllite and actinolite. U.S. Department of Labor, Occupational Safety and Health Administration. Federal Register 61:43454–43459.
*OSHA. 1998a. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1001.
*OSHA. 1998b. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1101.
*OSHA. 1998c. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1001.
*OSHA. 2001a. OSHA Regulations: Asbestos. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1001. Http://www.osha-slc.gov/OshStd_data/1910_1001.html. January 18,2001.
*OSHA. 2001b. OSHA Regulations: Asbestos. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1101. Http://www.osha-slc.gov/OshStd_data/1926_1101.html. January 18,2001.
*OSHA. 2001c. OSHA Regulations: Asbestos. U. S. Department of Labor. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1001. Http://www.osha-slc.gov/OshStd_data/1915_1001.html. January 18,2001.
*Oshimura M, Hesterberg TW, Barrett JC. 1986. An early, nonrandom karyotypic change in immortal Syrian hamster cell lines transformed by asbestos: Trisomy of chromosome 11. Cancer Genet Cytogenet 22:225–237.3708554
Oshimura M, Hesterberg TW, Tsutsui T, . 1984. Correlation of asbestos-induced cytogenetic effect with cell transformation of Syrian hamster embryo cells in culture. Cancer Res 44:5017–5022 6091868
Osinubi OYO, Gochfeld M, Kipen HM. 2000. Health effects of asbestos and nonasbestos fibers. Environ Health Perspect 108(Suppl. 4):665–674.10931785
Ostergaard G, Knudsen I. 1998. The applicability of the ADI (acceptable daily intake) for food additives to infants and children. Food Addit Contam 15:63–74.9602914
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment, U.S. Congress. OTA-BA-436. April 1990.
*Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human Development. Philadelphia, PA: WB Saunders, 222–238.
Ozdemir N, Metintas M, Uefun I, . 1996. Environmental asbestos exposure and malignant pleural mesothelioma. Eur Resp J 9:248S.
Ozdemir T, Cöplü L, Dincer N, . 1997. Environmental tremolite exposure in a village located in southwest of Turkey [Abstract]. Eur Resp J 10:230s.
Pache JC, Janssen YMW, Walsh ES, . 1998. Increased epidermal growth factor-receptor protein in a human mesothelial cell line in response to long asbestos fibers. Am J Pathol 152:333–340.9466557
Paci E, Zappa M, Paoletti L, . 1991. Further evidence of an excess of risk of pleural malignant mesothelioma in textile workers in Prato [Italy]. Br J Cancer 64(2):377–378.1892768
Pailes WH, Judy DJ, Resnick H, . 1984. Relative effects of asbestos and wollastonite on alveolar macrophages. J Toxicol Environ Health 14:497–510.6096570
Pairon JC, Martinon L, Iwatsubo Y, . 1994. Retention of asbestos bodies in the lungs of welders. Am J Ind Med 25:793–804.8067357
Pairon JC, Orlowski E, Iwatsubo Y, . 1994. Pleural mesothelioma and exposure to asbestos: Evaluation from work histories and analysis of asbestos bodies in bronchoalveolar lavage fluid or lung tissue in 131 patients. Occup Environ Med 51(4):244–249.8199666
*Palekar LD, Eyre JF, Most BM, . 1987. Metaphase and anaphase analysis of V79 cells exposed to erionite, UICC chrysotile and UICC crocidolite. Carcinogenesis 8:553–560.3030579
*Palekar LD, Most BM, Coffin DL. 1988. Significance of mass and number of fibers in the correlation of V79 cytotoxicity with tumorigenic potential of mineral fibers. Environ Res 46:142–152.2841105
*Pang TW, Schonfeld-Starr FA, Patel K. 1989. An improved membrane filter technique for evaluation of asbestos fibers. Am Ind Hyg Assoc J 50:174–180.
*Pang ZC, Zhang Z, Wang Y, . 1997. Mortality from a Chinese asbestos plant: Overall cancer mortality. Am J Ind Med 32:442–444.9327066
*Paoletti L, Caiazza S, Donnelli G, . 1984. Evaluation by electron microscopy techniques of asbestos contamination in industrial, cosmetic, and pharmaceutical talcs. Regul Toxicol Pharmacol 4:222–235.6494497
Park SH, Aust AE. 1998. Participation of iron and nitric oxide in the mutagenicity of asbestos in hgprt-, gpt+ Chinese hamster V79 cells. Cancer Res 58:1144–1148.9515798
Parkin DM, Wahrendorf J, Demaret E, . 1987. Directory of on-going research in cancer epidemiology. Lyon, France: International Agency for Research on Cancer.
*Parnes SM. 1990. Asbestos and cancer of the larynx: Is there a relationship? Laryngoscope 100:254–261.2407917
Parnes SM, Sherman M. 1991. Head and neck surveillance program for factory personnel exposed to asbestos. Ann Otol Rhinol Laryngol 100(9 Pt 1):731–736.1952666
Parry WT. 1985. Calculated solubility of chrysotile asbestos in physiological systems. Environ Res 37:410–418.2990889
Partanen R, Hemminki K, Brandt-Rauf P, . 1994a. Serum levels of growth factor receptors, EGFR and neu in asbestosis patients: A follow-up study. Int J Oncol 4:1025–1028.21567014
Partanen R, Hemminki K, Koskinen H, . 1994b. The detection of increased amounts of the extracellular domain of the epidermal growth factor receptor in serum during carcinogenesis in asbestosis patients. J Occup Med 36:1324–1328.7884573
Partanen R, Koskinen H, Oksa P, . 1995. Serum oncoproteins in asbestosis patients. Clin Chem 41:1844–1847.7497643
Pasqualetti P, Casale R, Colantonio D, . 1991. Occupational risk for hematological malignancies. Am J Hematol 38(2):147–149.1951308
Pasqualetti P, Collacciani A, Casale R. 1996. Risk of monoclonal gammopathy of undetermined significance: A case-referent study. Am J Hematol 52:217–220.8756092
Pass HI. 1994. Contemporary approaches in the investigation and treatment of malignant pleural mesothelioma. Chest Surg Clin N Am 4:497–515.7953481
Pass HI, Mew DJY. 1996. In vitro and in vivo studies of mesotheliom. J Cell Biochem 24:142–151.
*Patel-Mandlik KJ, Millette JR. 1983. Chrysotile asbestos in kidney cortex of chronically gavaged rats. Arch Environ Contam Toxicol 12:247–255.6303228
*Patel-Mandlik K, Manos CG, Johnson KEB, . 1994. Prevalence of asbestos in sludges from 16 sewage plants in large American cities in 1993. Chemosphere 29:1369–1372.
*Patel-Mandlik KJ, Manos CG, Lisk DJ, . 1988. Identification of asbestos and glass fibers in sewage sludges of small New York state cities. Chemosphere 17:1025–1032.
Pearce N. 1988. Multistage modeling of lung cancer mortality in asbestos textile workers. Int J Epidemiol 17:747–752.3225081
Pele JP, Calvert R. 1983. Hemolysis by chrysotile asbestos fibers. I. Influence of the sialic acid content in human, rat, and sheep red blood cell membranes. J Toxicol Environ Health 12:827–840.6321749
*Pelin K, Hirvonen A, Taavitsainen M, . 1995a. Cytogenic response to asbestos fibers in cultured human primary mesothelial cells from 10 different donors. Mutat Res 334:225–233.7885376
*Pelin K, Kivipensas P, Linnainmaa K. 1995b. Effects of asbestos and man-made vitreous fibers on cell division in cultured human mesothelial cells in comparison to rodent cells. Environ Mol Mutagen 25:118–125.7698105
*Pelin-Enlund K, Husgafvel-Pursiainen K, Tammilehto L, . 1990. Asbestos-related malignant mesothelioma: Growth, cytology, tumorigenicity and consistent chromosome findings in cell lines from five patients. Carcinogenesis 11:673–681.2323006
Perderiset M, Marsh JP, Mossman BT. 1991. Activation of protein kinase C by crocidolite asbestos in hamster tracheal epithelial cells. Carcinogenesis 12:1499–1502.1650293
*Perkins RC, Scheule RK, Hamilton R, . 1993. Human alveolar macrophage cytokine release in response to in vitro and in vivo asbestos exposure. Exp Lung Res 19(1):55–65.8440202
*Pernis B, Vigliani EC, Selikoff IJ. 1965. Rheumatoid factor in serum of individuals exposed to asbestos. Ann NY Acad Sci 132:112–120.5219543
Peterson JT Jr, Greenberg SD, Buffler PA. 1984. Non-asbestos-related malignant mesothelioma: A review. Cancer 54 (September 1):951–960.6331632
*Peterson MW, Kirschbaum J. 1998. Asbestos-induced lung epithelial permeability: Potential role of nonoxidant pathways. Am J Physiol 275:L262–L268.9700086
*Peterson MW, Walter ME, Gross TJ. 1993. Asbestos directly increases lung epithelial permeability. Am J Physiol 265(3 Pt 1):L308–L317.7692746
*Peto J. 1980. The incidence of pleural mesothelioma in chrysotile asbestos textile workers. IARC Sci Pub 30:703–711.
Peto J. 1989. Fibre carcinogenesis and environmental hazards. IARC Sci Pub 90:457–470.
*Peto J, Decarli A, La Vecchhia C, . 1999. The European mesothelioma epidemic. Br J Cancer 79:666–672.10027347
*Peto J, Doll R, Hermon C, . 1985. Relationship of mortality to measures of environmental asbestos pollution in an asbestos textile factory. Ann Occup Hyg 29:305–345.4073702
*Peto J, Hodgson JT, Matthews FE, . 1995. Continuing increase in mesothelioma mortality in Britain. Lancet 345:535–539.7776771
*Peto J, Seidman H, Selikoff IJ. 1982. Mesothelioma mortality in asbestos workers: Implications for models of carcinogenesis and risk assessment. Br J Cancer 45:124–135.7059455
Petrini MF. 1998. Cigarette smoking, asbestos exposure, lung cancer, and sample size [Letter]. Am J Respir Crit Care Med 158:1688.9867396
*Petruska JM, Leslie KO, Mossman BT. 1991. Enhanced lipid peroxidation in lung lavage of rats after inhalation of asbestos. Free Radical Biol Med 11:425–432.1665839
Pettinari A, Mengucci R, Belli S, . 1994. [Mortality of workers employed at an asbestos cement manufacturing plant in Senigallia.] Med Lav 85:223–230. (Italian)7935144
*Phalen RF, Cuddihy RG, Fisher GL, . 1991. Main features of the proposed NCRP respiratory tract model. Radiat Prot Dosim 38:159–184.
*Phalen RF, Oldham MJ, Beaucage CB, . 1985. Postnatal enlargement of human tracheobronchial airways and implications for particle deposition. Anat Rec 212:368–380.4073554
PHRED. 1988. Public Health Risk Evaluation Database. Washington, DC: U. S. Environmental Protection Agency. March 1988.
*Pietarinen-Runtti P, Raivio KO, Linnainmaa K, . 1996. Differential effects of tumor necrosis factor and asbestos fibers on manganese superoxide dismutase induction and oxidant-induced cytotoxicity in human mesothelial cells. Cell Biol Toxicol 12:167–175.8817062
Piirila P, Sovijarvi ARA. 1995. Crackles: Recording, analysis and clinical significance. Eur Resp J 8:2139–2148.
*Pinkerton KE, Brody AR, Miller FJ, . 1989. Exposure to low levels of ozone results in enhanced pulmonary retention of inhaled asbestos fibers. Am Rev Respir Dis 140:1075–1081.2529800
*Pinkerton KE, Plopper CG, Mercer RR, . 1986. Airway branching patterns influence asbestos fiber location and the extent of tissue injury in the pulmonary parenchyma. Lab Invest 55:688–695.3784538
*Pinkerton KE, Pratt PC, Brody AR, . 1984. Fiber localization and its relationship to lung reaction in rats after chronic inhalation of chrysotile asbestos. Am J Pathol 117:484–498.6095671
*Pitt R. 1988. Asbestos as an urban area pollutant. J Water Pollut Control Fed 60:1993–2001.
*Platek SF, Groth DH, Ulrich CE, . 1985. Chronic inhalation of short asbestos fibers. Fundam Appl Toxicol 5:327–340.2985462
Plato N, Tornling G, Hogsted C, . 1995. An index of past asbestos exposure as applied to car and bus mechanics. Ann Occup Hyg 39:441–454.7661512
*Plowman PN. 1982. The pulmonary macrophage population of human smokers. Ann Occup Hyg 25:393–405.6762129
*Polissar L, Severson RK, Boatman ES, . 1982. Cancer incidence in relation to asbestos in drinking water in the Puget Sound region. Am J Epidemiol 116:314–328.7114040
Polissar L, Severson RK, Boatman ES. 1983. Cancer risk from asbestos in drinking water: Summary of a case-control study in western Washington. Environ Health Perspect 53:57–60.6662095
*Polissar L, Severson RK, Boatman ES. 1984. A case-control study of asbestos in drinking water and cancer risk. Am J Epidemiol 119:456–471.6702819
Pontefract RD. 1974. Penetration of asbestos through the digestive wall in rats [Commentary]. Environ Health Perspect 9:213–214.
*Pontefract RD, Cunningham HM. 1973. Penetration of asbestos through the digestive tract of rats. Nature 243:352–353.4745031
Pontius FW. 1998. New horizons in federal regulation: New requirements and schedules have dramatically accelerated the pace of regulatory activity. J Am Water Works Assoc 90:38–50.
*Pooley FD. 1976. An examination of the fibrous mineral content of asbestos lung tissue from the Canadian chrysotile mining industry. Environ Res 12:281–298.1001300
Pooley FD, Clark NJ. 1979. Quantitative assessment of inorganic fibrous particulates in dust samples with an analytical transmission electron microscope. Ann Occup Hyg 22:253–271.543586
Pott F. 1987. [The fibre as a carcinogenic agent.] Zentralbl Bakteriol Hyg [B] 184:1–23. (German)
Pott F, Bellman B, Muhle H, . 1989a. Proceedings of the First International Conference on Health Related Effects of Phyllosilicates, Paris, France.
Pott F, Roller M, Ziem U, . 1989b. Carcinogenicity studies on natural and man-made fibres with the intraperitoneal test in rats. IARC Sci Pub 90:173–179.
Préat B. 2000. Confusion about the precision of asbestos fibres counting by electron microscopy. Ann Occup Hyg 44(1):75.10689761
*Price B. 1997. Analysis of current trends in United States mesothelioma incidence. Am J Epidemiol 145:211–218.9012593
Price B, Crump KS, Baird EC 3d. 1992. Airborne asbestos levels in buildings: Maintenance worker and occupant exposures. J Expo Anal Environ Epidemiol 2(3):357–374.1422164
*Price-Jones MJ, Gubbings G, Chamberlain M. 1980. The genetic effects of crocidolite asbestos: Comparison of chromosome abnormalities and sister-chromatid exchanges. Mutat Res 79:331–336.
Prior AJ, Ball ABS. 1993. Intestinal obstruction complicating malignant mesothelioma of the pleura. Respir Med 87(2):147–148.8497685
Prowse OW, Reddy PP, Barrieras D, . 1998. Pediatric genitourinary tumors. Curr Opin Oncol 10:253–260.9619362
Pylev LN. 1987. [The role of modifying factors in the carcinogenic effects of asbestos and asbestos-containing dusts.] Eksp Onkol 9:14–17. (Russian)
Pylev LN, Kogan FM, Kulagina TF. 1988. [Carcinogenic activity of asbestos cement dust.] Gig Tr Prof Zabol (July):55–57 (Russian)
Quinlan TR, Berube KA, Hacker MP, . 1998. Mechanisms of asbestos-induced nitric oxide production by rat alveolar macrophages in inhalation and in vitro models. Free Radic Biol Med 24:778–788.9586808
*Quinlan TR, Berube KA, Marsh JP, . 1995. Patterns of inflammation, cell proliferation, and related gene expression in lung after inhalation of chrysotile asbestos. Am J Pathol 147:728–739.7677184
*Quinlan TR, Marsh JP, Janssen YMW, . 1994. Dose-responsive increases in pulmonary fibrosis after inhalation of asbestos. Am J Resp Crit Care Med 150:200–206.8025751
*Raffn E, Lynge E, Juel K, . 1989. Incidence of cancer and mortality among employees in the asbestos cement industry in Denmark. Br J Ind Med 46:90–96.2923830
Raffn E, Villadsen E, Engholm G, . 1996a. Lung cancer in asbestos cement workers in Denmark. Occup Environ Med 53:399–402.8758035
*Raffn E, Villadsen E, Lynge E. 1996b. Colorectal cancer in asbestos cement workers in Denmark. Am J Ind Med 30:267–272.8876793
Rafnsson V, Jahannesdottir SG, Oddsson H, . 1988. Mortality and cancer incidence among marine engineers and machinists in Iceland. Scand J Work Environ Health 14:197–200.3393856
*Rahman Q, Khan SG, Ali S. 1990. Effect of chrysotile asbestos on cytochrome P-450 - dependent monooxygenase and glutathione-s-transferase activities in rat lung. Chem Biol Interactions 75:305–314.
Raithel HJ, Weltle D, Bohlig H, . 1989. Health hazards from fine asbestos dusts. Int Arch Occup Environ Health 61:527–541.2807571
Rajan KT, Wagner JC, Evans PH. 1972. The response of human pleura in organ culture to asbestos. Nature 238:346–347.4561847
Rapiti, E, Turi E, Forastiere F, . 1992. A mortality cohort study of seamen in Italy. Am J Ind Med 21(6):863–872.1621694
*Reeves AL, Puro HE, Smith RG, . 1971. Experimental asbestos carcinogenesis. Environ Res 4:496–511.
*Reeves AL, Puro HE, Smith RG. 1974. Inhalation carcinogenesis from various forms of asbestos. Environ Res 8:178–202.4455505
Reid AS, Causton BE, Jones JS, . 1991. Malignant mesothelioma after exposure to asbestos in dental practice [Letter]. Lancet 338(8768):696.
Reiss B, Millette JR, Williams GM. 1980a. The activity of environmental samples in a cell culture test for asbestos toxicity. Environ Res 22:315–321.7408823
*Reiss B, Solomon S, Tong C, . 1982. Absence of mutagenic activity of three forms of asbestos in liver epithelial cells. Environ Res 27:389–397.6282580
Reiss B, Solomon S, Weisburger JH, . 1980b. Comparative toxicities of different forms of asbestos in a cell culture assay. Environ Res 22:109–129.7418670
Reiss B, Tong C, Telang S, . 1983. Enhancement of benzo[a]pyrene mutagenicity by chrysotile asbestos in rat liver epithelial cells. Environ Res 31:100–104.6303771
*Ren H, Lee DR, Hruban RH, . 1991. Pleural plaques do not predict asbestosis: High-resolution computed tomography and pathology study. Mod Pathol 4(2):201–209.2047383
Renke W. 1990. Evaluation of pathological changes in respiratory system of workers exposed to asbestos dust. Bull Inst Mar Trop Med Gdynia 41:5–15.
*Rey F, Boutin C, Steinbauer J, . 1993. Environmental pleural plaques in an asbestos exposed population of northeast Corsica. Eur Respir J 6(7):978–982.8396536
Rey F, Boutin C, Viallat JR, . 1994. Environmental asbestotic pleural plaques in northeast Corsica: Correlations with airborne and pleural mineralogic analysis. Environ Health Perspect Suppl 102:251–252.
Reynolds SJ, Kreiger RA, Bohn JA, . 1994. Factors affecting airborne concentrations of asbestos in a commercial building. Am Ind Hyg Assoc J 55:823–828.
Ribak J, Lilis R, Suzuki Y, . 1988. Malignant mesothelioma in a cohort of asbestos insulation workers: Clinical presentation, diagnosis, and causes of death. Br J Ind Med 45:182–187.3348994
Ribak J, Lilis R, Suzuki Y, . 1991. Death certificate categorization of malignant pleural and peritoneal mesothelioma in a cohort of asbestos insulation workers. J Soc Occup Med 41(3):137–139.1921345
Ribak J, Seidman H, Selikoff IJ. 1989. Amosite mesothelioma in a cohort of asbestos workers. Scan J Work Environ Health 15:106–110.
Richter ED, Berdugo M, Laster R, . 1995. Chrysotile and crocidolite asbestos in Israel: Uses, exposures and risks. Med Lav 86:449–456.8684295
*Rickards, AL. 1994. Levels of workplace exposure. Ann Occup Hyg 38(4):469–475.7978968
Riediger G, Rödelsperger K. 2000. Confusion about the precision of asbestos fibres counting by electron microscopy. Ann Occup Hyg 44(1):76.
*Rihn B, Coulais C, Kauffer E, . 2000. Inhaled crocidolite mutagenicity in lung DNA. Environ Health Perspect 108(4):341–346.10753093
Rihn B, Kauffer E, Martin P, . 1996. Short-term crocidolite inhalation studies in mice: Validation of an inhalation chamber. Toxicology 109:147–156.8658545
Rittmeyer L, Yang P, Schwartz AG, . 1995. Genetic and environmental factors in lung cancer susceptibility [Abstract]. Am J Hum Genet 57:A76.
Robb JA, Hammar SP, Yokoo H. 1993. Pseudomesotheliomatous lung carcinoma a rare asbestos-related malignancy readily separable from epithelial pleural mesothelioma. 1993 Annual Meeting of the United States and Canadian 68(1):134A.
Robins TG, Green MA. 1988. Respiratory morbidity in workers exposed to asbestos in the primary manufacture of building materials. Am J Ind Med 14:433–448.3189358
Robinson BWS. 1989. Asbestos and cancer: Human natural killer cell activity is suppressed by asbestos fibers but can be restored by recombinant interleukin-2. Am Rev Respir Dis 139:897–901.2784645
Robinson C, Dtern F, Halperin W, . 1995. Assessment of mortality in the construction industry in the United States, 1984-1986. Am J Ind Med 28:49–70.7573075
Robinson CF, Petersen M, Sieber WK, . 1996. Mortality of carpenters’ union members employed in the US construction or wood products industries, 1987-1990. Am J Ind Med 30:674–694.8914714
*Robledo R, Mossman B. 1999. Cellular and molecular mechanisms of asbestos-induced fibrosis. J Cell Physiol 180:158–166.10395285
Robledo RF, Buder-Hoffmann SA, Cummins AB, . 2000. Increased phosphorylated extracellular signal-regulated kinase immunoreactivity associated with proliferative and morphologic lung alterations after chrysotile asbestos inhalation in mice. Am J Pathol 156(4):1307–1316.10751356
Rockley PF, Trieff N, Wagner RF, . 1994. Nonsunlight risk factors for malignant melanoma Part I: Chemical agents, physical conditions, and occupation. Int J Dermatol 33:398–406.8056470
Rocskay AZ, Harbut MR, Green MA, . 1996. Respiratory health in asbestos-exposed ironworkers. Am J Ind Med 29:459–466.8732919
*Rödelsperger K, Woitowitz H-J. 1995. Airborne fibre concentrations and lung burden compared to the tumour response in rats and humans exposed to asbestos. Ann Occup Hyg 39:715–725.8526402
*Rödelsperger K, Woitowitz H-J, Brückel B, . 1999. Dose-response relationship between amphibole fiber lung burden and mesothelioma. Cancer Detect Prev 23(3):183–193.10336997
Roe FJ, Carter RL, Walters MA, . 1967. The pathological effects of subcutaneous injections of asbestos fibres in mice: Migration of fibres to submesothelial tissues and induction of mesotheliomata. Int J Cancer 2:628–638.5582282
*Rogan WJ, Gladen BC, Ragan NB, . 1987. U.S. prevalence of occupational pleural thickening: A look at chest x-rays from the first National Health And Nutrition Examination Survey. Am J Epidemiol 126:893–900.3661537
Rogers A, Nevill M. 1995. Occupational and environmental mesotheliomas due to crocidolite mining activities in Wittenoon, Western Australia. Scand J Work Environ Health 21:259–264.8552999
*Rogers AJ. 1984. Determination of mineral fibre in human lung tissue by light microscopy and transmission electron microscopy. Ann Occup Hyg 28(1):1–12.
*Rogers AJ, Baker EM, Conaty GJ. 1997. Asbestiform minerals: Worker exposure and risk assessment in some contaminated Australian mines. Appl Occup Environ Hyg 12:867–871.
*Rogers AJ, Leigh J, Berry G, . 1991. Relationship between lung asbestos fiber type and concentration and relative risk of mesothelioma. Cancer 67:1912–1920.1848472
*Rogers RA, Antonino JM, Brismar H, . 1999. In situ microscopic analysis of asbestos and synthetic vitreous fibers retained in hamster lungs following inhalation. Environ Health Perspect 107:367–375.10210692
Roggli VL. 1995. Malignant mesothelioma and duration of asbestos exposure: Correlation with tissue mineral fibre content. Ann Occup Hyg 39:363–374.7793754
Roggli VL, Benning TL. 1990. Asbestos bodies in pulmonary Hilar lymph nodes. Modern Pathol 3:513–517.
*Roggli VL, Longo WE. 1991. Mineral fiber content of lung tissue in patients with environmental exposure: Household contacts vs. building occupants. Ann NY Acad Sci 511–518.
*Roggli VL, Coin PG, MacIntyre NR, . 1994a. Asbestos content of bronchoalveolar lavage fluid: A comparison of light and scanning electron microscopic analysis. Acta Cytol 38:502–510.8042413
*Roggli VL, George MH, Brady AR. 1987a. Clearance and dimensional changes of crocidolite asbestos fibers isolated from lungs of rats following short-term exposure. Environ Res 42:94–105.3026797
Roggli VL, Hammar SP, Pratt PC, . 1994b. Does asbestos or asbestosis cause carcinoma of the lung? Am J Ind Med 26:835–838.7892835
Roggli VL, Kolbeck J, Sanfilippo F, . 1987b. Pathology of human mesothelioma: Etiologic and diagnostic considerations. Pathol Annu 22(Pt 2):91–131.2825103
Roggli VL, Pratt PC, Brody AR. 1986. Asbestos content of lung tissue in asbestos associated diseases: A study of 110 cases. Br J Ind Med 43:18–28.3947558
Roggli VL, Pratt PC, Brody AR. 1993. Asbestos fiber type in malignant mesothelioma: An analytical scanning electron microscopic study of 94 cases. Am J Ind Med 23(4):605–614.8480769
Roller M, Pott F, Kamino K, . 1997. Dose-response relationship of fibrous dusts in intraperitoneal studies. Environ Health Perspect Suppl 105:1253–1256.9400733
*Rom WN. 1991. Relationship of inflammatory cell cytokines to disease severity in individuals with occupational inorganic dust exposure. Am J Ind Med 19:15–27 1846507
*Rom WN. 1992. Accelerated loss of lung function and alveolitis in a longitudinal study of non-smoking individuals with occupational exposure to asbestos. Am J Ind Med 21:835–844.1621691
*Rom WN, Travis WD. 1992. Lymphocyte-macrophage alveolitis in nonsmoking individuals occupationally exposed to asbestos. Chest 101(3):779–786.1541147
*Rom WN, Livingston GK, Casey KR, . 1983. Sister chromatid exchange frequency in asbestos workers. J Natl Cancer Inst 70:45–48.6571920
Rom WN, Travis WD, Brody AR. 1991. Cellular and molecular basis of the asbestos-related diseases. Am Rev Respir Dis 143:408–422.1990961
*Roney PL, Holian A. 1989. Possible mechanism of chrysotile asbestos-stimulated superoxide anion production in guinea pig alveolar macrophages. Toxicol App Pharmacol 100:132–144.
Rosenman KD, Reilly MJ. 1998. Asbestos-related x-ray changes in foundry workers. Am J Ind Med 34:197–201.9651631
Rosenman KD, Zhu Z. 1995. Pneumoconiosis and associated medical conditions. Am J Ind Med 27:107–113.7900728
*Rosenthal GJ, Corsini E, Simeonova P. 1998. Selected new developments in asbestos immunotoxicity. Environ Health Perspect Suppl 106:159–169.9539011
Rosenthal GJ, Simeonova P, Corsini E. 1999. Asbestos toxicity: An immunologic perspective. Rev Environ Health 14(1):11–20.10372416
Rosler JA, Woitowitz HJ, Lange HJ, . 1994. Mortality rates in a female cohort following asbestos exposure in Germany. J Occup Med 36:889–893.7807270
Ross D, McDonald JC. 1995. Occupational and geographical factors in the epidemiology of malignant mesothelioma. Monaldi Arch Chest Dis 50:459–462.8834957
*Ross M. 1981. The geologic occurrences and health hazards of amphibole and serpentine asbestos. In: Veblen DR, ed. Reviews in mineralogy: Amphiboles and other hydrous pyriboles-mineralogy. Chelsea, MI: Mineralogical Society of America, BookCrafters, Inc., 279–323.
Rossiter CE, Chase JR. 1995. Statistical analysis of results of carcinogenicity studied of synthetic vitreous fibres at research and consulting company, Geneva. Ann Occup Hyg 39:759–769.8526406
RTECS. 1999a. Tremolite asbestos. Registry of Toxic Effects of Chemical Substances. National Institute for Occupational Safety and Health. April 19, 1999.
RTECS. 1999b. Chrysotile asbestos. Registry of Toxic Effects of Chemical Substances. National Institute for Occupational Safety and Health. April 19, 1999.
Rubin ES. 1999. Toxic releases from power plants. Environ Sci Technol 33:3062–3067.
*Rubino GF, Piolatto G, Newhouse ML, . 1979. Mortality of chrysotile asbestos workers at the Balangero Mine, Northern Italy. Br J Ind Med 36:187–194.500777
*Rudd R. 1989. Malignant mesothelioma. J R Soc Med 82:126–129.2649672
Rudd RM. 1988. Exposure to asbestos and the risk of gastrointestinal cancer [Letter]. Br J Ind Med 45:573–574.3415928
Ryan PJ, Oates JL, Crocker J, . 1997. Distinction between pleural mesothelioma and pulmonary adenocarcinoma using MOC31 in an asbestos sprayer. Resp Med 91:57–60.
*Saarikoski ST, Reinikainen M, Antilla S, . 2000. Role of NAT2 deficiency in susceptibility to lung cancer among asbestos-exposed individuals. Pharmacogenetics 10:183–185.10762006
*Sadler TD, Rom WN, Lyon JL, . 1984. The use of asbestos-cement pipe for public water supply and the incidence of cancer in selected communities in Utah. J Community Health 9:285–293.6480892
Saffiotii U. 1998. Respiratory tract carcinogenesis by mineral fibres and dusts: Models and mechanisms. Monaldi Arch Chest Dis 53:160–167.9689803
Saffiotti U, Stinson SF. 1988. Lung cancer induction by crystalline silica: Relationships to granulomatous reactions and host factors. J Environ Sci Health 6:197–222.
*Sahin AA, Cöplü L, Selcuk ZT, . 1993. Malignant pleural mesothelioma caused by environmental exposure to asbestos or erionite in rural Turkey: CT findings in 84 patients. AJR Am J Roentgenol 161(3):533–537.8394641
Sahu AP. 1989. Effect on choline and mineral fibres (chrysotile asbestos) on guinea-pigs. New Delhi, India: Scientific Commission for Continuing Studies on Effects of Bhopal Gas Leakage on Life Systems, 185–189.
*Sahu AP, Dogra RKS, Shanker R, . 1975. Fibrogenic response in murine lungs to asbestos. Exp Pathol 11:21–24.
Sakai K, Hisanaga N, Huang J, . 1994. Asbestos and nonasbestos fiber content in lung tissue of Japanese patients with malignant mesothelioma. Cancer 73(7):1825–1835.8137206
*Sakellariou K, Malamou-Mitsi V, Haritou A, . 1996. Malignant pleural mesothelioma from nonoccupational asbestos exposure in Metsovo (north-west Greece): Slow end of an epidemic? Eur Resp J 9:1206–1210.
*Sampson C, Hansell DM. 1992. The prevalence of enlarged mediastinal lymph nodes in asbestos-exposed individuals a CT study. Clin Radiol 45(5):340–342.1516346
Samudra AV, Harwood CF. 1977. Electron microscope measurement of airborne asbestos concentrations: A provisional methodology manual. Report to U. S. Environmental Protection Agency, Office of Research and Development, Research Triangle Park, NC, by IIT Research Institute, Chicago, IL. EPA 600/2-77-178. NTIS No. PB-285945.
Sanden A, Jarvholm B, Larsson S, . 1992. The risk of lung cancer and mesothelioma after cessation of asbestos exposure: A prospective cohort study of shipyard workers. Eur Respir J 5:281–285.1572439
Sanden A, Jarvholm B, Larsson S. 1993. The importance of lung-function, nonmalignant diseases associated with asbestos, and symptoms as predictors of ischemic heart disease in shipyard workers exposed to asbestos. Br J Ind Med 50(9):785–790.8398871
*Sandhu H, Dehnen W, Roller M, . 2000. mRNA expression patterns in different stages of asbestos-induced carcinogenesis in rats. Carcinogenesis 21(5):1023–1029.10783328
*Saracci R. 1987. The interactions of tobacco-smoking and other agents in cancer etiology. Epidemiol Rev 9:175–193.3315716
Saric M, Curin K. 1996. Malignant tumours of the gastrointestinal tract in an area with an asbestos-cement plant. Cancer Lett 103:191–199.8635157
Saric M, Vujovic M. 1994. Malignant tumors in an area with an asbestos processing plant. Public Health Rev 22:293–303.7708941
Sauni R, Oksa P, Jarvenpaa R, . 1998. Asbestos exposure: A potential cause of retroperitoneal fibrosis. Am J Ind Med 33:418–421.9513650
Sax NI, Lewis RJ Sr. 1987. Hawley’s condensed chemical dictionary. 11th ed. New York, NY: Van Nostrand Reinhold Company, 100–101.
Scansetti G, Chiesa A, Capellaro E, . 1996. Asbestos bodies in sputum of asbestos exposed workers. Med Lav 87:283–288.8956540
Scatarige JC, Stitik FP. 1988. Induction of thoracic malignancy in inorganic dust pneumoconiosis. J Thorac Imaging 3:67–79.
*Schapira RM, Ghio AJ, Effros RM, . 1994. Hydroxyl radicals are formed in the rat lung after asbestos instillation in vivo. Am J Resp Cell Mol Biol 10:573–579.
Schimmelpfeng J, Seidel A. 1991. Cytotoxic effects of quartz and chrysotile asbestos: In vitro interspecies comparison with alveolar macrophages. J Toxicol Environ Health 33:131–140.2051490
*Schneider J, Rödelsperger K, Brückel B, . 1998. Environmental exposure to tremolite asbestos: Pleural mesothelioma in two Turkish workers in Germany. Rev Environ Health 13(4):213–220.9987816
Schneider J, Straif K, Woitowitz H-J. 1996. Pleural mesothelioma and household asbestos exposure. Rev Environ Health 11:65–70.8869527
*Schneider U, Maurer RR. 1977. Asbestos and embryonic development. Teratology 15:273–280.882916
Schoenberger CI, Hunninghake GW, Kawanami O, . 1982. Role of alveolar macrophages in asbestosis: Modulation of neutrophil migration to the lung after acute asbestos exposure. Thorax 37:803–809.7163997
Scholze H, Conradt R. 1987. An in vitro study of the chemical durability of siliceous fibres. Ann Occup Hyg 31:683–692.
*Schwartz DA, Davis CS, Merchant JA, . 1994. Longitudinal changes in lung function among asbestos-exposed workers. Am J Resp Crit Care Med 150:1243–1249.7952547
*Schwartz DA, Fuortes LJ, Galvin JR, . 1990. Asbestos-induced pleural fibrosis and impaired lung function. Am Rev Respir Dis 141:321–326.2301850
*Schwartz DA, Galvin JR, Frees KL, . 1993. Clinical relevance of cellular mediators of inflammation in workers exposed to asbestos. Am Rev Respir Dis 148(1):68–74.8317818
Schwartz DA, Galvin JR, Merchant RK, . 1992. Influence of cigarette smoking on bronchoalveolar lavage cellularity in asbestos-induced lung disease. Am Rev Respir Dis 145(2):400–405.1736749
*Searl A. 1997. A comparative study of the clearance of respirable para-aramid, chrysotile and glass fibres from rat lungs. Ann Occup Hyg 41:217–233.9155241
Searl A, Buchanan D, Cullen RT, . 1999. Biopersistence and durability of nine mineral fibre types in rat lungs over 12 months. Ann Occup Hyg 43(3):143–153.10366896
*Sebastien P, Armstrong B, Case BW, . 1988a. Estimation of amphibole exposure from asbestos body and macrophage counts in sputum: A survey in vermiculite miners. Ann Occup Hyg 32(Suppl 1):195–201. .
*Sebastien P, Armstrong B, Monchaux G, . 1988b. Asbestos bodies in bronchoalveolar lavage fluid and in lung parenchyma. Am Rev Respir Dis 137:75–78.3337472
*Sebastien P, Begin R, Masse S. 1990. Mass, number and size of lung fibres in the pathogenesis of asbestosis in sheep. J Exp Path 71:1–10.
*Sebastien P, Bignon J, Barris YI, . 1984. Ferruginous bodies in sputum as an indication of exposure to airborne mineral fibers in the mesothelioma villages of Cappadocia. Arch Environ Health 39:18–23.6324702
*Sebastien P, Janson X, Gaudichet A, . 1980a. Asbestos retention in human respiratory tissues: Comparative measurements in lung parenchyma and in parietal pleura. IARC Sci Publ 30:237–246.
*Sebastien P, Masse R, Bignon J. 1980b. Recovery of ingested asbestos fibers from the gastrointestinal lymph in rats. Environ Res 22:201–216.7418678
*Sebastien P, McDonald JC, McDonald AD, . 1989. Respiratory cancer in chrysotile textile and mining industries: Exposure inferences from lung analysis. Br J Ind Med 46:180–187.2539184
*Segers K, Ramael M, Singh SK, . 1995. Detection of numerical chromosomal aberrations in paraffin-embedded malignant pleural mesothelioma by non-isotopic in situ hybridization. J Pathol 175:219–226.7738718
*Seidman H. 1984. Short-term asbestos work exposure and long-term observation. In: Docket of current rulemaking for revision of the asbestos (dust) standard. Washington, DC: U.S. Department of Labor, Occupational Safety and Health Administration. Available for inspection at: U.S. Department of Labor, OSHA Technical Data Center, Francis Perkins Building; docket no. HO33C, exhibit nos. 261-A and 261-B.
*Seidman H, Selikoff IJ, Gelb SK. 1986. Mortality experience of amosite asbestos factory workers: Dose-response relationships 5 to 40 years after onset of short-term work exposure. Am J Ind Med 10:479–514.2880502
*Seidman H, Selikoff IJ, Hammond EC. 1979. Short-term asbestos work exposure and long-term observation. Ann NY Acad Sci 330:61–89.294213
Sekhon H, Keeling B, Churg A. 1993. Rat pleural mesotheliomal cells show damage after exposure to external but not internal cigarette smoke. Environ Health Perspect 101(4):326–330.8275990
*Sekhon H, Wright J, Churg A. 1995. Effects of cigarette smoke and asbestos on airway, vascular and mesothelial cell proliferation. Int J Exp Pathol 76:411–418.8652361
Selby TW. 1996. Method for converting asbestos to non-carcinogenic compounds. Application: USA 278,487, 21 Jul 1994. USA Patent 5,543,120, issued 6 Aug 1996.
*Selcuk ZT, Cöplü L, Emri S, . 1992. Malignant pleural mesothelioma due to environmental mineral fiber exposure in Turkey: Analysis of 135 cases. Chest 102(3):790–796.1325339
Selikoff IJ. 1965. The occurrence of pleural calcification among asbestos insulation workers. Ann N Y Acad Sci 132:351–367.5219560
Selikoff IJ. 1990. Historical developments and perspectives in inorganic fiber toxicity in man. Environ Health Perspect 88:269–276.2272322
*Selikoff IJ, Lee DHK, eds. 1978. Asbestos and disease. New York, NY: Academic Press, 143–187, 357–375, 377–392.
Selikoff IJ, Lilis R. 1991. Radiological abnormalities among sheet-metal workers in the construction industry in the United States and Canada: Relationship to asbestos exposure. Arch Environ Health 46:30–36.1992930
*Selikoff IJ, Hammond EC, Churg J. 1968. Asbestos exposure, smoking and neoplasia. JAMA 204:104–110.
*Selikoff IJ, Hammond EC, Seidman H. 1979. Mortality experience of insulation workers in the United States and Canada, 1943-1976. Ann NY Acad Sci 330:91–116.294225
Selikoff IJ, Lilis R, Levin G. 1990. Asbestotic radiological abnormalities among United States merchant marine seamen. Br J Ind Med 47:292–297.2357448
*Selikoff IJ, Nicholson WJ, Langer AM. 1972. Asbestos air pollution. Arch Environ Health 25:1–13.5033276
*Selikoff IJ, Seidman H, Hammond EC. 1980. Mortality effects of cigarette smoking among amosite asbestos factory workers. J Natl Cancer Inst 65:507–513.6931931
*Serio G, Ceppi M, Fonte A, . 1992. Malignant mesothelioma of the testicular tunica vaginalis. Eur Urol 21(2):174–176.1499621
*Seshan K. 1983. How are the physical and chemical properties of chrysotile asbestos altered by a 10-year residence in water and up to 5 days in simulated stomach acid? Environ Health Perspect 53:143–148.6319116
*Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shabad LM, Pylev LN, Krivosheeva LV, . 1974. Experimental studies on asbestos carcinogenicity. J Natl Cancer Inst 52:1175–1180.4826587
*Shatos MA, Doherty JM, Marsh JP, . 1987. Prevention of asbestos-induced cell death in rat lung fibroblasts and alveolar macrophages by scavengers of active oxygen species. Environ Res 44:103–116.3115771
Sheehan MJ, Reynolds JW. 1992. Airborne asbestos analysis of low fiber density samples: A comparison of the A and B counting rules of the NIOSH method 7400. Applied Occupational Environmental Hygiene 7(1):38–41.
*Shepherd JR, Hillerdal G, McLarty J. 1997. Progression of pleural and parenchymal disease on chest radiographs of workers exposed to amosite asbestos. Occup Environ Med 54:410–415.9245947
Shepherd KE, Oliver LC, Kazemi H. 1989. Diffuse malignant pleural mesothelioma in an urban hospital: Clinical spectrum and trend in incidence over time. Am J Ind Med 16:373–383.2610210
Shih JF, Wilson JS, Broderick A, . 1994. Asbestos-induced pleural fibrosis and impaired exercise physiology. Chest 105:1370–1376.8181322
Shin DM, Fossella FV, Umsawasdi T, . 1995. Prospective study of combination chemotherapy with cyclophosphamide, doxorubicin, and cisplatin for unresectable or metastatic malignant pleural mesothelioma. Cancer 76:2230–2236.8635025
Shivapurkar N, Wiethege T, Wistuba II, . 1999. Presence of simian virus 40 sequences in malignant mesotheliomas and mesothelial cell proliferations. J Cell Biochem 76:181–188.10618635
Siemiatycki J, Boffetta P. 1998. Invited commentary: Is it possible to investigate the quantitative relation between asbestos and mesothelioma in a community-based study. Am J Epidemiol 148:143–147.9676695
Sigurdson EE. 1983. Observations of cancer incidence surveillance in Duluth, Minnesota. Environ Health Perspect 53:61–67.6662096
*Sigurdson EE, Levy BS, Mandel J, . 1981. Cancer morbidity investigations: Lessons from the Duluth study of possible effects of asbestos in drinking water. Environ Res 25:50–61.7238468
*Simeonova PP, Luster MI. 1995. Iron and reactive oxygen species in the asbestos-induced tumor necrosis factor-alpha response from alveolar macrophages. Am J Resp Cell Mol Biol 12:676–683.
*Simeonova PP, Luster MI. 1996. Asbestos induction of nuclear transcription factors and interleukin 8 gene regulation. Am J Resp Cell Mol Biol 15:787–795.
*Simeonova PP, Toriumi W, Kommineni C, . 1997. Molecular regulation of IL-6 activation by asbestos in lung epithelial cells: Role of reactive oxygen species. J Immunol 159:3921–3928.9378980
*Sincock AM. 1977. Preliminary studies of the in vitro cellular effects of asbestos and fine glass dusts. In: Hiatt HH, Watson JD, Winsten JA, eds. Origins of human cancer. Book B: Mechanisms of carcinogenesis. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory, 941–954.
*Sincock A, Seabright M. 1975. Induction of chromosome changes in Chinese hamster cells by exposure to asbestos fibres. Nature 257:56–58.1161005
*Sincock AM, Delhanty JD, Casey G. 1982. A comparison of the cytogenetic response to asbestos and glass fibre in Chinese hamster and human cell lines: Demonstration of growth inhibition in primary human fibroblasts. Mutat Res 101:257–268.7087986
Sinks T, Hartle R, Boeniger M, . 1994. Exposure to biogenic silica fibers and respiratory health in Hawaii sugarcane workers. J Occup Med 36:1329–1334.7884574
Siracusa A, Forcina A, Volpi R, . 1988. An 11-year longitudinal study of the occupational dust exposure and lung function of polyvinyl chloride, cement and asbestos cement factory workers. Scand J Work Environ Health 14:181–188.3393854
Sison RF, Hruban RH, Moore GW, . 1989. Pulmonary disease associated with pleural “asbestos” plaques. Chest 95(4):831–835.2924611
Sittig M. 1985. Handbook of toxic and hazardous chemicals and carcinogens. 2nd ed. Park Ridge, NJ: Noyes Publications, 92–96.
Skevas AT, Kastanioudakis IG, Constantopoulos SH, . 1995. Acquired nasopharyngeal obstruction and “Metsovo lung”. Rhinology 33:240–243.8919220
*Skinner HC, Ross M, Frondel C. 1988. Health effects of inorganic fibers. In: Asbestos and other fibrous materials: Mineralogy, crystal chemistry, and health effects. New York, NY: Oxford University Press, 103–162.
*Sluis-Cremer GK. 1991. Asbestos disease at low exposure after long residence time in amphibole miners. Toxicol Ind Health 7:89–95.1853357
Sluis-Cremer GK, Bezuidenhout BN. 1989. Relation between asbestosis and bronchial cancer in amphibole asbestos miners. Br J Ind Med 46:537–540.2550049
*Sluis-Cremer GK, Liddell FDK, Logan WPD, . 1992. The mortality of amphibole miners in South Africa 1946-80. Br J Ind Med 49:566–575.1325180
*Sluis-Cremer GK, Thomas RG, Schmaman IB. 1984. The value of computerized axial tomography in the assessment of workers exposed to asbestos. Am J Ind Med 6:27–35.6741943
Smith AH. 1998. Amphibole fibers, chrysotile fibers, and pleural mesothelioma [Letter]. Am J Ind Med 33:96.
*Smith AH, Wright CC. 1996. Chrysotile asbestos is the main cause of pleural mesothelioma. Am J Ind Med 30:252–266.8876792
*Smith AH, Handley MA, Wood R. 1990. Epidemiological evidence indicates asbestos causes laryngeal cancer. J Occup Med 32:499–507.2143221
*Smith AH, Shearn VI, Wood R. 1989. Asbestos and kidney cancer: The evidence supports a causal association. Am J Ind Med 16:159–166.2672801
Smith CM, Batcher S, Catanzaro A, . 1987. Sequence of bronchoalveolar lavage and histopathologic findings in rat lungs early in inhalation asbestos exposure. J Toxicol Environ Health 20:147–161.3806701
Smith WE, Miller L, Churg J. 1970. An experimental model for study of cocarcinogenesis in the respiratory tract. In: Nettesheim P, Hanna MG Jr, Deatherage JW Jr, eds. Morphology of experimental respiratory carcinogenesis. Oak Ridge, TN: U.S. Atomic Energy Commission, AEC Symposium Series 21, 299–316.
*Spencer JW, Plisko MJ, Balzer JL. 1999. Asbestos fiber release from the brake pads of overhead industrial cranes. Appl Occup Environ Hyg 14:397–402.10429735
*Spengler JD, Ozkaynak H, McCarthy JF, . 1989. Symposium on health aspects of exposure to asbestos in buildings, December 14-16, 1988. Cambridge, MA: Energy and Environmental Policy Center, Harvard University. 1–297.
*Spirtas R, Connelly RR, Tucker MA. 1988. Survival patterns for malignant mesothelioma: The seer experience. Int J Cancer 41:525–530.3356487
*Spirtas R, Heineman EF, Bernstein L, . 1994. Malignant mesothelioma: Attributable risk of asbestos exposure. Occup Environ Med 51:804–811.7849863
*Sprince NL, Oliver LC, McLoud TC, . 1991. Asbestos exposure and asbestos-related pleural and parenchymal disease. Am Rev Respir Dis 143:822–828.1826194
*Sprince NL, Oliver LC, McLoud TC, . 1992. T-cell alveolitis in lung lavage of asbestos-exposed subjects. Am J Ind Med 21:311–319.1585942
Spurny KR. 1989. Asbestos fibre release by corroded and weathered asbestos-cement products. IARC Sci Pub 90:367–371.
*Spurny KR. 1994. Sampling, analysis, identification and monitoring of fibrous dusts and aerosols. Analyst 119(1):41–51.
*Srebro SH, Roggli VL. 1994. Asbestos-related disease associated with exposure to asbestiform tremolite. Am J Ind Med 26:809–819.7892832
Srebro SH, Roggli VL, Samsa GP. 1995. Malignant mesothelioma associated with low pulmonary tissue asbestos burdens: A light and scanning electron microscopic analysis of 18 cases. Mod Pathol 8:614–621.8532693
*SRI. 1982. Chemical economics handbook. Asbestos-salient statistics. Menlo Park, CA: SRI International.
*Stanton MF, Layard M, Tegeris A, . 1981. Relation of particle dimension to carcinogenicity in amphibole asbestosis and other fibrous minerals. J Natl Cancer Inst 57:965–975.
STAPPA/ALAPCO. 1999. State and Territorial Air Pollution Program Administrators/Association of Local Air Pollution Control Officials. Washington, DC: Http://www.4cleanair.org/states.html#NorthC. May 6, 1999.
Stayner L, Bailer AJ, Smith R, . 1999. Sources of uncertainty in dose-response modeling of epidemiological data for cancer risk assessment. Ann N Y Acad Sci 895:212–222.10676419
*Stayner LT, Dankovic DA, Lemen RA. 1996. Occupational exposure to chrysotile asbestos and cancer risk: A review of the amphibole hypothesis. Am J Public Health 86(2):179–186.8633733
*Stayner L, Smith R, Bailer J, . 1997. Exposure-response analysis of risk of respiratory disease associated with occupational exposure to chrysotile asbestos. Occup Environ Med 54:646–652.9423577
Steenland K, Stayner L. 1997. Silica, asbestos, man-made mineral fibers, and cancer. Cancer Causes Control 8:491–503.9498906
*Steenland K, Thun M. 1986. Interaction between tobacco smoking and occupational exposures in the causation on lung cancer. J Occup Med 28:110–118.3512802
*Stephens M, Gibbs AR, Pooley FD, . 1987. Asbestos induced diffuse pleural fibrosis: Pathology and mineralogy. Thorax 42:583–588.3660310
*Stober W, McClellan RO. 1997. Pulmonary retention and clearance of inhaled biopersistent aerosol particles: Data-reducing interpolation models and models of physiologically based systems. Crit Rev Toxicol 27:539–598.9408732
Stober W, Morrow PE, Hoover MD. 1989. Compartmental modeling of the long-term retention of insoluble particles deposited in the alveolar region of the lung. Fundam Appl Toxicol 13:823–842.2620799
*Stober W, Morrow PE, Koch W . 1994. Alveolar clearance and retention of inhaled insoluble particles in rats simulated by a model inferring macrophage particle load distributions. J Aerosol Sci 25:975–1002.
Stokinger HE. 1981. The halogens and the nonmetals boron and silicon. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. 3rd ed. Vol. 2B. New York, NY: John Wiley and Sons, 3021–3023.
Storer RD, Cartwright ME, Cook WO, . 1995. Short-term carcinogenesis bioassay of genotoxic procarcinogens in PIM transgenic mice. Carcinogenesis 16(2):285–293.7859360
*Storeygard AR, Brown AL Jr. 1977. Penetration of the small intestinal mucosa by asbestos fibers. Mayo Clin Proc 52:809–812.592895
*Strokova B, Evstatieva S, Dimitrova S, . 1998. Study of asbestos exposure in some applications of asbestos materials in the chemical industry. Int Arch Occup Environ Health 71(Suppl.):19–21.9523245
Sturm W, Menze B, Krause J, . 1994. Use of asbestos, health risks and induced occupational diseases in the former East Germany. Toxicol Lett 72:317–324.8202946
Sulotto F, Capellero E, Chiesa A, . 1997. Relationship between asbestos bodies in sputum and the number of specimens. Scand J Work Environ Health 23:48–53.9098912
Szeszenia-Dabrowska N, Wilczynska U, Szymczak W, . 1998. Environmental exposure to asbestos in asbestos cement workers: A case of additional exposure from indiscriminate use of industrial wastes. Int J Occup Med Environ Health 11:171–177.9753896
*Tagesson C, Chabiuk D, Axelson O, . 1993. Increased urinary excretion of the oxidative DNA adduct, 8-hydroxydeoxyguanosine, as a possible indicator of occupational cancer hazards in the asbestos, rubber, and azo-dye industries. Pol J Occup Med Environ Health 6(4):357–368.8019198
*Taguchi T, Jhanwar SC, Siegfried JM, . 1993. Recurrent deletions of specific chromosomal sites in 1p, 3p, 6q, and 9p in human malignant mesothelioma. Cancer Res 53:4349–4355.8364929
Takagi M. 1991. Histopathological changes in the lung with low-dose asbestos exposure. Acta Med Biol 39(1):11–20.
*Takahashi K, Case BW, Dufresne A, . 1994. Relation between lung asbestos fibre burden and exposure indices based on job history. Occup Environ Med 51:461–469.8044245
*Takeuchi T, Nakajima M, Morimoto K. 1999. A human cell system for detecting asbestos cytogenotoxicity in vitro. Mutat Res 438:63–70.9858688
Talcott JA, Thurber WA, Kantor AF, . 1989. Asbestos-associated diseases in a cohort of cigarette-filter workers. N Engl J Med 321:1220–1223.2552314
Tammilehto L. 1992. Malignant mesothelioma: Prognostic factors in a prospective study of 98 patients. Lung Cancer (The Netherlands) 8(3–4):175–184.
*Tammilehto L, Tuomi T, Tiainen M, . 1992. Malignant mesothelioma: Clinical characteristics, asbestos mineralogy and chromosomal abnormalities of 41 patients. Eur J Cancer 28A:1373–1379.1325175
Tamura M, Tokuyama T, Kasuga JH, . 1996. [Study on correlation between chest X-P course findings and change in antinuclear antibody in asbestos plant employees.] J Occup Health 38:138–141. (Japanese)
Tanaka S, Choe N, Hemenway DR, . 1998. Asbestos inhalation induces reactive nitrogen species and nitrotyrosine formation in the lungs and pleura of the rat. J Clin Invest 102:445–454.9664087
Tarchi M, Orsi D, Comba P, . 1994. Cohort mortality study of rock salt workers in Italy. Am J Ind Med 25(2):251–256.8147397
Tarter ME, Cooper RC, Freeman WR. 1983. A graphical analysis of the interrelationships among waterborne asbestos, digestive system cancer and population density. Environ Health Perspect 53:79–89.6662097
*Teschke K, Ahrens W, Andersen A, . 1999. Occupational exposure to chemical and biological agents in the nonproduction departments of pulp, paper, and paper product mills: An international study. Am Ind Hyg Assoc J 60:73–83.10028618
*Teschke K, Morgan MS, Checkoway H, . 1997. Mesothelioma surveillance to locate sources of exposure to asbestos. Can J Public Health 88(3):163–168.9260356
*Teschler H, Friedrichs KH, Hoheisel GB, . 1994. Asbestos fibers in bronchoalveolar lavage and lung tissue of former asbestos workers. Am J Resp Crit Care Med 149:641–645.8118631
Teschler H, Thompson AB, Dollenkamp R, . 1996. Relevance of asbestos bodies in sputum. Eur Resp J 9:680–686.
*Testa JR. 1999. Written communication to the Agency for Toxic Substances and Disease Registry in response to the call for public comments on the draft Toxicological Profile for Asbestos.
Testa JR, Carbone M, Hirvonen A, . 1998. A multi-institutional study confirms the presence and expression of Simian virus 40 in human malignant mesotheliomas. Cancer Res 58:4505–4509.9788590
*Teta MJ, Lewinsohn HC, Meigs JW, . 1983. Mesothelioma in Connecticut, 1955-1977: Occupational and geographic associations. J Occup Med 25(10):749–756.6631560
*Thomas DC, Whittmore AS. 1988. Methods for testing interactions, with applications to occupational exposures, smoking, and lung cancer. Am J Ind Med 13:131–147.3344752
*Tiainen M, Tammilehto L, Rautonen J, . 1989. Chromosomal abnormalities and their correlations with asbestos exposure and survival in patients with mesothelioma. Br J Cancer 60(4):618–626.2803935
Tilkes F, Beck EG. 1989. Cytotoxicity and carcinogenicity of chrysotile fibres from asbestos-cement products. IARC Sci Pub 90:190–196.
Timblin CR, Janssen YMW, Goldberg JL, . 1998. GRP78, HSP72/73, and CJUN stress protein levels in lung epithelial cells exposed to asbestos, cadmium, or H2O2. Free Radic Biol Med 24:632–642.9559875
*Timbrell V. 1982. Deposition and retention of fibres in the human lung. Ann Occup Hyg 26:347–369.7181276
Tocilj J, Dujic Z, Boschi S, . 1990. Correlation between radiological and functional findings in workers exposed to chrysotile asbestos. Med Lav 81:373–381.1965219
*Toft P, Wigle D, Meranger JC, . 1981. Asbestos and drinking water in Canada. Sci Total Environ 18:77–89.6262910
*Tomasini M, Chiappino G. 1981. Hemodynamics of pulmonary circulation in asbestosis: Study of 16 cases. Am J Ind Med 2:167–174.7349043
*Topping DC, Nettesheim P. 1980. Two-stage carcinogenesis studies with asbestos in Fischer 344 rats. J Natl Cancer Inst 65:627–630.6774154
Tossavainen A, Karjalaine A, Karhunen PJ. 1994. Retention of asbestos fibers in the human body. Environ Health Perspect Suppl 102:253–255.7882945
TRI92. 1994. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI96. 1999. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
TRI98. 2000. Toxic Chemical Release Inventory. National Library of Medicine, National Toxicology Information Program, Bethesda, MD.
*TRI99. 2001. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Offices of Environmental Information. U.S. Environmental Protection Agency. Toxic Release Inventory. Http://www.epa.gov/triexplorer/. April 27, 2001.
*Trosic I, Brumen V, Horbat D. 1997. In vitro assessment of asbestos fibers genotoxicity. Zentralbl Hyg Umeweltmed 199:558–567.
Truhaut R, Chouroulinkov I. 1989. Effect of long-term ingestion of asbestos fibres in rats. IARC Sci Pub 90:127–133.
Tsai SP, Waddell LCJ, Gilstrap EL, . 1996. Mortality among maintenance employees potentially exposed to asbestos in a refinery and petrochemical plant. Am J Ind Med 29:89–98.8808046
*Tsang PH, Chu FN, Fischbein A, . 1988. Impairments in functional subsets of T-suppressor (CD8) lymphocytes, monocytes, and natural killer cells among asbestos-exposed workers. Clin Immunol Immunopathol 47:323–332.2967138
*Tsuda A, Stringer BK, Mijailovich SM, . 1999. Alveolar cell stretching in the presence of fibrous particles induces interleukin-8 responses. Am J Respir Cell Mol Biol 21:455–462.10502555
Tsuda T, Morimoto Y, Yamato H, . 1997. Effects of mineral fibers on the expression of genes whose product may play a role in fiber pathogenesis. Environ Health Perspect Suppl 105:1173–1178.9400719
*Tulchinsky TH, Ginsberg GM, Shihab S, . 1992. Mesothelioma mortality among former asbestos-cement workers in Israel, 1953-90. Isr J Med Sci 28(8–9):543–547.1428808
Tuomi T. 1992. Fibrous minerals in the lungs of mesothelioma patients: Comparison between data on SEM, TEM and personal interview information. Am J Ind Med 21:155–162.1311147
Tuomi T, Huuskonen MS, Tammilehto L, . 1991c. Occupational exposure to asbestos evaluated from work histories and analysis of lung tissues from patients with mesothelioma. Br J Ind Med 48:48–52.1993160
Tuomi T, Huuskonen MS, Virtamo M, . 1991a. Relative risk of mesothelioma associated with different levels of exposure to asbestos. Scad J Work Environ Health 17:404–408.
*Tuomi T, Oksa P, Anttila S, . 1991b. Fibres and asbestos bodies in bronchoalveolar lavage fluids of asbestos sprayers. Br J Ind Med 49:480–485.
UATW. 1999. Unified Air Toxics Website. U.S. Environmental Protection Agency, Office of Air Quality Planning and Standards. Http://www.epa.gov/ttnuatw1/uatwn.html. May 6, 1999
Unfried K, Kociok N, Roller M, . 1997a. P53 mutations in tumours induced by intraperitoneal injection of crocidolite asbestos and benzo[a]pyrene in rats. Exp Toxicol Pathol 49:181–187.9314051
Unfried K, Roller M, Pott F, . 1997b. Fiber-specific molecular features of tumors induced in rat peritoneum. Environ Health Perspect Suppl 105:1103–1108.9400707
Upton AC, Shaikh RA. 1995. Asbestos exposures in public and commercial buildings. Am J Ind Med 27:433–437.7747748
*U.S. Bureau of Mines. 1992. Mineral commodity summaries. Asbestos, 28–29.
*U.S. Bureau of Mines. 1994. Mineral commodity summaries. Asbestos, 26–27.
USC. 1998. United States Code. 42 USC 7412.
*USC. 2001a. Clean Water Act. National standards of performance. U.S. Code. 33 USC 1316. Http://www4.law.cornell.edu/uscode/33/1316.text.html. May 01, 2001.
*USC. 2001b. Congressional findings and purpose. U.S. Code. 15 USC 2641. Http://www4.law.cornell.edu/uscode/15/2641.text.html. May 01, 2001.
*USC. 2001c. Hazardous air pollutants. U.S. Code. 42 USC 4712. Http://www4.law.cornell.edu/uscode/42/7412.text.html. May 01, 2001.
*USGS. 1997. Asbestos. Minerals Yearbook 1997. U.S. Geological Survey. Http://minerals.usgs.gov/minerals/pubs/commodity/asbestos/070497.pdf. April 25, 1997.
*USGS. 1998. Asbestos. Commodity Summaries. U.S. Geological Survey. Http://minerals.usgs.gov/minerals/pubs/commodity/asbestos/070398.pdf. April 29, 1998.
*USGS. 1999a. Asbestos. Commodity Summaries. U.S. Geological Survey. Http://minerals.usgs.gov/minerals/pubs/commodity/asbestos070399.pdf. January 15, 1999.
*USGS. 1999b. Asbestos. Minerals Yearbook 1999. U.S. Geological Survey. Http://minerals.usgs.gov/pubs/commodity/asbestos/070499.pdf. January 15, 1999.
*USGS. 2000. Asbestos. Commodity Summaries. U.S. Geological Survey. Http://minerals.usgs.gov/minerals/commodity/asbestos/070300.pdf. January 23, 2000.
Vacek PM. 1997. Assessing the effect of intensity when exposure varies over time. Stat Med 16:505–513.9089959
Vacek PM. 1998. Effects of the intensity and timing of asbestos exposure on lung cancer risk at two mining areas in Quebec. J Occup Environ Med 40:821–828.9777567
Vainio H, Boffetta P. 1994. Mechanisms of the combined effect of asbestos and smoking in the etiology of lung cancer. Scand J Work Environ Health 20:235–242.7801068
Vainio H, Husgafvel-Pursiainen K, Antilla S, . 1993. Interaction between smoking and asbestos in human lung adenocarcinoma. Environ Health Perspect Suppl 101 (3):189–192.
*Valerio F, De Ferrari M, Ottaggio L, . 1980. Cytogenetic effect of Rhodesian chrysotile on human lymphocytes in vitro. IARC Sci Publ 30:485–489.
Valic F, Beritic-Stahuljak D, Cigula M. 1990. Ventilatory lung function changes in family members of asbestos workers. Acta Med Iug 44:205–209.
Valkila EH, Nieminen MM, Moilanen AK, . 1995. Asbestos-induced visceral pleural fibrosis reduces pulmonary compliance. Am J Ind Med 28:363–372.7485190
Vallyathan V, Green FH. 1985. The role of analytical techniques in the diagnosis of asbestos-associated disease. CRC Crit Rev Clin Lab Sci 22:1–42.
Van Der Meeren A, Fleury J, Nebut M, . 1992. Mesothelioma in rats following intrapleural injection of chrysotile and phosphorylated chrysotile (chrysophosphate). Int J Cancer 50:937–942.1313399
van Gelder T, Hoogsteden HC, Versnel MA, . 1989. Malignant peritoneal mesothelioma: A series of 19 cases. Digestion 43:222–227.2612745
Varga C, Horvath G, Pocsai Z, . 1998. On the mechanism of cogenotoxic action between ingested amphibole asbestos fibres and benzo[a]pyrene: I. Urinary and serum mutagenicity studies with rats. Cancer Lett 128:165–169.9683278
*Varga C, Horvath G, Timbrell V. 1996a. In vivo studies on genotoxicity and cogenotoxicity of ingested UICC anthophyllite asbestos. Cancer Lett 105:181–185.8697442
*Varga C, Pocsai Z, Horvath G, . 1996b. Studies on genotoxicity of orally administered crocidolite asbestos in rats: Implications for ingested asbestos induced carcinogenesis. Anticancer Res 16:811–814.8687133
Varouchakis G, Velonakis EG, Amfilochiou S, . 1991. Asbestos in strange places: Two case reports of mesothelioma among merchant seamen. Am J Ind Med 19(5):673–676.2053581
*Verma DK, Clark NE. 1995. Relationships between phase contrast microscopy and transmission electron microscopy results of samples from occupational exposure to airborne chrysotile asbestos. Am Ind Hyg Assoc J 56:866–873.
Versar. 1988. Final report: Asbestos modeling study. Report to U. S. Environmental Protection Agency, Office of Toxic Substances, Washington, DC, by Versar, Inc., Springfield, VA. EPA 560/3-88/091.
*Viallat JR, Boutin C. 1980. Radiographic changes in chrysotile mine and mill ex-workers in Corsica: A survey 14 years after cessation of exposure. Lung 157:155–163.6247583
*Viallat JR, Raybuad F, Passarel M, . 1986. Pleural migration of chrysotile fibers after intratracheal injection in rats. Arch Environ Health 41:282–286.3026258
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vineis P, Ciccone G, Magnino A. 1993. Asbestos exposure, physical activity and colon cancer: A case-control study. Tumori 79(5):301–303.8116070
Voisin C, Fisekci F, Voisin-Saltiel S, . 1995. Asbestos-related rounded atelectasis: Radiologic and mineralogic data in 23 cases. Chest 107:477–481.7842780
*Voisin C, Marin I, Brochard P, . 1994. Environmental airborne tremolite asbestos pollution and pleural plaques in Afghanistan. Chest 106:974–976.8082397
*Volkheimer G. 1974. Passage of particles through the wall of the gastrointestinal tract. Environ Health Perspect 9:215–225.4470938
Voytek P, Anver M, Thorslund T, . 1990. Mechanism of asbestos carcinogenicity. J Am Coll Toxicol 9:541–550.
*Vu VT. 1993. Regulatory approaches to reduce human health risks associated with exposures to mineral fibers. In: Guthrie GD, Mossman BT, eds. Health Effects of Mineral Dusts. Washington, D.C.: Mineralogical Society of America, 545–554.
Vu V, Barrett JC, Roycroft J, . 1996. Chronic inhalation toxicity and carcinogenicity testing of respirable fibrous particles. Regul Toxicol Pharmacol 24:202–212.8975745
Waage HP, Johnson ES, Hilt B, . 1994. Asbestosis and pleural changes as risk factors for asbestos-induced lung cancer. Intl J Occup Med Toxicol 3:319–327.
*Waage HP, Vatten LJ, Opedal E, . 1996. Lung function and respiratory symptoms related to changes in smoking habits in asbestos-exposed subjects. J Occup Environ Med 38:178–183.8673522
Wagner JC. 1972. Current opinions on the asbestos cancer problem. Ann Occup Hyg 15:61–64.5044507
Wagner JC. 1975. Asbestos carcinogenesis. Br J Cancer 32:258–259.
Wagner JC. 1979. Diseases associated with exposure to asbestos dusts. Practitioner 223:28–33.482244
Wagner JC. 1983. The risk assessment of asbestos carcinogenicity in the normal population. Animal to human correlations. VDI-Berichte Nr 475:305–308.
Wagner JC. 1984. Mineral fiber carcinogenesis. In: Searle CE, ed. Chemical carcinogens. 2nd ed. Vol 1. Washington, DC: American Chemical Society, 634–641.
Wagner JC, Berry G. 1969. Mesotheliomas in rats following inoculation with asbestos. Br J Cancer 23:567–581.5360333
Wagner JC, Pooley FD. 1986. Mineral fibers and mesothelioma [Editorial]. Thorax 41:161–166.3715773
*Wagner JC, Berry G, Pooley FD. 1982a. Mesotheliomas and asbestos type in asbestos textile workers: A study of lung contents. Br Med J 285:603–606.6297656
*Wagner JC, Berry G, Skidmore JW, . 1974. The effects of the inhalation of asbestos in rats. Br J Cancer 29:252–269.4364384
*Wagner JC, Berry G, Skidmore JW, . 1980a. The comparative effects of three chrysotiles by injection and inhalation in rats. IARC Sci Publ 30:363–372.
*Wagner JC, Berry G, Timbrell V. 1973. Mesotheliomata in rats after inoculation with asbestos and other materials. Br J Cancer 28:173–185.4354178
*Wagner JC, Chamberlain M, Brown RC, . 1982c. Biological effects of tremolite. Br J Cancer 45:352–360.6280741
Wagner JC, Gilson JC, Berry G, . 1971. Epidemiology of asbestos cancer. Br Med Bull 27:71–76.5543167
Wagner JC, Griffiths DM, Hill RJ. 1984. The effect of fibre size on the in vivo activity of UICC crocidolite. Br J Cancer 49(4):453–458.6324841
Wagner JC, Hill RJ, Berry G, . 1980b. Treatments affecting the rate of asbestos-induced mesotheliomas. Br J Cancer 41:918–922.6252922
*Wagner JC, Moncrieff CB, Coles R, . 1986. Correlation between fibre content of the lungs and disease in naval dockyard workers. Br J Ind Med 43:391–395.3718883
*Wagner JC, Pooley FD, Berry G, . 1982b. A pathological and mineralogical study of asbestos-related deaths in the United Kingdom in 1977. Ann Occup Hyg 26:423–431.7181279
*Wagner JC, Sleggs CA, Marchand P. 1960. Diffuse pleural mesothelioma and asbestos exposure in the north western Cape Province. Br J Ind Med 17:260–271.13782506
Walach N, Novikov I, Milievskaya I, . 1998. Cancer among spouses. Cancer 82:180–185.9428496
Walker C, Bermudez E, Everitt J. 1991a. Growth factor and receptor expression by mesothelial cells: A comparison between rodents and humans. In: Cellular and molecular aspects of fiber carcinogenesis. Cold Spring Harbor Laboratory Press, 149–158.
Walker C, Bermudez E, Stewart W, . 1991b. Growth factor and growth factor receptor expression in transformed rat mesothelial cells. In: Brown RC, ed. Mechanisms in fibre carcinogenesis. New York, NY: Plenum Press, 377–383.
Walker C, Bermudez E, Stewart W, . 1992a. Characterization of platelet-derived growth factor and platelet-derived growth factor receptor expression in asbestos-induced rat mesothelioma. Cancer Res 52:301–306.1309438
Walker C, Everitt J, Barrett JC. 1992b. Possible cellular and molecular mechanisms for asbestos carcinogenicity. Am J Ind Med 21:253–273.1536158
Walker C, Everitt J, Ferriola PC, . 1995. Autocrine growth stimulation by transforming growth factor alpha in asbestos-transformed rat mesothelial cells. Cancer Res 55:530–536.7530596
Walton WH. 1982. The nature, hazards and assessment of occupational exposure to airborne asbestos dust: A review. Ann Occup Hyg 25:117–247.6753691
Wang X, Araki S, Yano E, . 1995a. Effects of smoking on respiratory function and exercise performance in asbestos workers. Ind Health 33:173–180.8557538
*Wang X, Christiani DC, Wiencke JK, . 1995b. Mutations in the p53 gene in lung cancer are associated with cigarette smoking and asbestos exposure. Cancer Epidemiol Biomarkers Prev 4:543–548.7549812
*Wang X, Yano E, Nonaka K, . 1997. Respiratory impairments due to dust exposure: A comparative study among workers exposed to silica, asbestos, and coalmine dust. Am J Ind Med 31:495–502.9099350
*Wang XR, Yano E, Nonaka K, . 1998. Pulmonary function of nonsmoking female asbestos workers without radiographic signs of asbestosis. Arch Environ Health 53:292–298.9709994
*Ward JM, Frank AL, Wenk M, . 1980. Ingested asbestos and intestinal carcinogenesis in F344 rats. J Environ Pathol Toxicol 3:301–312.7441086
Warheit DB. 1989. Interspecies comparisons of lung responses to inhaled particles and gases. CRC Crit Rev Toxicol 20:1–29.
*Warheit DB, Hartsky MA. 1994. Influences of gender, species, and strain differences in pulmonary toxicological assessments of inhaled particles and/or fibers. In: Mohr U, Dungworth DL, Mauderly JL, ., ed. Toxic and carcinogenic effects of solid particles in the respiratory tract. Washington, DC: ILSI Press, 253–265.
*Warheit DB, Chang KY, Hill LH, . 1984. Pulmonary macrophage accumulation and asbestos-induced lesions at sites of fiber deposition. Am Rev Respir Dis 129:301–310.6696328
*Warheit DB, George G, Hill LH, . 1985. Inhaled asbestos activates a complement-dependent chemoattractant for macrophages. Lab Invest 52:505–514.3990243
Warheit DB, Harsky MA, Frame SR. 1996. Pulmonary effects in rats inhaling size-separated chrysotile asbestos fibers or p-aramid fibrils: differences in cellular proliferative responses. Toxicol Lett 88:287–292.8920750
Warheit DB, Hartsky MA, McHugh TA, . 1994. Biopersistence of inhaled organic and inorganic fibers in the lungs of rats. Environ Health Perspect Suppl 102:151–157.
*Warheit DB, Hill LH, George G, . 1986. Time course of chemotactic factor generation and the corresponding macrophage response to asbestos inhalation. Am Rev Respir Dis 134:128–133.3729150
*Warheit DB, Overby LH, George G, . 1988. Pulmonary macrophages are attracted to inhaled particles through complement activation. Exp Lung Res 14:51–66.2830106
*Warheit DB, Snajdr SI, Hartsky MA, . 1997. Lung proliferative and clearance responses to inhaled para-aramid RFP in exposed hamsters and rats: Comparisons with chrysotile asbestos fibers. Environ Health Perspect Suppl 105:1219–1222.9400727
*Warner M. 1988. Asbestos. Anal Chem 60:395A–396A.
Warnock ML. 1989. Lung asbestos burden in shipyard and construction workers with mesothelioma: Comparison with burdens in subjects with asbestosis or lung cancer. Environ Res 50:68–85.2792062
*Warwick MT, Parkes R, Hanson A, . 1973. Immunology and asbestos. IARC Sci Publ 8:258–263.
Watanabe M, Kimura N, Kato M, . 1994. An autopsy case of malignant mesothelioma associated with asbestosis. Pathol Int 44:785–792.7834080
Watanabe Y, Yamaguchi M, Kawakami Y, . 1993. Human CD4+ CD45RA+ T lymphocytes can be stimulated by crocidolite, anthophyllite and amosite asbestos in vitro. Int J Oncol 2(2):209–212.21573538
Weant GE, McCormick GS. 1984. Nonindustrial sources of potentially toxic substances and their applicability to source apportionment methods. Research Triangle Park, NC: U.S. Environmental Protection Agency (MD 14). EPA-450/4-84-003. NTIS No. PB84-231232.
*Webber JS, Covey JR, King MV. 1989. Asbestos in drinking water supplied through grossly deteriorated a-c pipe. J AWWA (February 1989):80–85.
*Webber JS, Syrotynski S, King MV. 1988. Asbestos-contaminated drinking water: Its impact on household air. Environ Res 46:153–167.3402404
*Webster I, Goldstein B, Coetzee FS, . 1993. Malignant mesothelioma induced in baboons by inhalation of amosite asbestos. Am J Ind Med 24(6):659–666.8311096
Weidner N. 1991. Malignant mesothelioma of peritoneum. Ultrastruct Pathol 15(4–5):515–520.1721749
*Weill H, Hughes J, Waggenspack C. 1979. Influence of dose and fiber type on respiratory malignancy risk in asbestos cement manufacturing. Am Rev Respir Dis 120:345–354.475155
Weill H, Hughes JM, Jones RN. 1995. Asbestos: A risk too far? [Letter]. Lancet 346:304–306.
*Weill H, Ziskind MM, Waggenspack C, . 1975. Lung function consequences of dust exposure in asbestos cement manufacturing plants. Arch Environ Health 30:88–97.1115533
*Weinzweig M, Richards RJ. 1983. Quantitative assessment of chrysotile fibrils in the bloodstream of rats which have ingested the mineral under dietary conditions. Environ Res 31:245–255.6309509
*Weiss W. 1984. Cigarette smoke, asbestos, and small irregular opacities. Amer Rev Respir Dis 130:293–301.6380358
Weiss W. 1990. Asbestos and colorectal cancer. Gastroenterology 99:876–884.2199293
*Weiss W. 1993. Asbestos-related pleural plaques and lung cancer. Chest 103(6):1854–1859.8404113
*Weiss W. 1995. The lack of causality between asbestos and colorectal cancer. J Occup Environ Med 37:1364–1371.8749742
Weiss W. 1999. Asbestosis: A marker for the increased risk of lung cancer among workers exposed to asbestos. Chest 115:536–549.10027457
*Weitzman SA, Graceffa P. 1984. Asbestos catalyzes hydroxyl and superoxide radical generation from hydrogen peroxide. Arch Biochem Biophysics 228:373–376.
*Weitzman SA, Chester JF, Graceffa P. 1988. Binding of deferoxamine to asbestos fibers in vitro and in vivo. Carcinogenesis 9:1643–1645.3409466
Welch LS, Michaels D, Zoloth SR, . 1994. The national sheet metal workers asbestos disease screening program: Radiologic findings. Am J Ind Med 25:536–648.
*West JB ed. 1985. Physiological basis of medical practice. 11th ed. Baltimore, MD: Williams and Wilkins, 386–389.
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Westlake GE, Spjut HJ, Smith MN. 1965. Penetration of colonic mucosa by asbestos particles: An electron microscopic study in rats fed asbestos dust. Lab Invest 14:2029–2033.5854190
White KL Jr, Munson AE. 1986. Suppression of the in vitro humoral immune response by chrysotile asbestos. Toxicol Appl Pharmacol 82:493–504.3952732
Whitwell F. 1978. Problems in the pathology of disease caused by asbestos. J R Soc Med 71:919–922.739508
*Whitwell F, Scott J, Grimshaw M. 1977. Relationship between occupations and asbestos-fibre content of the lungs in patients with pleural mesothelioma, lung cancer, and other diseases. Thorax 32:377–386.929482
WHO. 1984. Asbestos. In: Guidelines for drinking water quality. Vol. 2. Health criteria and other supporting information. Geneva, Switzerland: World Health Organization, 68–75.
*WHO. 1986. Asbestos and other natural mineral fibers. Environmental health criteria 53. Geneva, World Health Organization, 10–31, 166–167, 178–179.
*WHO. 1998. Chrysotile asbestos: Environmental health criteria. Geneva: Switzerland: World Health Organization.
Whysner J, Covello VT, Kuschner M, . 1994. Asbestos in the air of public buildings: A public health risk? Prev Med 23:119–125.8016027
*Widdowson EM, Dickerson JWT. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
*Wigle DT. 1977. Cancer mortality in relation to asbestos in municipal water supplies. Arch Environ Health 32:185–190.889357
*Wignall BK, Fox AJ. 1982. Mortality of female gas mask assemblers. Br J Ind Med 39:34–38.7066218
Wilkinson P, Hansell DM, Janssens J, . 1995. Is lung cancer associated with asbestos exposure when there are no small opacities on the chest radiograph? Lancet 345:1074–1078.7715339
*Williams V, De Klerk NH, Whitaker D, . 1995. Asbestos bodies in lung tissue following exposure to crocidolite. Am J Ind Med 28:489–495.8533790
Windholz M, Budavari S, eds. 1983. The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 10th ed. Rahway, NJ: Merck and Company, Inc., 119.
Woitowitz HJ, Hausmann K. 1995. [Non-Hodgkin’s lymphoma of the tonsils following asbestos dust exposure.] Dtsch Med Wochenschr 120:626. (German)7736961
Woitowitz H-J, Rodelsperger K. 1994. Mesothelioma among car mechanics. Ann Occup Hyg 38:635–638.7978986
Wolff H, Saukkonen K, Anttila S, . 1998. Expression of cyclooxygenase-2 in human lung carcinoma. Cancer Res 58:4997–5001.9823297
*Wollmer P, Eriksson L, Jonson B, . 1987. Relation between lung function, exercise capacity, and exposure to asbestos cement. Br J Ind Med 44:542–549.3651353
*Wortley P, Vaughan TL, Davis S, . 1992. A case-control study of occupational risk factors for laryngeal cancer. Br J Ind Med 49(12):837–844.1472441
Wozniak H, Wiecek E, Tossavainen A, . 1986. Comparative studies of fibrogenic properties of wollastonite, chrysotile and crocidolite. Med Pr 37:288–296.3027496
Wright A, Cowie H, Gormley IP, . 1986. The in vitro cytotoxicity of asbestos fibers: I. P288D_l_ cells. Am J Ind Med 9:371–384.3706311
Wright A, Donaldson K, Davis JM. 1983. Cytotoxic effect of asbestos on macrophages in different activation states. Environ Health Perspect 51:147–152.6315355
Wright JL, Tron V, Wiggs, B, . 1988. Cigarette smoke potentiates asbestos-induced airflow abnormalities. Exp Lung Res 14:537–548.3208718
Wright JL, Wiggs B, Churg A. 1991. Pulmonary hypertension induced by amosite asbestos: A physiological and morphologic study in the guinea pig. Lung 169:31–42.1849213
Wunsch-Filho V, Moncau JE, Mirabelli D, . 1998. Occupational risk factors of lung cancer in Sao Paulo, Brazil. Scand J Work Environ Health 24:118–124.9630059
Wylie AG, Bailey KF. 1992. The mineralogy and size of airborne chrysotile and rock fragments: Ramifications of using the NIOSH 7400 method. Am Ind Hyg Assoc J 53(7):442–447.
*Wylie AG, Verkouteren JR. 2000. Amphibole asbestos from Libby, Montana: Aspects of nomenclature. Am Mineral 85:1540–1542.
Wylie AG, Bailey KF, Kelse JW, . 1993. The importance of width in asbestos fiber carcinogenicity and its implications for public policy. Am Ind Hyg Assoc J 54(5):239–252.8498359
Wylie AG, Skinner HCW, Marsh J, . 1997. Mineralogical features associated with cytotoxic and proliferative effects of fibrous talc and asbestos on rodent tracheal epithelial and pleural mesothelial cells. Toxicol Appl Pharmacol 147:143–150.9356317
*Xing Z, Jordana M, Gauldie J, . 1999. Cytokines and pulmonary inflammatory and immune disease. Histol Histopathol 14:185–201.9987664
*Xu A, Wu L-J, Santella RM, . 1999. Role of oxyradicals in mutagenicity and DNA damage induced by crocidolite asbestos in mammalian cells. Cancer Res 59:5922–5926.10606236
*Xu GB, Yu CP. 1986. Effects of age on deposition of inhaled aerosols in the human lung. Aerosol Sci Technol 5:349–357.
Xu X, Kelsey KT, Wiencke JK, . 1996. Cytochrome P450 CYP1A1 MspI polymorphism and lung cancer susceptibility. Cancer Epidemiol Biomarkers Prev 5:687–692.8877059
Yamada H, Hashimoto H, Akiyama M, . 1997. Talc and amosite/crocidolite preferentially deposited in the lungs of nonoccupational female lung cancer cases in urban areas of Japan. Environ Health Perspect 105:504–508.9222135
Yamaguchi N, Kido M, Hoshuyama T, . 1992. A case-control study on occupational lung cancer risks in an industrialized city of Japan. Jpn J Cancer Res 83(2):134–140.1555994
*Yano E. 1988. Mineral fiber-induced malondialdehyde formation and effects of oxidant scavengers in phagocytic cells. Int Arch Occup Environ Health 61:19–23.2848774
Yates DH, Browne K, Stidolph PN, . 1996. Asbestos-related bilateral diffuse pleural thickening: Natural history of radiographic and lung function abnormalities. Am J Resp Crit Care Med 153:301–306.8542134
Yates DH, Corrin B, Stidolph PN, . 1997. Malignant mesothelioma in south east England: Clinicopathological experience of 272 cases. Occup Environ Med 52:507–512.
*Yazicioglu S, Ilcayto R, Balci K, . 1980. Pleural calcification, pleural mesotheliomas, and bronchial cancers caused by tremolite dust. Thorax 35:564–569.7444823
*Yegles M, Janson X, Dong HY, . 1995. Role of fibre characteristics on cytotoxicity and induction of anaphase/telophase aberrations in rat pleural mesothelial cells in vitro: Correlations with in vivo animal findings. Carcinogenesis 16:2751–2758.7586195
*Yegles M, Saint-Etienne L, Renier A, . 1993. Induction of metaphase and anaphase/telophase abnormalities by asbestos fibers in rat pleural mesothelial cells in vitro. Am J Respir Cell Mol Biol 9(2):186–91.8393329
*Yu CP, Zhang L, Oberdorster G . 1994. Deposition modeling of refractory ceramic fibers (RCF) in the rat lung. J Aerosol Sci 25:407–417.
*Yu CP, Zhang L, Oberdorster G . 1995. Deposition of refractory ceramic fibers (RCF) in the human respiratory tract and comparison with rodent studies. Aerosol Sci Technol 23:291–300.
*Yu CP, Ding YJ, Zhang L . 1996. A clearance model of refractory ceramic fibers (RCF) in the rat lung including fiber dissolution and breakage. J Aerosol Sci 27:151–160.
*Yu CP, Ding YJ, Zhang L, . 1997. Retention modeling of refractory ceramic fibers (RCF) in humans. Regul Toxicol Pharmacol 25:18–25.9056498
Yu IJ, Moon YH, Sakai K, . 1998. Asbestos and non-asbestos fiber content in lungs of Korean subjects with no known occupational asbestos exposure history. Environ Int 24:293–300.
Zahm SH, Devesa SS. 1995. Childhood cancer: Overview of incidence trends and environmental carcinogens. Environ Health Perspect Suppl 103:177–184.
*Zanella CL, Timblin CR, Cummins A, . 1999. Asbestos-induced phosphorylation of epidermal growth factor receptor is linked to c-fos and apoptosis. Am J Physiol 277:L684–L693.10516208
Zelen M. 1985. Products liability issues in school asbestos litigation. Am J Law Med 10:467–489.3911775
*Zerva LV, Constantopoulos SH, Moutsopoulos HM. 1989. Humoral immunity alterations after environmental asbestos exposure. Respiration 55:237–241.2595107
*Zhang Y, Lee TC, Guillemin B, . 1993. Enhanced IL-1beta tumor necrosis factor-alpha release and messenger RNA expression in macrophages from idiopathic pulmonary fibrosis or after asbestos exposure. J Immunol 150:4188–4196.8473757
Zheng W, Blot WJ, Shu X-O, . 1992. Diet and other risk factors for laryngeal cancer in Shanghai China. Am J Epidemiol 136(2):178–191.1415140
Zhu HL, Wang ZM. 1993. Study of occupational lung-cancer in asbestos factories in China. Br J Ind Med 50(11):1039–1042.8280629
*Ziegler EE, Edwards BB, Jensen RL . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zitting AJ. 1995. Prevalence of radiographic small lung opacities and pleural abnormalities in a representative adult population sample. Chest 107(1):126–131.7813263
Zitting AJ, Karjalainen A, Impivaara I, . 1995. Radiographic small lung opacities and pleural abnormalities as a consequence of asbestos exposure in an adult population. Scand J Work Environ Health 21:470–477.8824753
Zitting AJ, Karjalainen A, Impivaara O, . 1996. Radiographic small lung opacities and pleural abnormalities in relation to smoking, urbanization status, and occupational asbestos exposure in Finland. J Occup Environ Med 38:602–609.8794959
Zoller T, Zeller WJ. 2000. Production of reactive oxygen species by phagocytic cells after exposure to glass wool and stone wool fibres - effect of fibre preincubation in aqueous solution. Toxicol Lett 114:1–9.10713463