# 8 REGULATIONS AND ADVISORIES

Because of its potential to cause adverse health effects in exposed people, numerous regulations and advisories have been established for asbestos by various international, national, and state agencies. Such regulations and advisories control asbestos in various media, such as air and water, and also how it is contained, handled, disposed, etc.

Major regulations and advisories pertaining to asbestos are summarized in Table 8-1. Most states have adopted and enforce the regulations and guidelines set by national agencies. For example, with regard to emissions standards, most states follow the National Emission Standards for Hazardous Air Pollutants established by EPA (in Volume 40, Part 61 of the Code of Federal Regulations) for asbestos emissions. States may establish their own standards, but they are comparable to or more stringent than the ones set forth by EPA, OSHA, etc. (CELDS 1994). In addition, states may establish regulations for asbestos when federal regulations do not exist for a particular scenario (Kaplan 1993).

Table 8-1 Regulations and Guidelines Applicable to Asbestos^a^

Agency | Description | Information | References
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenic classification | Group 1^b^ | IARC 2001
[underlined: NATIONAL]
Regulations and guidelines
a. Air
ACGIH | TLV-TWA | 0.1 f/mL | ACGIH 2000
EPA | Carcinogenic inhalation unit risk | 2.3×10^−1^ (f/mL)^−1^ | IRIS 2001
EPA | Carcinogenic classification | Group A^c^
EPA | NESHAP—HAP | | EPA 2000c; 40CFR61.01(a)
NIOSH | REL (100-minute TWA in a 400 L sample); f>5 μm in length | 0.1 f/mL | NIOSH 2001
OSHA | PEL (8-hour TWA) | 0.1 f/mL | OSHA 2001a; 29CFR1910.1001
OSHA | PEL (8-hour TWA) for construction | 0.1 f/mL | OSHA 2001b; 29CFR1926.1101
OSHA | PEL (excursion limit) averaged over a 30-minute sampling period for construction | 1.0 f/mL | OSHA 2001b; 29CFR1926.1101
OSHA | PEL (8-hour TWA) for shipyard | 0.1 f/mL | OSHA 2001c; 29CFR1915.1001
OSHA | PEL (excursion limit) averaged over a 30-minute sampling period for shipyard | 1.0 f/mL | OSHA 2001c; 29CFR1915.1001
USC | HAP | | USC 2001c; 42USC7412
b. Water
EPA | Concentration at cancer risk of 10^−4^ for drinking water | 700 MFL | EPA 2000a
EPA | Human health for consumption of: Water and organism | 7 MFL | EPA 1999a
EPA | MCL (f>10 μm in length) | 7 MFL | EPA 2001a
EPA | MCLG (f>10 μm in length) | 7 MFL
USC | Clean Water Act—National Standards of Performance | | USC 2001a; 33USC1316
c. Food
FDA | Indirect food additives: Adhesives and components of coatings | | FDA 2000a; 21CFR175.105(c)(5)
FDA | Indirect food additives: Polymers | | FDA 2000b; 21CFR177.2420 (b)
FDA | Indirect food additives: Polymers—phenolic resins in molded articles | | FDA 2000c; 21CFR177.2410(b)
d. Other
ACGIH | Carcinogenic classification | A1^d^ | ACGIH 2000
CPSC | Test results on crayons—manufacturers will reformulate crayons using substitute ingredients to eliminate fibers within one year | | CPSC 2001a
CPSC | Testing finds no asbestos fibers in children’s chalk | | CPSC 2001b
EPA | Asbestos—containing materials in schools; Asbestos abatement project | | EPA 2000b; 40CFR763
EPA | CERCLA—reportable quantity | 1 pound | EPA 1999b; 40CFR302.4
EPA | Toxic chemical release reporting; Community Right-to-Know—effective date | 01/01/87 | EPA 2001c; 40CFR372.65(a)
USC | Congressional findings and purpose—implementation of appropriate response actions with respect to asbestos-containing material in the Nation’s schools | | USC 2001b; 15USC2641
DHHS | Carcinogen classification | Known to be ahumancarcinogen | NTP 2001
[underlined: STATE]
Regulations and Guidelines
a. Air
Alabama | HAP | | BNA 2001
Arizona | Research HAPs List | | ADEQ 2001
California | Toxic air contaminant | | Environmental Defense 2001
Colorado | HAP | | BNA 2001
Hawaii | HAP | | BNA 2001
Illinois | Toxic air contaminant | | BNA 2001
Kansas | HAP | | BNA 2001
Kentucky | HAP | | BNA 2001
Louisiana | Toxic air pollutant | | BNA 2001
Louisiana | Minimum emission rate | 25.0 pounds/year
Maryland | Toxic air pollutant | | BNA 2001
Minnesota | HAP threshold | | BNA 2001
Minnesota | De minimis level (tons/year) | Zero
Missouri | Air contaminant | | BNA 2001
Missouri | De minimis emission level | 0.007 tons/year
Nebraska | HAP | | BNA 2001
New York | HAP | | BNA 2001
Rhode Island | HAP | | BNA 2001
Vermont | Hazardous air contaminant | | BNA 2001
Vermont | Hazardous ambient air standards | | BNA 2001
Vermont | Annual average | 1.2×10^−4^ μg/m^3^
Vermont | Action level | 1×10^−5^ pounds/8 hours
Washington | HAP—threshold level | 4×10^−5^ f/mL | BNA 2001
Wyoming | HAP | | BNA 2001
b. Water
Alabama | Primary drinking water standard | | BNA 2001
Alabama | MCL (f>10 μm in length) | 7 MFL
Alaska | Drinking water standard | | BNA 2001
Alaska | MCL (f>10 μm in length) | 7 MFL
Arizona | Safe drinking water | | BNA 2001
Arizona | MCL (f>10 μm in length) | 7 MFL
California | Primary MCL | 7 MFL | California DHS 1999
Colorado | Groundwater standard | 7 MFL | BNA 2001
Colorado | Primary drinking water regulation | | BNA 2001
Colorado | MCL (f>10 μm in length) | 7 MFL
Connecticut | Public drinking water standard | | BNA 2001
Connecticut | MCL (f>10 μm in length) | 7 MFL
Florida | Drinking water standard | | BNA 2001
Florida | MCL | 7 MFL
Georgia | Safe drinking water | | BNA 2001
Georgia | MCL (f>10 μm in length) | 7 MFL
Hawaii | MCL (f>10 μm in length) | 7 MFL | CDC 1999
Illinois | Primary drinking water standard | | BNA 2001
Illinois | MCL | 7 MFL
Indiana | MCL | 7 MFL | IDEM 2001a
Kansas | Surface water quality criteria | | BNA 2001
Kansas | Domestic water supply | 7 MFL
Kentucky | Surface water standards | | BNA 2001
Kentucky | Domestic water supply use | 7 MFL
Maryland | Drinking water | | BNA 2001
Maryland | MCL (f>10 μm in length) | 7 MFL
Massachusetts | Water quality standard (f>10 μm in length) | 7 MFL | FSTRAC 1999
Michigan | Drinking water standard | | BNA 2001
Michigan | MCL (f>10 μm in length) | 7 MFL
Michigan | Effective date | 07/30/92
Montana | Public water supply requirement | | BNA 2001
Montana | MCL (f>10 μm in length) | 7 MFL
Nebraska | Drinking water standard | | BNA 2001
Nebraska | MCL (f>10 μm in length) | 7 MFL
Nebraska | Water quality standard | | BNA 2001
Nebraska | Water supply (f>10 μm in length) | 7 MFL
New Hampshire | Drinking water rule | | BNA 2001
New Hampshire | MCL (f>10 μm in length) | 7 MFL
New Hampshire | MCLG (f>10 μm in length) | 7 MFL
New Hampshire | Surface water quality regulation | | BNA 2001
New Hampshire | Water and fish ingestion | 7 MFL
New Mexico | Drinking water | | BNA 2001
New Mexico | MCL (f>10 μm in length) | 7 MFL
New York | Drinking water supplies | | BNA 2001
New York | MCL (f>10 μm in length) | 7 MFL
North Dakota | Public water supply systems | | BNA 2001
North Dakota | MCL (f>10 μm in length) | 7 MFL
Rhode Island | Groundwater quality standard | 7 MFL | BNA 2001
Rhode Island | Preventive action limit | 3.5 MFL
South Carolina | Drinking water | | BNA 2001
South Carolina | MCL (f>10 μm in length) | 7 MFL
South Carolina | Water quality criteria | | BNA 2001
South Carolina | Organism consumption | 7 MFL
South Dakota | Surface water quality standard | | BNA 2001
South Dakota | Human health value concentration | 7 MFL
Tennessee | Groundwater quality criteria | 7 MFL | BNA 2001
Tennessee | Public water systems | | BNA 2001
Tennessee | MCL (f>10 μm in length) | 7 MFL
Utah | Primary drinking water standard | | BNA 2001
Utah | MCL (f>10 μm in length) | 7 MFL
Vermont | Drinking water quality requirement | | BNA 2001
Vermont | MCL (f>10 μm in length) | 7 MFL
Vermont | MCLG (f>10 μm in length) | 7 MFL
Vermont | Groundwater quality standard | | BNA 2001
Vermont | Enforcement standard | 7 MFL
Vermont | Preventive action limit | 3.5 MFL
Washington | Public water supplies | | BNA 2001
Washington | MCL (f>10 μm in length) | 7 MFL
Wisconsin | Groundwater quality standard | | BNA 2001
Wisconsin | Enforcement standard | 7 MFL
Wisconsin | Preventive action limit | 0.7 MFL
c. Food | | No data
d. Other
California | Chemical known to cause cancer or reproductive toxicity | | BNA 2001
California | Effective date | 02/27/87
California | Hazardous substance | | BNA 2001
California | Identification and listing of hazardous waste—characteristics of toxicity | | BNA 2001
California | TTLC (wet-weight mg/kg) | 1.0 (as a percent)
Florida | Toxic substances in the workplace | | BNA 2001
Indiana | Regulations for asbestos hazards to the atmosphere and disposal of asbestos-containing waste; licenses asbestos personnel | | IDEM 2001b
Maine | Emissions standard | 200 pounds | BNA 2001
Massachusetts | Oil and hazardous material Toxic substance | | BNA 2001
Massachusetts | Toxic substance | | BNA 2001
New Jersey | Hazardous substance | | BNA 2001
New York | Occupation lung disease | | BNA 2001
New York | Hazardous substance—reportable quantity | | BNA 2001
New York | Air | 1 pound
New York | Land and water | 1 pound
Ohio | Toxic chemical list | | Ohio EPA 2001
Oregon | Toxic substance | | BNA 2001
Pennsylvania | Hazardous substance | | BNA 2001
South Carolina | Toxic pollutant | | BNA 2001

a Includes: Actinolite, amosite, anthophyllite, chrysotile, crocidolite, and tremolite.

b Group 1: Carcinogenic to humans

c Group A: Human carcinogen

d A1: Confirmed human carcinogen

ACGIH = American Conference of Governmental Industrial Hygienists; ADEQ = Arizona Department of Environmental Quality; BNA = Bureau of National Affairs; CDC = Center for Disease Control; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CPSC = Consumer Product Safety Commission; dHs = Department of Health Services; DHHS = Department of Health and Human Services; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FSTRAC = Federal-State Toxicology Risk Analysis Committee; HAP = Hazardous Air Pollutant; IARC = International Agency for Research on Cancer; IDEM = Indiana Department of Environmental Management; IRIS = Integrated Risk Information System;MCL = maximum contaminant level; MCLG = maximum contaminant level goal; MFL = million fibers per liter;NESHAP = National Emission Standards for Hazardous Air Pollutants; NIOSH = National Institute of Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration;PEL = permissible exposure limit; REL = recommended exposure limit; TLV = threshold limit value; TTLC = total threshold limit concentration; TWA = time-weighted average; USC = United States Code