# APPENDIX D RISK ASSESSMENT SUMMARY

## 1.0 LUNG CANCER

Most studies of the risk of asbestos-related lung cancer in occupationally exposed workers indicate that the dose-response relationship is best described by a relative risk model, given by the equation:

Relative Risk = 1.00 + K_L_ ⋅ ( cumulative dose )

Using this equation, EPA (1986a) calculated the value of K_L_ (the fractional increase in relative risk of lung cancer per f-yr/mL) for 14 sets of lung cancer mortality data from studies of workers in textile production, friction products manufacture, asbestos mining and milling, insulation products manufacture, and asbestos cement manufacture. The resulting values varied widely, ranging from 0.0006 (f-yr/mL)^−1^ (McDonald et al. 1980) to 0.067 (f-yr/mL)^−1^ (Finkelstein 1983). The geometric mean of all of the studies was 0.065 (f-yr/mL)^−1^. When studies involving mining and milling were excluded (these were judged to be less typical of the risks likely to be encountered in the environment), the resulting geometric mean value was 0.010 (f-yr/mL)^−1^. It is important to stress that this relates to fibers measured by PCM, and not to the total number of fibers measured by TEM.

Since this is a relative risk model, the absolute risk of lung cancer due to asbestos exposure depends not only on cumulative asbestos dose, but also on the underlying risk of lung cancer due to other causes:

Absolute Risk = Relative Risk × Underlying Risk

Based on national average lung cancer risk data for male and female smokers and nonsmokers, EPA (1986a) calculated that lifetime exposure to 0.0001 f/mL corresponded to the excess lung cancer risks tabulated in Table D-1.

For the purposes of preparing a simplified graphical display of cancer risk levels for presentation in Figure 3-1, risks from males and females were averaged, both for smokers and nonsmokers, and the cumulative doses corresponding to a lifetime lung cancer risk of 1×10^−4^ were calculated and shown in Table D-1.

## 2.0 MESOTHELIOMA

Several studies (e.g., Newhouse and Berry 1976; Nicholson et al. 1982; Peto et al. 1982) indicate that the risk of mesothelioma from a given level of exposure to asbestos depends primarily upon the time elapsed since exposure (latency), with risk increasing exponentially with time after a lag period of about 10 years. Based on this, EPA (1986a) fit exposure-incidence data from four studies (Finkelstein 1983; Peto 1980; Peto et al. 1982; Seidman 1984) to the following equation:

Incidence = K_M_ ⋅ f ⋅ [ ( T − 10 )^3^ − ( T − 10 − d )^3^ ]

where:

- K_M_ = empirical constant
- f = intensity of exposure (f/mL)
- T = latency (years since first exposure)
- d = duration of exposure (years)

Table D-1 Risk Assessment for Asbestos-associated Lung Cancer

| Smokers | | | Nonsmokers
Parameter | Male^a^ | Female^a^ | Average^b^ | Male^a^ | Female^a^ | Average^b^
Lung cancer risk from lifetime exposure to 0.0001 f/mL | 2.4×10^−5^ | 1.5×10^−5^ | 2.0×10^−5^ | 0.2×10^−5^ | 0.2×10^−5^ | 0.2×10^−5^
Concentration (f/mL) corresponding to lifetime excess risk level of 10^−4^ | | | 0.0005 | | | 0.005
Cumulative dose (f·yr/mL) for a 70-year exposure corresponding to 10^−4^ risk level | | | 0.035 | | | 0.35

a Source: EPA 1986a

b Average of males and females

The resulting values of K_M_ ranged from 1×10^−8^ to 3×10^−8^ for three of the studies, with one study (Finkelstein 1983) giving a higher value (12×10^−8^). Based on an analysis of the relative risk of mesothelioma compared to lung cancer in other studies, a value of 1×10^−8^ was identified as the most reasonable estimate for K_M_ (EPA 1986a). Although this value has considerable uncertainty (about a factor of 10), it can be used to make rough predictions of mesothelioma incidence at low exposure levels, similar to those likely to be encountered in the environment. Assuming lifetime continuous exposure to air containing 0.0001 f/mL, the expected incidence is 2 to 3 mesothelioma deaths per 100,000 persons (EPA 1986a), as shown in Table D-2.

For the purposes of preparing a simple graphical presentation of these risk estimates for inclusion in Figure 3-1, the data from all four groups were combined (since there is little difference between males and females or between smokers and nonsmokers), to yield an average 10^−4^ risk level of 3.1×10^−2^ f-yr/mL.

## 3.0 COMBINED RISK OF LUNG CANCER AND MESOTHELIOMA

The combined risk of lung cancer and mesothelioma has been estimated by EPA (IRIS 2001), based on the risk calculations presented in EPA (1986a). The average unit risk value was calculated as a composite value for males and females. The epidemiological data show that cigarette smoking and asbestos exposure interact synergistically for production of lung cancer and do not interact with regard to mesothelioma. The unit risk value is based on risks calculated using U.S. general population cancer rates and mortality patterns without consideration of smoking habits. The risks associated with occupational exposure were adjusted to continuous exposure by applying a factor of 140/50, based on the assumption of 20 m^3^/day (140 m^3^/week) for total ventilation and 10 m^3^/8-hour workday (40 m^3^/week) in the occupational setting. The results of these calculations indicate that a concentration of 4×10^−4^ f/mL corresponds to a lifetime excess risk level of 10^−4^. This combined risk estimate was not presented in Figure 3-1, since both the text and the Figure deal with lung cancer and mesothelioma separately.

The Health Effect Institute estimates lifetime cancer risks from lung cancer and mesothelioma combined based on levels of asbestos detected in 198 ACM-containing buildings (HEI 1991). These estimates, presented in Table D-3, should be interpreted with caution because of uncertainty associated with the estimation of average exposure levels and with the risk assessment model. The “high” levels represented in the table are approximately equal to the upper 95th percentile of the exposure levels detected. It should be noted that if the single highest public building sample was excluded from the calculation of the average exposure level, then the average value would be reduced from 0.0002 to 0.00008 TEM f/mL and risk would be similarly reduced by one half. The occupational exposure level of 0.1 f/mL is equivalent to the PEL proposed by OSHA. Actual worker exposures are expected to be lower.

Table D-2 Risk Assessment for Asbestos-related Mesothelioma

| Smokers | | Nonsmokers
Parameter | Male^a^ | Female^a^ | Male^a^ | Female^a^ | Average^b^
Risk of mesothelioma from lifetime exposure to 0.0001 f/mL | 1.8×10^−5^ | 2.5×10^−5^ | 2.2×10^−5^ | 2.7×10^−5^ | 2.2×10^−5^
Concentration (f/mL) corresponding to lifetime excess risk level of 10^−4^ | | | | | 0.00045
Cumulative dose (f·yr/mL) for a 70-year exposure corresponding to 10^−4^ risk level | | | | | 0.031

a Source: EPA 1986a

b Average of all four groups

Table D-3 Estimated Lifetime Risks of Lung Cancer and Mesothelioma Combined for Different Scenarios of Exposure to Airborne Asbestos Fibers

Conditions | Premature cancer deaths (lifetime risks) per million exposed persons (male and female)
Lifetime, continuous outdoor exposure
- 0.00001 TEM f/mL (2×10^−7^ PCM f/mL from birth rural | 4
- 0.0001 TEM f/mL (2×10^−6^ PCM f/mL) from birth (high urban) | 40
Exposure in a school containing ACM, from age 5 to 18 years
(180 days/year, 5 hours/day)
- 0.0005 TEM f/mL (8×10^−6^ PCM f/mL) (average) | 6
- 0.005 TEM f/mL (8×10^−5^ PCM f/mL) (high) | 60
Exposure in a public building containing ACM age 25 to 45 years (240 days/year, 8 hours/day)
- 0.0002 TEM f/mL (3×10^−6^ PCM f/mL) (average) | 4
- 0.002 TEM f/mL (3×10^−5^ PCM f/mL) (high) | 40
Occupational exposure from age 25 to 45
- 0.1 PCM f/mL (current occupational levels) | 2,000
- 10 PCM f/mL (historical industrial exposures) | 200,000

Source: HEI 1991

## 4.0 GASTROINTESTINAL CANCER

### 4.1 Risk Estimate Based on Animal Data

In a lifetime feeding study in rats, exposure to intermediate length chrysotile fibers led to an increased incidence of intestinal polyps (NTP 1985). Based on these data, EPA (1985b) calculated that the 10^−4^ risk level corresponded to an asbestos concentration of 7.1×10^8^ f/L in drinking water.

In order to present this risk estimate in Figure 3-4, the concentration of 7.1×10^8^ f/L was converted to a dose of 2.0×10^7^ f/kg/day (assuming ingestion of 2 L/day by a 70-kg adult), and this was converted to a dose of 0.16 mg/kg/day by dividing by 0.129×10^9^ f/mg (reported in NTP 1985).

### 4.2 Risk Estimate Based on Human Inhalation Data

Since there are no human studies in which ingestion of a known amount of asbestos can be associated with a clear increase in gastrointestinal cancer risk, NAS (1983) extrapolated data on gastrointestinal risk from epidemiological studies of workers exposed to asbestos by inhalation. These calculations indicated that lifetime ingestion of 1.1×10^6^ TEM fibers/liter of water corresponded to an excess gastrointestinal cancer risk of 10^−4^ (NAS 1983).

In order to present this risk estimate in Figure 3-4, the concentration of 1.1×10^6^ f/L was converted to a dose of 3.1×10^4^ f/kg/day (assuming ingestion of 2 L/day by a 70-kg adult), and this was converted to a dose of 1.6×10^−5^ mg/kg/day by multiplying by a factor of 5.0×10^−10^ mg/TEM fiber (NRC 1984).