# 9 REFERENCES

*Not cited in profile

Abernathy CO, Chappell WR, Meek ME, 1996. Is ingested inorganic arsenic a “threshold” carcinogen? Fundam Appl Toxicol 29(2):168–175.8742312
ACGIH. 2004. Arsenic. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Ademuyiwa O, Elsenhans B, Nguyen PT, 1996. Arsenic-copper interaction in the kidney of the rat: Influence of arsenic metabolites. Pharmacol Toxicol 78(3):154–160.8882348
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Adobe Lumber. 2002. Consumer information sheet for CCA pressure treated lumber. Adobe Lumber. http://www.adobelumber.com/ccaconsumer.shtml. August 27, 2007.
Adonis M, Martinez V, Marin P, 2005. CYP1A1 and GSTM1 genetic polymorphisms in lung cancer populations exposed to arsenic in drinking water. Xenobiotica 35(5):519–530.16012082
Agahian B, Lee JS, Nelson JH, 1990. Arsenic levels in fingernails as a biological indicator of exposure to arsenic. Am Ind Hyg Assoc J 51(12):646–651.2270832
Agency for Toxic Substances and Disease Registry. 1989. Agency for Toxic Substances and Disease Registry. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
Agency for Toxic Substances and Disease Registry. 1990a. Arsenic toxicity. Case studies in environmental medicine. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health & Human Services, Public Health Services. HE20.7917:5 504-U.
Agency for Toxic Substances and Disease Registry. 1990b. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Atlanta, GA: Subcommittee on Biomarkers of Organ Damage and Dysfunction, Agency for Toxic Substances and Disease Registry.
Aguilar MV, Martínez-Para MC, Gonzalez MJ. 1997. Effects of arsenic (V)-chromium (III) interaction on plasma glucose and cholesterol levels in growing rats. Ann Nutr Metab 41(3):189–195.9286469
Ahmad S, Anderson WL, Kitchin KT. 1999a. Dimethylarsinic acid effects on DNA damage and oxidative stress related biochemical parameters in B6C3F1 mice. Cancer Lett 139(2):129–135.10395169
Ahmad SA, Bandaranayake D, Khan AW, 1997. Arsenic contamination in ground water and arsenicosis in Bangladesh. Int J Environ Health Res 7(4):271–276.
Ahmad SA, Sayed MH, Barua S, 2001. Arsenic in drinking water and pregnancy outcomes. Environ Health Perspect 109(6):629–631.11445518
Ahmad SKA, Sayed MHSU, Hadi SA, 1999b. Arsenicosis in a village in Bangladesh. Int J Environ Health Res 9(3):187–195.
Ahsan H, Chen Y, Parvez F, 2006. Arsenic exposure from drinking water and risk of premalignant skin lesions in Bangladesh: Baseline results from the health effects of arsenic longitudinal study. Am J Epidemiol 163(12):1138–1148.16624965
Ahsan H, Perrin M, Rahman A, 2000. Associations between drinking water and urinary arsenic levels and skin lesions in Bangladesh. J Occup Environ Med 42(12):1195–1205.11125683
Akkari KH, Frans RE, Lavy TL. 1986. Factors affecting degradation of MSMA in soil. Weed Sci 34:781–787.
Alain G, Tousignant J, Rozenfarb E. 1993. Chronic arsenic toxicity. Int J Dermatol 32(12):899–901.8125698
Albores A, Cebrian ME, Bach PH, 1989. Sodium arsenite induced alterations in bilirubin excretion and heme metabolism. J Biochem Toxicol 4(2):73–78.2593134
Albores A, Koropatnick J, Cherian MG, 1992. Arsenic induces and enhances rat hepatic metallothionein production in vivo. Chem Biol Interact 85:127–140.1493605
Almela C, Algora S, Benito V, 2002. Heavy metal, total arsenic, and inorganic arsenic contents of algae food products. J Agric Food Chem 50:918–923.11829668
Altman PK, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III, 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Amacher DE, Paillet SC. 1980. Induction of trifluorothymidine-resistant mutants by metal ions in L5178Y/TK^*/-^ cells. Mutat Res 78:279–288.7432364
American Wood Preservers Association. 2007. FAQ’s: Treated wood uses. American Wood Preserver’s Association. http://www.awpa.com/references/faq.asp#uses. August 28, 2007.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically-based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically-based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson LCD, Bruland KW. 1991. Biogeochemistry of arsenic in natural waters: The importance of methylated species. Environ Sci Technol 25:420–427.
Anderson HA, Falk C, Hanrahan L, 1998. Profiles of Great Lakes critical pollutants: A sentinel analysis of human blood and urine. Environ Health Perspect 106(5):279–289.9560354
Andreae MO. 1977. Determination of arsenic species in natural waters. Anal Chem 49(6):820–823.855924
APHA. 1977. Tentative method of analysis for arsenic content of atmospheric particulate matter. In: Kate M, ed. Methods of air sampling and analysis. Washington, DC: American Public Health Association, 435–438.
APHA. 1989a. Arsenic. In: Clesceri LS, Greenberg AE, Trussell RR, eds. Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, 3–74-3–78.
APHA. 1989b. Metals by electrothermal atomic absorption spectrometry. In: Clesceri LS, Greenberg AE, Trussell RR, eds. Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, 3–32-3–50.
APHA. 1989c. Metals by hydride generation/atomic absorption spectrometry. In: Clesceri LS, Greenberg AE, Trussell RR, eds. Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, 3–43-3–50.
APHA. 1989d. Metals by plasma emission spectrometry. In: Clesceri LS, Greenberg AE, Trussell RR, eds. Standard methods for the examination of water and wastewater. 17th ed. Washington, DC: American Public Health Association, 3–53-3–78.
Aposhian HV. 1989. Biochemical toxicology of arsenic. Rev Biochem Toxicol 10:265–299.
*Aposhian HV. 1998. Mobilization of mercury and arsenic in humans by sodium 2,3-dimercapto-1-propane sulfonate (DMPS). Environ Health Perspect Suppl 106(4):1017–1025.
Aposhian HV, Arroyo A, Cebrian ME, 1997. DMPS-arsenic challenge test. I: Increased urinary excretion of monomethylarsonic acid in humans given dimercaptopropane sulfonate. J Pharmacol Exp Ther 282(1):192–200.9223554
Aposhian HV, Gurzau ES, Le XC, 2000a. Occurrence of monomethylarsonous acid in urine of humans exposed to inorganic arsenic. Chem Res Toxicol 13(8):693–697.10956055
Aposhian HV, Zheng B, Aposhian MM, 2000b. DMPS-arsenic challenge test. 11. Modulation of arsenic species, including monomethylarsonous acid (MMA)(111), excreted in human urine. Toxicol Appl Pharmacol 165(1):74–83.10814555
*Apostoli P, Alessio L, Romeo L, 1997. Metabolism of arsenic after acute occupational arsine intoxication. J Toxicol Environ Health 52(4):331–342.9354178
Apostoli P, Bartoli D, Alessio L, 1999. Biological monitoring of occupational exposure to inorganic arsenic. Occup Environ Med 56(12):825–832.10658539
Aranyi C, Bradof JN, O'Shea WJ, 1985. Effects of arsenic trioxide inhalation exposure on pulmonary antibacterial defenses in mice. J Toxicol Environ Health 15:163–172.3884825
*Arbouine MW, Wilson HK. 1992. The effect of seafood consumption on the assessment of occupational exposure to arsenic by urinary arsenic speciation measurements. J Trace Elem Electrolytes Health Dis 6(3):153–160.1483034
Arenas V, Stoeppler M, Bergerhoff G. 1988. Arsenic determination in the ultratrace range by atomic absorption spectrometry after preconcentration of the hydride. Fresenius Z Anal Chem 332:447–452.
*Armbrust KL, Bridges DC. 2002. Dissipation of monosodium methane arsonate (MSMA) on peanuts. J Agric Food Chem 50(7):1959–1963 11902940
Armienta MA, Rodriguez R, Cruz O. 1997. Arsenic content in hair of people exposed to natural arsenic polluted groundwater at Zimapan, Mexico. Bull Environ Contam Toxicol 59:583–589.9307423
Armstrong CW, Stroube RB, Rubio T, 1984. Outbreak of fatal arsenic poisoning caused by contaminated drinking water. Arch Environ Health 39(4):276–279.6497443
Arnold LL, Cano M, St. John M, 1999. Effects of dietary dimethylarsinic acid on the urine and urothelium of rats. Carcinogenesis 20(11):2171–2179.10545422
Arnold LL, Eldan M, Nyska A, 2006. Dimethylarsinic acid: Results of chronic toxicity/oncogenicity studies in F344 rats and B6C3F1 mice. Toxicology 223(1–2):82–100.16677751
Arnold LL, Eldan M, van Gemert M, 2003. Chronic studies evaluating the carcinogenicity of monomethylarsonic acid in rats and mice. Toxicology 190:197–219.12927375
Aschengrau A, Zierler S, Cohen A. 1989. Quality of community drinking water and the occurrence of spontaneous abortion. Arch Environ Health 44(5):283–290.2554824
Aurillo AC, Mason RP, Hemond HF. 1994. Speciation and fate of arsenic in three lakes of the Aberjona Watershed. Environ Sci Tech 28(4):577–585.
Axelson O, Dahlgren E, Jansson C-D, 1978. Arsenic exposure and mortality: A case referent study from a Swedish copper smelter. Br J Ind Med 35:8–15.629894
Azcue JM, Nriagu JO. 1994. Arsenic: Historical perspectives. In: Nriagu JO, ed. Arsenic in the Environment, part 1: Cycling and characterization. New York, NY: John Wiley and Sons, Inc., 1–15.
Babich H, Martin-Alguacil N, Borenfreund E. 1989. Arsenic-selenium interactions determined with cultured fish cells. Toxicol Lett 45:157–164.2919396
Bagla P, Kaiser J. 1996. India's spreading health crisis draws global arsenic experts. Science 274(5285):174–175.8927976
Baker BA, Topliff AR, Messing RB, 2005. Persistent neuropathy and hyperkeratosis from distant arsenic exposure. J Agromedicine 10(4):43–54.16702122
*Baker EL, Hayes CG, Landrigan PJ, 1977. A nationwide survey of heavy metal absorption in children living near primary copper, lead, and zinc smelters. Am J Epidemiol 106(4):261–273.910795
Baker LW, Fitzell DL, Seiber JN, 1996. Ambient air concentrations of pesticides in California. Environ Sci Tech 30(4):1365–1368.
*Barbaud A, Mougeolle JM, Schmutz JL. 1995. Contact hypersensitivity to arsenic in a crystal factory worker. Contact Dermatitis 33(4):272–273.8654085
Barbey JT, Pezzullo JC, Soignet SL. 2003. Effect of arsenic trioxide on QT interval in patients with advanced malignancies. J Clin Oncol 21(19):3609–15.14512391
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Baroni C, van Esch GJ, Saffiotti U. 1963. Carcinogenic tests of two inorganic arsenicals. Arch Environ Health 7:668–674.14077213
Bartolome B, Cordoba S, Nieto S, 1999. Acute arsenic poisoning: Clinical and histopathological features. Br J Dermatol 141:1106–1109.10606861
Barton EN, Gilbert DT, Raju K, 1992. Arsenic: The forgotten poison? West Indian Med J 41(1):36–38.1314470
Bashir S, Sharma Y, Irshad M, 2006. Arsenic induced apoptosis in rat liver following repeated 60 days exposure. Toxicology 217(1):63–70.16288947
Basu A, Ghosh P, Das JK, 2004. Micronuclei as biomarkers of carcinogen exposure in populations exposed to arsenic through drinking water in West Bengal, India: A comparative study in three cell types. Cancer Epidemiol Biomarkers Prev 13(5):820–827.15159315
Bates MN, Rey OA, Biggs ML, 2004. Case-control study of bladder cancer and exposure to arsenic in Argentina. Am J Epidemiol 159(4):381–389.14769642
*Bates MN, Smith AH, Cantor KP. 1995. Case-control study of bladder cancer and arsenic in drinking water. Am J Epidemiol 141(6):523–530.7900719
Battista G, Bartoli D, Iaia TE, 1996. Art glassware and sinonasal cancer: Report of three cases. Am J Ind Med 30(1):31–35.8837679
Baxley MN, Hood RD, Vedel GC, 1981. Prenatal toxicity of orally administered sodium arsenite in mice. Bull Environ Contam Toxicol 26:749–756.6894881
Beane Freeman LE, Dennis LK, Lynch CF, 2004. Toenail arsenic content and cutaneous melanoma in Iowa. Am J Epidemiol 160(7):679–687.15383412
Beauchemin D, Bednas ME, Berman SS, 1988. Identification and quantitation of arsenic species in a dogfish muscle reference material for trace elements. Anal Chem 60:2209–2212.3239793
Beaudoin AR. 1974. Teratogenicity of sodium arsenate in rats. Teratology 10:153–158.4428424
Beck B, Boardman PD, Hook GC, 1995. Response to Smith et al. Arsenic risk assessment. Environ Health Perspect 103:15–17.7614938
Beckett WS, Moore JL, Keogh JP, 1986. Acute encephalopathy due to occupational exposure to arsenic. Br J Ind Med 43:66–67.3947565
Beckman L, Nordenson I. 1986. Interaction between some common genotoxic agents. Hum Hered 36:397–401.3793119
Beckman G, Beckman L, Nordenson I. 1977. Chromosome aberrations in workers exposed to arsenic. Environ Health Perspect 19(5–6):145–146.908292
Beerman DH. 1994. Growth regulators (animal). In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 12. New York, NY: John Wiley and Sons, 795–815.
Bekemeier H, Hirschelmann R. 1989. Reactivity of resistance blood vessels ex vivo after administration of toxic chemicals to laboratory animals: Arteriolotoxicity. Toxicol Lett 49:49–54.2815114
Bencko V. 2005. Hair and exposure to environmental pollutants. In: Tobin DJ, eds. Hair in toxicology: An important bio-marker. Cambridge, MA: RSC Publishing, 159–174.
Bencko V, Symon K. 1977. Health aspects of burning coal with a high arsenic content 1. Arsenic in hair, urine, and blood in children residing in a polluted area. Environ Res 13:378–385.880934
Bencko V, Franek P, Rames J. 2005. Non-melanoma skin and lung cancer incidence in relation to arsenic exposure: 20 years of observation. In: Edler L, Kitsos CP, eds. Recent advances in quantitative methods in cancer and human health risk assessment. West Sussex, England: John Wiley & Sons, 383–394.
Bencko V, Geist T, Arbetová D, 1986. Biological monitoring of environmental pollution and human exposure to some trace elements. J Hyg Epidemiol Microbiol Immunol 30(1):1–10.
Bencko V, Symon K, Chlader V, 1977. Health aspects of burning coal with a high arsenic content II. Hearing changes in exposed children. Environ Res 13:386–395.880935
Bencko V, Symon K, Stalnik L, 1980. Rate of malignant tumor mortality among coal burning power plant workers occupationally exposed to arsenic. J Hyg Epidemiol Microbiol Immunol 24(3):278–284.
Bencko V, Wagner V, Wagnerová M, 1988. Immunological profiles in workers of a power plant burning coal rich in arsenic content. J Hyg Epidemiol Microbiol Immunol 32:137–146.
*Bennett BG. 1986. Exposure assessment for metals involved in carcinogenesis. IARC Sci Publ 71(8):115–127.
Benramdane L, Accominotti M, Fanton L, 1999a. Arsenic speciation in human organs following fatal arsenic trioxide poisoning--a case report. Clin Chem 45(2):301–306.9931060
Benramdane L, Bressolle F, Vallon J-J. 1999b. Arsenic speciation in humans and food products: A review. J Chromatogr Sci 37:330–344.10497786
Benson AA. 1989. Arsonium compounds in algae. Proc Natl Acad Sci USA 86:6131–6132.16594059
Berg M, Tran HC, Nguyen TC, 2001. Arsenic contamination of groundwater and drinking water in Vietnam: A human health threat. Environ Sci Technol 35(13):2621–2626.11452583
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
*Berry MR, Johnson LS, Jones JW, 1997. Dietary characterizations in a study of human exposures in the lower Rio Grande Valley: I. Foods and beverages. Environ Int 23(5):675–692.
Berti PR, Receveur O, Chan HM, 1998. Dietary exposure to chemical contaminants from traditional food among adult dene/métis in the western Northwest territories, Canada. Environ Res A 76:131–142.
Bertolero F, Pozzi G, Sabbioni E, 1987. Cellular uptake and metabolic reduction of pentavalent to trivalent arsenic as determinants of cytotoxicity and morphological transformation. Carcinogenesis 8:803–808.3608077
Bettley FR, O'Shea JA. 1975. The absorption of arsenic and its relation to carcinoma. Br J Dermatol 92:563–568.1174468
Bhumbla DK, Keefer RF. 1994. Arsenic mobilization and bioavailability in soils. In: Nriagu JO, ed. Arsenic in the environment, part 1: Cycling and characterization. New York, NY: John Wiley & Sons, Inc., 51–82.
Bickley LK, Papa CM. 1989. Chronic arsenicism with vitiligo, hyperthyroidism, and cancer. N J Med 86(5):377–380.2739949
*Biggs ML, Kalman DA, Moore LE, 1997. Relationship of urinary arsenic to intake estimates and a biomarker of effect, bladder cell micronuclei. Mutat Res 386(3):185–195.9219557
*Binder S, Forney D, Kaye W, 1987. Arsenic exposure in children living near a former copper smelter. Bull Environ Contam Toxicol 39:114–121.3607308
Bird MJ, MacIntosh DL, Williams PL. 2004. Occupational exposures during routine activities in coal-fueled power plants. J Occup Environ Hyg 1:403–413.15238330
Biswas BK, Dhar RK, Samanta G, 1998. Detailed study report of Samta, one of the arsenic-affected villages of Jessore District, Bangladesh. Curr Sci 74(2):134–145.
Biswas S, Talukder G, Sharma A. 1999. Prevention of cytotoxic effects of arsenic by short-term dietary supplementation with selenium in mice in vivo. Mutat Res 441:155–160.10224332
Blakley BR. 1987. Alterations in urethan-induced adenoma formation in mice exposed to selenium and arsenic. Drug Nutr Interact 5:97–102.3608832
Bloch P, Shapiro IM. 1986. An x-ray fluorescence technique to measure in situ the heavy metal burdens of persons exposed to these elements in the workplace. J Occup Med 28(8):609–614.3018206
Blom S, Lagerkvist B, Linderholm H. 1985. Arsenic exposure to smelter workers: Clinical and neurophysiological studies. Scand J Work Environ Health 11:265–269.2997912
Bodwell JE, Gosse JA, Nomikos AP, 2006. Arsenic disruption of steroid receptor gene activation: Complex dose-response effects are shared by several steroid receptors. Chem Res Toxicol 19:1619–1629.17173375
Bodwell JE, Kingsley LA, Hamilton JW. 2004. Arsenic at very low concentrations alters glucocorticoid receptor (GR)-mediated gene activation but not GR-mediated gene repression: Complex dose-response effects are closely correlated with levels of activated GR and require a functional GR DNA binding domain. Chem Res Toxicol 17:1064–1076.15310238
Bolla-Wilson K, Bleecker ML. 1987. Neuropsychological impairment following inorganic arsenic exposure. J Occup Med 29(6):500–503.3612324
Bolliger CT, van Zijl P, Louw JA. 1992. Multiple organ failure with the adult respiratory distress syndrome in homicidal arsenic poisoning. Respiration 59(1):57–61.1315982
Bonnevie NL, Huntley SL, Found BW, 1994. Trace metal contamination in surficial sediments from Newark Bay, New Jersey. Sci Total Environ 144:1–16.
Borgoño JM, Greiber R. 1972. Epidemiological study of arsenicism in the city of Antofagasta. Trace Subst Environ Health 5:13–24.
Borgoño JM, Venturino H, Vicent P. 1980. [Clinical and epidemiological study of arsenism in northern Chile.] Rev Med Chile 108:1039–1048. (Spanish).7244449
*Börzsönyi M, Bereczky A, Rudnai P, 1992. Epidemiological studies on human subjects exposed to arsenic in drinking water in southeast Hungary [letter]. Arch Toxicol 66(1):77–78.1580796
Bourrain JL, Morin C, Béani JC, 1998. Airborne contact dermatitis from cacodylic acid. Contact Dermatitis 38(6):364–365.9687061
Boutwell RK. 1963. A carcinogenicity evaluation of potassium arsenite and arsanilic acid. Agric Food Chem 11:381–385.
Braman RS, Foreback CC. 1973. Methylated forms of arsenic in the environment. Science 182:1247–1249.4800529
Braman RS, Johnson DL, Foreback CC, 1977. Separation and determination of nanogram amounts of inorganic arsenic and methylarsenic compounds. Anal Chem 49(4):621–625.848769
*Braun W. 1958. Carcinoma of the skin and the internal organs caused by arsenic. German Med Monthly 3:321–324.
*Brenard R, Laterre PF, Reynaert M, 1996. Increased hepatocytic mitotic activity as a diagnostic marker of acute arsenic intoxication: A report of two cases. J Hepato 25(2):218–220.
Brender JD, Suarez L, Felkner M, 2006. Maternal exposure to arsenic, cadmium, lead, and mercury and neural tube defects in offspring. Environ Res 101(1):132–139.16171797
Breslin VT, Adler-Ivanbrook L. 1998. Release of copper, chromium and arsenic from CCA-C treated lumber in estuaries. Estuarine Coastal Shelf Sci 46:111–125.
Brooks KM. 1996. Evaluating the environmental risks associated with the use of chromated copper arsenate-treated wood products in aquatic environments. Estuaries 19(2A):296–305.
Broomhall J, Kovar IZ. 1986. Environmental pollutants in breast milk. Rev Environ Health 6(1–4):311–337.3321244
Brouwer OF, Onkenhout W, Edelbroek PM, 1992. Increased neurotoxicity of arsenic in methylenetetrahydrofolate reductase deficiency. Clin Neurol Neurosurg 94(4):307–310.1335858
Brown CC, Chu KC. 1982. Environmental epidemiology: Risk assessment: Proceedings of a conference. In: Prentice RL, Whittemore AS, eds. Philadelphia, PA: Society for Industrial and Applied Mathematics, 94–106.
Brown CC, Chu KC. 1983a. A new method for the analysis of cohort studies: Implications of the multistage theory of carcinogenesis applied to occupational arsenic exposure. Environ Health Perspect 50:293–308.6873020
Brown CC, Chu KC. 1983b. Implications of the multistage theory of carcinogenesis applied to occupational arsenic exposure. J Natl Cancer Inst 70(3):455–463.6572736
Brown EJ, Button DK. 1979. A simple method of arsenic speciation. Bull Environ Contam Toxicol 21:37–42.444707
Brown JL, Kitchin KT. 1996. Arsenite, but not cadmium, induces ornithine decarboxylase and heme oxygenase activity in rat liver: Relevance to arsenic carcinogenesis. Cancer Lett 98:227–231.8556713
Brown KG, Guo H-R, Greene HL. 1997a. Uncertainty in cancer risk at low doses of inorganic arsenic. Hum Ecol Risk Assess 3(3):351–362.
Brown KG, Guo H-R, Kuo T-L, 1997b. Skin cancer and inorganic arsenic: Uncertainty-status of risk. Risk Anal 17(1):37–42.9131824
Brown JL, Kitchin KT, George M. 1997c. Dimethylarsinic acid treatment alters six different rat biochemical parameters: Relevance to arsenic carcinogenesis. Teratog Carcinog Mutagen 17:71–84.9261921
Brown LM, Pottern LM, Blot WJ. 1984. Lung cancer in relation to environmental pollutants emitted from industrial sources. Environ Res 34:250–261.6745227
Brown MM, Rhyne BC, Goyer RA, 1976. Intracellular effects of chronic arsenic administration on renal proximal tubule cells. J Toxicol Environ Health 1:505–514.1246090
Brown RM, Newton D, Pickford CJ, 1990. Human metabolism of arsenobetaine ingested with fish. Hum Exp Toxicol 9:41–46.2328148
Bruce BW, McMahon PB. 1996. Shallow ground-water quality beneath a major urban center: Denver, Colorado, USA. J Hydrol 186:129–151.
Brumbaugh WG, Ingersoll CG, Kemble NE, 1994. Chemical characterization of sediments and pore water from the upper Clark Fork River and Milltown Reservoir, Montana. Environ Toxicol Chem 13(12):1971–1983.
*Brune O, Nordberg G, Wester PO. 1980. Distribution of 23 elements in kidney, liver and lung of a control group in Northern Sweden and of exposed workers from a smelter and refinery. Sci Total Environ 16:13–35.7433969
Buchancová J, Klimentova G, Knizkova M, 1998. Health status of workers of a thermal power station exposed for prolonged periods to arsenic and other elements from fuel. Cent Eur J Public Health 6(1):29–36.9524739
Buchet JP, Lauwerys R. 1985. Study of inorganic arsenic methylation by rat liver in vitro: Relevance for the interpretation of observations in man. Arch Toxicol 57:125–129.4026571
Buchet JP, Lauwerys R. 1987. Study of factors influencing the in vivo methylation of inorganic arsenic in rats. Toxicol Appl Pharmacol 91:65–74.3672518
Buchet JP, Lauwerys R. 1988. Role of thiols in the in vitro methylation of inorganic arsenic by rat liver cytosol. Biochem Pharmacol 37(16):3149–3153.3401245
Buchet JP, Lison D. 1998. Mortality by cancer in groups of the Belgian population with a moderately increased intake of arsenic. Int Arch Occup Environ Health 71(2):125–130.9553788
Buchet JP, Lauwerys R, Mahieu P, 1982. Inorganic arsenic metabolism in man. Arch Toxicol Suppl 5:326–327.
Buchet JP, Lauwerys R, Roels H. 1981a. Comparison of the urinary excretion of arsenic metabolites after a single oral dose of sodium arsenite, monomethylarsonate or dimethylarsinate in man. Int Arch Occup Environ Health 48:71–79.6894292
Buchet JP, Lauwerys R, Roels H. 1981b. Urinary excretion of inorganic arsenic and its metabolites after repeated ingestion of sodium metaarsenite by volunteers. Int Arch Occup Environ Health 48:111–118.6894910
*Buchet JP, Lison D, Ruggeri M, 1996b. Assessment of exposure to inorganic arsenic, a human carcinogen, due to the consumption of seafood. Arch Toxicol 70(11):773–778.8896724
Buchet JP, Pauwels J, Lauwerys R. 1994. Assessment of exposure to inorganic arsenic following ingestion of marine organisms by volunteers. Environ Res 66(1):44–51.8013437
*Buchet JP, Staessen J, Roels H, 1996a. Geographical and temporal differences in the urinary excretion of inorganic arsenic: A Belgian population study. Occup Environ Med 53(5):320–327.8673179
Budavari S, O'Neil MJ, Smith A, , eds. 2001. The Merck index an encyclopedia of chemicals, drugs and biologicals. 13th ed. Whitehouse Station, NJ: Merck & Co., Inc., 440, 462.
Bulbulyan MA, Jourenkova NJ, Boffetta P, 1996. Mortality in a cohort of Russian fertilizer workers. Scand J Work Environ Health 22(1):27–33.
Burgdorf W, Kurvink K, Cervenka J. 1977. Elevated sister chromatid exchange rate in lymphocytes of subjects treated with arsenic. Hum Genet 36:69–72.870411
Burger J, Dixon C, Shukla T, 2003. Metals in horseshoe crabs from Delaware Bay. Arch Environ Contam Toxicol 44:36–42.12434217
Burger J, Gaines KF, Boring CS, 2002. Metal levels in fish from the Savannah River: Potential hazards to fish and other receptors. Environ Res 89:85–97.12051789
*Burger J, Gochfeld M, Rooney AA, 2000. Metals and metalloids in tissues of American alligators in three Florida lakes. Arch Environ Contam Toxicol 38:501–508.10787102
Burkhard EG, Dutkiewicz VA, Husain L. 1994. A study of SO_2_, SO_4_^2^ and trace elements in clear air and clouds above the midwestern United States. Atmos Environ 28(8):1521–1533.
Burlo F, Guijarro I, Carbonell-Barrachina AA, 1999. Arsenic species: Effects on and accumulation by tomato plants. J Agric Food Chem 47:1247–1253.10552445
Burns LA, Munson AE. 1993. Gallium arsenide selectively inhibits T cell proliferation and alters expression of CD25 (IL-2R/P55). J Pharmacol Exp Ther 265(1):178–186.8097242
Butler ECV. 1988. Determination of inorganic arsenic species in aqueous samples by ion-exclusion chromatography with electrochemical detection. J Chromatogr 450:353–360.
Butte W, Heinzow B. 2002. Pollutants in house dust as indicators of indoor contamination. Rev Environ Contam Toxicol 175:1–46.12206053
Byrd DM, Roegner ML, Griffiths JC, 1996. Carcinogenic risks of inorganic arsenic in perspective. Int Arch Occup Environ Health 68(6):484–494.8891790
Byron WR, Bierbower GW, Brouwer JB, 1967. Pathologic changes in rats and dogs from two-year feeding of sodium arsenite or sodium arsenate. Toxicol Appl Pharmacol 10:132–147.6031922
*Caffery-Nolan RE, McCoy KL. 1998. Direct exposure to gallium arsenide upregulates costimulatory activity of murine macrophages. Toxicol Appl Pharmacol 151:330–339.9707509
Calderón J, Navarro ME, Jimenez-Capdeville ME, 2001. Exposure to arsenic and lead an neuropsychological development in Mexican children. Environ Res 85(Section A):69–76.
Calderon RL, Hudgens E, Le CX, 1999. Excretion of arsenic in urine as a function of exposure to arsenic in drinking water. Environ Health Perspect 107:663–667.10417365
Campbell JP, Alvarez JA. 1989. Acute arsenic intoxication. Am Fam Physician 40(6):93–97.
Cannon JR, Edmonds JS, Francesconi KA, 1981. Isolation, crystal structure and synthesis of arsenobetaine, a constituent of the western rock lobster, the dusty shark, and some samples of human urine. Aust J Chem 34:787–798.
Cannon JR, Saunders JB, Toia RF. 1983. Isolation and preliminary toxicological evaluation of arsenobetaine- the water-soluble arsenical constituent from the hepatopancreas of the western rock lobster. Sci Total Environ 31:181–185.6362002
Capar SG, Cunningham WC. 2000. Element and radionuclide concentrations in food: FDA Total Diet Study 1991–1996. J AOAC Int 83:157–177.10693017
Carapella SC. 1992. Arsenic and arsenic alloys. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 3. New York, NY: John Wiley and Sons, 624–633.
Carbonell-Barrachina AA, Burló F, Valero D, 1999. Arsenic toxicity and accumulation in turnip as affected by arsenic chemical speciation. J Agric Food Chem 47:2288–2294.10794624
Carbonell-Barrachina AA, Jugsujinda A, Burlo F, 2000. Arsenic chemistry in municipal sewage sludge as affected by redox potential and pH. Water Res 34:216–224.
Carlson-Lynch H, Beck BD, Boardman PD. 1994. Arsenic risk assessment. Environ Health Perspect 102(4):354–356.7503825
Carpenter SJ. 1987. Developmental analysis of cephalic axial dysraphic disorders in arsenic-treated hamster embryos. Anat Embryol 176:345–365.
Casto BC, Meyers J, DiPaolo JA. 1979. Enhancement of viral transformation for evaluation of the carcinogenic or mutagenic potential of inorganic metal salts. Cancer Res 39:193–198.570089
Cebrián ME, Albores A, Aguilar M, 1983. Chronic arsenic poisoning in the north of Mexico. Hum Toxicol 2:121–133.6840787
Chaineau E, Binet S, Pol D, 1990. Embryotoxic effects of sodium arsenite and sodium arsenate on mouse embryos in culture. Teratology 41:105–112.2305370
Chakraborti D, Hussam A, Alauddin M. 2003b. Arsenic: Environmental health aspects with special reference to groundwater in South Asia. J Environ Sci Health Part A 38(1):xi-xv.
Chakraborti D, Mukherjee SC, Pati S, 2003c. Arsenic groundwater contamination in Middle Ganga Plain, Bihar, India: A future danger? Environ Health Perspect 111:1194–1201.12842773
Chakraborti D, Mukherjee SC, Saha KC, 2003a. Arsenic toxicity from homeopathic treatment. J Toxicol Clin Toxicol 41(7):963–967.14705842
Chakraborty AK, Saha KC. 1987. Arsenical dermatosis from tubewell water in west Bengal. Indian J Med Res 85:326–334.2956191
Chan PC, Huff J. 1997. Arsenic carcinogenesis in animals and in humans: Mechanistic, experimental, and epidemiological evidence. J Environ Health Sci, C15(2):83–122.
Chan TYK. 1994. The prevalence use and harmful potential of some Chinese herbal medicines in babies and children. Vet Hum Toxicol 36(3):238–240.8066974
Chang CC, Ho SC, Tsai SS, 2004. Ischemic heart disease mortality reduction in an arseniasis-endemic area in southwestern Taiwan after a switch in the tap-water supply system. J Toxicol Environ Health A 67(17):1353–1361.15371236
Chao CC. 1996. Inhibition by arsenite of anticancer drug cis-diamminedichloroplatinum(II) induced DNA repair and drug resistance in HeLa cells. Environ Toxicol Pharmacol 1(3):199–205.21781682
Chappell WR, Beck BD, Brown KG, 1997. Inorganic arsenic: A need and an opportunity to improve risk assessment. Environ Health Perspect 105(10):1060–1067.9349827
Charbonneau SM, Spencer K, Bryce F, 1978. Arsenic excretion by monkeys dosed with arsenic-containing fish or with inorganic arsenic. Bull Environ Contam Toxicol 20:470–477.102385
Chattopadhyay S, Ghosh S, Debnath J, 2001. Protection of sodium arsenite-induced ovarian toxicity by coadministration of L-ascorbate (vitamin C) in mature wistar strain rat. Arch Environ Contam Toxicol 41(1):83–89.11385593
ChemIDplus. 2007. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. August 28, 2007.
Chen CJ, Wang CJ. 1990. Ecological correlation between arsenic level in well water and age-adjusted mortality from malignant neoplasms. Cancer Res 50:5470–5474.2386951
*Chen CL, Whanger PD. 1994. Interaction of selenium and arsenic with metallothionein: Effect of vitamin B12. J Inorg Biochem 54(4):267–276.8014637
Chen CJ, Chen CW, Wu MM, 1992. Cancer potential in liver, lung, bladder and kidney due to ingested inorganic arsenic in drinking water. Br J Cancer 66(5):888–892.1419632
Chen CJ, Chiou HY, Chiang MH, 1996. Dose-response relationship between ischemic heart disease mortality and long-term arsenic exposure. Arterioscler Thromb Vasc Biol 16(4):504–510.8624771
Chen CJ, Chuang YC, Lin TM, 1985. Malignant neoplasms among residents of a blackfoot disease-endemic area in Taiwan: High-arsenic artesian well water and cancers. Cancer Res 45:5895–5899.4053060
Chen CJ, Chuang YC, You SL, 1986. A retrospective study on malignant neoplasms of bladder, lung and liver in blackfoot disease endemic area in Taiwan. Br J Cancer 53:399–405.3964542
Chen CJ, Hsu LI, Shih WL, 2005. Biomarkers of exposure, effect, and susceptibility of arsenic-induced health hazards in Taiwan. Toxicol Appl Pharmacol 206(2):198–206.15967209
Chen CJ, Hsueh YM, Lai MS, 1995. Increased prevalence of hypertension and long-term arsenic exposure. Hypertension 25(1):53–60.7843753
Chen CJ, Kuo T-L, Wu MM. 1988a. Arsenic and cancers [Letter]. Lancet (February 20):414–415.
Chen CJ, Wu MM, Lee SS, 1988b. Atherogenicity and carcinogenicity of high-arsenic artesian well water: Multiple risk factors and related malignant neoplasms of blackfoot disease. Arteriosclerosis 8:452–460.3190552
*Chen KS, Huang CC, Liaw CC, 1988c. [Multiple primary cancers in blackfoot endemic area: Report of a case.] J Formosan Med Assoc 87:1125–1128. (Chinese)
Chen M, Ma LQ, Harris WG. 1999. Baseline concentrations of 15 trace elements in Florida surface soils. J Environ Qual 28:1173–81.
Chen Y, Ahsan H, Parvez F, 2004. Validity of a food-frequency questionnaire for a large prospective cohort study in Bangladesh. Br J Nutr 92(5):851–859.15533275
Chen YC, Guo YL, Su HJ, 2003. Arsenic methylation and skin cancer risk in southwestern Taiwan. J Occup Environ Med 45(3):241–248.12661181
Chernoff N, Setzer W, Miller DB, 1990. Effects of chemically induced maternal toxicity on prenatal development in the rat. Teratology 42:651–658.2087686
Chhuttani PN, Chawla LS, Sharma TD. 1967. Arsenical neuropathy. Neurology 17:269–274.6066957
*Ch’i I, Blackwell RQ. 1968. A controlled retrospective study of blackfoot disease, an endemic peripheral gangrene disease in Taiwan. Am J Epidemiol 88(1):7–24.5661537
Chiang CE, Luk HN, Wang TM, 2002. Prolongation of cardiac repolarization by arsenic trioxide. Blood 100(6):2249–2252.12200393
*Chiang HS, Hong CL, Guo HR, 1988. Comparative study on the high prevalence of bladder cancer in the blackfoot disease endemic area in Taiwan. J Formosan Med Assoc 87(11):1074–1080.
Chiba M, Masironi R. 1992. Toxic and trace elements in tobacco and tobacco smoke. Bull WHO 70(2):269–275.1600587
Flameproof Chicago. 2000. Pressure-treated Supatimber. Montgomery, IL: Chicago Flameproof. http://www.chicagoflameproof.com/supatimber.html. July 29, 2005.
Chilvers DC, Peterson PJ. 1987. Global cycling of arsenic. In: Hutchinson TC, Meema KM, eds. Lead, mercury, cadmium and arsenic in the environment. New York, NY: John Wiley & Sons, 279–301.
Chiou HY, Chiou ST, Hsu YH, 2001. Incidence of transitional cell carcinoma and arsenic in drinking water: A follow-up study of 8,102 residents in an arseniasis-endemic area in northeastern Taiwan. Am J Epidemiol 153(5):411–418.11226969
Chiou HY, Hsueh YM, Liaw KF, 1995. Incidence of internal cancers and ingested inorganic arsenic: A seven-year follow-up study in Taiwan. Cancer Res 55(6):1296–1300.7882325
Chiou HY, Huang WI, Su CL, 1997. Dose-response relationship between prevalence of cerebrovascular disease and ingested inorganic arsenic. Stroke 28(9):1717–1723.9303014
Chirenje T, Ma LQ, Clark C, 2003a. Cu, Cr and As distribution in soils adjacent to pressure-treated decks, fences and poles. Environ Pollut 124(3):407–417.12758021
Chirenje T, Ma LQ, Szulczewski M, 2003b. Arsenic distribution in Florida urban soils: Comparison between Gainsville and Miami. J Environ Qual 32:109–119.12549549
*Chiu HF, Ho SC, LY, 2004. Does arsenic exposure increase the risk for liver cancer? J Toxicol Environ Health A 67(19):1491–1500.15371225
Choucair AK, Ajax ET. 1988. Hair and nails in arsenical neuropathy. Ann Neurol 23(6):628–629.2841904
Chow NH, Guo YL, Lin JSN, 1997. Clinicopathological features of bladder cancer associated with chronic exposure to arsenic. Br J Cancer 75(11):1708–1710.9184192
Chowdhury UK, Biswas BK, Chowdhury TR, 2000. Groundwater arsenic contamination in Bangladesh and West Bengel, India. Environ Health Perspect 108(5):393–397.10811564
Christian JW, Hopenhayn C, Centeno JA, 2006. Distribution of urinary selenium and arsenic among pregnant women exposed to arsenic in drinking water. Environ Res 100(1):115–122.16337848
Chun JS, Killeen JC. 1989a. Salmonella/mammalian-microsome plate incorporation mutagenicity assay (Ames test) with and without metabolic activation with methanearsonic acid (MAA). Fermenta ASC Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41651902.
Chun JS, Killeen JC. 1989b. In vitro chromosomal aberration assay in Chinese hamster ovary (CBO) cells with methanarsonic acid (MAA). Fermenta ASC Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41651903.
Chun JS, Killeen JC. 1989c. L5178Y TK^*/-^ mouse lymphoma mutagenesis assay with methanearsonic acid. Fermenta ASC Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41651904.
Chun JS, Killeen JC. 1989d. Unscheduled DNA synthesis assay in rat primary hepatocytes with methanearsonic acid (MAA). Fermenta ASC Corporation. Submitted to the U.S. Environmental Protection Agency. MRID41651905.
Chung JS, Kalman DA, Moore LE, 2002. Family correlations of arsenic methylation patterns in children and parents exposed to high concentrations of arsenic in drinking water. Environ Health Perspect 110(7):729–733.
Cikrt M, Mravcová A, Malátová I, 1988. Distribution and excretion of ^74^As and ^75^Se in rats after their simultaneous administration: The effect of arsenic, selenium and combined pretreatment. J Hyg Epidemiol Microbiol Immunol 32(1):17–29.
Civantos DP, Rodríguez AL, Aguado-Borruey JM, 1995. Fulminant malignant arrhythmia and multiorgan failure in acute arsenic poisoning. Chest 108(6):1774–1775.7497814
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell HJ, Thomas RS, Gentry PR, 2007. Research toward the development of a biologically based dose response assessment for inorganic arsenic carcinogenicity: A progress report. Toxicol Appl Pharmacol 222(3):388–398.17499324
Clyne N, Ericsson F, Lins L, 1989. Plasma trace elements in pre-dialytic uremic patients determined by energy dispersive X-ray fluorescence. Trace Elem Med 6(1):37–40.
Cohen SM, Arnold LL, Eldan M, 2006. Methylated arsenicals: The implications of metabolism and carcinogenicity studies in rodents to human risk assessment. Crit Rev Toxicol 36(2):99–133.16736939
Cohen SM, Yamamoto S, Cano M, 2001. Urothelial cytotoxicity and regeneration induced by dimethylarsinic acid in rats. Toxicol Sci 59(1):68–74.11134545
Cöl M, Cöl C, Soran A, 1999. Arsenic-related Bowen’s disease, Palmer keratosis, and skin cancer. Environ Health Perspect 107(8):687–689.
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Coles DG, Ragaini RC, Ondov JM, 1979. Chemical studies of stack fly ash from a coal-fired power plant. Environ Sci Tech 13(4):455–459.
Comber SDW, Howard AG. 1989. Arsenic speciation by hydride generation atomic absorption spectrometry and its application to the study of biological cycling in the coastal environment. Anal Proc 26:20–22.
Concha G, Nermell B, Vahter M. 1998a. Metabolism of inorganic arsenic in children with chronic high arsenic exposure in northern Argentina. Environ Health Perspect 106(6):355–359.9618352
Concha G, Vogler G, Lezcano D, 1999. Exposure to inorganic arsenic metabolites during early human development. Toxicol Sci 44:185–190.
Concha G, Vogler G, Nermell B, 1998b. Low-level arsenic excretion in breast milk of native Andean women exposed to high levels of arsenic in the drinking water. Int Arch Occup Environ Health 71(1):42–46.9523248
Concha G, Vogler G, Nermell B, 2002. Intra-individual variation in the metabolism of inorganic arsenic. Int Arch Occup Environ Health 75:576–580.12373320
Cooper PA. 1991. Leaching of CCA from treated wood: pH effects. For Prod J 41(1):30–32.
Cooper CM, Gillespie WB. 2001. Arsenic and mercury concentrations in major landscape components of an intensively cultivated watershed. Environ Pollut 111:67–74.11202716
Cordier S, Thériault G, Iturra H. 1983. Mortality patterns in a population living near a copper smelter. Environ Res 31:311–322.6884292
Costa M, Zhitkovich A, Harris M, 1997. DNA-protein cross-links produced by various chemicals in cultured human lymphoma cells. J Toxicol Environ Health 50(5):433–449.9140463
Crecelius EA. 1977. Changes in the chemical speciation of arsenic following ingestion by man. Environ Health Perspect 19:147–150.908293
Crecelius EA. 1978. Modification of the arsenic speciation technique using hydride generation. Anal Chem 50(6):826–827.
Crown S, Kenan G, Nyska A, 1987. Cacodylic acid toxicity in dietary administration to rats for 13 weeks: A preliminary study. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID42767701.
Crown S, Nyska A, Waner T. 1990. Methanearsonic acid combined chronic feeding and oncogenicity study in the rat. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41669001.
Csanaky I, Gregus Z. 2002. Species variations in the biliary and urinary excretion of arsenate, arsenite and their metabolites. Comp Biochem Physiol C 131(3):355–365.
*Cullen WR. 1998. Arsenic in the environment. In: Bunnett JF, Mikolajczyk M, eds. Arsenic and old mustard: Chemical problems in the destruction of old arsenical and 'mustard' munitions. Netherlands: Kluwer Academic Publishers, 123–134.
Cullen NM, Wolf LR, St Clair D. 1995. Pediatric arsenic ingestion. Am J Emerg Med 13(4):432–435.7605532
Curatola CJ, Grunder FI, Moffitt AE. 1978. Hydride generation atomic absorption spectrophotometry for determination of arsenic in hair. Am Ind Hyg Assoc Journal 39:933–938.742594
Cuzick J, Sasieni P, Evans S. 1992. Ingested arsenic, keratoses, and bladder cancer. Am J Epidemiol 136(4):417–421.1415161
*Czarnecki GL, Baker DH, Garst JE. 1984. Arsenic-sulfur amino acid interactions in the chick. J Anim Sci 59:1573–1581.6526761
Dabeka RW, Lacroix GMA. 1987. Total arsenic in foods after sequential wet digestion, dry ashing, coprecipitation with ammonium pyrrolidine dithiocarbamate, and graphite-furnace atomic absorption spectrometry. J Assoc Off Anal Chem 70(5):866–870.3680127
Dabeka RW, McKenzie AD, Lacroix GM, 1993. Survey of arsenic in total diet food composites and estimation of the dietary intake of arsenic by Canadian adults and children. J AOAC Int 76(1):14–25.8448438
Dallaire L, Beliveau R. 1992. Phosphate transport by capillaries of the blood-brain barrier. J Biol Chem 267(31):22323–22327.1429584
Danan M, Dally S, Conso F. 1984. Arsenic-induced encephalopathy. Neurology 34:1524.
Darland JE, Inskeep WP. 1997. Effects of pH and phosphate competition on the transport of arsenate. J Environ Qual 26(4):1133–1139.
Das T, Roychoudhury A, Sharma A, 1993. Modification of clastogenicity of three known clastogens by garlic extract in mice in vivo. Environ Mol Mutagen 21(4):383–388.8491218
Datta S, Talukder G, Sharma A. 1986. Cytotoxic effects of arsenic in dietary oil primed rats. Sci Cult 52(6):196–198.
Davey JC, Bodwell JE, Gosse JA, 2007. Arsenic as an endocrine disruptor: Effects of arsenic on estrogen receptor-mediated gene expression in vivo and in cell culture. Toxicol Sci 98(1):75–86.17283378
Davidson CI, Goold WD, Mathison TP, 1985. Airborne trace elements in Great Smoky Mountains, Olympic, and Glacier National Parks. Environ Sci Technol 19:27–35.
Davis A, Ruby MV, Bergstrom PD. 1992. Bioavailability of arsenic and lead in soils from the Butte, Montana, mining district. Environ Sci Technol 26(3):461–468.
Davis A, Ruby MV, Bloom M, 1996. Mineralogic constraints on the bioavailability of arsenic in smelter-impacted soils. Environ Sci Technol 30(2):392–399.
Dekundt GH, Leonard A, Arany J, 1986. In vivo studies in male mice on the mutagenic effects of inorganic arsenic. Mutagenesis 1(1):33–34.3325733
de la Rosa ME, Magnusson J, Ramel C, 1994. Modulating influence of inorganic arsenic on the recombinogenic and mutagenic action of ionizing radiation and alkylating agents in Drosophila melanogaster. Mutat Res 318(1):65–71.7519316
de Peyster A, Silvers JA. 1995. Arsenic levels in hair of workers in a semiconductor fabrication facility. Am Ind Hyg Assoc J 56(4):377–383.7726103
Dhar P, Jaitley M, Kalaivani M, 2005. Preliminary morphological and histochemical changes in rat spinal cord neurons following arsenic ingestion. Neurotoxicology 26(3):309–320.15935203
DHHS. 1995. Report to Congress on workers' home contamination study conducted under the workers' family protection act (29 U.S.C. 671a). Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control and Prevention, National Institute for Occupational Safety and Health. September 1995. Pub no. 95–123. PB96192000.
*Díaz-Barriga F, Batres L, Calderón J, 1997. The El Paso smelter 20 years later: Residual impact on Mexican children. Environ Res 74(1):11–16.9339209
Dieke SH, Richter CP. 1946. Comparative assays of rodenticides on wild Norway rats. Public Health Rep 61:672–679.21027329
DiPaolo JA, Casto BC. 1979. Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39:1008–1013.427740
*Diwan A, Ward JM, Waalkes MP. 2002. Multiorgan transplacental carcinogenesis by arsenic in mice. Proc Am Assoc Cancer Res 43:1032.
Dix K, Cappon CJ, Toribara TY. 1987. Arsenic speciation by capillary gas-liquid chromatography. J Chromatogr Sci 25:164–169.3584388
Dolan SP, Nortrup DA, Bolger PM, 2003. Analysis of dietary supplements for arsenic, cadmium, mercury, and lead using inductively coupled plasma mass spectrometry. J Agric Food Chem 51(5):1307–1312.12590474
*Domingo JL, Bosque MA, Piera V. 1991. meso-2,3-Dimercaptosuccinic acid and prevention of arsenite embryotoxicity and teratogenicity in the mouse. Fundam Appl Toxicol 17:314–320.1662650
Dong JT, Luo XM. 1993. Arsenic-induced DNA-strand breaks associated with DNA-protein crosslinks in human fetal lung fibroblasts. Mutat Res 302(2):97–102.7684511
Dong JT, Luo XM. 1994. Effects of arsenic on DNA damage and repair in human fetal lung fibroblasts. Mutat Res 315(1):11–15.7517005
Dopp E, Hartmann LM, Florea AM, 2004. Uptake of inorganic and organic derivatives of arsenic associated with induced cytotoxic and genotoxic effects in Chinese hamster ovary (CHO) cells. Toxicol Appl Pharmacol 201(2):156–165.15541755
Driesback RH, ed. 1980. Arsenic and arsine. In: Handbook of poisoning: Prevention, diagnosis and treatment. 11th ed. Los Altos, CA: Lange Medical Publications, 241–245.
Dueñas C, Pérez-Alvarez JC, Busteros JI, 1998. Idiopatic portal hypertension and angiosarcoma associated with arsenical salts therapy. J Clin Gastroenterol 26(4):303–305.9649017
*Dulout FN, Grillo CA, Seoane AI, 1996. Chromosomal aberrations in peripheral blood lymphocytes from native Andean women and children from northwestern Argentina exposed to arsenic in drinking water. Mutat Res 370(3–4):151–158.8917661
Dunlap LG. 1921. Perforations of the nasal septum due to inhalation of arsenous oxide. JAMA 76(9):568–569.
*Durant JL, Chen J, Hemond HF, 1995. Elevated incidence of childhood leukemia in Woburn, Massachusetts: NIEHS Superfund basic research program searches for causes. Environ Health Perspect 103(Suppl 6):93–98.
Dutkiewicz T. 1977. Experimental studies on arsenic absorption routes in rats. Environ Health Perspect 19:173–177.908295
Ebdon L, Fisher A, Roberts NB, 1999. Determination of organoarsenic species in blood plasma by HPLC-ICP MS. Appl Organomet Chem 13:183–187.
Edelman GM. 1992. Morphoregulation. Dev Dynamics 193:2–10.
Edmonds JS, Francesconi KA. 1987. Transformations of arsenic in the marine environment. Experientia 43:553–557.3556209
Edmonds MS, Baker DH. 1986. Toxic effects of supplemental copper and roxarsone when fed alone or in combination to young pigs. J Anim Sci 63:533–537.3759688
Eguchi N, Kuroda K, Endo G. 1997. Metabolites of arsenic induced tetraploids and mitotic arrest in cultured cells. Arch Environ Contam Toxicol 32(2):141–145.9069188
Eisler R. 1994. A review of arsenic hazards to plants and animals with emphasis on fishery and wildlife. In: Nriagu JO, ed. Arsenic in the environment: Part II: Human health and ecosystem effects. New York, NY: John Wiley & Sons, Inc, 185–259.
Eitzer BD, Iannucci-Berger WA, Mark G, 1997. Fate of toxic compounds during composting. Bull Environ Contam Toxicol 58(6):953–960.9136660
Ellenhorn MJ. 1997. Ellenhorn's medical toxicology. Diagnosis and treatment of human poisoning. Baltimore, MD: Williams & Wilkins, 1538–1542.
Ellenhorn MJ, Barceloux DG. 1988. Medical toxicology: Diagnosis and treatment of human poisoning. New York, NY: Elsevier, 1012–1048.
Endo G, Kuroda K, Okamoto A, 1992. Dimethylarsenic acid induces tetraploids in Chinese hamster cells. Bull Environ Contam Toxicol 48(1):131–137.1581670
Engel RR, Receveur O. 1993. Re: “Arsenic ingestion and internal cancers: A review”. Am J Epidemiol 138(10):896–897.8237974
Engel RR, Smith AH. 1994. Arsenic in drinking water and mortality from vascular disease: An ecologic analysis in 30 counties in the United States. Arch Environ Health 49(5):418–427.7944575
Enterline PE, Marsh GM. 1982. Cancer among workers exposed to arsenic and other substances in a copper smelter. Am J Epidemiol 116(6):895–911.7148816
Enterline PE, Day R, Marsh GM. 1995. Cancers related to exposure to arsenic at a copper smelter. Occup Environ Med 52(1):28–32.7697137
Enterline PE, Henderson VL, Marsh GM. 1987a. Exposure to arsenic and respiratory cancer: A reanalysis. Am J Epidemiol 125(6):929–938.3578251
Enterline PE, Marsh GM, Esmen NA, 1987b. Some effects of cigarette smoking, arsenic, and SO_2_ on mortality among U.S. copper smelter workers. J Occup Med 29(10):831–838.3681494
Environment Canada. 1993. Canadian environmental protection act priority substances list assessment report: Arsenic and its compounds. Ottawa, Canada: Canada Communication Group.
EPA. 1977a. Selected non-carcinogenic effects of industrial exposure to inorganic arsenic. Washington, DC: U.S. Environmental Protection Agency. PB276988. EPA560677018.
*EPA. 1977b. The evaluation of the acute inhalation toxicology of technical grade organoarsenical pesticides. Research Triangle Park, NC: U.S. Environmental Protection Agency, Health Effects Research Laboratory.
EPA. 1979. Water-related environmental fate of 129 priority pollutants: Vol. I. Introduction and technical background, metals and inorganics, pesticides and PCBs. Washington, DC: U.S. Environmental Protection Agency, Office of Water Planning and Standard. EPA440479029a.
EPA. 1980a. Ambient water quality criteria for arsenic. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. EPA440580021.
*EPA. 1980b. Lung cancer/mortality in proximity to a pesticide plant. Washington, DC: U.S. Environmental Protection Agency. PB80207376.
*EPA. 1980c. STORET. Washington, DC: U.S. Environmental Protection Agency, Monitoring and Data Support Division.
*EPA. 1980d. U.S. Environmental Protection Agency. Fed Regist 45:33132–33133.
*EPA. 1980e. U.S. Environmental Protection Agency: Part V. Fed Regist 45:79325–79327.
EPA. 1980f. Failure to produce arsenic neurotoxicity in the rat. An experimental study. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances. EPA5601180022.
*EPA. 1980g. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency, U.S. Environmental Sciences Research Lab. PB80221948.
*EPA. 1980h. Lung cancer mortality in proximity to a pesticide plant. Washington, DC: American Public Health Association and U.S. Environmental Protection Agency, Office of Toxic Substances. PB80207376.
*EPA. 1981a. Effluent guidelines and standards. Toxic pollutants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.
EPA. 1981b. Community health associated with arsenic in drinking water in Millard County, Utah. Cincinnati, OH: U.S. Environmental Protection Agency, Health Effects Research Laboratory. EPA600181064. PB82108374.
EPA. 1981c. The carcinogen assessment group's final risk assessment on arsenic. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600681002. PB81206013.
*EPA. 1981d. Effluent guidelines and standards. Timber products processing point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 429.
*EPA. 1981e. Assessment of exposure to arsenic from CCA-treated wood: Final report. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment.
*EPA. 1982a. Effluent guidelines and standards. Inorganic chemicals manufacturing point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 415.
EPA. 1982b. Exposure and risk assessment for arsenic. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards. PB85221711. EPA440485005. 1.1–4.68.
EPA. 1982c. Inductively coupled plasma-atomic emission spectrometric method for trace element analysis of water and wastes - method 200.7. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory.
*EPA. 1982d. Arsenic. In: Intermedia priority pollutant guidance documents. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticides and Toxic Substances.
*EPA. 1982e. Speciation of arsenic compounds in water supplies. Cincinnati, OH: U.S. Environmental Protection Agency, Health Effects Research Laboratory. EPA6005182010.
*EPA. 1983a. Effluent guidelines and standards. Electrical and electronic components point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 469.
EPA. 1983b. Method 206.2: atomic absorption, furnace technique. In: Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600479020.
EPA. 1983c. Method 206.3: atomic absorption-gaseous hydride. In: Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600479020.
EPA. 1983d. Method 206.4: spectrophotometric - SDDC. In: Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600479020.
EPA. 1983e. Method 206.5: sample digestion prior to total arsenic analysis by silver diethyldithiocarbamate or hydride procedures. In: Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. EPA600479020.
*EPA. 1983f. Treatability manual: Vol. I: Treatability data. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, I.4.2.1-I.4.2.6. EPA600282001a.
EPA. 1983g. Feasibility study to resolve questions on the relationship of arsenic in drinking water to skin cancer. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development.
*EPA. 1983h. Compliance monitoring data from federal reporting data system. U.S. Environmental Protection Agency, Office of Drinking Water, State Programs Division.
EPA. 1984a. Health Assessment Document for Arsenic. Research Triangle Park, NC: U.S. Environmental Protection Agency. EPA600823021F.
*EPA. 1984b. Health assessment document for inorganic arsenic. Final report. Research Triangle Park, NC: U.S. Environmental Protection Agency, Environmental Criteria and Assessment Office. EPA600883021F. 2–1-3–22, 9–1-9–4.
*EPA. 1984c. Health effects assessment for arsenic. Washington, DC: U.S. Environmental Protection Agency, Office of Emergency and Remedial Response. EPA540186020.
*EPA. 1984d. Occurrence of arsenic in drinking water, food and air. Washington, DC: U.S. Environmental Protection Agency, Office of Water Regulations and Standards.
*EPA. 1986a. Evaluation of the potential carcinogenicity of arsenic (7940–38-2) in support of reportable quantity adjustments pursuant to CERCLA Section 102. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. OHEA C-073–5.
*EPA. 1986b. Inorganic arsenic risk assessment for primary and secondary zinc smelters, primary lead smelters, zinc oxide plants, cotton gins, and arsenic chemical plants. Research Triangle Park, NC: U.S. Environmental Protection Agency, Strategies and Air Standards Division. PB86245255.
*EPA. 1986c. Method 7060 – Arsenic: atomic absorption, furnace technique. In: Test methods for evaluating solid waste. 3rd ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
*EPA. 1986d. National emission standard for inorganic arsenic emissions from arsenic trioxide and metallic arsenic production facilities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart P.
*EPA. 1986e. Creosote, pentachlorophenol, and inorganic arsenicals: Amendment of notice to cancel registrations. U.S. Environmental Protection Agency. Fed Regist 51(7):1334–1348.
EPA. 1986f. National emission standards for household air pollutants; Standards for inorganic arsenic. U.S. Environmental Protection Agency: Part II. Fed Regist 51(149):27956–27960.
*EPA. 1986g. National emission standard for inorganic arsenic emissions from primary copper smelters. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61, Subpart O.
*EPA. 1987a. U.S. Environmental Protection Agency. Fed Regist 52:12278.
*EPA. 1987b. U.S. Environmental Protection Agency: Part II. Fed Regist 52(77):13396–13398, 13402.
*EPA. 1987c. List (phase 1) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency: Part II. Fed Regist 52(131):25942–25953.
*EPA. 1987d. Land disposal restrictions for certain “California list” hazardous wastes and modifications to the framework. U.S. Environmental Protection Agency: Part V. Fed Regist 52(130):25760–25763.
EPA. 1987e. The risk assessment guidelines of 1986. Washington, DC: U.S. Environmental Protection Agency. EPA600887045.
*EPA. 1987f. Carcinogenic effects of arsenic compounds in drinking water. Cincinnati, OH: U.S. Environmental Protection Agency, Health Effects Research Laboratory. PB87232542. EPA 600187007.
*EPA. 1988a. Inorganic arsenicals; Intent to cancel registrations for pesticide products registered for non-wood preservative use; conclusion of special review. U.S. Environmental Protection Agency. Fed Regist 53(126):24787–24796.
*EPA. 1988b. U.S. Environmental Protection Agency: Part II. Fed Regist 53:31138–31222.
*EPA. 1988c. U.S. Environmental Protection Agency: Part II. Fed Regist 53:4500–4501.
EPA. 1988d. Special report on ingested inorganic arsenic: Skin cancer; nutritional essentiality. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA625387013F. PB89125975
EPA. 1988e. Reference physiological parameters in pharmacokinetic modeling. Washington, DC: U.S. Environmental Protection Agency. EPA600688004. PB88196019.
*EPA. 1989a. Guidance for the reregistration of wood preservative pesticide products containing arsenic, chromium, and chromated arsenical compounds as the active ingredient. Washington, DC: U.S. Environmental Protection Agency, Office of Pesticide Programs. PB89102842.
EPA. 1989b. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F. PB90145723.
*EPA. 1989c. U.S. Environmental Protection Agency: Part II. Fed Regist 54:35988–35992.
*EPA. 1989d. Reportable quantity adjustments; Digesting of ammonium trisulfate. U.S. Environmental Protection Agency: Part V. Fed Regist 54(155):33426, 33450, 33453–33454, 33456, 33463–33465, 33470.
EPA. 1989e. Recognition and management of pesticide poisonings. U.S. Environmental Protection Agency. EPA540988001. PB91145656, 54–62
*EPA. 1990a. Effluent guidelines and standards. Nonferrous metals manufacturing point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 421.
*EPA. 1990b. Calcium arsenate; Revocation of tolerances. U.S. Environmental Protection Agency. Fed Regist 55(158):33332–33335.
*EPA. 1990c. Land disposal restrictions for third scheduled wastes. U.S. Environmental Protection Agency: Part II. Fed Regist 55(106):22520–22536, 22683–22714.
*EPA. 1990d. Notice of intent to remove certain active ingredients from list B and to those pesticides containing those ingredients. U.S. Environmental Protection Agency: Part V. Fed Regist 55(147):31164–31174.
EPA. 1990e. Pollutant concentration estimates from the National Sewage Sludge Survey: Arsenic. U.S. Environmental Protection Agency: Part III. Fed Regist 55(218):47229.
*EPA. 1990f. Toxics in the community: 1988: National and local perspectives. Washington, DC: U.S. Environmental Protection Agency, Office of Toxic Substances.
*EPA. 1990g. National emissions standard for inorganic arsenic emissions from glass manufacturing plants. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 61. Subpart N.
*EPA. 1990h. Standards of performance for volatile organic compounds (VOC) emissions from synthetic organic chemical manufacturing industry (SOCMI) distillation operation. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 60.667.
EPA. 1990i. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office. EPA600890066A.
EPA. 1991. Method 200.8 - Determination of trace elements in waters and wastes by inductively coupled plasma - mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency, EPA monitoring and support laboratory.
*EPA. 1993a. Arsenic: Supply, demand, and the environment. In: Mercury and arsenic wastes: removal, recovery, treatment, and disposal. U.S. Environmental Protection Agency Pollution Technology Review No. 214, 67–71.
EPA. 1993b. Standards for the management of hazardous waste and specific types of hazardous waste facilities. Health-based limits for exclusion of waste-dericed residues. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 266; Subpart H; Appendix VII.
EPA. 1994a. Method 6020 - Inductively coupled plasma - mass spectrometry. In: Test methods for evaluating sold waste. 3^rd^ ed. SW-846. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1994b. Method 7060A- Arsenic: atomic absorption, furnace technique. In: Test methods for evaluating sold waste. 3^rd^ ed. SW-846. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1994c. Method 200.7 - Inductively coupled plasma-atomic emission spectrometric method for trace element analysis of water and wastes. Revision 4.4, EMMC version. Cincinnati, OH: U.S. Environmental Protection Agency, Environmental Monitoring and Support Laboratory. http://www.nemi.gov/. April 6, 2005.
*EPA. 1995a. Designation, reportable quantities, and notification. List of hazardous substance and reportable quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1995b. Determination of reportable quantities for hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.
EPA. 1995c. Effluent guidelines and standards. Pesticide chemicals. Metallo-organic pesticide chemicals manufacturing subcategory. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Subpart B.
*EPA. 1995d. Toxic chemical release reporting: Community right-to-know. Specific toxic chemical listings. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1995e. Maximum contaminant levels for inorganic chemicals. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141, Subpart B.
*EPA. 1995f. Determination of background concentrations of inorganics in soil and sediments at hazardous waste sites. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development. EPA540S96500.
*EPA. 1996a. Effluent guidelines and standards. Pesticide chemicals. List of appropriate pollution control technologies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 455, Table 10.
EPA. 1996b. Proposed guidelines for carcinogen risk assessment. U.S. Environmental Protection Agency. Fed Regist 61(79):17960–18011.
*EPA. 1996c. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notification. Emergency planning and notification. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A.
EPA. 1996d. Method 6010B- Inductively coupled plasma-atomic emission spectrometry. In: Test methods for evaluating sold waste. 3^rd^ ed. SW-846. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1996e. Method 7063- Arsenic in aqueous samples and extracts by anodic stripping voltammetry (ASV). In: Test methods for evaluating solid waste. 3^rd^ ed. SW-846. Washington DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1996f. Land disposal restrictions. Prohibitions on storage. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, Subpart E.
*EPA. 1996g. Land disposal restrictions. Metal bearing wastes prohibited from dilution in a combustion unit according to 40 CFR 268.3(c). U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268, Appendix XI.
EPA. 1996h. Method 1632: Inorganic arsenic in water by hydride generation quartz furnace atomic absorption. U.S. Environmental Protection Agency, Office of Water, Engineering and Analysis Division.
*EPA. 1997a. Identification and listing of hazardous waste. Hazardous constituents. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.
*EPA. 1997b. Standards for owners and operators of hazardous waste treatment, storage, and disposal facilities. Ground-water monitoring list. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 264, Appendix IX.
*EPA. 1997c. National emission standards for wood furniture manufacturing operations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63, Subpart JJ.
*EPA. 1997d. Land disposal restrictions Phase IV: Treatment standards for wood preserving wastes, paperwork reduction and streamlining, exemptions from RCRA for certain processed materials; and miscellaneous hazardous waste provision. U.S. Environmental Protection Agency. Fed Regist 62(91)25998.
*EPA. 1997e. Fish and wildlife advisory database. U.S. Environmental Protection Agency. http://www.epa.gov/ost/fishadvice/. March 31, 2005.
*EPA. 1997f. Addition of facilities in certain industry sectors; Revised interpretation of otherwise use; Toxic release inventory reporting; Community right-to-know. U.S. Environmental Protection Agency. Fed Regist 62(84):23834.
EPA. 1997g. Relative bioavailability of arsenic in mining wastes. Denver, CO: U.S. Environmental Protection Agency. Document control no. 4500–88-AORH.
EPA. 1997h. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
*EPA. 1997i. Report on the expert panel on arsenic carcinogenicity: Review and workshop. Washington, DC: U.S. Environmental Protection Agency.
*EPA. 1998a. List of pesticides banned and severely restricted in the U.S. U.S. Environmental Protection Agency. http://www.epa.gov.oppfead1/international/piclist.htm. March 31, 2005.
*EPA. 1998b. Effluent limitations guidelines, pretreatment standards and new source performance standards for the industrial waste combustor subcategory of the waste combustors point source category. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 444. Fed Regist 63(25)6392.
*EPA. 1998c. National emission standards for hazardous air pollutants; proposed standards for hazardous air pollutants emissions for the Portland cement manufacturing industry. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63. Fed Regist 63(56)14182.
*EPA. 1998d. National emissions standards for hazardous air pollutants for primary lead smelters. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 63. Fed Regist 63(74)19200.
*EPA. 1998e. National emission standards for hazardous air pollutants for source categories: national emission standards for primary copper smelters. U.S. Environmental Protection Agency. Fed Regist 63(75)19582.
*EPA. 1998f. Land disposal restrictions phase IV: final rule promulgating treatment standards for metal wastes and mineral processing wastes; mineral processing secondary materials and bevill exclusion issues; treatment standards for hazardous soils, and exclusion of recycled wood preserving wastewaters. U.S. Environmental Protection Agency. Fed Regist 63(100)28556.
EPA. 1998g. Listing of fish and wildlife advisories - 1997. Washington, DC: U.S. Environmental Protection Agency, Office of Water/Office of Science and Technology. EPA823C98001, version 3.
*EPA. 1998h. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4.
*EPA. 1998i. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 401.15.
EPA. 1998j. Method 6020A- Inductively coupled plasma - mass spectrometry. In: Test methods for evaluating solid waste. 3^rd^ ed. SW-846. Washington, DC: U.S. Environmental Protection Agency, Office of Solid Waste and Emergency Response.
EPA. 1998k. Notice of filing of pesticide petitions. U.S. Environmental Protection Agency. Fed Regist 63:40273–40279.
EPA. 1998l. Method 1632. Chemical speciation of arsenic in water and tissue by hydride generation quartz furnace atomic absorption spectrometry. Revision A. U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/methods/method/files/1632.pdf. August 27, 2007.
*EPA. 1999a. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65.
*EPA. 1999b. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141.11.
*EPA. 1999c. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4.
*EPA. 1999d. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33.
*EPA. 1999e. National Recommended Water Quality Criteria-Correction. U.S. Environmental Protection Agency, Office of Water. EPA822Z99001.
*EPA. 1999f. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.180.
*EPA. 1999g. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.3.
EPA. 1999h. International Pesticide Notice: EPA cancels the last agricultural use of arsenic acid in the United States. U.S. Environmental Protection Agency. http://www.epa.gov/oppfead1/17b/arsenic.htm. November 3, 1999.
*EPA. 1999i. Pesticide chemicals classified as known, probable or possible human carcinogens. Environmental Protection Agency. http://www.epa.gov/pesticides/carlist/table.htm. November 3, 1999.
*EPA. 2000a. NCOD query results. Arsenic. Drinking water data. National Contaminant Occurrence Database. Public Water Systems. U.S. Environmental Protection Agency. http://www.epa.gov/ncod/. March 31, 2005.
*EPA. 2000b. National primary drinking water regulations; Arsenic and clarifications to compliance and new source contaminants monitoring; Proposed rule. U.S. Environmental Protection Agency. Fed Regist 65:38888.
EPA. 2000c. Method 6010C - Inductively coupled plasma-atomic emission spectrometry. U.S. Environmental Protection Agency, Office of Solid Waste. http://www.nemi.gov/. April 6, 2005.
EPA. 2001. National primary drinking water regulations; arsenic and clarifications to compliance and new source contaminants monitoring. U.S. Environmental Protection Agency. Fed Regist 66(14):6976–7066.
EPA. 2002a. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F02013. http://www.epa.gov/safewater/mcl.html. February 15, 2005.
EPA. 2002b. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. EPA822R02047. http://www.epa.gov/waterscience/pc/revcom.pdf. February 15, 2005.
EPA. 2003a. Response to requests to cancel certain chromated copper arsenate (CCA) wood preservative products and amendments to terminate certain uses of other CCA products. Fed Regist 68 (68):17366–17372.
EPA. 2003b. Technical summary of information available on the bioaccumulation of arsenic in aquatic organisms. Washington, DC: U.S. Environmental Protection Agency. EPA822R03032. http://www.epa.gov/waterscience/criteria/arsenic/tech-sum-bioacc.pdf. August 27, 2007
EPA. 2004a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R04005. http://www.epa.gov/waterscience/drinking/standards/dwstandards.pdf. February 15, 2005.
EPA. 2004b. Hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2004c. National fish tissue study. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/fishstudy/. April 1, 2005.
*EPA. 2004d. Risk assessment guidance for Superfund. Volume I: Human health evaluation manual. Part E: Supplemental guidance for dermal risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA540R99005. OSWER9285702EP. PB99963312, 3–16, 4–6, 6–2, R-1, R-5, B-20.
EPA. 2005b. 1996. Emissions of arsenic compounds. Technology Transfer Network. National Air Toxics Assessment. Pollutant-Specific Data Tables. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/atw/nata/tablemis.html. March 31, 2005.
EPA. 2005a. Chromated copper arsenate (CCA). U.S. Environmental Protection Agency. http://www.epa.gov/oppad001/reregistration/cca/. February 25, 2005.
EPA. 2005d. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://www.epa.gov/ttn/atw/orig189.html. February 15, 2005.
EPA. 2005e. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005c. STORET data warehouse. U.S. Environmental Protection Agency. http://www.epa.gov/storet/dw_home.html. April 8, 2005.
EPA. 2005f. Superfund, emergency planning, and community right-to-know programs. Designation, reportable quantities, and notifications. Code of Federal Regulations. 40 CFR 302.4. U.S. Environmental Protection Agency. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005g. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005h. Superfund, emergency planning, and community right-to-know programs. Toxic chemical release reporting. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 16, 2005.
EPA. 2005i. Tolerances and exemptions from tolerances for pesticide chemicals in food. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.311. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, 2005.
EPA. 2005j. Tolerances and exemptions from tolerances for pesticide chemicals in food. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.289. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. February 15, .
EPA. 2005k. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
*EPA. 2005l. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
EPA. 2006. Revised reregistration eligibility decision for MSMA, DSMA, CAMA, and cacodylic acid, August 10, 2006. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/REDs/organic_arsenicals_red.pdf. September 12, 2006.
EPA. 2007a. Chromated copper arsenate (CCA): Consumer awareness program (CAP). U.S. Environmental Protection Agency. http://www.epa.gov/oppad001/reregistration/cca/cap.htm. January 16, 2007.
EPA. 2007b. Framework for metals risk assessment. U.S. Environmental Protection Agency. EPA120R07001. http://www.epa.gov/osa/metalsframework/pdfs/metals-risk-assessment-final.pdf. August 30, 2007.
Erdogan S, Celik S, Erdogan Z. 2004. Comparison of selected toxic elements in cow serum and milk samples from industrial and rural regions. Bull Environ Contam Toxicol 72(5):931–936.15266688
Erry BV, Macnair MR, Meharg AA, 1999. Seasonal variation in dietary and body organ arsenic concentrations in wood mice Apodemus sylvaticus and bank voles Clethrionomys glareolus. Bull Environ Contam Toxicol 63:567–574.10541674
*Falk H, Caldwell GG, Ishak KG, 1981a. Arsenic-related hepatic angiosarcoma. Am J Ind Med 2:43–50.6891179
Falk H, Herbert JT, Edmonds L, 1981b. Review of four cases of childhood hepatic angiosarcoma– elevated environmental arsenic exposure in one case. Cancer 47:382–391.7193080
Fan S, Ho I, Yeoh FL, 1996. Squalene inhibits sodium arsenite-induced sister chromatid exchanges and micronuclei in Chinese hamster ovary-K1 cells. Mutat Res 368(3–4):165–169.8692222
Farag AM, Woodward DF, Goldstein JN, 1998. Concentrations of metal associated with mining waste in sediments, biofilm, benthic macroinvertebrates, and fish from the Coeur d’Alene River basin, Idaho. Arch Environ Contam Toxicol 34:119–127.9469853
Farago ME. 1997. Arsenic in the marine environment. In: Gianguzza A, Pelizzetti E, Sammartano S, eds. Marine chemistry. Netherlands: Kluwer Academic Publishers, 275–291.
FDA. 2000. FDA approves arsenic trioxide for leukemia treatment in record time for a cancer drug development program. Food and Drug Administration. http://www.fda.gov/bbs/topics/ANSWERS/ANS01040.html. August 30, 2007.
FDA. 2005. Beverages. Bottled water. Final Rule. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. Fed Regist 70:33694–33701. http://www.fda.gov/OHRMS/DOCKETS/98fr/05-11406.pdf. September 1, 2005.
FEDRIP. 2006. Arsenic. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
FEDRIP. 2007. Arsenic. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Feldman RG, Niles CA, Kelly-Hayes M, 1979. Peripheral neuropathy in arsenic smelter workers. Neurology 29:939–944.224345
Feng X, Melander AP, Klaue B. 2000. Contribution of municipal waste incineration to trace metal deposition on the vicinity. Water Air Soil Pollut 119:295–316.
Ferm VH, Carpenter SJ. 1968. Malformations induced by sodium arsenate. J Reprod Fertil 17:199–201.5748739
*Ferm VH, Hanlon DP. 1985. Constant rate exposure of pregnant hamsters to arsenate during early gestation. Environ Res 37:425–432.4017994
Ferm VH, Saxon A, Smith BM. 1971. The teratogenic profile of sodium arsenate in the golden hamster. Arch Environ Health 22:557–560.5550172
*Ferreccio CR, Gonzalez CW, Solari JS, 1995. [Lung cancer in workers exposed to arsenic. A case control study.] Rev Med Chil 124:119–123. (Spanish)
Ferreccio CR, Gonzalez CW, Solari JS, 1996. [Bronchopulmonary cancer in workers exposed to arsenic: A case control study.] Rev Med Chil 124(1):119–123. (Spanish)8762629
Ferreccio C, Gonzalez Psych C, Milosavjlevic Stat V, 1998. Lung cancer and arsenic exposure in drinking water: A case-control study in northern Chile. Cad Saude Publica 14(Suppl 3):193–198.
Ferreccio C, Gonzalez C, Milosavjlevic V, 2000. Lung cancer and arsenic concentrations in drinking water in Chile (Erratum in: Epidemiology 12(2):283). Epidemiology 11(6):673–679.11055628
Fincher R, Koerker RM. 1987. Long-term survival in acute arsenic encephalopathy: Follow-up using newer measures of electrophysiologic parameters. Am J Med 82:549–552.3826108
Flora SJS, Tripathi N. 1998. Hepatic and renal metallothionein induction following single oral administration of gallium arsenide in rats. Biochem Mol Biol Int 45(6):1121–1127.9762410
*Flora SJS, Dube SN, Pant SC, 1994. Effects of multiple gallium arsenide exposure on some biochemical alterations in rat brain [letter]. Ind Health 32(4):247–252.7591854
Flora SJS, Dube SN, Vijayaraghavan R, 1997a. Changes in certain hemetological and physiological variables following single gallium arsenide exposure in rats. Biol Trace Elem Res 58:197–208.9403132
Flora SJS, Kumar P, Kannan GM, 1998. Acute oral gallium arsenide exposure and changes in certain hematological, hepatic, renal and immunological indices at different time intervals in male Wistar rats. Toxicol Lett 94:103–113.9574807
Flora SJS, Pant SC, Malhotra PR, 1997b. Biochemical and histopathological changes in arsenic-intoxicated rats coexposed to ethanol. Alcohol 14(6):563–568.9401671
Florea AM, Yamoah EN, Dopp E. 2005. Intracellular calcium disturbances induced by arsenic and its methylated derivatives in relation to genomic damage and apoptosis induction. Environ Health Perspect 113(6):659–664.15929885
FNB/IOM. 2001. Arsenic, boron, nickel, silicon, and vanadium. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc (2000). A Report of the Panel on Micronutrients, subcommittees on upper reference levels of nutrients and of interpretation and uses of dietary reference intakes, and the standing committee on the scientific evaluation of dietary reference intakes. Food and Nutrition Board. Institute of Medicine. Washington, DC: National Academy Press, 502–553. http://books.nap.edu/openbook.php?record_id=10026&page=R2. August 30, 2007.
Foà V, Colombi A, Maroni M, 1984. The speciation of the chemical forms of arsenic in the biological monitoring of exposure to inorganic arsenic. Sci Total Environ 34:241–259.6719100
Foà V, Colombi A, Maroni M, 1987. Study of kidney function of workers with chronic low level exposure to inorganic arsenic. In: DeRosa E, Bartolucci GB, Foa V, eds. Occupational and environmental chemical hazards: Cellular and biochemical indices for monitoring toxicity. Horwood, NY: Halsted Press, 362–367.
Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Fowler BA, Woods JS. 1977. The transplacental toxicity of methyl mercury to fetal rat liver mitochondria: Morpho-metric and biochemical studies. Lab Invest 36:122–130.190475
Fowler BA, Woods JS. 1979. The effects of prolonged oral arsenate exposure on liver mitochondria of mice: Morphometric and biochemical studies. Toxicol Appl Pharmacol 50:177–187.505450
Fowler BA, Woods JS, Schiller CM. 1977. Ultrastructural and biochemical effects of prolonged oral arsenic exposure on liver mitochondria of rats. Environ Health Perspect 19:197–204.198204
Foy HM, Tarmapai S, Eamchan P, 1992. Chronic arsenic poisoning from well water in a mining area in Thailand. Asia Pac J Public Health 6(3):150–152.1342803
Francesconi KA, Edmonds JS, Morita M. 1994. Determination of arsenic and arsenic species in marine environmental samples. In: Nriagu JO, ed. Arsenic in the environment: Part II: Human health and ecosystem effects. New York, NY: John Wiley & Sons, Inc., 185–259.
Francis CW, White GH. 1987. Leaching of toxic metals from incinerator ashes. J Water Pollut Control Fed 59(11):979–986.
Franklin M, Bean WB, Harden RC. 1950. Fowler's solution as an etiologic agent in cirrhosis. Am J Med Sci 219:589–596.15419170
Franzblau A, Lilis R. 1989. Acute arsenic intoxication from environmental arsenic exposure. Arch Environ Health 44(6):385–390.2610527
Freeman GB, Johnson JD, Killinger JM, 1993. Bioavailability of arsenic in soil impacted by smelter activities following oral administration in rabbits. Fundam Appl Toxicol 21(1):83–88.8365590
Freeman GB, Schoof RA, Ruby MV, 1995. Bioavailability of arsenic in soil and house dust impacted by smelter activities following oral administration in cynomolgus monkeys. Fundam Appl Toxicol 28(2):215–222.8835231
Frey MM, Edwards MA. 1997. Surveying arsenic occurrence. J Am Water Works Assoc 89(3):105–117.
*Frost DV. 1987. Interrelationships of selenium and arsenic in biology. In: Combs GF, Levander OA, Spallholz JE, , eds. Selenium in biology and medicine: Part A: Proceedings of the Third International Symposium, Beijing, China, May 27-June 1, 1984. New York, NY: Van Nostrand Reinhold Company, 308–323.
Frost F, Harter L, Milham S, 1987. Lung cancer among women residing close to an arsenic emitting copper smelter. Arch Environ Health 42(2):148–152.3606212
Frost FJ, Muller T, Petersen HV, 2003. Identifying US populations for the study of health effects related to drinking water arsenic. J Expo Anal Environ Epidemiol 13(3):231–239.12743617
*Fujino Y, Guo X, Liu J, 2004. Mental health burden amongst inhabitants of an arsenic-affected area in Inner Mongolia, China. Soc Sci Med 59(9):1963–1973.
Gailer J, George GN, Pickering IJ, 2002. Biliary excretion of [(GS)2AsSe]- after intravenous injection of rabbits with arsenite and selenate. Chem Res Toxicol 15:1466–1471.12437338
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99.13825957
Gallagher RE. 1998. Arsenic--new life for old potion. N Engl J Med 339(19):1389–1391.9801402
Gao S, Burau RG. 1997. Environmental factors affecting rates of arsine evolution from and mineralization of arsenicals in soils. J Environ Qual 26(3):753–763.
Garbarino JR, Bednar AJ, Rutherford DW, 2003. Environmental fate of roxarsone in poultry litter. I. Degradation of roxarsone during composting. Environ Sci Technol 37:1509–1514.12731831
Garcia F, Ortega A, Domingo JL, 2001. Accumulation of metals in autopsy tissues of subjects living in Tarragona county, Spain. J Environ Sci Health Part A 36(9):1767–1786.
García-Vargas GG, Hernández-Zavala A. 1996. Urinary porphyrins and heme biosynthetic enzyme activities measured by HPLC in arsenic toxicity. Biomed Chromatogr 10(6):278–284.8949908
*García-Vargas GG, Del Razo LM, Cebrián ME, 1994. Altered urinary porphyrin excretion in a human population chronically exposed to arsenic in Mexico. Hum Exp Toxicol 13(12):839–847.7718303
*Garland M, Morris JS, Rosner BA, 1993. Toenail trace element levels as biomarkers: Reproducibility over a 6-year period. Cancer Epidemiol Biomarkers Prev 2(5):493–497.8220096
Gartrell MJ, Craun JC, Podrebarac DS, 1986. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):146–161.3949687
Garvey GJ, Hahn G, Lee RV, 2001. Heavy metal hazards of Asian traditional remedies. Int J Environ Health Res 11(1):63–71.11260788
*Gebel T. 1997. Arsenic and antimony: Comparative approach on mechanistic toxicology. Chem Biol Interact 107:131–144.9448748
Gebel T, Birkenkamp P, Luthin S, 1998a. Arsenic(III), but not antimony(III), induces DNA-protein crosslinks. Anticancer Res 18:4253–4258.9891475
Gebel T, Christensen S, Dunkelberg H. 1997. Comparative and environmental genotoxicity of antimony and arsenic. Anticancer Res 17(4a):2603–2607.9252688
Gebel TW, Suchenwirth RHR, Bolten C, 1998b. Human biomonitoring of arsenic and antimony in case of an elevated geogenic exposure. Environ Health Perspect 106(1):33–39.9417766
*Geiszinger A, Goessler W, Pedersen SN, 2001. Arsenic biotransformation by the brown macroalga, Fucus serratus. Environ Toxicol Chem 20(10):2255–2262.11596758
Gentry PR, Covington TR, Mann S, 2004. Physiologically based pharmacokinetic modeling of arsenic in the mouse. J Toxicol Environ Health A 67(1):43–71.14668111
Gerhardsson L, Brune D, Nordberg IGF, 1985. Protective effect of selenium on lung cancer in smelter workers. Br J Ind Med 42:617–626.4041390
Gerhardsson L, Brune D, Nordberg IGF, 1988. Multielemental assay of tissues of deceased smelter workers and controls. Sci Total Environ 74:97–110.3222699
*Gerhardt RE, Hudson JB, Rao RN, 1978. Chronic renal insufficiency from cortical necrosis induced by arsenic poisoning. Arch Intern Med 138:1267–1269.677984
*Germolec DR, Spalding J, Boorman GA, 1997. Arsenic can mediate skin neoplasia by chronic stimulation of keratinocyte-derived growth factors. Mutat Res 86(3):209–218.
Germolec DR, Spalding J, Yu H, 1998. Arsenic enhancement of skin neoplasia by chronic stimulation of growth factors. Am J Pathol 153(6):1775–1785.9846968
Gerr F, Letz R, Ryan PB, 2000. Neurological effects of environmental exposure to arsenic in dust and soil among humans. Neurotoxicology 21(4):475–87.11022857
Geubel AP, Mairlot MC, Buchet JP, 1988. Abnormal methylation capacity in human liver cirrhosis. Int J Clin Pharmacol Res 8(2):117–122.3378853
Ghosh P, Basu A, Mahata J, 2006. Cytogenic damage and genetic variants in the individuals susceptible to arsenic-induced cancer through drinking water. Int J Cancer 118(10):2470–2478.16353154
*Gianessi LP, Anderson JE. 1995a. Cacodylic acid. Pesticide use in U.S. crop production: National data report. Washington DC: National Center for Food and Agricultural Policy.
*Gianessi LP, Anderson JE. 1995b. Pesticide use in U.S. crop production. Washington, DC: National Center for Food and Agricultural Policy.
Gibson DP, Brauninger R, Shaffi HS, 1997. Induction of micronuclei in Syrian hamster embryo cells: Comparison of results in the SHE cell transformation assay for national toxicology program test chemicals. Mutat Res 392(1–2):61–70.9269331
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Glazener FS, Ellis JG, Johnson PK. 1968. Electrocardiographic findings with arsenic poisoning. Calif Med 109(2):158–162.5673990
Goddard MJ, Tanhehco JL, Dau PC. 1992. Chronic arsenic poisoning masquerading as Landry-Guillain-Barre syndrome. Electromyogr Clin Neurophysiol 32(9):419–423.1396293
Goebel HH, Schmidt PF, Bohl J, 1990. Polyneuropathy due to acute arsenic intoxication: Biopsy studies. J Neuropathol Exp Neurol 49(2):137–149.2155304
Goering PL, Maronpot RR, Fowler BA. 1988. Effect of intratracheal gallium arsenide administration on [image]-aminolevulinic acid dehydratase in rats: Relationship to urinary excretion of aminolevulinic acid. Toxicol Appl Pharmacol 92:179–193.3341032
Goldfrank RL, Flomenbaum NE, Lewin NA, , eds. 1998. Goldfrank's toxicologic emergencies. 6^th^ ed. Stamford, CT: Appleton and Lange, 1261–1273.
Goldsmith JR, Deane M, Thom J, 1972. Evaluation of health implications of elevated arsenic in well water. Water Res 6:1133–1136.
Goldsmith S, From AHL. 1986. Arsenic-induced atypical ventricular tachycardia. N Engl J Med 303:1096–1097.
Golomb D, Ryan D, Eby N, 1997. Atmospheric deposition of toxics onto Massachusetts Bay-I. Metals. Atmos Environ 31(9):1349–1359.
*Gonsebatt ME, Vega L, Salazar AM, 1997. Cytogenetic effects in human exposure to arsenic. Mutat Res 386(3):219–228.9219560
Gonzalez MJ, Aguilar MV, Martínez Para MC. 1995. Gastrointestinal absorption of inorganic arsenic (V): The effect of concentration and interactions with phosphate and dichromate. Vet Human Toxicol 37:131–136.
Grandjean P, Weihe P, Needham LL, 1995. Relation of a seafood diet to mercury, selenium, arsenic, and polychlorinated biphenyl and other organochlorine concentrations in human milk. Environ Res 71(1):29–38.8757236
*Greenberg SA. 1996. Acute demyelinating polyneuropathy with arsenic ingestion. Muscle Nerve 19(12):1611–1613.8941278
Groen K, Vaessen HAMG, Kliest JJG, 1993. Bioavailability of inorganic arsenic from bog ore-containing soil in the dog. Environ Health Perspect 102(2):182–184.
Guerin T, Astruc A, Astruc M. 1999. Speciation of arsenic and selenium compounds by HPLC hyphenated to specific detectors: A review of the main separation techniques. Talanta 50:1–24.18967689
Guha Mazumder DN. 1996. Treatment of chronic arsenic toxicity as observed in West Bengal. J Indian Med Assoc 94(2):41–42.8810172
Guha Mazumder DN. 2005. Effect of chronic intake of arsenic-contaminated water on liver. Toxicol Appl Pharmacol 206(2):169–175.15967205
Guha Mazumder DN, Chakraborty AK, Ghose A, 1988. Chronic arsenic toxicity from drinking tubewell water in rural west Bengal. Bull WHO 66(4):499–506.3262450
Guha Mazumder DN, Das Gupta J, Santra A, 1998a. Chronic arsenic toxicity in west Bengal--the worst calamity in the world. J Indian Med Assoc 96(1):4–7.9601181
Guha Mazumder DN, Ghoshal UC, Saha J, 1998b. Randomized placebo-controlled trial of 2,3-dimercaptosuccinic acid in therapy of chronic arsenicosis due to drinking arsenic-contaminated subsoil water. Clin Toxicol 36(7):683–690.
Guha Mazumder DN, Haque R, Ghosh N, 1998c. Arsenic levels in drinking water and the prevalence of skin lesions in West Bengal, India. Int J Epidemiol 27:871–877.9839746
Guha Mazumder DN, Steinmaus C, Bhattacharya P, 2005. Bronchiectasis in persons with skin lesions resulting from arsenic in drinking water. Epidemiology 16(6):760–765.16222165
Gunderson EL. 1995a. Dietary intake of pesticides, selected elements, and other chemicals: FDA total diet study, June 1984-April 1986. J AOAC Int 78(4):910–921.7580329
Gunderson EL. 1995b. FDA total diet study, July 1986-April 1991, dietary intakes of pesticides, selected elements, and other chemicals. J AOAC Int 78(6):1353–63.8664570
Gunn TM, Juriloff DM, Harris MJ. 1992. Further genetic studies of the cause of exancephaly in SELH mice. Teratology 45:679–686.1412061
Guo HR. 2004. Arsenic level in drinking water and mortality of lung cancer (Taiwan). Cancer Causes Control 15:171–177.15017129
Guo HR, Tseng YC. 2000. Arsenic in drinking water and bladder cancer: Comparison between studies based on cancer registry and death certificates. Environ Geochem Health 22: 83–91.
Guo HR, Yu HS, Hu H, 2001b. Arsenic in drinking water and skin cancers: Cell-type specificity (Taiwan, R.O.C.). Cancer Causes Control 12(10):909–916.11808710
Guo T, Baasner J, Tsalev DL. 1997. Fast automated determination of toxicologically relevant arsenic in urine by flow injection-hydride generation atomic absorption spectrometry. Analytica Chimica Acta 349(1–3):313–318.
Guo X, Fujino Y, Kaneko S, 2001a. Arsenic contamination of groundwater and prevalence of arsenical dermatosis in the Hetao plain area, Inner Mongolia, China. Mol Cell Biochem 222(1–2):137–140.11678595
Gur E, Nyska A. 1990. Acute oral toxicity study in rats. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID45405601.
Gur E, Nyska A, Pirak M, 1989a. Cacodylic acid oncogenicity study in the mouse. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41914601.
Gur E, Nyska A, Waner T, 1989b. Cacodylic acid combined chronic feeding and oncogenicity study in the rat. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41862101.
Gur E, Pirak M, Waner T. 1991. Methanearsonic acid oncogenicity study in the mouse. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID42173201.
Gutleb AC, Helsberg A, Mitchell C. 2002. Heavy metal concentrations in fish from a pristine rainforest valley in Peru: A baseline study before the start of oil-drilling activities. Bull Environ Contam Toxicol 69:523–529.12232723
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Haddad LM, Winchester JF. 1990. Clinical management of poisoning and drug overdose. 2nd ed. Philadelphia, PA: W.B. Saunders Company, 1024–1027, 18, 92, 97, 98.
*Hall JC, Harruff R. 1989. Fatal cardiac arrhythmia in a patient with interstitial myocarditis related to chronic arsenic poisoning. South Med J 82(12):1557–1560.2595426
Hamel SC, Buckley B, Lioy PJ. 1998. Bioaccessibility of metals in soils for different liquid to solid ratios in synthetic gastric fluid. Environ Sci Tech 32(3):358–362.
Hanlon DP, Ferm VH. 1977. Placental permeability of arsenate ion during early embryogenesis in the hamster. Experientia 33(9):1221–1222.891884
Hanlon DP, Ferm VH. 1986. Teratogen concentration changes as the basis of the heat stress enhancement of arsenate teratogenesis in hamsters. Teratology 34:189–193.3775670
*Hanlon DP, Ferm VH. 1987. The concentration and chemical status of arsenic in the early placentas of arsenate-dosed hamsters. Environ Res 42:546–552.3569187
Hantson P, Verellen-Dumoulin C, Libouton JM, 1996. Sister chromatid exchanges in human peripheral blood lymphocytes after ingestion of high doses of arsenicals. Int Arch Occup Environ Health 68:342–344.8832300
Hanusch K, Grossmann H, Herbst K, 1985. Arsenic and arsenic compounds. In: Gerhartz W, Yamamoto YS, Campbell FT, , eds. Ullman's encyclopedia of industrial chemistry. Weinham, Germany: VCH Verlagsgesellschaft, 113–141
Haque R, Mazumder DN, Samanta S, 2003. Arsenic in drinking water and skin lesions: Dose-response data from West Bengal, India. Epidemiology 14(2):174–182.12606883
Harrington JM, Middaugh JP, Morse DL, 1978. A survey of a population exposed to high concentrations of arsenic in well water in Fairbanks, Alaska. Am J Epidemiol 108(5):377–385.727207
Harrisson JWE, Packman EW, Abbott DD. 1958. Acute oral toxicity and chemical and physical properties of arsenic trioxides. Arch Ind Health 17:118–123.
Hartmann A, Speit G. 1994. Comparative investigations of the genotoxic effects of metals in the single cell gel (SCG) assay and the sister chromatid exchange (SCE) test. Environ Mole Mutagen 23(4):299–305.
Hartmann A, Speit G. 1996. Effect of arsenic and cadmium on the persistence of mutagen-induced DNA lesions in human cells. Environ Mol Mutagen 27(2):98–104.8603672
*Hartwell TW, Handy RW, Harris BS, 1983. Heavy metal exposure in populations living around zinc and copper smelters. Arch Environ Health 38(5):284–295.6651353
Hartwig A, Gröblinghoff UD, Beyersmann D, 1997. Interaction of arsenic(III) with nucleotide excision repair in UV-irradiated human fibroblasts. Carcinogenesis 18(2):399–405.9054635
Hartwig A, Mullenders L, Asmuá M, 1998. Disruption of DNA repair process by carcinogenic metal compounds. Fresenius J Anal Chem 361:377–380.
Haupert TA, Wiersma JH, Goldring JM. 1996. Health effects of ingesting arsenic-contaminated groundwater. Wis Med J 95(2):100–104.8819705
Hayakawa T, Kobayashi Y, Cui X, 2005. A new metabolic pathway of arsenite: Arsenite-glutathione complexes are substrates for human arsenic methyltransferase Cyt19. Arch Toxicol 79:183–191.15526190
Hayashi H, Kanisawa M, Yamanaka K, 1998. Dimethylarsinic acid, a main metabolite of inorganic arsenics, has tumorigenecity and progression effects in the pulmonary tumors of A/J mice. Cancer Lett 125:83–88.9566700
HazDat. 2006. Arsenic. ATSDR’s Hazardous substance release and health effects database. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. October 16, 2006.
He X, Logan TJ, Traina SJ. 1995. Physical and chemical characteristics of selected US municipal solid waste compost. J Environ Qual 24:543–552.
Healy SM, Casarez EA, Ayala-Fierro F, 1998. Enzymatic methylation of arsenic compounds. V. Arsenite methyltransferase activity in tissues of mice. Toxicol Appl Pharmacol 148(1):65–70.9465265
Heck JE, Gamble MV, Chen Y, 2007. Comsumption of folate-related nutrients and metabolism of arsenic in Bangladesh. Am J Clin Nutr 85:1367–1374.17490975
Hei TK, Liu SX, Waldren C. 1998. Mutagenicity of arsenic in mammalian cells: Role of reactive oxygen species. Proc Natl Acad Sci U S A 95:8103–8107.9653147
Heiny JS, Tate CM. 1997. Concentration, distribution, and comparison of selected trace elements in bed sediment and fish tissue in the South Platte River basin, USA, 1992–1993. Arch Environ Contam Toxicol 32(3):246–259.9096073
Heit M, Klusek C, Baron J. 1984. Evidence of deposition of anthropogenic pollutants in remote Rocky Mountain lakes. Water Air Soil Pollut 22:403–416.
Heitkemper DT, Kaine LA, Jackson DS, 1994. Practical applications of element-specific detection by inductively coupled plasma atomic emission spectroscopy and inductively coupled plasma mass spectrometry to ion chromatography of foods. J Chromatogr A 671(1–2):101–108.8049760
Helgesen H, Larsen EH. 1998. Bioavailability and speciation of arsenic in carrots grown in contaminated soil. Analyst 123(5):791–796.9709475
Helleday T, Nilsson R, Jenssen D. 2000. Arsenic [111] and heavy metal ions induce intrachromosomal homologous recombination in the hprt gene V79 Chinese hamster cells. Environ Mol Mutagen 35(2):114–122.10712745
Hemond HF, Solo-Gabriele HM. 2004. Children's exposure to arsenic from CCA-treated wooden decks and playground structures. Risk Anal 24(1):51–64.15028000
Hernández-Zavala A, Del Razo LM, Aguilar C, 1998. Alteration in bilirubin excretion in individuals chronically exposed to arsenic in Mexico. Toxicol Lett 99:79–84.9817078
Hershey JW, Oostdyk TS, Keliher PN. 1988. Determination of arsenic and selenium in environmental and agricultural samples by hydride generation atomic adsorption spectrometry. J Assoc Off Anal Chem 71(6):1090–1093.3240958
Hertz-Picciotto I, Smith AH. 1993. Observations on the dose-response curve for arsenic exposure and lung cancer. Scand J Work Environ Health 19(4):217–226.8235510
*Hessl SM, Berman E. 1982. Severe peripheral neuropathy after exposure to monosodium methyl arsonate. J Toxicol Clin Toxicol 19:281–287.6290685
Hewitt DJ, Millner GC, Nye AC, 1995. Investigation of arsenic exposure from soil at a Superfund site. Environ Res 68(2):73–81.7601075
Heydorn K. 1970. Environmental variation of arsenic levels in human blood determined by neutron activation analysis. Clin Chim Acta 28:349–357.5447411
Heyman A, Pfeiffer JB, Willett RW, 1956. Peripheral neuropathy caused by arsenical intoxication: A study of 41 cases with observations on the effects of BAL (2,3 dimercapto-propanol). N Engl J Med 254(9):401–409.13297123
Heywood R, Sortwell RJ. 1979. Arsenic intoxication in the Rhesus monkey. Toxicol Lett 3:137–144.
Hill CH. 1975. Interrelationships of selenium with other trace elements. Fed Proc 34(11):2096–2100.1175797
Hindmarsh JT, McCurdy RF. 1986. Clinical and environmental aspects of arsenic toxicity. CRC Crit Rev Clin Lab Sci 23:315–347.
Hindmarsh JT, McLetchie OR, Heffernan LPM, 1977. Electromyographic abnormalities in chronic environmental arsenicalism. J Anal Toxicol 1:270–276.
Hingston JA, Collins CD, Murphy RJ, 2001. Leaching of chromated copper arsenate wood preservatives: A review. Environ Pollut 111(1):53–66.11202715
Hirata M, Hisanaga A, Tanaka A, 1988. Glutathione and methylation of inorganic arsenic in hamsters. Appl Organomet Chem 2:315–321.
Historic Pesticide Contamination Task Force. 1999. Findings and recommendations for the remediation of historic pesticide contamination. New Jersey Department of Environmental Protection. Historic Pesticide Contamination Task Force. http://www.state.nj.us/dep/special/hpctf/final/hpctf99.pdf. August 27, 2007.
Hochadel JF, Waalkes MP. 1997. Sequence of exposure to cadmium and arsenic determines the extent of toxic effects in male Fischer rats. Toxicology 116:89–98.9020510
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoff RM, Strachan WMJ, Sweet CW, 1996. Atmospheric deposition of toxic chemicals to the Great Lakes: A review of data through 1994. Atmos Environ 30(20):3505–3527.
Holland JW. 1904. Arsenic. In: Peterson F, Haines WS, eds. A textbook of legal medicine and toxicology. Philadelphia, PA: WB Saunders and Co., 404–433.
Holland RH, McCall MS, Lanz HC. 1959. A study of inhaled arsenic-74 in man. Cancer Res 19:1154–1156.
Holmberg RE, Ferm VH. 1969. Interrelationships of selenium, cadmium and arsenic in mammalian teratogenesis. Arch Environ Health 18:873–877.5814194
Holmqvist I. 1951. Occupational arsenical dermatitis: A study among employees at a copper ore smelting work including investigations of skin reactions to contact with arsenic compounds. Acta Derm Venerol 31(Suppl 26):26–29, 44–45, 110–112, 195–204.
Holson JF, Stump DG, Clevidence KJ, 2000. Evaluation of the prenatal developmental toxicity of orally administered arsenic trioxide in rats. Food Chem Toxicol 38:459–466.10762732
Holson JF, Stump DG, Ulrich CE, 1999. Absence of prenatal developmental toxicity from inhaled arsenic trioxide in rats. Toxicol Sci 51:87–97.10496680
Hood RD. 1985. Cacodylic acid: Agricultural uses, biological effects and environmental fate. Washington, DC: Agent Orange Projects Office. Veterans Administration Central Office, 1–2, 22–24, 35–49, 95–106.
*Hood RD. 1998. Developmental effects of methylated arsenic metabolites in mice. Bull Environ Contam Toxicol 61:231–238.9702361
Hood RD, Bishop SL. 1972. Teratogenic effects of sodium arsenate in mice. Arch Environ Health 24:62–65.5009633
Hood RD, Harrison WP. 1982. Effects of prenatal arsenite exposure in the hamster. Bull Environ Contam Toxicol 29:671–678.7159777
*Hood RD, Harrison WP, Vedel JC. 1982. Evaluation of arsenic metabolites for prenatal effects in the hamster. Bull Environ Contam Toxicol 29:679–687.7159778
Hood RD, Thacker GT, Patterson BL, 1978. Prenatal effects of oral versus intraperitoneal sodium arsenate in mice. J Environ Pathol Toxicol 1:857–864.731182
Hood RD, Vedel GC, Zaworotko MJ, 1988. Uptake distribution and metabolism of trivalent arsenic in the pregnant mouse. J Toxicol Environ Health 25:423–434.3199456
Hood RD, Vedel-Macrander GC, Zaworotko MJ, 1987. Distribution, metabolism and fetal uptake of pentavalent arsenic in pregnant mice following oral or intraperitoneal administration. Teratology 35:19–25.3563933
Hopenhayn C, Bush HM, Bingcang A, 2006. Asociation between arsenic exposure from drinking water and anemia during pregnancy. J Occup Environ Hyg 48(6):635–643.
Hopenhayn C, Ferreccio C, Browning SR, 2003a. Arsenic exposure from drinking water and birth weight. Epidemiology 14(5):593–602.14501275
Hopenhayn C, Huang B, Christian J, 2003b. Profile of urinary arsenic metabolites during pregnancy. Environ Health Perspect 111(16):1888–1891.14644662
Hopenhayn-Rich C, Biggs ML, Fuchs A, 1996a. Bladder cancer mortality associated with arsenic in drinking water in Argentina. Epidemiology 7(2):117–124.8834549
Hopenhayn-Rich C, Biggs ML, Smith AH, 1996b. Methylation study of a population environmentally exposed to arsenic in drinking water. Environ Health Perspect 104(6):620–628.8793350
Hopenhayn-Rich C, Biggs ML, Smith AH. 1998. Lung and kidney cancer mortality associated with arsenic in drinking water in Córdoba, Argentina. Int J Epidemiol 27:561–569.9758107
Hopenhayn-Rich C, Browning SR, Hertz-Picciotto I, 2000. Chronic arsenic exposure and risk of infant mortality in two areas of Chile. Environ Health Perspect 108(7):667–673.10903622
Howell GO, Hill CH. 1978. Biological interaction of selenium with other trace elements in chicks. Environ Health Perspect 25:147–150.720301
HSDB. 2007. Arsenic. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. January 16, 2007.
*Hsieh LL, Chen HJ, Hsieh JT, 1994. Arsenic-related Bowen's disease and paraquat-related skin cancerous lesions show no detectable ras and p53 gene alterations. Cancer Lett 86:59–65.7954356
Hsu CH, Yang SA, Wang JY, 1999. Mutational spectrum of p53 gene in arsenic-related skin cancers from the blackfoot disease endemic area of Taiwan. Br J Cancer 80(7):1080–1086.10362120
Hsu YH, Li SY, Chiou HY, 1997. Spontaneous and induced sister chromatid exchanges and delayed cell proliferation in peripheral lymphocytes of Bowen's disease patients and matched controls of arseniasis-hyperendemic villages in Taiwan. Mutat Res 386(3):241–251.9219562
Hsueh YM, Cheng GS, Wu MM, 1995. Multiple risk factors associated with arsenic-induced skin cancer: Effects of chronic liver disease and malnutritional status. Br J Cancer 71(1):109–14.7819025
Hsueh YM, Huang YL, Huang CC, 1998a. Urinary levels of inorganic and organic arsenic metabolites among residents in an arseniasis-hyperendemic area in Taiwan. J Toxicol Environ Health 54(6):431–444.
Hsueh YM, Lin P, Chen HW, 2005. Genetic polymorphisms of oxidative and antioxidant enzymes and arsenic-related hypertension. J Toxicol Environ Health A 68(17–18):1471–1484.16076760
Hsueh YM, Wu WL, Huang YL, 1998b. Low serum carotene level and increase risk of ischemic heart disease related to long-term arsenic exposure. Atherosclerosis 141:249–257.9862173
Hu Y, Su L, Snow ET. 1998. Arsenic toxicity is enzyme specific and its effects on ligation are not caused by the direct inhibition of DNA repair enzymes. Mutat Res 408:203–218.9806419
Huang H, Huang CF, Huang JS, 1992. The transition from late G_1_ to early S phase is most vulnerable to the coclastogenic effect of ultraviolet radiation plus arsenite. Int J Radiat Biol 61(1):57–62.1345932
Huang H, Huang CF, Wu DR, 1993. Glutathione as a cellular defense against arsenite toxicity in cultured Chinese hamster ovary cells. Toxicology 79(3):195–204.8316949
Huang RN, Ho IC, Yih LH, 1995. Sodium arsenite induces chromosome endoreduplication and inhibits protein phosphatase activity in human fibroblasts. Environ Mol Mutagen 25(3):188–196.7737136
*Huang SY, Chang CS, Tang JL, 1998. Acute and chronic arsenic poisoning associated with treatment of acute promyelocytic leukaemia. Br J Haematol 103:1092–1095.9886325
Huang YZ, Qian XC, Wang GQ, 1985. Endemic chronic arsenism in Xinjiang. Chin Med J 98(3):219–222.3924515
Huggett DB, Khan IA, Allgood JC, 2001. Organochlorine pesticides and metals in select botanical dietary supplements. Bull Environ Contam Toxicol 66:150–155.11116308
Hughes MF. 2002. Arsenic toxicity and potential mechanisms of action. Toxicol Lett 133(1):1–16.12076506
Hughes MF. 2006. Biomarkers of exposure: A case study with inorganic arsenic. Environ Health Perspect 114:1790–1796.17107869
*Hughes MF, Kenyon EM. 1998. Dose-dependent effects on the disposition of monomethylarsonic acid and dimethylarsinic acid in the mouse after intravenous administration. J Toxicol Environ Health A 53(2):95–112.9444314
Hughes MF, Del Razo LM, Kenyon EM. 2000. Dose-dependent effects on tissue distribution and metabolism of dimethylarsinic acid in the mouse after intravenous administration. Toxicology 143(2):155–166.10755702
Hughes MF, Devesa V, Adair BM, 2005. Tissue dosimetry, metabolism and excretion of pentavalent and trivalent monomethylated arsenic in mice after oral administration. Toxicol Appl Pharmacol 208:186–197.16183392
Hughes MF, Kenyon EM, Edwards BC, 2003. Accumulation and metabolism of arsenic in mice after repeated oral administration of arsenate. Toxicol Appl Pharmacol 191(3):202–210.13678653
Hughes MF, Menache M, Thompson DJ. 1994. Dose-dependent disposition of sodium arsenate in mice following acute oral exposure. Fundam Appl Toxicol 22(1):80–89.8125217
*Hullinger G, Sangster L, Colvin B, 1998. Bovine arsenic toxicosis from ingestion of ashed copper-chrome-arsenate treated timber. Vet Hum Toxicol 40(3):147–148.9610492
Hwang YH, Chen SC. 2000. Monitoring of low level arsenic exposure during maintenance of ion implanters. Arch Environ Health 55(5):347–354.11063410
Hwang YH, Bornschein RL, Grote J, 1997a. Environmental arsenic exposure of children around a former copper smelter site. Environ Res 72(1):72–81.9012374
Hwang YH, Bornschein RL, Grote J, 1997b. Urinary arsenic excretion as a biomarker of arsenic exposure in children. Arch Environ Health 52(2):139–147.9124875
IARC. 1980. Arsenic and arsenic compounds. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Vol. 23. Some metals and metallic compounds. Lyon, France: International Agency for Research on Cancer, 39–141.
IARC. 2004. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (at total of 900 agents, mixtures and exposures). Lyon, France: International Agency for Research on Cancer. http://www-cie.iarc.fr/monoeval/crthall.html. March 08, 2006.
Ide CW, Bullough GR. 1988. Arsenic and old glass. J Soc Occup Med 38:85–88.3172732
Ihrig MM, Shalat SL, Baynes C. 1998. A hospital-based case-control study of stillbirths and environmental exposure to arsenic using and atmospheric dispersion model linked to a geographical information system. Epidemiology 9(3):290–294.9583421
Inoue Y, Kawabata K, Takahashi H, 1994. Determination of arsenic compounds using inductively coupled plasma mass spectrometry with ion chromatography. J Chromatog A675(1–2):149–154.
IRIS. 2007. Arsenic. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. August 28, 2007.
Irvine L, Boyer IJ, DeSesso JM. 2006. Monomethylarsonic acid and dimethylarsenic acid: Developmental toxicity studies with risk assessment. Birth Defects Res B Dev Reprod Toxicol 77:53–68.16496296
*Ishinishi N, Kodama Y, Nobutomo K, 1977. Preliminary experimental study on carcinogenicity of arsenic trioxide in rat lung. Environ Health Perspect 19:191–196.908298
Ishinishi N, Yamamoto A, Hisanaga A, 1983. Tumorigenicity of arsenic trioxide to the lung in Syrian golden hamsters by intermittent instillations. Cancer Lett 21:141–147.6652618
ITA. 2007a. U.S. trade quick-reference tables: December 2005 imports. 280480: Arsenic. International Trade Association, U.S. Department of Commerce. http://hq-tpisweb.ita.doc.gov/portal/page/portal/rptsforms/p_hsmthly?p_year=2005&p_hs=2804800000&p_month="December"&p_flow="imports"&p_table=ita.hs_10dig_mcons_mth_Dec_2005. February 07, 2007.
ITA. 2007b. U.S. trade quick-reference tables: December 2005 imports. 281129: Arsenic trioxide. International Trade Association, U.S. Department of Commerce. http://hq-tpisweb.ita.doc.gov/portal/page/portal/rptsforms/p_hsmthly?p_year=2005&p_hs=2811291000&p_month="December"&p_flow="imports"&p_table=ita.hs_10dig_mcons_mth_Dec_2005. February 07, 2007.
*Ivankovic S, Eisenbrand G, Preussmann R. 1979. Lung carcinoma induction in BD rats after a single intratracheal instillation of an arsenic-containing pesticide mixture formerly used in vineyards. Int J Cancer 24:786–788.544532
*Jacobson-Kram D, Montalbano D. 1985. The reproductive effects assessment group's report on the mutagenicity of inorganic arsenic. Environ Mutagen 7:787–804.3899634
Jager JW, Ostrosky-Wegman P. 1997. Arsenic: A paradoxical human carcinogen. Mutat Res 386(3):181–184.9219556
Jaghabir MTW, Abdelghani A, Anderson AC. 1988. Oral and dermal toxicity of MSMA to New Zealand white rabbits, Oryctalagus cuniculus. Bull Environ Contam Toxicol 40:119–122.3345356
Jaghabir MTW, Abdelghani AA, Anderson AC. 1989. Histopathological effects of monosodium methanearsonate (MSMA) on New Zealand white rabbits (Oryctalagus cuniculus). Bull Environ Contam Toxicol 42:289–293.2920237
Jain A, Loeppert RH. 2000. Effect of competing anions on the adsorption of arsenate and arsenite by ferrihydrite. J Environ Qual 29:1422–1430.
Jain A, Raven KP, Loeppert RH. 1999. Arsenite and arsenate adsorption on ferrihydrite: Surface charge reduction and net OH- release stoichiometry. Environ Sci Technol 33:1179–1184.
Jan KY, Huang RY, Lee TC. 1986. Different modes of action of sodium arsenite, 3-aminobenzamide and caffeine on the enhancement of ethyl methanesulfonate clastogenicity. Cytogenet Cell Genet 41:202–208.3754809
Janssen RPT, Peijnenburg WJGM, Posthuma L, 1997. Equilibrium partitioning of heavy metals in Dutch field soils: I. Relationship between metal partition coefficients and soil characteristics. Environ Toxicol Chem 16(12):2470–2478.
Järup L, Pershagen G. 1991. Arsenic exposure, smoking, and lung cancer in smelter workers - a case-control study. Am J Epid 134(6):545–551.
Järup L, Pershagen G, Wall S. 1989. Cumulative arsenic exposure and lung cancer in smelter workers: A dose-response study. Am J Ind Med 15:31–41.2929606
Jelinek CF, Corneliussen PE. 1977. Levels of arsenic in the United States food supply. Environ Health Perspect 19:83–87.908317
Jenkins RB. 1966. Inorganic arsenic and the nervous system. Brain 89:479–498.5921127
Jensen GE, Hansen ML. 1998. Occupational arsenic exposure and glycosylated haemoglobin. Analyst 123(1):77–80.9581024
Jensen GE, Olsen ILB. 1995. Occupational exposure to inorganic arsenic in wood workers and taxidermists-air sampling and biological monitoring. J Environ Sci Health A 30(4):921–938.
Jha AN, Noditi M, Nilsson R, 1992. Genotoxic effects of sodium arsenite on human cells. Mutat Res 284(2):215–221.1281272
*Jiang JQ. 2001. Removing arsenic from groundwater for the developing world--a review. Water Sci Technol 44(6):89–98.
*Jianhua N, Guoqiang C, Zhiziang S, 1998. Pharmacokinetics of intravenous arsenic trioxide in the treatment of acute promyelocytic leukemia. Chin Med J 111(12):1107–1110.11263375
Jin Y, Xi S, Li X, 2006. Arsenic speciation transported through the placenta from mother mice to their newborn pups. Environ Res 101(3):349–355.16458287
Johansen MG, McGowan JP, Tu SH, 1984. Tumorigenic effect of dimethylarsinic acid in the rat. Proc West Pharmacol Soc 27:289–291.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson LR, Farmer JG. 1989. Urinary arsenic concentrations and speciation in Cornwall residents. Environ Geochem Health 11:39–44.24202288
Jones CA, Inskeep WP, Neuman DR. 1997. Arsenic transport in contaminated mine tailings following liming. J Environ Qual 26(2):433–439.
*Jonnalagadda SB, Nenzou G. 1996. Studies on arsenic rich mine dumps: III. Effect on the river water. J Environ Sci Health A 31(10):2547–2555.
Kachinskas DJ, Qin Q, Phillips MA, 1997. Arsenate suppression of human keratinocyte programming. Mutat Res 386(3):253–261.9219563
Kaise T, Watanabe S, Itoh K. 1985. The acute toxicity of arsenobetaine. Chemosphere 14(9):1327–1332.
Kaise T, Yamauchi H, Horiguchi Y, 1989. A comparative study on acute toxicity of methylarsonic acid, dimethylarsinic acid and trimethylarsine oxide in mice. Appl Organomet Chem 3:273–277.
Kala SV, Neely MW, Kala G, 2000. The MRP2/cMOAT transporter and arsenic-glutathione complex formation are required for biliary excretion of arsenic. J Biol Chem 275(43):33404–33408.10938093
Kalbitz K, Wennrich R. 1998. Mobilization of heavy metals and arsenic in polluted wetland soils and its dependence on dissolved organic matter. Sci Total Environ 209:27–39.9496662
Kalman DA. 1987. Dietary contributions to arsenic species in urine. In: Trace elements in human health and disease: Extended abstracts from the second Nordic symposium, Odense, 17–21 August 1987. Copenhagen: World Health Organization, 136–139, 230–233.
Kamijo Y, Soma K, Asari Y, 1998. Survival after massive arsenic poisoning self-treated by high fluid intake. Clin Toxicol 36(1–2):27–29.
Kannan GM, Tripathi N, Dube SN, 2001. Toxic effects of arsenic (III) on some hematopoietic and central nervous system variables in rats and guinea pigs. J Toxicol Clin Toxicol 37(7):675–682.
Karagas MR, Morris JS, Weiss JE, 1996. Toenail samples as an indicator of drinking water arsenic exposure. Cancer Epidemiol Biomarkers Prev 5(10):849–852.8896897
Karagas MR, Stukel TA, Morris JS, 2001. Skin cancer risk in relation to toenail arsenic concentrations in a US population-based case-control study. Am J Epidemiol 153(6):559–565.11257063
Karagas MR, Tosteson TD, Blum J, 1998. Design of an epidemiologic study of drinking water arsenic exposure and skin and bladder cancer risk in a U.S. population. Environ Health Perspect Suppl 106(4):1047–1050.
Karagas MR, Tosteson TD, Morris JS, 2004. Incidence of transitional cell carcinoma of the bladder and arsenic exposure in New Hampshire. Cancer Causes Control 15:465–472.15286466
Kashiwada E, Kuroda K, Endo G. 1998. Aneuploidy induced by dimethylarsinic acid in mouse bone marrow cells. Mutat Res 413:33–38.9602856
Kasper ML, Schoenfield L, Strom RL, 1984. Hepatic angiosarcoma and bronchioloalveolar carcinoma induced by Fowler's solution. JAMA 252(24):3407–3408.6094851
Kato K, Hayashi H, Hasegawa A, 1994. DNA damage induced in cultured human alveolar (L-132) cells by exposure to dimethylarsinic acid. Environ Health Perspect 102(Suppl 3):285–8.7843116
*Katsnelson BA. 1998. Re: Arsenic carcinogenicity testing. Environ Health Perspect 106(12):582.
Kavanagh PJ, Farago ME, Thornton I, 1997. Bioavailability of arsenic in soil and mine wastes of the Tamar Valley, SW England. Chem Speciat Bioavail 9(3):77–81.
Kavlock RJ, Chernoff N, Rogers EH. 1985. The effect of acute maternal toxicity on fetal development in the mouse. Teratog Carcinog Mutagen 5:3–13.2859660
Kawaguchi K, Oku N, Rin K, 1996. Dimethylarsenics reveal DNA damage induced by superoxide anion radicals. Biol Pharm Bull 19(4):551–553.8860956
Kennedy S, Rice DA, Cush PF. 1986. Neuropathology of experimental 3-nitro-4-hydroxyphenylarsonic acid toxicosis in pigs. Vet Pathol 23:454–461.3018982
*Kenyon EM, Hughes MF. 2001. A concise review of the toxicity and carcinogenicity of dimethylarsinic acid. Toxicology 160(1–3):227–236.11246143
Kenyon EM, Del Razo LM, Hughes MF. 2005. Tissue distribution and urinary excretion of inorganic arsenic and its methylated metabolites in mice following acute oral administration of arsenate. Toxicol Sci 85(1):468–475.15703264
*Kenyon EM, Hughes MF, Levander OA. 1997. Influence of dietary selenium on the disposition of arsenate in the female B6C3F1 mouse. J Toxicol Environ Health 51(3):279–299.9183383
Kerckaert GA, Brauninger R, LeBoeuf RA, 1996. Use of the Syrian hamster embryo cell transformation assay for carcinogenicity prediction of chemicals currently being tested by the national toxicology program in rodent bioassays. Environ Health Perspect 104(Suppl. 5):1075–1084.8933057
Kerkvliet NI, Steppan LB, Koller LD, 1980. Immunotoxicology studies of sodium arsenate - effects of exposure on tumor growth and cell-mediated tumor immunity. J Environ Pathol Toxicol 4:65–79.
Kerr HD, Saryan LA. 1986. Arsenic content of homeopathic medicines. Clin Toxicol 24(5):451–459.
Kerr KB, Cavett JW, Thompson OL. 1963. The toxicity of an organic arsenical, 3-nitro-4-hydroxyl-phenylarsonic acid. I. Acute and subacute toxicity. Toxicol Appl Pharmacol 5:507–525.14032087
Kersjes MP, Maurer JR, Trestrail JH, 1987. An analysis of arsenic exposures referred to the Blodgett Regional Poison Center. Vet Hum Toxicol 29(1):75–78.3824880
Kessel M, Liu SX, Xu A, 2002. Arsenic induces oxidative DNA damage in mammalian cells. Mol Cell Biochem 234–235(1–2):301–308.
Khan AH, Tarafdar SA, Ali M, 1989. The status of trace and minor elements in some Bangladeshi foodstuffs. J Radioanalyt Nuc Chem 134(2):367–381.
Kidwell JM, Phillips LJ, Birchard GF. 1995. Comparative analyses of contaminant levels in bottom feeding and predatory fish using the national contaminant biomonitoring program data. Bull Environ Contam Toxicol 54(6):919–923.7647509
Kim MJ, Nriagu J, Haack S. 2002. Arsenic species and chemistry in groundwater of southeast Michigan. Environ Pollut 120(2):379–390.12395852
Kingston RL, Hall S, Sioris L. 1993. Clinical observations and medical outcome in 149 cases of arsenate ant killer ingestion. J Toxicol Clin Toxicol 31(4):581–591.8254700
Kinney PL, Chillrud SN, Ramstrom S, 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl 4):539–546.12194883
Kitamura M, Kuroda K, Endo Y, 2002. Cysteine enhances clastogenic activity of dimethylarsinic acid. Appl Organomet Chem 16:391–396.
Kitchin KT. 2001. Recent advances in arsenic carcinogenesis: Modes of action, animal model systems, and methylated arsenic metabolites. Toxicol Appl Pharmacol 172(3):249–261.11312654
*Kitchin KT, Ahmad S. 2003. Oxidative stress as a possible mode of action for arsenic carcinogenesis. Toxicol Lett 137(1–2):3–13.12505428
Klemmer HW, Leitis E, Pfenninger K. 1975. Arsenic content of house dusts in Hawaii. Bull Environ Contam Toxicol 14(4):449–452.1191798
Ko Y. 1986. A critical review of epidemiologic studies on blackfoot disease. J Voeh 8(3)339–353.
Kochhar TS, Howard W, Hoffman S, 1996. Effect of trivalent and pentavalent arsenic in causing chromosome alterations in cultured Chinese hamster ovary (CHO) cells. Toxicol Lett 84(1):37–42.8597176
Koh E, Kondoh N, Kaihara H, 1989. Ureteral tumor with multiple Bowen's disease forty-two years after exposure to arsenic. Eur Urol 16:398–400.2776813
*Kollmer WE. 1992. Arsenic in induced hair of the rat and its relation to the content in various organs during chronic exposure. J Trace Elem Electrolytes Health Dis 6(1):11–14.1638178
Komori M, Nishio K, Kitada M 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
Kraus RJ, Ganther HE. 1989. Synergistic toxicity between arsenic and methylated selenium compounds. Biol Trace Elem Res 20:105–113.2484390
Kraus T, Quidenus G, Schaller KH. 2000. Normal values for arsenic and selenium concentrations in human lung tissue. Arch Environ Contam Toxicol 38:384–389.10667938
Kreiss K, Zack MM, Feldman RG, 1983. Neurologic evaluation of a population exposed to arsenic in Alaskan well water. Arch Environ Health 38(2):116–121.6847252
Kreppel H, Bauman JW, Liu J, 1993. Induction of metallothionein by arsenicals in mice. Fundam Appl Toxicol 20:184–189.8449390
Kreppel H, Liu J, Liu Y, 1994. Zinc induced arsenite tolerance in mice. Fundam Appl Toxicol 23:32–37.7958560
Kreppel H, Reichl FX, Kleine A, 1995. Antidotal efficacy of newly synthesized dimercaptosuccinic acid (DMSA) monoesters in experimental arsenic poisoning in mice. Fundam Appl Toxicol 26(2):239–245.7589912
Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kroemer G, de Thé H. 1999. Arsenic trioxide, a novel mitochondriotoxic anticancer agent? J Natl Cancer Inst 91(9):743–745.10328097
Kroes R, van Logten MJ, Berkvens JM, 1974. Study on the carcinogenicity of lead arsenate and sodium arsenate and on the possible synergistic effect of diethylnitrosamine. Food Cosmet Toxicol 12(5–6):671–679.4452539
Kumana CR, Au WY, Lee NSL, 2002. Systemic availability of arsenic from oral arsenic-trioxide used to treat patients with hematological malignancies. Eur J Clin Pharmacol 58:521–526.12451429
Kumaresan M, Riyazuddin P. 2001. Overview of speciation chemistry of arsenic. Curr Sci 80(7):837–846.
Kuroda K, Yoshida K, Yoshimura M, 2004. Microbial metabolite of dimethylarsinic acid is highly toxic and genotoxic. Toxicol Appl Pharmacol 198(3):345–353.15276414
Kurokawa Y, Takahashi M, Maekawa A, 1989. Promoting effect of metal compounds on liver, stomach, kidney, pancreas, and skin carcinogenesis. J Am Coll Toxicol 8(7)1235–1239.
Kurttio P, Komulain H, Hakala E, 1998. Urinary excretion of arsenic species after exposure to arsenic present in drinking water. Arch Environ Contam Toxicol 34:297–305.9504979
Kurttio P, Pukkala E, Kahelin H, 1999. Arsenic concentrations in well water and risk of bladder and kidney cancer in Finland. Environ Health Perspect 107(9):705–710.10464069
Kwon E, Zhang H, Wang Z, 2004. Arsenic on the hands of children after playing in playgrounds. Environ Health Perspect 112(14):1375–1380.15471728
Kyle RA, Pease GL. 1965. Hematologic aspects of arsenic intoxication. N Engl J Med 273(1):18–23.14297088
LaForce MJ, Fendorf SE, Li GC, 1998. A laboratory evaluation of trace element mobility from flooding and nutrient loading of Coeur d'Alene River sediments. J Environ Qual 27:318–328.
Lagerkvist BJ, Zetterlund B. 1994. Assessment of exposure to arsenic among smelter workers: A five-year follow-up. Am J Ind Med 25(4):477–488.7516623
Lagerkvist B, Linderholm H, Nordberg GF. 1986. Vasospastic tendency and Raynaud's phenomenon in smelter workers exposed to arsenic. Environ Res 39:465–474.3956470
Lagerkvist BEA, Linderholm H, Nordberg GF. 1988. Arsenic and Raynaud's phenomenon: Vasospastic tendency and excretion of arsenic in smelter workers before and after the summer vacation. Int Arch Occup Environ Health 60:361–364.3384494
Lai MS, Hsueh YM, Chen CJ, 1994. Ingested inorganic arsenic and prevalence of diabetes mellitus. Am J Epidemiol 139(5):484–492.8154472
*Lakso JU, Peoples SA. 1975. Methylation of inorganic arsenic by mammals. J Agric Food Chem 23:674–676.1141512
*Lambert TW, Lane S. 2004. Lead, arsenic, and polycyclic aromatic hydrocarbons in soil and house dust in the communities surrounding the Sydney, Nova Scotia, tar ponds. Environ Health Perspect 112(1):35–41.14698928
*Lamm SH, Kruse MB. 2004. Ingested arsenic and cancer. What’s new? Presentation of the US Senate Committee on the environment and public works. http://www.ruralwater.org/arsenic/lamm1.ppt. May 09, 2007.
Lamm SH, Engel A, Kruse MB, 2004. Arsenic in drinking water and bladder cancer mortality in the United States: An analysis based on 133 U.S. counties and 30 years of observation. J Occup Environ Med 46(3):298–306.15091293
Lander JJ, Stanley RJ, Sumner HW, 1975. Angiosarcoma of the liver associated with Fowler's solution (potassium arsenite). Gastroenterology 68(6):1582–1586.1169181
Landolph JR. 1994. Molecular mechanisms of transformation of C3H/10T1/2 C1 8 mouse embryo cells and diploid human fibroblasts by carcinogenic metal compounds. Environ Health Perspect 102(Suppl3):119–125.
*Landrigan PJ. 1981. Arsenic-state of the art. Am J Ind Med 2:5–14.6295141
Landsberger S, Simsons A. 1987. Chromium, nickel, and arsenic determinations in human samples by thermal and epithermal neutron activation analyses. Biol Trace Elem Res 13:357–362.24254690
Landsberger S, Wu D. 1995. The impact of heavy metals from environmental tobacco smoke on indoor air quality as determined by Compton suppression neutron activation analysis. Sci Total Environ 173–174(1–6):323–337.
Lantz RC, Hays AM. 2006. Role of oxidative stress in arsenic-induced toxicity. Drug Metab Rev 38:791–804.17145702
Lantzsch H, Gebel T. 1997. Genotoxicity of selected metal compounds in the SOS chromotest. Mutat Res 389(2–3):191–197.9093383
Lanz H, Wallace PC, Hamilton JG. 1950. The metabolism of arsenic in laboratory animals using As^74^ as a tracer. Univ California Publ Pharmacol 2(29):263–282.
Laparra JM, Velez D, Montoro R, 2003. Estimation of arsenic bioaccessibility in edible seaweed by an in vitro digestion method. J Agric Food Chem 51:6080–6085.13129320
*Larochette N, Decaudin D, Jacotot E, 1999. Rapid communication: Arsenite induces apoptosis via a direct effect on the mitochondrial permeability transition pore. Exp Cell Res 249:413–421.10366441
Larramendy ML, Popescu NC, DiPaolo J. 1981. Induction by inorganic metal salts of sister chromatid exchanges and chromosome aberrations in human and Syrian hamster strains. Environ Mutagen 3:597–606.
Larsen EH, Moseholm L, Nielsen MM. 1992. Atmospheric deposition of trace elements around point sources and human health risk assessment: II. Uptake of arsenic and chromium by vegetables grown near a wood preservation factory. Sci Total Environ 126(3):263–275.1439755
Lasky T, Sun W, Kadry A, 2004. Mean total arsenic concentrations in chicken 1989–2000 and estimated exposures for consumers of chicken. Environ Health Perspect 112(1):18–21.14698925
Le XC, Lu X, Li XF. 2004. Arsenic speciation. Anal Chem 76:27A-33A.
Lebow S, Williams RS, Lebow P. 2003. Effect of simulated rainfall and weathering on release of preservative elements from CCA treated wood. Environ Sci Technol 37:4077–4082.14524438
Lebow ST, Lebow PT, Foster DO, 2000. Environmental impact of preservative-treated wood in a wetland boardwalk. U.S. Department of Agriculture, Forest Service. FPL-RP-582.
Lee AM, Fraumeni JF. 1969. Arsenic and respiratory cancer in man: An occupational study. J Natl Cancer Inst 42:1045–1052.5797547
Lee DC, Roberts JR, Kelly JJ, 1995. Whole-bowel irrigation as an adjunct in the treatment of radiopaque arsenic [letter]. Am J Emerg Med 13(2):244–245.7893320
Lee MY, Bae ON, Chung SM, 2002. Enhancement of platelet aggregation and thrombus formation by arsenic in drinking water: A contributing factor to cardiovascular disease. Toxicol Appl Pharmacol 179(2):83–88.11884240
Lee TC, Ho IC. 1994. Differential cytotoxic effects of arsenic on human and animal cells. Environ Health Perspect 102(Suppl 3):101–105.
Lee TC, Oshimura M, Barrett JC. 1985. Comparison of arsenic-induced cell transformation, cytotoxicity, mutation and cytogenetic effects in Syrian hamster embryo cells in culture. Carcinogenesis 6(10):1421–1426.3840060
Lee TC, Tanaka N, Lamb PW, 1988. Induction of gene amplification by arsenic. Science 241:79–81.3388020
Lee TC, Wang-Wuu S, Huang RY, 1986. Differential effects of pre- and posttreatment of sodium arsenite on the genotoxicity of methyl methanesulfonate in Chinese hamster ovary cells. Cancer Res 46:1854–1857.3753897
Lee-Chen SF, Gurr JR, Lin IB, 1993. Arsenite enhances DNA double-strand breaks and cell killing of methyl methanesulfonate-treated cells by inhibiting the excision of alkali-labile sites. Mutat Res 294(1):21–28.7683755
Lee-Chen SF, Yu CT, Jan KY. 1992. Effect of arsenite on the DNA repair of UV-irradiated Chinese hamster ovary cells. Mutagenesis 7(1):51–55.1635456
Lee-Chen SF, Yu CT, Wu DR, 1994. Differential effects of luminol, nickel, and arsenite on the rejoining of ultraviolet light and alkylation-induced DNA breaks. Environ Mol Mutagen 23(2):116–120.8143698
Lee-Feldstein A. 1983. Arsenic and respiratory cancer in man: Follow-up of an occupational study. In: Lederer W, Fensterheim R, eds. Arsenic: Industrial, biomedical and environmental perspectives. New York, NY: Van Nostrand Reinhold, 245–265.
Lee-Feldstein A. 1986. Cumulative exposure to arsenic and its relationship to respiratory cancer among copper smelter employees. J Occup Med 28(4):296–302.3701479
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
Léonard A, Lauwerys RR. 1980. Carcinogenicity, teratogenicity and mutagenicity of arsenic. Mutat Res 75:49–62.6987506
Le Quesne PM, McLeod JG. 1977. Peripheral neuropathy following a single exposure to arsenic. J Neurol Sci 32:437–451.196051
Lerda D. 1994. Sister-chromatid exchange (SCE) among individuals chronically exposed to arsenic in drinking water. Mutat Res 312(2):111–120.7510822
Lerman BB, Ali N, Green D. 1980. Megaloblastic, dyserythropoietic anemia following arsenic ingestion. Ann Clin Lab Science 10(6):515–517.
Lerman S, Clarkson TW, Gerson RJ. 1983. Arsenic uptake and metabolism by liver cells is dependent on arsenic oxidation state. Chem Biol Interact 45:401–406.6883581
Leung HW. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Leung PL, Huang HM. 1997. Analysis of trace elements in the hair of volunteers suffering from nasopharyngeal cancer. Biol Trace Elem Res 57(1):19–25.9258465
Levander OA. 1977. Metabolic interrelationships between arsenic and selenium. Environ Health Perspect 19:159–164.332496
Levander OA, Baumann CA. 1966. Selenium metabolism: VI. Effect of arsenic on the excretion of selenium in the bile. Toxicol Appl Pharm 9:106–115.
Levin-Scherz JK, Patrick JD, Weber FH, 1987. Acute arsenic ingestion. Ann Emerg Med 16(6):702–704.3578979
Lewis DR, Southwick JW, Ouellet-Hellstrom R, 1999. Drinking water in Utah: A cohort mortality study. Environ Health Perspect 107(5):359–365.10210691
*Lewis TA, Hartman CB, McCoy KL. 1998a. Gallium arsenide differentially affects processing of phagolysosmal targeted antigen by macrophages. J Leukoc Biol 63:321–330.9500519
*Lewis TA, Hartmann CB, McCoy KL. 1998b. Gallium arsenide modulates proteolytic cathepsin activities and antigen processing by macrophages. J Immunol 161:2151–2157.9725206
Li JH, Rossman TG. 1989. Inhibition of DNA ligase activity by arsenite: A possible mechanism of its comutagenesis. Mol Toxicol 2:1–9.2615768
Li JH, Rossman TG. 1991. Comutagenesis of sodium arsenite with ultraviolet radiation in Chinese hamster V79 cells. Biol Met 4:197–200.1777354
Li W, Chou IN. 1992. Effects of sodium arsenite on the cytoskeleton and cellular glutathione levels in cultured cells. Toxicol Appl Pharmacol 114(1):132–139.1585365
Li W, Wanibuchi H, Salim EI, 1998. Promotion of the NCI-Black-Reiter male rat bladder carcinogenesis by dimethylarsinic acid an organic arsenic compound. Cancer Lett 134(1):29–36.10381127
*Li W, Wei C, Zhang C, 2003. A survey of arsenic species in Chinese seafood. Food Chem Toxicol 41(8):1103–1110.12842178
*Li YM, Broome JD. 1997. Apoptosis induced in premyelocytic leukemia cells by arsenic and proteasome inhibitors. Blood 90(10):203b.
*Li YM, Broome JD. 1999. Arsenic targets tubulins to induce apoptosis in myeloid leukemia cells. Cancer Res 59:776–780.10029061
Lianfang W, Jianzhong H. 1994. Chronic arsenism from drinking water in some areas of Xinjiang, China. In: Nriagu JO, ed. Arsenic in the environment: Part II: Human health and ecosystem effects. New York, NY: John Wiley and Sons, Inc., 159–172.
Liao WT, Chang KL, Chen GS, 2004. Arsenic induces human keratinocyte apoptosis by the FAS/FAS ligand pathway, which correlates with alterations in nuclear factor-κB and activator protein-1 activity. J Invest Dermatol 122(1):125–129.14962100
Liebscher K, Smith H. 1968. Essential and nonessential trace elements: A method of determining whether an element is essential or nonessential in human tissue. Arch Environ Health 17:881–890.5699297
Lin JK, Tseng S. 1992. Chromosomal aberrations and sister-chromatid exchanges induced by N-nitroso-2-acetylaminofluorene and their modifications by arsenite and selenite in Chinese hamster ovary cells. Mutat Res 265(2):203–210.1370719
*Lin TH, Huang Y, Tseng W. 1995. Arsenic and lipid peroxidation in patients with blackfoot disease. Bull Environ Contam Toxicol 54(4):488–493.7767024
Lindgren A, Danielsson BRG, Dencker L, 1984. Embryotoxicity of arsenite and arsenate: Distribution in pregnant mice and monkeys and effects on embryonic cells in vitro. Acta Pharmacol Toxicol 54:311–320.
Lindgren A, Vahter M, Dencker L. 1982. Autoradiographic studies on the distribution of arsenic in mice and hamsters administered ^74^As-arsenite or -arsenate. Acta Pharmacol Toxicol 51:253–265.
Liou SH, Lung JC, Chen YH, 1999. Increased chromosome-type chromosome aberration frequencies as biomarkers of cancer risk in a blackfoot endemic area. Cancer Res 59(7):1481–1484.10197617
Lithner G, Holm K, Borg H. 1995. Bioconcentration factors for metals in humic waters at different pH in the Röbbskär area (N. Sweden). Water, Air and Soil Pollution 85:785–790.
Little RE, Kay GN, Cavender JB, 1990. Torsade de pointes and T-U wave alternans associated with arsenic poisoning. PACE 13:164–170.1689832
Liu YC, Huang H. 1997. Involvement of calcium-dependent protein kinase C in arsenite-induced genotoxicity in Chinese hamster ovary cells. J Cell Biochem 64(3):423–433.9057100
Liu YT, Chen Z. 1996. A retrospective lung cancer mortality study of people exposed to insoluble arsenic and radon. Lung Cancer 14(Suppl 1):137–148.
Liu J, Liu Y, Goyer RA, 2000. Metallothionein-I/II null mice are more sensitive than wild-type mice to the hepatotoxic and nephrotoxic effects of chronic oral or injected inorganic arsenicals. Toxicol Sci 55(2):460–467.10828279
*Liu J, Y, Ducharme DM, 2006. Global gene expression associated with hepatocarcinogenesis in adult male mice induced by in utero arsenic exposure. Environ Health Perspect 114(3):404–411.16507464
Liu J, Zheng B, Aposhian HV, 2002. Chronic arsenic poisoning from burning high-arsenic-containing coal in Guizhou, China. Environ Health Perspect 110(2):119–122.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
Loebenstein JR. 1994. The materials flow of arsenic in the United States. Washington, DC: Bureau of Mines, Division of Mineral Commodities, United States Department of the Interior. BUMINES-IC-9382.
Loffredo CA, Aposhian HV, Cebrian ME, 2003. Variability in human metabolism of arsenic. Environ Res 92(2):85–91.12854687
Löfroth G, Ames BN. 1978. Mutagenicity of inorganic compounds in Salmonella typhimurium: arsenic, chromium, and selenium. Mutat Res 53:65–66.
López-Gonzálvez MA, Gómez MM, Cámara C, 1994. On-line microwave oxidation for the determination of organoarsenic compounds by high-performance liquid chromatography-hydride generation atomic absorption spectrometry. J Anal Atom Spectrom 9(3):291–295.
Lovell MA, Farmer JG. 1985. Arsenic speciation in urine from humans intoxicated by inorganic arsenic compounds. Hum Toxicol 4:203–214.4007884
Lowney YW, Ruby MV, Wester RC, 2005. Percutaneous absorption of arsenic from environmental media. Toxicol Ind Health 21(1–2):1–14.15986571
Lu FJ, Shih SR, Liu TM, 1990. The effect of fluorescent humic substances existing in the well water of blackfoot disease endemic areas in Taiwan on prothrombin time and activated partial thromboplastin time in vitro. Thromb Res 57:747–753.2140208
Lu M, Wang H, Li XF, 2004a. Evidence of hemoglobin binding to arsenic as a basis for the accumulation of arsenic in rat blood. Chem Res Toxicol 17(12):1733–1742.15606151
*Lu SN, Chow NH, Wu WC, 2004b. Characteristics of hepatocellular carcinoma in a high arsenicism area in Taiwan: A case-control study. J Occup Environ Med 46(5):437–441.15167390
*Lubin JH, Fraumeni JF. 2000. Re: "Estimates of the annual number of clinically recognized pregnancies in the United States, 1981–1991". Am J Epidemiol 152(3):297–293.10968374
Lubin JH, Pottern LM, Stone BJ, 2000. Respiratory cancer in a cohort of copper smelter workers: Results from more than 50 years of follow-up. Am J Epidemiol 151(6):554–565.10733037
Lüchtrath H. 1983. The consequences of chronic arsenic poisoning among Moselle wine growers: Pathoanatomical investigations of post-mortem examinations performed between 1960 and 1977. J Cancer Res Clin Oncol 105:173–182.6826638
Lugo G, Cassady G, Palmisano P. 1969. Acute maternal arsenic intoxication with neonatal death. Am J Dis Child 117:328–330.5765153
Luong KVQ, Nguyen LTH. 1999. Organic arsenic intoxication from bird's nest soup. Am J Med Sci 317(4):269–271.10210366
Luten JB, Riekwel-Booy G, Rauchbaar A. 1982. Occurrence of arsenic in plaice (Pleuronectes platessa), nature of organo-arsenic compound present and its excretion by man. Environ Health Perspect 45:165–170.7140692
Lynn S, Lai HT, Gurr JR, 1997. Arsenite retards DNA break rejoining by inhibiting DNA ligation. Mutagenesis 12(5):353–358.9379914
Mabuchi K, Lilienfeld AM, Snell LM. 1979. Lung cancer among pesticide workers exposed to inorganic arsenicals. Arch Environ Health 34:312–320.496426
MacIntosh DL, Williams PL, Hunter DJ, 1997. Evaluation of a food frequency questionnaire-food composition approach for estimating dietary intake of inorganic arsenic and methylmercury. Cancer Epidemiol Biomarkers Prev 6(12):1043–1050.9419401
Maehashi H, Murata Y. 1986. Arsenic excretion after treatment of arsenic poisoning with DMSA or DMPS in mice. Jpn J Pharmacol 40:188–190.3007828
Mahaffey KR, Fowler BA. 1977. Effects of concurrent administration of lead, cadmium, and arsenic in the rat. Environ Health Perspect 19:165–171.198203
Mahaffey KR, Capar SG, Gladen BC, 1981. Concurrent exposure to lead, cadmium and arsenic. Effects on toxicity and tissue metal concentrations in the rat. J Lab Clin Med 98(1):463–481.7288264
*Mahajan SK, Aggarwal HK, Wig N, 1992. Arsenic induced neuropathy. J Assoc Physicians India 40(4):268–269.1333468
Mahata J, Basu A, Ghosal S, 2003. Chromosomal aberrations and sister chromatid exchanges in individuals exposed to arsenic through drinking water in West Bengel, India. Mutat Res 534(1–2):133–143.12504762
Maher WA. 1989. Some observations on the determination of total arsenic in biological tissues. Microchem J 40:132–135.
*Mahieu P, Buchet J, Lauwerys R. 1987. Evolution clnique et biologique d'une intoxication orale aiguë par l'anhydride arsénieux et considérations sur l'attitude thérapeutique. J Toxicol Clin Exp 7:273–278.3694557
Maiorino RM, Aposhian HV. 1985. Dimercaptan metal-binding agents influence the biotransformation of arsenite in the rabbit. Toxicol Appl Phamacol 77:240–250.
Maitani T, Saito N, Abe M, 1987a. Chemical form-dependent induction of hepatic zinc-thionein by arsenic administration and effect of co-administered selenium in mice. Toxicol Lett 39:63–70.3672556
*Maitani T, Uchiyama S, Saito Y. 1987b. Hydride generation-flame atomic-absorption spectrometry as an arsenic detector for high-performance liquid chromatography. J Chromatogr 391:161–168.3584315
*Man ACK, Zheng YH, Mak PK. 1996. Trace elements in scalp hair of professional drivers and university teachers in Hong Kong. Biol Trace Elem Res 53(1–3):241–247.8862753
Mandal BK, Suzuki KT. 2002. Arsenic around the world: A review. Talanta 58:201–235.18968746
Mandal BK, Ogra Y, Suzuki KT. 2001. Identification of dimethylarsinous and monomethylarsonous. Chem Res Toxicol 14(4):371–378.11304125
Mandal BK, Ogra Y, Suzuki KT. 2003. Speciation of arsenic in human nail and hair from arsenic-affected area by HPLC-inductively coupled argon plasma mass spectrometry. Toxicol Appl Pharmacol 189(2):73–83.12781625
Mann S, Droz PO, Vahter M. 1996a. A physiologically based pharmacokinetic model for arsenic exposure. I. Development in hamsters and rabbits. Toxicol Appl Pharmacol 137(1):8–22.8607145
Mann S, Droz PO, Vahter M. 1996b. A physiologically based pharmacokinetic model for arsenic exposure. II. Validation and application in humans. Toxicol Appl Pharmacol 140(2):471–486.8887465
Mappes R. 1977. [Experiments on excretion of arsenic in urine.] Int Arch Occup Environ Health 40:267–272. (German)598936
Marafante E, Vahter M. 1984. The effect of methyltransferase inhibition on the metabolism of [^74^As] arsenite in mice and rabbits. Chem Biol Interact 50:49–57.6733804
Marafante E, Vahter M. 1986. The effect of dietary and chemically induced methylation deficiency on the metabolism of arsenate in the rabbit. Acta Pharmacol Toxicol 59(Suppl 7):35–38.
Marafante E, Vahter M. 1987. Solubility, retention and metabolism of intratracheally and orally administered inorganic arsenic compounds in the hamster. Environ Res 42:72–82.3803345
Marafante E, Lundborg M, Vahter M, 1987a. Dissolution of two arsenic compounds by rabbit alveolar macrophages in vitro. Fundam Appl Toxicol 8:382–388.3569708
*Marafante E, M, Dencker L. 1984. Metabolism of arsenocholine in mice, rats and rabbits. Sci Total Environ 34:223–240.6719099
Marafante E, Vahter M, Envall J. 1985. The role of the methylation in the detoxication of arsenate in the rabbit. Chem Biol Interact 56:225–238.4075449
Marafante E, Vahter M, Norin H, 1987b. Biotransformation of dimethylarsinic acid in mouse, hamster and man. J Appl Toxicol 7(2):111–117.3624766
Marcus WL, Rispin AS. 1988. Threshold carcinogenicity using arsenic as an example. In: Cothern CR, Mehlman MA, Marcus WL, eds. Advances in modern environmental toxicology. Vol. XV: Risk assessment and risk management of industrial and environmental chemicals. Princeton, NJ: Princeton Scientific Publishing Co., 133–158.
Margitich DJ, Ackerman LJ. 1991a. Caccdylic acid 21 day toxicity study in rabbit. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41872801.
Margitich DJ, Ackerman LJ. 1991b. Methanearsonic acid 21 day dermal toxicity study in rabbits. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41872701.
Mariner PE, Holzmer FJ, Jackson RE, 1996. Effects of high pH on arsenic mobility in a shallow sandy aquifer and on aquifer permeability along the adjacent shoreline, Commencement Bay Superfund Site, Tacoma, Washington. Environ Sci Tech 30(5):1645–1651.
*Marlowe M, Cossairt A, Moon C, 1985. Main and interaction effects of metallic toxins on classroom behavior. J Abnorm Child Psychol 13(2):185–198.4008752
Martin DS, Willis SE, Cline DM. 1990. N-Acetylcysteine in the treatment of human arsenic poisoning. J Am Board Fam Pract 3:293–296.2248097
Martínez V, Creus A, Venegas W, 2004. Evaluation of micronucleus induction in a Chilean population environmentally exposed to arsenic. Mutat Res 564(1):65–74.15474412
Martínez V, Crues A, Venegas W, 2005. Micronuclei assessment in buccal cells of people environmentally exposed to arsenic in northern Chile. Toxicol Lett 155:319–327.15603927
Mason RP, Laporte JM, Andres S. 2000. Factors controlling the bioaccumulation of mercury, methylmercury, arsenic, selenium, and cadmium by freshwater invertebrates and fish. Arch Environ Contam Toxicol 38:283–97.10667925
Mason RW, Edwards IR, Fisher LC. 1989. Teratogenicity of combinations of sodium dichromate, sodium arsenate and copper sulphate in the rat. Comp Biochem Physiol 93(2):407–411.
Matanoski G, Landau E, Tonascia J, 1981. Cancer mortality in an industrial area of Baltimore. Environ Res 25:8–28.7238470
Matschullat J. 2000. Arsenic in the geosphere - a review. Sci Total Environ 249:297–312.10813460
Matsui M, Nishigori C, Toyokuni S, 1999. The role of oxidative DNA damage in human arsenic carcinogenesis: Detection of 8-hydroxy-2'-deoxyguanosine in arsenic-related Bowen's disease. J Invest Dermatol 113:26–31.10417614
Matthews EJ, Spalding JW, Tennant RW. 1993. Transformation of BALB/c-3T3 cells: V. Transformation responses of 168 chemicals compared with mutagenicity in Salmonella and carcinogenicity in rodent bioassays. Environ Health Perspect 101(Suppl 2):347–482.8243403
May TW, Wiedmeyer RH, Gober J, 2001. Influence of mining-related activities on concentrations of metals in water and sediment from streams of the Black Hills, South Dakota. Arch Environ Contam Toxicol 40:1–9.11116335
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mazumdar S, Redmond CK, Enterline PE, 1989. Multistage modeling of lung cancer mortality among arsenic-exposed copper-smelter workers. Risk Anal 9(4):551–563.2608948
McDorman EW, Collins BW, Allen JW. 2002. Dietary folate deficiency enhances induction of micronuclei by arsenic in mice. Environ Mol Mutagen 40(1):71–77.12211079
McFall TL, Richards S, Matthews G. 1998. Rehabilitation in an individual with chronic arsenic poisoning: Medical, psychological, and social implications. J Spinal Cord Med 21(2):142–147.9697091
McGeehan SL. 1996. Arsenic sorption and redox reactions: Relevance to transport and remediation. J Environ Sci Health A 31(9):2319–2336.
McGeehan SL, Fendorf SE, Naylor DV. 1998. Alteration of arsenic sorption in flooded-dried soils. Soil Sci Soc Am J 62:828–833.
McLaren RG, Naidu R, Smith J, 1998. Fractionation and distribution of arsenic in soils contaminated by cattle dip. J Environ Qual 27:348–354.
Meacher DM, Menzel DB, Dillencourt MD, 2002. Estimation of multimedia inorganic arsenic intake in the U.S. population. Hum Ecol Risk Assess 8(7):1697–1721.
Meharg AA, Rahman M. 2003. Arsenic contamination of Bangladesh paddy field soils: Implications fro rice contribution to arsenic consumption. Environ Sci Technol 37:229–234.12564892
Meister RT, ed. 1987. Farm chemicals handbook. Willoughby, OH: Meister Publishing. Section C:21, 46–47, 101, 177–178, 230–231.
Meister RT, ed. 1999. Farm chemicals handbook '99. Willoughby, OH: Meister Publishing Company.
Meister RT, Sine C, Sharp DT, 2006. Crop protection handbook 2006. Willohughby, OH: Meister Media Worldwide, D 65.
Meng Z. 1993a. Effects of arsenic on DNA synthesis in human lymphocytes stimulated by phytohemagglutinin. Biol Trace Elem Res 39(1):73–80.7505101
Meng Z. 1993b. Effects of arsenic on DNA synthesis in human lymphocytes. Arch Environ Contam Toxicol 25(4)525–528.8239717
Meng Z. 1994. Effects of arsenic on DNA synthesis in human lymphocytes. In: Nraigu JO, ed. Arsenic in the environment, part II: Human health and ecosystem effects. New York, NY: John Wiley & Sons, Inc., 133–142.
Meng Z, Hsie AW. 1996. Polymerase chain reaction-based deletion analysis of spontaneous and arsenite-enhanced gpt mutants in CHO-As_52_ cells. Mutat Res 356(2)255–259.8841493
Menzel DB, Rasmussen RE, Lee E, 1998. Human lymphocyte heme oxygenase 1 as a response biomarker to inorganic arsenic. Biochem Biophys Res Commun 250:653–656.9784401
Menzel DB, Ross M, Oddo SV, 1994. A physiologically based pharmacokinetic model for ingested arsenic. Environ Geochem Health 16:209–218.
Merwin I, Pruyne PT, Ebel JG, 1994. Persistence, phytotoxicity, and management of arsenic, lead and mercury residues in old orchard soils of New York State. Chemosphere 29(6):1361–1367.
*Meyer I, Heinrich J, Lippold U. 1999. Factors affecting lead, cadmium, and arsenic levels in house dust in a smelter town in eastern Germany. Environ Res 81:32–44.10361024
Michaud DS, Wright ME, Cantor KP, 2004. Arsenic concentrations in prediagnostic toenails and the risk of bladder cancer in a cohort study of male smokers. Am J Epidemiol 160(9):853–859.15496537
Miles AK, Tome MW. 1997. Spatial and temporal heterogeneity in metallic elements in industrialized aquatic bird habitats. Environ Pollut 95(1):75–84.15093476
Milham S, Strong T. 1974. Human arsenic exposure in relation to a copper smelter. Environ Res 7:176–182.
Miller M. 1998. Scientists explore use of arsenic in therapy. J Natl Cancer Inst 90(24):1866–1867.9862622
Milton AH, Rahman M. 2002. Respiratory effects and arsenic contaminated well water in Bangladesh. Int J Environ Health Res 12(2):175–179.12400554
Milton AH, Hasan Z, Shahidullah SM, 2004. Association between nutritional status and aresnicosis due to chronic arsenic exposure in Bangladesh. Int J Environ Health Res 14(2):99–108.15203455
Milton AH, Smith W, Rahman B, 2005. Chronic arsenic exposure and adverse pregnancy outcomes in Bangladesh. Epidemiology 16(1):82–86.15613949
Mirkes PE, Cornel L. 1992. A comparison of sodium arsenite- and hyperthermia-induced stress responses
*Mitra K, Kundu SN, Khuda AR Bukhsh. 1999. Efficacy of a potentized homoeopathic drug (Arsenic Album-30) in reducing toxic effects produced by arsenic trioxide in mice: II. On alterations in body weight and total protein. Complement Ther Med 7:24–34.10361568
Mitra SR, Mazumder DN, Basu A, 2004. Nutritional factors and susceptibility to arsenic-caused skin lesions in West Bengal, India. Environ Health Perspect 112(10):1104–1109.15238285
Miyazaki K, Ushijima K, Kadono T, 2003. Negative correlation between urinary selenium and arsenic levels of the residents living in an arsenic-contaminated area in Bangladesh. J Health Sci 49(3):239–242.
Mizuta N, Mizuta M, Ito F, 1956. An outbreak of acute arsenic poisoning caused by arsenic-contaminated soy-sauce (shoyu): A clinical report of 220 cases. Bull Yamaguchi Med Sch 4(2–3):131–149.
Mohamed KB. 1998. Occupational contact dermatitis from arsenic in a tin-smelting factory. Contact Dermatitis 38:224–225.
Mok WM, Wai CM. 1994. Mobilization of arsenic in contaminated river waters. In: Nriagu JO, ed. Arsenic in the environment, part 1: Cycling and characterization. New York, NY: John Wiley & Sons, Inc., 99–117.
Mok WM, Riley JA, Wai CM. 1988. Arsenic speciation and quality of groundwater in a lead-zinc mine, Idaho. Water Res 22(6):769–774.
Moore, O'Callaghan CA, Berlyne G, 1994a. Acute arsenic poisoning: Absence of polyneuropathy after treatment with 2,3-dimercaptopropanesulphonate (DMPS). J Neurol Neurosurg Psychiatry 57(9):1133–1135.8089687
Moore JN, Ficklin WH, Johns C. 1988. Partitioning of arsenic and metals in reducing sulfidic sediments. Environ Sci Technol 22:432–437.
Moore LE, Lu M, Smith AH. 2002. Childhood cancer incidence and arsenic exposure in drinking water in Nevada. Arch Environ Health 57(3):201–206.12507173
Moore LE, Smith AH, Hopenhayn-Rich C, 1995. Increased bladder cells micronuclei in two populations environmentally exposed to arsenic in drinking water. Clin Chem 41(12 Part 2)1915–1917.
Moore LE, Smith AH, Hopenhayn-Rich C, 1997a. Micronuclei in exfoliated bladder cells among individuals chronically exposed to arsenic in drinking water. Cancer Epidemiol Biomarkers Prev 6(1)31–36.8993795
Moore LE, Warner ML, Smith AH, 1996. Use of the fluorescent micronucleus assay to detect the genotoxic effects of radiation and arsenic exposure in exfoliated human epithelial cells. Environ Mol Mutagen 27(3):176–184.8625953
Moore MM, Harrington-Brock K, Doerr CL. 1994b. Genotoxicity of arsenic and its methylated metabolites. Environ Geochem Health 16:191–198.24197213
*Moore MM, Harrington-Brock K, Doerr CL. 1997b. Relative genotoxic potency of arsenic and its methylated metabolites. Mutat Res 386(3):279–290.9219565
*Moreira JC. 1996. Threats by heavy metals: Human and environmental contamination in Brazil. Sci Total Environ 188(Suppl 1):S61–S71.8888629
Morris JS, Schmid M, Newman S, 1974. Arsenic and noncirrhotic portal hypertension. Gastroenterology 66(1):86–94.4809505
Morrissey RE, Mottet NK. 1983. Arsenic-induced exencephaly in the mouse and associated lesions occurring during neurulation. Teratology 28:399–411.6665738
Moriss-Kay GM, Wood H, Chen W. 1994. Normal neurulation in mammals. In: Ciba Foundation Symposium, neural tube defects. New York: John Wiley & Sons, 51–69.
Morse DL, Harrington JM, Housworth J, 1979. Arsenic exposure in multiple environmental media in children near a smelter. Clin Toxicol 14(4):389–399.466981
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
Morton W, Starr G, Pohl D, 1976. Skin cancer and water arsenic in Lane County, Oregon. Cancer 37:2523–2532.1260732
Morton WE, Caron GA. 1989. Encephalopathy: An uncommon manifestation of workplace arsenic poisoning? Am J Ind Med 15:1–5.2929604
Mottet NK, Ferm VH. 1983. The congenital teratogenicity and perinatal toxicity of metals. In: Clarkson TW, Nordberg GF, Sager PR, eds. Reproductive and developmental toxicity of metals. New York, NY: Plenum Press, 93–125.
Moxon AL, Paynter CR, Halverson AW. 1945. Effect of route of administration on detoxication of selenium by arsenic. J Pharmacol Exp Ther 84:115–119.
Mukherjee S, Das D, Darbar S, 2003. Dietary intervention affects arsenic-generated nitric oxide and reactive oxygen intermediate toxicity in islet cells of rats. Curr Sci 85(6):786–793.
Mukherjee S, Das D, Darbar S, 2004. Arsenic trioxide generates oxidative stress and islet cell toxicity in rabbit. Curr Sci 86(6):854–857.
Mumford JL, Wu K, Xia Y, 2007. Chronic arsenic exposure and cardiac repolarization abnormalities with QT interval prolongation in a population-based study. Environ Health Perspect 115(5):690–694.17520054
Mumma RO, Raupach DC, Waldman JP, 1984. National survey of elements and other constituents in municipal sewage sludges. Arch Environ Contam Toxicol 13:75–83.
Murai T, Iwata H, Otoshi T, 1993. Renal lesions induced in F34/DuCrj rats by 4-weeks oral administration of dimethylarsinic acid. Toxicol Lett 66:53–61.8427021
*Murata K, Iwazawa T, Takayama T, 1994. Quadruple cancer including Bowen's disease after arsenic injections 40 years earlier: Report of a case. Surg Today 24(12):1115–1118.7780240
Mure K, Uddin AN, Lopez LC, 2003. Arsenite induces delayed mutagenesis and transformation in human osteosarcoma cells at extremely low concentrations. Environ Mol Mutagen 41:322–331.12802802
Murphy MJ, Lyon LW, Taylor JW. 1981. Subacute arsenic neuropathy: Clinical and electrophysiological observations. J Neurol Neurosurg Psychiatry 44:896–900.6273506
Mushak P, Crocetti AF. 1995. Risk and revisionism in arsenic cancer risk assessment. Environ Health Perspect 103(7–8):684–689.7588479
Mushak P, Dessauer K, Walls EL. 1977. Flameless atomic absorption (FAA) and gas-liquid chromatographic studies in arsenic bioanalysis. Environ Health Perspect 19:5–10.908312
Muzi G, dell'Omo M, Madeo G, 2001. Arsenic poisoning caused by Indian ethnic remedies. J Pediatr 139(1):169.11445819
Nagai N, Usui T, Asahi A, 1956. Comparison of biochemical findings and clinical pictures on subacute or chronic arsenic poisoning of infants due to arsenic containing powdered milk. NTIS no. PB-258710-T.
Nagymajtényi L, Selypes A, Berencsi G. 1985. Chromosomal aberrations and fetotoxic effects of atmospheric arsenic exposure in mice. J Appl Toxicol 5(2):61–63.3998376
Nakadaira H, Endoh K, Katagiri M, 2002. Elevated mortality from lung cancer associated with arsenic exposure for a limited duration. J Occup Environ Med 44(3):291–299.11911031
Nakamuro K, Sayato Y. 1981. Comparative studies of chromosomal aberrations induced by trivalent and pentavalent arsenic. Mutat Res 88:73–80.7207493
NAS. 1977a. Medical and biologic effects of environmental pollutants: Arsenic. Washington, DC: National Academy of Sciences. http://www.nap.edu/books/0309026040/html/index.html. May 12, 2005.
NAS. 1977b. Arsenic. Drinking water and health. Washington, DC: National Academy of Sciences, 316–344, 428–430.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
Navas-Acien A, Sharrett AR, Silbergeld EK, 2005. Arsenic exposure and cardiovascular disease: A systematic review of the epidemiologic evidence. Am J Epidemiol 162(11):1037–1049.16269585
*Navas-Acien A, Silbergeld EK, Streeter RA, 2006. Arsenic exposure and type 2 diabetes: A systematic review of the experimental and epidemiological evidence. Environ Health Perspect 114(5):641–648.16675414
Neiger RD, Osweiler GD. 1989. Effect of subacute low level dietary sodium arsenite on dogs. Fundam Appl Toxicol 13:439–451.2612777
Neiger RD, Osweiler GD. 1992. Arsenic concentrations in tissues and body fluids of dogs on chronic low level dietary sodium arsenite. J Vet Diagn Invest 4:334–337.1515496
*Nelson WC, Lykins MH, Mackey J, 1973. Mortality among orchard workers exposed to lead arsenate spray: A cohort study. J Chronic Dis 26:105–118.4694190
Nemec MD, Holson JF, Farr CH, 1998. Developmental toxicity assessment of arsenic acid in mice and rabbits. Reprod Toxicol 12(6):647–658.9875698
Newman JA, Archer VE, Saccomanno G, 1976. Histologic types of bronchogenic carcinoma among members of copper-mining and smelting communities. Ann N Y Acad Sci 271:260–268.187098
Nielson KK, Sanders RW. 1983. Multielement analysis of unweighed biological and geological samples using backscatter and fundamental parameters. Advances in X-ray Analysis 26:385–390.
NIOSH. 1984. Arsenic trioxide, as As - method 7901. In: NIOSH manual of analytical methods. 3rd ed. Vol. 1. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, DHHS (NIOSH) Publication no. 84–100. PB85179018.
NIOSH. 1994a. Method 7900. Arsenic and compounds, as As (except AsH_3_ and As_2_O_3_). In: NIOSH manual of analytical methods (NMAM). 4th edition. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7900.pdf. August 10, 2007.
NIOSH. 1994b. Method 7901. Arsenic trioxide, as As. In: NIOSH manual of analytical methods (NMAM). 4th edition. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/7901.pdf. August 10, 2007.
NIOSH. 1994c. Method 5022. Arsenic, organo-. In: NIOSH manual of analytical methods (NMAM). 4th edition. National Institute for Occupational Safety and Health. August 1994. http://www.cdc.gov/niosh/nmam/pdfs/5022.pdf. August 10, 2007.
NIOSH. 1994d. Method 6001. Arsine. In: NIOSH manual of analytical methods (NMAM). 4th edition. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/nmam/pdfs/6001.pdf. August 10, 2007.
*NIOSH. 1994e. NIOSH Manual of Analytical Methods. 4th ed., August 15, 1994. Cincinnati, OH: U.S. Department of Health and Human Services, Public Health Service, Centers for Disease Control, National Institute for Occupational Safety and Health, DHHS. Method 7300 - Elements by ICP; Method 7900 - Arsenic; method 5022 - Arsenic, organo; Method 7901 - Arsenic trioxide.
NIOSH. 2003. Method 7300. Elements by ICP (nitric/perchloric acid ashing). NIOSH manual of analytical methods (NMAM). 4th ed. Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication 94–113. http://www.cdc.gov/niosh/nmam/pdfs/7300.pdf. March 21, 2006.
NIOSH. 2005a. Arsenic. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgdname.html. February 15, 2004.
*NIOSH. 2005b. International Chemical Safety Cards (ICSCs): U.S. National Version. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/ipcs/nicstart.html. April 7, 2005.
Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31:185–189.805366
NOES. 1990. National Occupational Exposure Survey, National Institute for Occupational Safety and Health, Cincinnati, OH. July 16, 1990.
Nordenson I, Beckman G, Beckman L, 1978. Occupational and environmental risks in and around a smelter in northern Sweden: II. Chromosomal aberrations in workers exposed to arsenic. Hereditas 88:47–50.649424
Nordenson I, Salmonsson S, Brun E, 1979. Chromosome aberrations in psoriatic patients treated with arsenic. Hum Genet 48:1–6.457124
Nordenson I, Sweins A, Beckman L. 1981. Chromosome aberrations in cultured human lymphocytes exposed to trivalent and pentavalent arsenic. Scand J Work Environ Health 7:277–281.6897125
Nordström S, Beckman L, Nordenson I. 1978a. Occupational and environmental risks in and around a smelter in northern Sweden. I. Variations in birthweight. Hereditas 88:43–46.649423
Nordström S, Beckman L, Nordenson I. 1978b. Occupational and environmental risks in and around a smelter in northern Sweden. III. Frequencies of spontaneous abortion. Hereditas 88:51–54.649425
Nordström S, Beckman L, Nordenson I. 1979a. Occupational and environmental risks in and around a smelter in northern Sweden. V. Spontaneous abortion among female employees and decreased birth weight in their offspring. Hereditas 90:291–296.437992
Nordström S, Beckman L, Nordenson I. 1979b. Occupational and environmental risks in and around a smelter in northern Sweden. VI. Congenital malformations. Hereditas 90:297–302.437993
Norin H, Vahter M. 1981. A rapid method for the selective analysis of total urinary metabolites of inorganic arsenic. Scand J Work Environ Health 7:38–44.7313608
Norin H, Christakopoulos A, Rondahl L, 1987. Identification and quantification of arsenocholine and acetylarsenocholine in trace amounts in biological material by use of pyrolysis gas chromatography/mass spectrometry. Biomed Environ Mass Spectrom 14:117–125.2953397
NPIRS. 2007. Chemical ingredients: Arsenic. National Pesticide Information Retrieval System. http://ppis.ceris.purdue.edu/htbin/epachem.com. February 7, 2007.
NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
NRC. 1999. Arsenic in drinking water. National Research Council. Washington, DC: National Academy Press.
NRC. 2001. Arsenic in drinking water. 2001 Update. National Research Council. Washington, DC: National Academy Press.
*Nriagu JO. 1988. A silent epidemic of environmental metal poisoning? Environ Pollut 50:139–161.15092656
Nriagu JO, Lin T. 1995. Trace metals in wild rice sold in the United States. Sci Total Environ 172(2–3):223–228.
Nriagu JO, Pacyna JM. 1988. Quantitative assessment of worldwide contamination of air, water and soils by trace metals. Nature 333:134–139.3285219
*NTP. 1989a. National Toxicology Program. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. NTP 89–239.
NTP. 1989b. National Toxicology Program - technical report series no. 345. Toxicology and carcinogenesis studies of roxarsone (CAS No. 121–19-7) in F344/N rats and B6C3F1 mice (feed studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health. NTP-TR-345. NIH pub no. 89–2800.
NTP. 2005. Report on carcinogens. 11 ed. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. February 15, 2004.
Nygren O, Nilsson CA, Lindahl R. 1992. Occupational exposure to chromium, copper and arsenic during work with impregnated wood in joinery shops. Ann Occup Hyg 36(5)509–517.1444070
Oberly TJ, Hoffman WP, Garriott ML. 1996. An evaluation of the twofold rule for assessing a positive response in the L5178Y TK^*/-^mouse lymphoma assay. Mutat Res 369 (3–4):221–232.8792840
Oberly TJ, Piper CE, McDonald DS. 1982. Mutagenicity of metal salts in the L5178Y mouse lymphoma assay. J Toxicol Environ Health 9:367–376.7097791
Odanaka Y, Matano O, Goto S. 1980. Biomethylation of inorganic arsenic by the rat and some laboratory animals. Bull Environ Contam Toxicol 24:452–459.
Odanaka Y, Tsuchiya N, Matano O, 1983. Determination of inorganic arsenic and methylarsenic compounds by gas chromatography and multiple ion detection mass spectrometry after hydride generation-heptane cold trap. Anal Chem 55:929–932.6881522
*O’Day PA, Carroll SA, Waychunas GA. 1998. Rock-water interactions controlling zinc, cadmium, and lead concentrations in surface waters and sediments, U.S. Tri-State Mining District. 1. Molecular identification using x-ray absorption spectroscopy. Environ Sci Technol 32(7):943–955.
Offergelt JA, Roels H, Buchet JP, 1992. Relation between airborne arsenic trioxide and urinary excretion of inorganic arsenic and its methylated metabolites. Br J Ind Med 49(6)387–393.1606024
*Ohnishi Y, Murakami S, Ohtsuka H, 1997. Merkel cell carcinoma and multiple Bowen's disease: Incidental association or possible relationship to inorganic arsenic exposure? J Dermatol 24(5):310–316.9198320
Ohyama S, Ishinishi N, Hisanaga A, 1988. Comparative chronic toxicity, including tumorigenicity, of gallium arsenide and arsenic trioxide intratracheally instilled into hamsters. Appl Organomet Chem 2:333–337.
Okada S, Yamanaka K. 1994. Induction of lung-specific DNA damage by methylarsenics via the production of free radials. InNriagu JO, ed. Arsenic in the environment. New York, NY: John Wiley & Sons, Inc., 143–157.
*O’Kamura S, Inoue N. 1999. [Hematological disturbances caused by arsenic poisoning.] Fukuoka Igaku Zasshi 90(2):33–38. (Japanese)10328682
Okui T, Fujiwara Y. 1986. Inhibition of human excision DNA repair by inorganic arsenic and the comutagenic effect in V79 Chinese hamster cells. Mutat Res 172:69–76.3762570
O’Rourke MK, Rogan SP, Jin S, 1999. Spatial distributions of arsenic exposure and mining communities from NHEXAS Arizona. National Human Exposure Assessment Survey. J Expo Anal Environ Epidemiol 9(5):446–455.
OSHA. 2005a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005b. Gases, vapors, fumes, dusts, and mists. Safety and health regulations for construction. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55, Appendix A. http://www.osha.gov/comp-links.html. February 15, 2005.
OSHA. 2005c. Inorganic arsenic. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1018. http://www.osha.gov/comp-links.html. March 24, 2005.
OSHA. 2005d. Limits for air contaminants. Occupational safety and health standards. Washington, DC: Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://www.osha.gov/comp-links.html. February 15, 2005.
O’Shaughnessy E, Kraft GH. 1976. Arsenic poisoning: Long-term follow-up of a nonfatal case. Arch Phys Med Rehabil 57:403–406.949239
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Ott MG, Holder BB, Gordon HL. 1974. Respiratory cancer and occupational exposure to arsenicals. Arch Environ Health 29:250–255.4472855
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Oya-Ohta Y, Kaise T, Ochi T. 1996. Induction of chromosomal aberrations in cultured human fibroblasts by inorganic and organic arsenic compounds and the different roles of glutathione in such induction. Mutat Res 357(1–2)123–129.8876688
Øygard JK, Lundebye A, Julshamin K. 1999. Determination of inorganic arsenic in marine food samples by hydrochloric acid distillation and flow-injection hydride-generation atomic absorption spectrometry. J AOAC Int 82(5):1217–1223.10513019
Pacyna JM. 1987. Atmospheric emissions of arsenic, cadmium, lead and mercury from high temperature processes in power generation and industry. In: Hutchinson TC, Meema KM, eds. Lead, mercury, cadmium and arsenic in the environment. New York: John Wiley & Sons Ltd., 69–87.
Pacyna JM, Scholtz MT, Li Y. 1995. Global budget of trace metal sources. Environ Rev 3(2):145–159.
Page BJ, Loar GW. 1993. Chromium compounds. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 6. New York, NY: John Wiley and Sons, 297–298.
Page GW. 1981. Comparison of groundwater and surface water for patterns and levels of contamination by toxic substances. Environ Sci Technol 15(12):1475–1481.
Pantsar-Kallio M, Manninen PKG. 1997. Speciation of mobile arsenic in soil samples as a function of pH. Sci Total Environ 204(2):193–200.
Park J, Presley BJ. 1997. Trace metal contamination of sediments and organisms from the Swan Lake area of Galveston Bay. Environ Pollut 98(2):209–221.
Paschal DC, DiPietro ES, Phillips DL, 1989. Age dependence of metals in hair in a selected US population. Environ Res 48:17–28.2914563
Pascoe GA, Blanchet RJ, Linder G. 1994. Bioavailability of metals and arsenic to small mammals at a mining waste-contaminated wetland. Arch Environ Contam Toxicol 27:44–50.8024321
Pedersen GA, Mortensen GK, Larsen EH. 1994. Beverages as a source of toxic trace element intake. Food Addit Contam 11(3):351–363.7926169
*Pellizzari ED, Smith DJ, Clayton CA, 2001. An assessment of the data quality for NHEXAS-Part I: Exposure to metals and volatile organic chemicals in Region 5. J Expo Anal Environ Epidemiol 11:140–154.11409006
Peoples SA, Maddy KT, Peifer WR, 1979. Occupational exposures to pesticides containing organoarsenicals in California. Vet Hum Toxicol 21:417–421. (Retrieval in progress)161110
Permapost. 2000. Chromated copper arsenate, CCA-C. Permapost Products Co., Hillsboro, Oregon. http://www.permapost.com/cca.htm. March 3, 2005.
Perry K, Bowler RG, Buckell HM, 1948. Studies in the incidence of cancer in a factory handling inorganic compounds of arsenic--II: Clinical and environmental investigations. Br J Ind Med 5:6–15.18904000
Pershagen G. 1985. Lung cancer mortality among men living near an arsenic-emitting smelter. Am J Epidemiol 122(4):684–694.4025308
Pershagen G, Björklund NE. 1985. On the pulmonary tumorigenicity of arsenic trisulfide and calcium arsenate in hamsters. Cancer Lett 27:99–104.4005826
Pershagen G, Bergman F, Klominek J, 1987. Histological types of lung cancer among smelter workers exposed to arsenic. Br J Ind Med 44:454–458.3040072
Pershagen G, Nordberg G, Bjorkland NE. 1984. Carcinomas of the respiratory tract in hamsters given arsenic trioxide and/or benzo[a]pyrene by the pulmonary route. Environ Res 34:227–241.6086305
Pershagen G, Wall S, Taube A, 1981. On the interaction between occupational arsenic exposure and smoking and its relationship to lung cancer. Scand J Work Environ Health 7:302–309.7347915
Pesch B, Ranft U, Jakubis P, 2002. Environmental arsenic exposure from a coal-burning power plant as a potential risk factor for nonmelanoma skin carcinoma: Results from a case-control study in the district of Prievidza, Slovakia. Am J Epidemiol 155(9):798–809.11978583
*Peters RA, Thompson RH, King AJ, 1944. The treatment of post-arsphenamine jaundice with sulphur-containing amino acids. Q J Med 14:35–56.
Peters SC, Blum JD, Klaue B, 1999. Arsenic occurrence in New Hampshire drinking water. Environ Sci Technol 33:1328–1333.
Peterson RG, Rumack BH. 1977. D-penicillamine therapy of acute arsenic poisoning. J Pediatr 91(4):661–666.908992
Petres J, Baron D, Hagedorn M. 1977. Effects of arsenic cell metabolism and cell proliferation: Cytogenic and biochemical studies. Environ Health Perspect 19:223–227.908303
Petrick JS, Ayala-Fierro F, Cullen WR, 2000. Monomethylarsenous acid (MMA III) is more toxic than arsenite in Chang human hepatocytes. Toxicol Appl Pharmacol 163:203–207.10698679
Petrick JS, Jagadish B, Mash EA, 2001. Monomethylarsenous acid (MMA^III^) and arsenite: LD_50_ in hamsters and in vitro inhibition of pyruvate dehydrogenase. Chem Res Toxicol 14(6):651–656.11409934
Philp RB, Leung FY, Bradley C. 2003. A comparison of the metal content of some benthic species from coastal waters of the Florida panhandle using high-resolution inductively coupled plasma mass spectrometry (ICP-MS) analysis. Arch Environ Contam Toxicol 44:218–223.12520394
Pi J, He Y, Bortner C, 2005. Low level, long-term inorganic arsenite exposure causes generalized resistance to apoptosis in cultured human keratinocytes: Potential role in skin co-carcinogenesis. Int J Cancer 116:20–26.15756686
*Pi J, Yamauchi H, Kumagai Y, 2002. Evidence for induction of oxidative stress caused by chronic exposure of Chinese residents to arsenic contained in drinking water. Environ Health Perspect 110:331–336.11940449
Pinto SS, McGill CM. 1953. Arsenic trioxide exposure in industry. Ind Med Surg 22(7):281–287.13061080
Pinto SS, Enterline PE, Henderson V, 1977. Mortality experience in relation to a measured arsenic trioxide exposure. Environ Health Perspect 19:127–130.908288
Pinto SS, Henderson V, Enterline PE. 1978. Mortality experience of arsenic-exposed workers. Arch Environ Health 33:325–331.736617
Pinto SS, Varner MO, Nelson KW, 1976. Arsenic trioxide absorption and excretion in industry. J Occup Med 18(10):677–680.987167
Piontek M, Hengels KJ, Borchard F, 1989. [Noncirrhotic liver fibrosis after chronic arsenic poisoning.] Dtsch Med Wochenschr 114:1653–1657. (German)2806096
Pirrone N, Keeler GJ. 1996. A preliminary assessment of the urban pollution in the Great Lakes region. Sci Total Environ 189/190:91–98.
Pitten F, Müller G, König P, 1999. Risk assessment of former military base contaminated with organoarsenic-based warfare agents: Uptake of arsenic by terrestrial plants. Sci Total Environ 226:237–245.10085570
Poddar S, Mukherjee P, Talukder G, 2000. Dietary protection by iron against clastogenic effects of short-term exposure to arsenic in mice in vivo. Food Chem Toxicol 38(8):735–737.10908821
Polissar L, Lowry-Coble K, Kalman DA, 1990. Pathways of human exposure to arsenic in a community surrounding a copper smelter. Environ Res 53:29–47.2226377
Poma K, Degraeve N, Kirsch-Volders M, 1981. Cytogenetic analysis of bone marrow cells and spermatogonia of male mice after in vivo treatment with arsenic. Experientia 37:129–130.7238736
Poma K, Degraeve N, Susanne C. 1987. Cytogenetic effects in mice after chronic exposure to arsenic followed by a single dose of ethylmethane sulfonate. Cytologia 52:445–449.
Pomroy C, Charbonnaeu SM, McCullough RS, 1980. Human retention studies with ^74^As. Toxicol Appl Pharm 53:550–556.
Pongratz R. 1998. Arsenic speciation in environmental samples of contaminated soil. Sci Total Environ 224:133–141.
Pouschat P, Zagury GJ. 2006. In vitro gastrointestinal bioavailability of arsenic in soils collected near CCA-treated utility poles. Environ Sci Technol 40(13):4317–4323.16856753
Prasad GVR, Rossi NF. 1995. Arsenic intoxication associated with tubulointerstitial nephritis. Am J Kidney Dis 26(2)373–376.7645544
Prier RF, Nees PO, Derse PH. 1963. The toxicity of an organic arsenical, 3-nitro-4-hydroxyphenyl-arsonic acid. II. Chronic toxicity. Toxicol Appl Pharmacol 5:526–542.13986172
Prukop JA, Savage NL. 1986. Some effects of multiple, sublethal doses of monosodium methanearsonate (MSMA) herbicide on hematology, growth, and reproduction of laboratory mice. Bull Environ Contam Toxicol 36:337–341.3955243
PSA. 2000. Excalibur atomic fluorescence: Measurements of arsenic, selenium, antimony, bismuth and tellurium. Orpington, England: PS Analytical Ltd. http://www.banian.com. March 31, 2005.
Qiao Y, Taylor PR, Yao S, 1997. Risk factors and early detection of lung cancer in a cohort of Chinese tin miners. Ann Epidemiol 7:533–541.9408549
Quatrehomme G, Ricq O, Lapalus P, 1992. Acute arsenic intoxication: Forensic and toxicologic aspects (an observation). J Forensic Sci 37(4)1163–1171.1506832
Rabano ES, Castillo NT, Torre KJ, 1989. Speciation of arsenic in ambient aerosols collected in Los Angeles. J Air Pollut Control Assoc 39:76–80.
*Rahman M, Axelson O. 1995. Diabetes mellitus and arsenic exposure: A second look at case-control data from a Swedish copper smelter. Occup Environ Med 52(11)773–774.8535499
Rahman FA, Allan DL, Rosen CJ, 2004. Arsenic availability from chromated copper arsenate (CCA)-treated wood. J Environ Qual 33(1):173–180.14964372
Rahman M, Tondel M, Ahmad SA, 1998. Diabetes mellitus associated with arsenic exposure in Bangladesh. Am J Epidemiol 148(2):198–203.9676702
*Rahman M, Wingren G, Axelson O. 1996. Diabetes mellitus among Swedish art glass workers–an effect of arsenic exposure? Scand J Work Environ Health 22(2):146–149.8738894
Rahman M, Tondel M, Ahmad SA, 1999. Hypertension and arsenic exposure in Bangladesh. Hypertension 33:74–78.9931084
Raie RM. 1996. Regional variation in As, Cu, Hg, and Se and interaction between them. Ecotoxicol Environ Saf 35:248–252.9007001
Ramirez P, Eastmond DA, Laclette JP, 1997. Disruption of microtubule assembly and spindle formation as a mechanism for the induction of aneuploid cells by sodium arsenite and vanadium pentoxide. Mutat Res 386(3):291–298.9219566
Ramos-Morales P, Rodríguez-Arnaiz R. 1995. Genotoxicity of two arsenic compounds in germ cells and somatic cells of Drosophila melanogaster. Environ Mol Mutagen 25(4):288–299.7607183
Ramsey JC, Andersen ME. 1984. A physiologically based description of the inhalation pharmacokinetics of styrene in rats and humans. Toxicol Appl Pharmacol 73:159–175.6710512
Rasmussen RE, Menzel DB. 1997. Variation in arsenic-induced sister chromatid exchange in human lymphocytes and lymphoblastoid cell lines. Mutat Res 386(3)299–306.9219567
Rastogi SC, Pritzl G. 1996. Migration of some toxic metals from crayons and water colors. Bull Environ Contam Toxicol 56(4)527–533.8645906
Reddy PRK, Reddy SJ. 1997. Elemental concentrations in medicinally important leafy materials. Chemosphere 34(9–10):2193–2212.9159914
Redman AD, Macalady DL, Ahmann D. 2002. Natural organic matter affects arsenic speciation and sorption onto hematite. Environ Sci Technol 36:2889–2896.12144264
Regelson W, Kim U, Ospina J, 1968. Hemangioendothelial sarcoma of liver from chronic arsenic intoxication by Fowler's solution. Cancer 21(3):514–522.5688987
*Reichl F, Hunder G, Liebl B, 1995. Effect of DMPS and various adsorbents on the arsenic excretion in guinea-pigs after injection with As_2_O_3_. Arch Toxicol 69(10):712–717.8572930
Reimann C, De Caritat P, Halleraker JH, 1997. Rainwater composition in eight arctic catchments in Northern Europe (Finland, Norway and Russia). Atmos Environ 31(2):159–170.
Reimer KJ. 1989. The methylation of arsenic in marine sediments. Appl Organomet Chem 3:475–490.
Reitz RH, Mendrala AL, Corley RA, 1990. Estimating the risk of liver cancer associated with human exposures to chloroform using physiologically based pharmacokinetic modeling. Toxicol Appl Pharm 105:443–459.
Reymann F, Mrller R, Nielsen A. 1978. Relationship between arsenic intake and internal malignant neoplasms. Arch Dermatol 114:378–381.629571
Rhine ED, Phelps CD, Young LY. 2006. Anaerobic arsenite oxidation by novel denitrifying isolates. Environ Microbiol 8(5):899–908.16623746
Rhoads K, Sanders CL. 1985. Lung clearance, translocation and acute toxicity of arsenic, beryllium, cadmium, cobalt, lead, selenium, vanadium, and ytterbium oxides following deposition in rat lung. Environ Res 36:359–378.3872210
Rice DA, Kennedy S, McMurray CH, 1985. Experimental 3-nitro-4-hydroxyphenylarsonic acid toxicosis in pigs. Res Vet Sci 39:47–51.4035090
Rin K, Kawaguchi K, Yamanaka K, 1995. DNA-strand breaks induced by dimethylarsinic acid, a metabolite of inorganic arsenics, are strongly enhanced by superoxide anion radicals. Biol Pharm Bull 18(1):45–48.7735248
Rivara MIZ, Cebrián MG, Corey G, 1997. Cancer risk in an arsenic contaminated area of Chile. In: International congress on hazardous waste: Impact on human and ecological health. Hazardous waste, impacts on human ecological health: Proceedings of the 2nd International Congress on Hazardous Waste, Impact on Human and Ecological Health. Princeton, New Jersey: Princeton Scientific Pub. Co., 408–426.
Roberts SM, Munson JW, Lowney YW, 2007. Relative oral bioavailablity of arsenic from contaminated soils measured in the cynomolgus monkey. Toxicol Sci 95(1):281–288.17005634
Roberts SM, Weimar WR, Vinson JRT, 2002. Measurement of arsenic bioavailability in soil using a primate model. Toxicol Sci 67:303–310.12011490
Robertson FN. 1989. Arsenic in ground-water under oxidizing conditions, southwest United States. Environ Geochem Health 11:171–185.24202428
Rodriguez RR, Basta NT, Casteel SW, 1999. An in vitro gastrointestinal method to estimate bioavailable arsenic in contaminated soils and solid media. Environ Sci Technol 33:642–649.
Rodriguez VM, Carrizales L, Jimenez-Capdeville ME, 2001. The effects of sodium arsenite exposure on behavioral parameters in the rat. Brain Res Bull 55(2):301–308.11470331
Rodriguez VM, Carrizales L, Mendoza MS, 2002. Effects of sodium arsenite exposure on development and behavior in the rat. Neurotoxicol Teratol 24(6):743–750.12460656
*Rogers CE, Tomita AV, Trowbridge PR, 1997. Hair analysis does not support hypothesized arsenic and chromium exposure from drinking water in Woburn, Massachusetts. Environ Health Perspect 105(10):1090–1097.9349834
Rogers EH, Chernoff N, Kavlock RJ. 1981. The teratogenic potential of cacodylic acid in the rat and mouse. Drug Chem Toxicol 4(1):49–61.7261946
Roper JM, Cherry DS, Simmers JW, 1996. Bioaccumulation of toxicants in the zebra mussel, Dreissena polymorpha, at the Times Beach confined disposal facility, Buffalo, New York. Environ Pollut 94(2):117–129.15093498
Rosen BP. 2002. Biochemistry of arsenic detoxification. FEBS Lett 529:86–92.12354618
Rosenbaum AS, Axelrad DA, Woodruff TJ, 1999. National estimates of outdoor air toxics concentrations. J Air Waste Manage Assoc 49:1138–1152.
Rosenberg HG. 1974. Systemic arterial disease and chronic arsenicism in infants. Arch Pathol 97:360–365.4825098
*Rosner MH, Carter DE. 1987. Metabolism and excretion of gallium arsenide and arsenic oxides by hamsters following intratracheal instillation. Fundam Appl Toxicol 9:730–737.3692028
Rossman TG. 2003. Mechanism of arsenic carcinogenesis: An integrated approach. Mutat Res 533:37–65.14643412
Rossman TG, Uddin AN. 2004. Selenium prevents spontaneous and arsenite-induced mutagenesis. Int Congr Ser 1275:173–179.
Rossman TG, Stone D, Molina M, 1980. Absence of arsenite mutagenicity in E coli and Chinese hamster cells. Environ Mut 2:371–379.
Rossman TG, Uddin AN, Burns FJ. 2004. Evidence that arsenite acts as a cocarcinogen in skin cancer. Toxicol Appl Pharmacol 198(3):394–404.15276419
Rössner P, Bencko V, Havránková H. 1977. Effect of the combined action of selenium and arsenic on suspension culture of mice fibroblasts. Environ Health Perspect 19:235–237.908304
Roth F. 1957. The sequelae of chronic arsenic poisoning in Moselle Vintners. Ger Med Mon 2:172–175.
Roy P, Saha A. 2002. Metabolism and toxicity of arsenic: A human carcinogen. Curr Sci 82(1):38–45.
RTECS. 2007. Arsenic. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. May 8, 2007
Rubin Y, Gal N, Nyska A, 1989. Cacodylic acid two generation reproduction study in the rat. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41059501.
Ruby MV, Davis A, Schoof R, 1996. Estimation of lead and arsenic bioavailability using a physiologically based extraction test. Environ Sci Technol 30(2):422–430.
Ruby MV, Schoof R, Brattin W, 1999. Advances in evaluating the oral bioavailability of inorganics in soil for use in human health risk assessment. Environ Sci Technol 33(21):3697–3705.
*Rudnai P, Borzonyi M. 1980. Carcinogenic effect of arsenic trioxide in transplacentally and neonatally treated CFLP mice. Nat Sci 2:11–18.
Rupa DS, Schuler M, Eastmond DA. 1997. Detection of hyperdiploidy and breakage affecting the 1cen-1q12 region of cultured interphase human lymphocytes treated with various genotoxic agents. Environ Mole Mutagen 29(2):161–167.
Rutherford DW, Bednar AJ, Garbarino JR, 2003. Environmental fate of roxarsone in poultry litter. Part II. Mobility of arsenic in soils amended with poultry litter. Environ Sci Technol 37:1515–1520.12731832
Ryan PB, Scanlon KA, MacIntosh DL. 2001. Analysis of dietary intake of selected metals in the NHEXAS-Maryland investigation. Environ Health Perspect 109(2):121–128.11266320
Saady JJ, Blanke RV, Poklis A. 1989. Estimation of the body burden of arsenic in a child fatally poisoned by arsenite weedkiller. J Anal Toxicol 13:310–312.2615344
Saha KC, Poddar D. 1986. Further studies on chronic arsenical dermatosis. Indian J Dermatol 31:29–33.3443472
Salim EI, Wanibuchi H, Morimura K, 2003. Carcinogenicity of dimethylarsinic acid in p53 heterozygous knockout and wild-type C57BL/6J mice. Carcinogenesis 24(2):335–342.12584185
Samsøe-Petersen L, Larsen EH, Larsen PB, 2002. Uptake of trace elements and PAHs by fruit and vegetables from contaminated soils. Environ Sci Technol 36:3057–3063.12141482
Sanders JG, Riedel GF, Osmann RW. 1994. Arsenic cycling and its impact in estuarine and coastal marine ecosystems. In: Nriagu JO, ed. Arsenic in the environment, part I: Cycling and characterization. New York, NY: John Wiley & Sons, Inc., 289–308.
Sandstrom AIM, Wall SGI, Taube A. 1989. Cancer incidence and mortality among Swedish smelter workers. Br J Ind Med 46:82–89.2923829
Sanok WJ, Ebel JG JR Manzell KL, 1995. Residues of arsenic and lead in potato soils on long island. Chemosphere 30(4):803–806.7889354
Santra A, Maiti A, Das S, 2000. Hepatic damage caused by chronic arsenic toxicity in experimental animals. J Toxicol Clin Toxicol 38(4):395–405.
Sardana MK, Drummond GS, Sassa S, 1981. The potent heme oxygenase inducing action of arsenic in parasiticidal arsenicals. Pharmacology 23:247–253.6895259
*Sarin SK, Sharma G, Banerjee S, 1999. Hepatic fibrogenesis using chronic arsenic ingestion studies in a murine model. Indian J Exp Biol 37:147–151.10641134
Sarkar D, Datta R. 2004. Arsenic fate and bioavailability in two soils contaminated with sodium arsenate pesticide: An incubation study. Bull Environ Contam Toxicol 72(2):240–247.15106757
Sass U, Grosshans E, Simonart JM. 1993. Chronic arsenicism: Criminal poisoning or drug-intoxication? Report of two cases. Dermatology 186(4)303–305.8513205
Schmitt CJ, Zajicek JL, May TW, 1999. Organochlorine residues and elemental contaminants in U.S. freshwater fish, 1976–1986: National contaminant biomonitoring program. Rev Environ Contam Toxicol 162:43–104.10392042
Schoenwolf GC, Smith JL. 1990. Mechanisms of neurulation: Traditional viewpoint and recent advances. Development 109:243–270.2205465
Schoof RA, Eickhoff J, Yost LJ, 1999a. Dietary exposure to inorganic arsenic. In: Chappell WR, Abernathy CO, Calderon RL, eds. Arsenic exposure and health effects. Amsterdam: Elsevier Science, 81–88.
Schoof RA, Yost LJ, Crecelius K, 1998. Dietary arsenic intake in Taiwanese districts with elevated arsenic in drinking water. Hum Ecol Risk Assess 4(1):117–135.
Schoof RA, Yost LJ, Eickhoff J, 1999b. A market basket survey of inorganic arsenic in food. Food Chem Toxicol 37:839–846.10506007
Schrauzer GN. 1987. Effects of selenium antagonists on cancer susceptibility: New aspects of chronic heavy metal toxicity. J UOEH 9(Suppl):208–215.3299603
Schrauzer GN, Ishmael D. 1974. Effects of selenium and of arsenic on the genesis of spontaneous mammary tumors in inbred C3H mice. Ann Clin Lab Sci 4(6):441–447.4473954
Schrauzer GN, White DA, McGinness JE, 1978. Arsenic and cancer: Effects of joint administration of arsenite and selenite on the genesis of adenocarcinoma in inbred female C3H/St mice. Bioinorg Chem 9:245–253.698283
Schrauzer GN, White DA, Schneider CJ. 1976. Inhibition of the genesis of spontaneous mammary tumors in C_3_H mice: Effects of selenium and of selenium-antagonistic elements and their possible role in human breast cancer. Bioinorg Chem 6:265–270.1053516
*Schroeder HA, Balassa JJ. 1966. Abnormal trace metals in man: Arsenic. J Chron Dis 19:85–106.5903856
Schroeder HA, Balassa JJ. 1967. Arsenic, germanium, tin and vanadium in mice: Effects on growth, survival and tissue levels. J Nutr 92:245–252.6029075
Schroeder HA, Mitchener M. 1971. Toxic effects of trace elements on the reproduction of mice and rats. Arch Environ Health 23:102–106.5558140
Schroeder HA, Kanisawa M, Frost DV, 1968. Germanium, tin and arsenic in rats: Effects on growth, survival, pathological lesions and life span. J Nutr 96:37–45.
Schroeder RE. 1994. A two-generation reproduction study in rats with methanearsonic acid (MAA). Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID43178301.
Schroeder WH, Dobson M, Kane DM, 1987. Toxic trace elements associated with airborne particulate matter: A review. J Air Pollut Control Assoc 37(11):1267–1285.
Schulz H, Nagymajtenyi L, Institoris L, 2002. A study on behavioral, neurotoxicological, and immunotoxicological effects of subchronic arsenic treatment in rats. J Toxicol Environ Health A 65(16):1181–1193.12167215
Scott N, Hatlelid KM, MacKenzie NE, 1993. Reactions of arsenic (III) and arsenic (V) species with glutathione. Chem Res Toxicol 6:102–106.8448339
Scudlark JR, Church TM. 1988. The atmospheric deposition of arsenic and association with acid precipitation. Atmos Environ 22(5):937–943.
Scudlark JR, Conko KM, Church TM. 1994. Atmospheric wet deposition of trace elements to Chesapeake Bay: CBAD study year 1 results. Atmos Environ 28(8):1487–1498.
Senesi GS, Baldassarre G, Senesi N, 1999. Trace element inputs into soils by anthropogenic activities and implications for human health. Chemosphere 39(2):343–377.10399847
Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
Shahin U, Yi SM, Paode RD, 2000. Long-term elemental dry deposition fluxes measured around Lake Michigan with an automated dry deposition sampler. Environ Sci Technol 34:1887–1892.
Shalat SL, Solo-Gabriele HM, Fleming LE, 2006. A pilot study of children's exposure to CCA-treated wood from playground equipment. Sci Total Environ 367(1):80–88.16487576
Shannon RL, Strayer DS. 1989. Arsenic-induced skin toxicity. Hum Toxicol 8:99–104.2663702
Sheehy JW, Jones JH. 1993. Assessment of arsenic exposures and controls in gallium arsenide production. Am Ind Hyg Assoc J 54(2):61–69.8452098
Shen J, Wanibuchi H, Salim EI, 2003. Induction of glutathione S-transferase placental form positive foci in liver and epithelial hyperplasia in urinary bladder, but no tumor development in male epithelial hyperplasia in urinary bladder, but no tumor development in male Fischer 344 rats treated with monomethylarsonic acid for 104 weeks. Toxicol Appl Pharmacol 193(3):335–345.14678743
*Shen Z, Chen G, Ni J, 1997. Use of arsenic trioxide (As_2_O_3_) in the treatment of acute promyelocytic leukemia (APL): II. Clinical efficacy and pharmacokinetics in relapsed patients. Blood 89(9):3354–3360.9129042
*Shi H, Shi X, Liu KJ. 2004. Oxidative mechanism of arsenic toxicity and carcinogenesis. Mol Cell Biochem 255(1–2):67–78.14971647
*Shibata A, Ohneseit PF, Tsai YC, 1994. Mutational spectrum in the p53 gene in bladder tumors from the endemic area of blackfoot disease in Taiwan. Carcinogenesis 15(6):1085–1087.8020137
Shirachi DY, Johansen MG, McGowan JP, 1983. Tumorigenic effect of sodium arsenite in rat kidney. Proc West Pharmacol Soc 26:413–415.6688469
Shum S, Whitehead J, Vaughn L, 1995. Chelation of organoarsenate with dimercaptosuccinic acid. Vet Hum Toxicol 37(3):239–242.7571355
Siewicki TC. 1981. Tissue retention of arsenic in rats fed witch flounder or cacodylic acid. J Nutr 111:602–609.7218032
Sikorski EE, McCay JA, White KL Jr, 1989. Immunotoxicity of the semiconductor gallium arsenide in female B6C3F1 mice. Fundam Appl Toxicol 13:843–858.2695379
Silver AS, Wainman PL. 1952. Chronic arsenic poisoning following use of an asthma remedy. JAMA 150(6):584–585.
Singh I. 1983. Induction of reverse mutation and mitotic gene conversion by some metal compounds in Saccharomyces cerevisiae. Mutat Res 117:149–152.6339905
Skeaff JM, Dubreuil AA. 1997. Calculated 1993 emission factors of trace metals for Canadian non-ferrous smelters. Atmos Environ 31(10):1449–1457.
Slayton TM, Beck BD, Reynolds KA, 1996. Issues in arsenic cancer risk assessment. Environ Health Perspect 104 (10):1012–1018.8930537
Smith AH, Biggs ML, Hopenhayn-Rich C, 1995. Correspondence: Arsenic risk assessment. Environ Health Perspect 103(1): http://www.ehponline.org/docs/1995/103-1/correspondence.html. August 30, 2007.
Smith AH, Goycolea M, Haque R, 1998. Marked increase in bladder and lung cancer mortality in a region of northern Chile due to arsenic in drinking water. Am J Epidemiol 147(7):660–669.9554605
Smith AH, Hopenhayn-Rich C, Bates MN, 1992. Cancer risks from arsenic in drinking water. Environ Health Perspect 97:259–267.1396465
Smith AH, Marshall G, Yuan Y, 2006. Increased mortality from lung cancer and bronchiectasis in young adults after exposure to arsenic in utero and in early childhood. Environ Health Perspect 114(8):1293–1296.16882542
Smith CJ, Livingston SD, Doolittle DJ. 1997. An international literature survey of "IARC group I carcinogens" reported in mainstream cigarette smoke. Food Chem Toxicol 35(10–11):1107–1130.9463546
Smith E, Naidu R, Alston AM. 1999. Chemistry of arsenic in soils: I. Sorption of arsenate and arsenite by four Australian soils. J Environ Qual 28:1719–1726.
Smith E, Naidu R, Alston AM. 2002. Chemistry of inorganic arsenic in soils: II. Effect of phosphorus, sodium, and calcium on arsenic sorption. J Environ Qual 31(2):557–563.11931447
Smith RA, Alexander RB, Wolman MG. 1987. Water-quality trends in the nation's rivers. Science 235:1607–1615.17795595
Smith TJ, Crecelius EA, Reading JC. 1977. Airborne arsenic exposure and excretion of methylated arsenic compounds. Environ Health Perspect 19:89–93.908318
Sobel W, Bond GG, Baldwin CL, 1988. An update of respiratory cancer and occupational exposure to arsenicals. Am J Ind Med 13:263–270.3354578
Sofuni T, Honma M, Hayashi M, 1996. Detection of in vitro clastogens and spindle poisons by the mouse lymphoma assay using the microwell method: Interim report of an international collaborative study. Mutagenesis 11(4):349–355.8671759
*Soignet SL, Maslak P, Wang Z, 1998. Complete remission after treatment of acute promyelocytic leukemia with arsenic trioxide. N Engl J Med 339(19):1341–1348.9801394
Sommers SC, McManus RG. 1953. Multiple arsenical cancers of the skin and internal organs. Cancer 6:347–359.13032927
Somogyi A, Beck H. 1993. Nurturing and breast-feeding: Exposure to chemicals in breast milk. Environ Health Perspect 101(Suppl 2):45–52.
Sotera JJ, Dulude GR, Stux RL. 1988. Determination of toxic elements in biological materials by furnace atomic absorption spectrometry. Sci Total Environ 71:45–48.3358116
SRI. 2006. Directory of chemical producers. Menlo Park, CA: SRI Consulting, 469, 533, 654, 784, 787.
Steinmaus C, Carrigan K, Kalman D, 2005a. Dietary intake and arsenic methylation in a U.S. population. Environ Health Perspect 113(9):1153–1159.16140620
Steinmaus C, Moore LE, Shipp M, 2007. Genetic polymorphisms in MTHFR 677 and 1298, GSTM1 and T1, and metabolism of arsenic. J Toxicol Environ Health A 70:159–170.17365577
Steinmaus C, Yuan Y, Bates MN, 2003. Case-control study of bladder cancer and drinking water arsenic in the western United States. Am J Epidemiol 158(12):1193–1201.14652304
*Steinmaus C, Yuan Y, Kalman D, 2005b. Intraindividual variability in arsenic methylation in a U.S. population. Cancer Epidemiol Biomarkers Prev 14(4):919–924.15824164
Steinnes E, Rambaek JP, Hanssen JK. 1992. Large scale multi-element survey of atmospheric deposition using naturally growing moss as a biomonitor. Chemosphere 25(5):735–752.
Sternowsky HJ, Moser B, Szadkowsky D. 2002. Arsenic in breast milk during the first 3 months of lactation. Int J Hyg Environ Health 205(5):405–409.12173541
Stevens JT, DiPasquale LC, Farmer JD. 1979. The acute inhalation toxicology of the technical grade organoarsenical herbicides, cacodylic acid and disodium methanearsonic acid; a route comparison. Bull Environ Contam Toxicol 21:304–311.444720
Stevens JT, Hall LL, Farmer JD, 1977. Disposition of ^14^C and/or ^74^As-cacodylic acid in rats after intravenous, intratracheal or peroral administration. Environ Health Perspect 19:151–157.908294
Stilwell DE, Graetz TJ. 2001. Copper, chromium, and arsenic levels in soil near highway traffic sound barriers built using CCA pressure-treated wood. Bull Environ Contam Toxicol 67:303–308.11429691
Storelli MM, Marcotrigiano GO. 2001. Total, organic, and inorganic arsenic in some commercial species of crustaceans from the Mediterranean Sea (Italy). J Food Prot 64(11):1858–1862.11726176
Storer RD, McKelvey TW, Kraynak AR, 1996. Revalidation of the in vitro alkaline elution/rat hepatocyte assay for DNA damage: Improved criteria for assessment of cytotoxicity and genotoxicity and results for 81 compounds. Mutat Res 368(2):59–101.8684406
Stump DG, Holson JF, Fleeman TL, 1999. Comparative effects of single intraperitoneal or oral doses of sodium arsenate or arsenic trioxide during in utero development. Teratology 60:283–291.10525206
Stutz DR, Janusz SJ. 1988. Hazardous materials injuries: A handbook for pre-hospital care. 2nd ed. Beltsville, MD: Bradford Communications Corporation, 208–209.
Styblo M, Thomas DJ. 2001. Selenium modifies the metabolism and toxicity of arsenic in primary rat hepatocytes. Toxicol Appl Pharmacol 172(1):52–61.11264023
Sweins A. 1983. Protective effect of selenium against arsenic-induced chromosomal damage in cultured human lymphocytes. Hereditas 98:249–252.6874396
Szinicz L, Forth W. 1988. Effect of As_2_O_3_ on gluconeogenesis. Arch Toxicol 61:444–449.3190442
Szuler IM, Williams CN, Hindmarsh JT, 1979. Massive variceal hemorrhage secondary to presinusoidal portal hypertension due to arsenic poisoning. Can Med Assoc J 120:168–171.310707
Tabacova S, Hunter ES, Gladen BC. 1996. Developmental toxicity of inorganic arsenic in whole embryo culture: Oxidation state, dose, time, and gestational age dependence. Toxicol Appl Pharmacol 138(2):298–307.8658531
Takahashi K, Yamauchi H, Yamato N, 1988. Methylation of arsenic trioxide in hamsters with liver damage induced by long-term administration of carbon tetrachloride. Appl Organomet Chem 2:309–314.
Tam GKH, Lacroix G. 1982. Dry ashing, hydride generation atomic absorption spectrometric determination of arsenic and selenium in foods. J Assoc Off Anal Chem 65(3):647–650.7096247
*Tam GK, Charbonneau SM, Lacroix G, 1979a. Confirmation of inorganic arsenic and dimethylarsenic acid in urine and plasma of dog by ion-exchange and TLC. Bull Environ Contam Toxicol 21:371–374.444728
Tam GKH, Charbonneau SM, Bryce F, 1979b. Metabolism of inorganic arsenic (^74^As) in humans following oral ingestion. Toxicol Appl Pharmacol 50:319–322.505460
Tam GKH, Charbonneau SM, Bryce F, 1982. Excretion of a single oral dose of fish-arsenic in man. Bull Environ Contam Toxicol 28:669–673.7104501
Tamaki S, Frankenberger WT. 1992. Environmental biochemistry of arsenic. Rev Environ Contam Toxicol 124:79–110.1732996
Tao SS, Bolger PM. 1999. Dietary intakes of arsenic in the United States. Food Addit Contam 16:465–472.10755138
Taubeneck MW, Daston GP, Rogers JM, 1994. Altered maternal zinc metabolism following exposure to diverse developmental toxicants. Reprod Toxicol 8(1):25–40.8186621
Tay C, Seah C. 1975. Arsenic poisoning from anti-asthmatic herbal preparations. Med J Aust 2:424–428.1186550
Taylor HE, Antweiler RC, Roth DA, 2001. The occurrence and distribution of selected trace elements in the upper Rio Grande and tributaries in Colorado and northern New Mexico. Arch Environ Contam Toxicol 41:410–426 11598778
Taylor PR, Qiao YL, Schatzkin A, 1989. Relation of arsenic exposure to lung cancer among tin miners in Yunnan Province. Br J Ind Med 46:881–886.2611163
Teräsahde P, Pantsar-Kallio M, Manninen PKG. 1996. Simultaneous determination of arsenic species by ion chromatography-inductively coupled plasma mass spectrometry. J Chromatog A750(1–2):83–88.
Tezuka M, Hanioka K, Yamanaka K, 1993. Gene damage induced in human alveolar type II (L-132) cells by exposure to dimethylarsinic acid. Biochem Biophys Res Commun 191(3):1178–1183.7682063
Thomas DC, Whittemore AS. 1988. Methods for testing interactions, with applications to occupational exposures, smoking, and lung cancer. Am J Ind Med 13:131–147.3344752
Thomas DJ, Li J, Waters SB, 2007. Arsenic (+3 oxidation state) methyltransferase and the methylation of arsenicals. Exp Biol Med 232(1):3–13.
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thomas P, Sniatecki K. 1995. Inductively coupled plasma mass spectrometry: Application to the determination of arsenic species. Fresenius J Anal Chem 351 (4–5):410–414.
Thomas DJ, Waters SB, Styblo M. 2004. Elucidating the pathway for arsenic methylation. Toxicol Appl Pharmacol 198(3):319–326.15276411
Thomas KW, Pellizzari ED, Berry MR. 1999. Population-based dietary intakes and tap water concentrations for selected elements in the EPA Region V National Human Exposure Assessment Survey (NHEXAS). J Expo Anal Environ Epidemiol 9:402–413.10554143
Thompson TS, Le MD, Kasick AR, 1999. Arsenic in well water supplies in Saskatchewan. Bull Environ Contam Toxicol 63:478–483.
Tian D, Ma H, Feng Z, 2001. Analyses of micronuclei in exfoliated epithelial cells from individuals chronically exposed to arsenic via drinking water in inner Mongolia, China. J Toxicol Environ Health A 64(6):473–484.11732698
Tice RR, Yager JW, Andrews P, 1997. Effect of hepatic methyl donor status on urinary excretion and DNA damage in B6C3F1 mice treated with sodium arsenite. Mutat Res 386(3):315–334.9219569
Tintinalli JE, Ruiz E, Krone RL, eds. 1996. Emergency medicine. A comprehensive study. American College of Emergency Physicians. 4^th^ ed. New York, NY: The McGraw-Hill Companies, Inc.
Tokunaga H, Roychowdhury T, Chandraskaran N, 2002. Urinary arsenic species in an arsenic-affected area of West Bengal, India. Appl Organomet Chem 16:406–414.
Tollestrup K, Daling JR, Allard J. 1995. Mortality in a cohort of orchard workers exposed to lead arsenate pesticide spray. Arch Environ Health 50(3):221–229.7618955
Tondel M, Rahman M, Magnuson A, 1999. The relationship of arsenic levels in drinking water and the prevalence rate of skin lesions in Bangladesh. Environ Health Perspect 107(9):727–729.10464073
*Trepka MJ, Heinrich J, Schulz C, 1996. Arsenic burden among children in industrial areas of eastern Germany. Sci Total Environ 180(2):95–105.8701301
TRI04. 2006. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. January 31, 2006.
Trocine RP, Trefry JH. 1996. Metal concentrations in sediment, water and clams from the Indian River Lagoon, Florida. Mar Pollut Bull 32(10):754–759.
Tsai M, Chien R, Hsieh S, 1998a. Primary hepatic angiosarcoma: Report of a case involving environmental arsenic exposure. Chang Keng I Hsueh Tsa Chih 21(4):469–474.10074736
Tsai S, Chou H, The H, 2003. The effects of chronic arsenic exposure from drinking water on the neurobehavioral development in adolescence. Neurotoxicology 24:747–753.12900089
*Tsai S, Wang T, Ko Y. 1998b. Cancer mortality trends in a blackfoot disease endemic community of Taiwan following water source replacement. J Toxicol Environ Health 55:389–404.
Tsai SM, Wang TN, Ko YC. 1999. Mortality for certain diseases in areas with high levels of arsenic in drinking water. Arch Environ Health 54(3):186–193.10444040
Tseng W. 1977. Effects and dose-response relationships of skin cancer and blackfoot disease with arsenic. Environ Health Perspect 19:109–119.908285
Tseng W. 1989. Blackfoot disease in Taiwan: A 30-year follow-up study. Angiology 40(6):547–558.2719339
Tseng CH, Chong CK, Chen CJ, 1995. Abnormal peripheral microcirculation in seemingly normal subjects living in blackfoot-disease-hyperendemic villages in Taiwan. Int J Microcirc Clin Exp 15(1):21–27.7558622
Tseng CH, Chong C, Chen CJ, 1996. Dose-response relationship between peripheral vascular disease and ingested inorganic arsenic among residents in blackfoot disease endemic villages in Taiwan. Atherosclerosis 120:125–133.8645353
Tseng CH, Chong CK, Tseng CP, 2003. Long-term arsenic exposure and ischemic heart disease in arseniasis-hyperendemic villages in Taiwan. Toxicol Lett 137(1–2):15–21.12505429
Tseng CH, Huang YK, Huang YL, 2005. Arsenic exposure, urinary arsenic speciation, and peripheral vascular disease in blackfoot disease-hyperendemic villages in Taiwan. (Erratum in: Toxicol Appl Pharmacol 211(2):175). Toxicol Appl Pharmacol 206(3):299–308.16039941
Tseng CH, Tai TY, Chong CK, 2000. Long-term arsenic exposure and incidence of non-insulin dependent diabetes mellitus: A cohort study in arseniasis-hyperendemic villages in Taiwan. Environ Health Perspect 108(9):847–851.11017889
Tseng WP, Chu HM, How SW, 1968. Prevalence of skin cancer in an endemic area of chronic arsenicism in Taiwan. J Natl Cancer Inst 40:453–463.5644201
Tsuda T, Babazono A, Yamamoto E, 1995a. Ingested arsenic and internal cancer: A historical cohort study followed for 33 years. Am J Epidemiol 141(3):198–209.
Tsuda T, Indue T, Kojima M, 1995b. Market basket and duplicate portion estimation of dietary intakes of cadmium, mercury, arsenic, copper, manganese, and zinc by Japanese adults. J AOAC Int 78(6):1363–1368.8664571
Tsuda T, Kume Y, Yamamoto M, 1987. An epidemiological study on cancer in certified arsenic poisoning patients in Toroku. Jpn J Ind Health 29:496–497.
Tsuji JS, Van Kerkhove MD, Kaetzel RS, 2005. Evaluation of exposure to arsenic in residential soil. Environ Health Perspect 113(12):1735–1740.16330356
Tsuruta D, Hamada T, Mochida K, 1998. Merkel cell carcinoma, Bowen's disease and chronic occupational arsenic poisoning. Br J Dermatol 139:291–294.9767246
Uddin AN, Burns FJ, Rossman TG. 2005. Vitamin E and organoselenium prevent the cocarcinogenic activity of arsenite with solar UVR in mouse skin. Carcinogenesis 26(12):2179–2186.16014701
Ueda H, Kuroda K, Endo G. 1997. The inhibitory effect of selenium on induction of tetraploidy by dimethylarsinic acid in Chinese hamster cells. Anticancer Res 17(3c):1939–1943.9216648
Uede K, Furukawa F. 2003. Skin manifestations in acute arsenic poisoning from the Wakayama curry-poisoning incident. Br J Dermatol 149(4):757–762.14616366
Ulitzur S, Barak M. 1988. Detection of genotoxicity of metallic compounds by the bacterial bioluminescence test. J Biolumin Chemilumin 2:95–99.3213595
Ulman C, Gezer S, Anal O, 1998. Arsenic in human and cow's milk: A reflection of environmental pollution. Water Air Soil Pollut 101(1–4):411–416.
Unnikrishnan D, Dutcher JP, Varshneya N, 2001. Torsades de pointes in 3 patients with leukemia treated with arsenic trioxide. Blood 97(5):1514–1516.11222403
Ursitti F, Vanderlinden L, Watson R, 2004. Assessing and managing exposure from arsenic in CCA-treated wood play structures. Can J Public Health 95(6):429–433.15622791
U.S. Bureau of Mines. 1988. Mineral commodity summaries. Washington, DC: U.S. Bureau of Mines, 14–15.
U.S. Bureau of Mines. 1990. Mineral commodity summaries. Washington, DC: U.S. Bureau of Mines, 22–23.
*U.S. Congress. 1990. Clean Air Act. Title III. Section 112. National emission standards for hazardous air pollutants. U.S. Congress. 42 USC 7412. Revised by Public Law 101–549. November 15, 1990.
USDA. 2004. Nonsynthetic substances prohibited for use in organic crop production. U.S. Department of Agriculture. Code of Federal Regulations 7 CFR 205.602. http://www.access.gpo.gov/nara/cfr/waisidx_04/7cfr205_04.html. February 15, 2005.
USDA/USDT. 2000. Assessment of the Environmental effects associated with wooden bridges preserved with creosote, pentachlorophenol, or chromated copper arsenate. U.S. Department of Agriculture. United States Department of Transportation. FPL-RP-587. http://www.fpl.fs.fed.us/documnts/fplrp/fplrp587.pdf. August 27, 2007.
USGS. 1984. Element concentrations in soils and other surficial materials on of the conterminous United States. U.S. Geological Survey. Professional Paper 1270.
USGS. 1987. Composition, distribution, and hydrologic effects of contaminated sediments resulting from the discharge of gold milling wastes to Whitewood Creek at Lead and Deadwood, South Dakota. Water-Resources Investigation Report 87–4051. U.S. Geological Survey. http://pubs.er.usgs.gov/usgspubs/wri/wri874051 August 27, 2007.
USGS. 1998. Arsenic. U.S. Geological Survey – Mineral Information – 1998. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/arsenic/160498.pdf.
*USGS. 1999a. Mineral Commodity Summaries 1999. Arsenic. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/arsenic/index.html.
USGS. 1999b. Arsenic in ground water of the Willamette Basin, Oregon. U.S. Geological Survey. http://or.water.usgs.gov/pubs_dir/Online/Pdf/98-4205.pdf. April 7, 2005.
USGS. 1999c. Arsenic-rich pyrite in the Mississippian Marshall Sandstone: Source of anomalous arsenic in southeastern Michigan ground water. U.S. Geological Survey. http://minerals.usgs.gov/east/midwest/abstract7.html. August 23,1999.
USGS. 2006a. Arsenic. 2005 Minerals yearbook. U.S. Department of the Interior, U.S. Geological Survey.:7.1–7.4, tables 1–3. http://minerals.usgs.gov/minerals/pubs/commodity/arsenic/arsenmyb05.pdf. September 12, 2006.
USGS. 2006b. Arsenic. Mineral commodity studies. U.S. Geological Survey, 26–27. http://minerals.usgs.gov/minerals/pubs/commodity/arsenic/arsenmcs06.pdf. September 12, 2006.
USGS. 2007a. Arsenic in ground water in the United States. U.S. Geological Survey. http://water.usgs.gov/nawqa/trace/pubs/geo_v46n11/fig2.html. August 29, 2007.
USGS. 2007b. The national geochemical survey-database and documentation. U.S. Geological Survey. http://tin.er.usgs.gov/geochem/doc/home.htm. August 29, 2007.
Vaessen HA, van Ooik A. 1989. Speciation of arsenic in Dutch total diets: Methodology and results. Z Lebensm Unters Forsch 189:232–235.2800710
Vahter M. 1981. Biotransformation of trivalent and pentavalent inorganic arsenic in mice and rats. Environ Res 25:286–293.7274192
Vahter M. 1983. Metabolism of arsenic. In: Fowler BA, ed. Biological and environmental effects of arsenic. New York, NY: Elsevier Science Publishers, 171–198.
Vahter M. 1986. Environmental and occupational exposure to inorganic arsenic. Acta Pharmacol Toxicol 59:31–34.
Vahter M. 2002. Mechanisms of arsenic biotransformation. Toxicology 181–182:211–217.
Vahter M, Envall J. 1983. In vivo reduction of arsenate in mice and rabbits. Environ Res 32:14–24.6617606
Vahter M, Marafante E. 1983. Intracellular interaction and metabolic fate of arsenite and arsenate in mice and rabbits. Chem Biol Interact 47:29–44.6640784
Vahter M, Marafante E. 1985. Reduction and binding of arsenate in Marmoset monkeys. Arch Toxicol 57:119–124.4026570
Vahter M, Marafante E. 1987. Effects of low dietary intake of methionine, choline or proteins on the biotransformation of arsenite in the rabbit. Toxicol Lett 37:41–46.3590229
Vahter M, Norin H. 1980. Metabolism of 74As-labeled trivalent and pentavalent inorganic arsenic in mice. Environ Res 21:446–457.7408817
*Vahter M, Concha G, Nermell B, 1995. A unique metabolism of inorganic arsenic in native Andean women. Eur J Pharmacol 293(4):455–462.8748699
Vahter M, Friberg L, Rahnster B, 1986. Airborne arsenic and urinary excretion of metabolites of inorganic arsenic among smelter workers. Int Arch Occup Environ Health 57:79–91.3949400
*Vahter M, Marafante E, Dencker L. 1983. Metabolism of arsenobetaine in mice, rats and rabbits. Sci Total Environ 30:197–211.6648507
Vahter M, Marafante E, Dencker L. 1984. Tissue distribution and retention of ^74^As-dimethylarsinic acid in mice and rats. Arch Environ Contam Toxicol 13:259–264.
Vahter M, Marafante E, Lindgren A, 1982. Tissue distribution and subcellular binding of arsenic in Marmoset monkeys after injection of ^74^As-arsenite. Arch Toxicol 51:65–77.
Valentine JL, Campion DS, Schluchter MD, 1981. Arsenic effects on human nerve conduction. In: Howell JC, Gawthorne JM, White L, eds. Trace element metabolism in man and animals - TEMA 4. Proceedings of the Fourth International symposium on Trace Elements or Man and Animals. Canberra: Australian Academy of Science, 409–411.
Valentine JL, He S, Reisbord LS, 1992. Health response by questionnaire in arsenic-exposed populations. J Clin Epidemiol 45(5):487–94.1588354
Valentine JL, Kang H, Spivey G. 1979. Arsenic levels in human blood, urine and hair in response to exposure via drinking water. Environ Res 20:24–32.499171
Valentine JL, Reisbord LS, Kang HK, 1985. Arsenic effects on population health histories. In: Mills CF, Bremner I, Chesters JK, eds. Trace elements in man and animals - TEMA 5: Proceedings of the Fifth International Symposium on Trace Elements in Man and Animals. Slough, UK: Commonwealth Agricultural Bureaux, 289–294.
Vallee BL, Ulmer DD, Wacker WE. 1960. Arsenic toxicology and biochemistry. Arch Ind Health 21:132–151.
van Netten C, Cann SAH, Morley DR, 2000. Elemental and radioactive analysis of commercially available seaweed. Sci Total Environ 255:169–175.10898404
Vantroyen B, Heilier JF, Meulemans A, 2004. Survival after a lethal dose of arsenic trioxide. J Toxicol Clin Toxicol 42(6):889–895.15533028
*Vargas M, Hamadeh H, Lee E, 1998. Activation of transcription factors by sodium arsenite in human lymphocytes. Toxicologist 42(1-S):323–324.
Vega L, Gonsebatt ME, Ostrosky-Wegman P. 1995. Aneugenic effect of sodium arsenite on human lymphocytes in vitro: An individual susceptibility effect detected. Mutat Res 334(3):365–373.7753100
Versieck J, Hoste J, Vanballenberghe L, 1983. Trace element measurements in serum by neutron activation analysis. In: Harling OK, Clark L, Von der Hardt P, eds. Use and development of low and medium flux research reactors. Proceedings of the International Symposium on the use and development of low and medium flux research reactors, Massachusetts Institute of Technology, Cambridge, Massachusetts, U.S.A., October 16–19, 1983. Munchen: Karl Thiemig, 717–723.
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Vienna A, Capucci E, Wolfsperger M, 1995. Heavy metal concentration in hair of students in Rome. Anthropol Anz 53(1):27–32.7755371
Vig BK, Figueroa ML, Cornforth MN, 1984. Chromosome studies in human subjects chronically exposed to arsenic in drinking water. Am J Ind Med 6:325–338.6517064
Vinas P, Lopez-Garcia I, Merino-Merono B, 2003. Stability of arsenobetaine levels in manufactured baby foods. J Food Prot 66(12):2321–2324.14672231
Viren JR, Silvers A. 1994. Unit risk estimates for airborne arsenic exposure: An updated view based on recent data from two copper smelter cohorts. Regul Toxicol Pharmacol 20(2):125–138.7846301
Viren J, Silvers A. 1999. Nonlinearity in the lung cancer dose-response for airborne arsenic: Apparent confounding by year of hire in evaluating lung cancer risks from arsenic exposure in Tacoma smelter workers. Regul Toxicol Pharmacol 30:117–129.10536107
von Ehrenstein OS, Guha Mazumder DN, Hira-Smith M, 2006. Pregnancy of outcomes, infant mortality, and arsenic in drinking water in West Bengal, India. Am J Epidemiol 163(7):662–669.16524957
von Ehrenstein OS, Mazumder DN, Yuan Y, 2005. Decrements in lung function related to arsenic in drinking water in West Bengal, India. Am J Epidemiol 162(6):533–541.16093295
von Ehrenstein O, Poddar S, Yuan Y, 2007. Children's intellectual function in relation to arsenic exposure. Epidemiology 18:44–51.17149142
Von Endt DW, Kearney PC, Kaufman DD. 1968. Degradation of monosodium methanearsonic acid by soil microorganisms. J Agric Food Chem 16(1):17–20.
Vuyyuri SB, Ishaq MKuppala D, Grover P, 2006. Evaluation of micronucleus frequencies and DNA damage in glass workers exposed to arsenic. Environ Mol Mutagen 47:562–570.16795086
Waalkes MP, Harvey MJ, Klaassen CD. 1984. Relative in vitro affinity of hepatic metallothionein for metals. Toxicol Lett 20:33–39.6695394
Waalkes MP, Liu J, Ward JM, 2004a. Mechanisms underlying arsenic carcinogenesis: Hypersensitivity of mice exposed to inorganic arsenic during gestation. Toxicology 198(1–3):31–38.15138027
Waalkes MP, Liu J, Ward J, 2004b. Animal models for arsenic carcinogenesis: Inorganic arsenic is a transplacental carcinogen in mice. Toxicol Appl Pharmacol 198(3):377–384.15276417
Waalkes MP, Liu J, Ward JM, 2006a. Enhanced urinary bladder and liver carcinogenesis in male CD1 mice exposed to transplancental inorganic arsenic and postnatal diethylstilbestrol or tamoxifen. Toxicol Appl Pharmacol 215(3):295–305.16712894
Waalkes MP, Liu J, Ward JM, 2006b. Urogenital carcinogenesis in female CD1 mice induced by in utero arsenic exposure is exacerbated by postnatal diethylstilbestrol treatment. Cancer Res 66(3):1337–1345.16452187
Waalkes MP, Ward JM, Diwan BA. 2004c. Induction of tumors of the liver, lung, ovary and adrenal in adult mice after brief maternal gestational exposure to inorganic arsenic: Promotional effects of postnatal phorbol ester exposure on hepatic and pulmonary, but not dermal cancers. Carcinogenesis 25(1):133–141.14514661
Waalkes MP, Ward JM, Liu J, 2003. Transplacental carcinogenicity of inorganic arsenic in the drinking water: Induction of hepatic, ovarian, pulmonary, and adrenal tumors in mice. Toxicol Appl Pharmacol 186(1):7–17.12583988
Wade HJ, Frazer ES. 1953. Toxipathic hepatitis due to Fowler's solution; A case treated with dimercaprol. Lancet (February):269–271.
Wadge A, Hutton M. 1987. The leachability and chemical speciation of selected trace elements in fly ash from coal combustion and refuse incineration. Environ Pollut 48:85–99.15092689
Wagner SL, Maliner JS, Morton WE, 1979. Skin cancer and arsenical intoxication from well water. Arch Dermatol 115:1205–1207.507863
Wahlberg JE, Boman A. 1986. Contact sensitivity to arsenical compounds: Clinical and experimental studies. Derm Beruf Umwelt 34:10–12.2937622
Wakao N, Koyatsu H, Komai Y, 1988. Microbial oxidation of arsenite and occurrence of arsenite-oxidizing bacteria in acid mine water from a sulfur-pyrite mine. Geomicrobiol J 6:11–24.
Walker S, Griffin S. 1998. Site-specific data confirm arsenic exposure predicted by the U.S. Environmental Protection Agency. Environ Health Perspect 106(3):133–139.9452415
Wall S. 1980. Survival and mortality pattern among Swedish smelter workers. Int J Epidemiol 9(1):73–87.7419333
Walton FS, Waters SB, Jolley SL, 2003. Selenium compounds modulate the activity of recombinant rat As111-methyltransferase and the methylation of arsenite by rat and human hepatocytes. Chem Res Toxicol 16(3):261–265.12641425
Wan B, Christian RT, Soukup SW. 1982. Studies of cytogenetic effects of sodium arsenicals on mammalian cells in vitro. Environ Mutagen 4:493–498.6896854
Waner T, Nyska A. 1988. Data evaluation report: Methanearsonic acid fifty-two week chronic oral toxicity study in beagle dogs. Permenta Plant Protection Company. Submitted to the U.S. Environmental Protection Agency. MRID40546101.
Wang ZY. 2001. Arsenic compounds as anticancer agents. Cancer Chemother Pharmacol 48(Suppl 1):S72–S76.11587371
Wang TS, Huang H. 1994. Active oxygen species are involved in the induction of micronuclei by arsenite in XRS-5 cells. Mutagenesis 9(3):253–257.7934966
Wang CH, Jeng JS, Yip PK, 2002. Biological gradient between long-term arsenic exposure and carotid atherosclerosis. Circulation 105:1804–1809.11956123
Wang SH, Wang ZH, Cheng XT, 2007. Arsenic and fluoride exposure in drinking water: Children's IQ and growth in Shanyin County, Shanxi Province, China. Environ Health Perspect 115(4):643–647.17450237
Wang SL, Chiou JM, Chen CJ, 2003. Prevalence of non-insulin-dependent diabetes mellitus and related vascular diseases in southwestern arseniasis-endemic and nonendemic areas in Taiwan. Environ Health Perspect 111(2):155–59.12573898
Wang TS, Shu YF, Liu YC, 1997. Glutathione peroxidase and catalase modulate the genotoxicity of arsenite. Toxicology 121(3):229–237.9231701
Wang Z, Kown E, Zhang H, 2005. Arsenic on the hands of children: Wang et al. Respond. Environ Health Perspect 113(6):364–365.
Wanibuchi H, Yamamoto S, Chen H, 1996. Promoting effects of dimethylarsinic acid on N-butyl-N-(4-hydroxybutyl)nitrosamine-induced urinary bladder carcinogenesis in rats. Carcinogenesis 17(11):2435–2439.8968060
*Warner ML, Moore LE, Smith MT, 1994. Increased micronuclei in exfoliated bladder cells of individuals who chronically ingest arsenic-contaminated water in Nevada. Cancer Epidemiol Biomarkers Prev 3(7):583–590.7827589
Washington State. 2006. What is area-wide soil contamination? In: Area-Wide Soil Contamination Project. Washington State. http://www.ecy.wa.gov/programs/tcp/area_wide/AW/toolbox_chap1.html. August 27, 2007.
Wasserman GA, Liu X, Parvez F, 2004. Water arsenic exposure and children's intellectual function in Araihazar, Bangladesh. Environ Health Perspect 112(13):1329–1333.15345348
Wasserman GA, Liu X, Parvez F, 2007. Water arsenic exposure and intellectual function in 6-year-old children in Arailhazar, Bangladesh. Environ Health Perspect 115(2):285–289.17384779
Watanabe C, Inaoka T, Kadono T, 2001. Males in rural Bangladeshi communities are more susceptible to chronic arsenic poisoning than females: Analyses based on urinary arsenic. Environ Health Perspect 109(12):1265–1270.11748034
Watrous RM, McCaughey MB. 1945. Occupational exposure to arsenic: In the manufacture of arsphenamine and related compounds. Ind Med 14(8):639–646.
Webb DR, Sipes IG, Carter DE. 1984. In vitro solubility and in vivo toxicity of gallium arsenide. Toxicol Appl Pharmacol 76:96–104.6484996
Webb DR, Wilson SE, Carter DE. 1986. Comparative pulmonary toxicity of gallium arsenide, gallium (III) oxide, or arsenic (III) oxide intratracheally instilled into rats. Toxicol Appl Pharmacol 82:405–416.3952726
Webb DR, Wilson SE, Carter DE. 1987. Pulmonary clearance and toxicity of respirable gallium arsenide particulates intratracheally instilled into rats. Am Ind Hyg Assoc J 48(7):660–667.3618480
Wedepohl KH. 1991. The composition of the upper earth's crust and the natural cycles of selected metals. Metals in natural raw materials. Natural resources. In: Merian E, ed. Metals and their compounds in the environment. Occurrence, analysis, and biological relevance. New York, NY: VCH, 3–17.
Wei M, Wanibuchi H, Morimura K, 2002. Carcinogenicity of dimethylarsinic acid in male F344 rats and genetic alterations in induced urinary bladder tumors. Carcinogenesis 23(8):1387–1397.12151359
Wei M, Wanibuchi H, Yamamoto S, 1999. Urinary bladder carcinogenicity of dimethylarsinic acid in male F344 rats. Carcinogenesis 20(9):1873–1876.10469637
Weis JS, Weis P, Proctor T. 1998. The extent of benthic impacts of CCA-treated wood structures in Atlanic coast estuaries. Arch Environ Contam Toxicol 34(4):313–322.9543499
*Weis P, Weis JS, Lores E. 1993. Uptake of metals from chromated-copper-arsenate (CCA)-treated lumber by Epibiota. Mar Pollut Bull 26(8):428–430.
Welch AH, Lico MS, Hughes JL. 1988. Arsenic in groundwater of the western United States. Ground Water 26(3):333–347.
Welch K, Higgins I, Oh M, 1982. Arsenic exposure, smoking and respiratory cancer in copper smelter workers. Arch Environ Health 37(6):325–335.7181533
Wendt PH, Van Dolah RF, Bobo MY, 1996. Wood preservative leachates from docks in an estuarine environment. Arch Environ Contam Toxicol 31(1):24–37.8687987
Werner MA, Knobeloch LM, Erbach T, 2001. Use of imported folk remedies and medications in the Wisconsin Hmong community. Wis Med J 100(7):32–34.
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatrics 32:10–18.
Wester RC, Maibach HI, Sedik L, 1993. In vivo and in vitro percutaneous absorption and skin decontamination of arsenic from water and soil. Fundam Appl Toxicol 20(3):336–340.8504907
Westhoff DD, Samaha RJ, Barnes A. 1975. Arsenic intoxication as a cause of megaloblastic anemia. Blood 45(2):241–246.1120185
Whitman FT. 1994. Subchronic (90-day) inhalation toxicity study in rats with cacodylate 3.25 (MRD-92–416). Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID44700301.
WHO. 1981. Environmental health criteria 18: Arsenic. IPCS International Programme on Chemical Safety. Geneva, Switzerland: World Health Organization.
WHO. 2000. Air quality guidelines. 2nd ed. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/Activities/20050104_1. February 15, 2005.
WHO. 2001. Arsenic and arsenic compounds. Environmental Health Criteria 224. Geneva: United Nations Environment Programme. International Labour Organisation. World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc224.htm. August 27, 2007.
WHO. 2004. Guidelines for drinking-water quality. 3rd ed. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. February 15, 2005.
*Wicklund KG, Daling JR, Allard J, 1988. Respiratory cancer among orchardists in Washington state, 1968–1980. J Occup Med 30:561–564.3397782
Wicks MJ, Archer VE, Auerbach O, 1981. Arsenic exposure in a copper smelter as related to histological type of lung cancer. Am J Ind Med 2:25–31.7349032
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The elements Part A. New York: Academic Press.
Wiencke JK, Yager JW. 1992. Specificity of arsenite in potentiating cytogenetic damage induced by the DNA crosslinking agent diepoxybutane. Environ Mol Mutagen 19(3):195–200.1572342
Wiencke JK, Yager JW, Varkonyi A, 1997. Study of arsenic mutagenesis using the plasmid shuttle vector pZ189 propagated in DNA repair proficient human cells. Mutat Res 386(3):335–344.9219570
Willhite CC. 1981. Arsenic-induced axial skeletal (dysraphic) disorders. Exp Mol Pathol 34:145–158.6894125
Willhite CC, Ferm VH. 1984. Prenatal and developmental toxicology of arsenicals. Adv Exp Med Biol 177:205–228.6388261
Williams L, Schoof RA, Yager JW, 2006. Arsenic bioaccumulation in freshwater fishes. Hum Ecol Risk Assess 12:904–923.
Williams TM, Rawlins BG, Smith B, 1998. In-vitro determination of arsenic bioavailability in contaminated soil and mineral beneficiation waste from Ron Phibun, Southern Thailand: A basis for improved human risk assessment. Environ Geochem Health 20(4):169–177.
Wingren G, Axelson O. 1993. Epidemiologic studies of occupational cancer as related to complex mixtures of trace elements in the art glass industry. Scand J Work Environ Health 19(Suppl 1):95–100.8159983
Wlodarczyk BJ, Bennett GD, Calvin JA, 1996. Arsenic-induced neural tube defects in mice: Alterations in cell cycle gene expression. Reprod Toxicol 10(6):447–454.8946558
Wolz S, Fenske RA, Simcox NJ, 2003. Residential arsenic and lead levels in an agricultural community with a history of lead arsenate use. Environ Res 93:293–300.14615240
Wong O, Whorton MD, Foliart DE, 1992. An ecologic study of skin cancer and environmental arsenic exposure. Int Arch Occup Environ Health 64(4):235–241.1468791
Wong SS, Tan KC, Goh CL. 1998a. Cutaneous manifestations of chronic arsenicism: Review of seventeen cases. J Am Acad Dermatol 38:179–185.9486671
Wong ST, Chan HL, Teo SK. 1998b. The spectrum of cutaneous and internal malignancies in chronic arsenic toxicity. Singapore Med J 39(4):171–173.9676149
Woods JS, Fowler BA. 1977. Effects of chronic arsenic exposure on hematopoietic function in adult mammalian liver. Environ Health Perspect 19:209–213.908300
Woods JS, Fowler BA. 1978. Altered regulation of mammalian hepatic heme biosynthesis and urinary porphyrin excretion during prolonged exposure to sodium arsenate. Toxicol Appl Pharmacol 43:361–371.635923
Woods JS, Southern MR. 1989. Studies on the etiology of trace metal-induced porphyria: Effects of porphyrinogenic metals on coproporphyrinogen oxidase in rat liver and kidney. Toxicol Appl Pharmacol 97:183–190.2916235
Woolson EA, Kearney PC. 1973. Persistence and reactions of ^14^C-cacodylic acid in soils. Environ Sci Technol 7:47–50.
*Woollons A, Russel-Jones R. 1998. Chronic endemic hydroarsenicism. Br J Dermatol 139:1092–1096.9990380
Woolson EA. 1976. Generation of dimethyl arsine from soil. 1976 Meeting of the Weed Science Society of America. February 3–5, 1976, No. 218.
WSDOE. 2005. Tacoma Shelter Plume: South King County mainland soil study. Washington State Department of Ecology. http://www.ecy.wa.gov/programs/tcp/sites/tacoma_smelter/soil_study.htm. July 14, 2005.
*Wu MM, Chiou HY, Wang TW, 2001. Association of blood arsenic levels with increased reactive oxidants and decreased antioxidant capacity in a human population of northeastern Taiwan. Environ Health Perspect 109(10):1011–1017.11675266
Wu MM, Kuo TL, Hwang Y, 1989. Dose-response relation between arsenic concentration in well water and mortality from cancers and vascular diseases. Am J Epidemiol 130(6):1123–1132.2589305
Wulff M, Högberg U, Sandstrom A. 1996. Cancer incidence for children born in a smelting community. Acta Oncologica (Stockholm) 35(2):179–183.
Wuyi W, Linsheng Y, Shaofan H, 2001. Prevention of endemic arsenism with selenium. Curr Sci 81(9):1215–1218.
Wyatt CJ, Fimbres C, Romo L, 1998b. Incidence of heavy metal contamination in water supplies in Northern Mexico. Environ Res A 76:114–119.
Wyatt CJ, Quiroga VL, Acosta RTO, 1998a. Excretion of arsenic (As) in urine of children, 7–11 years, exposed to elevated levels of As in the city water supply in Hermosillo, Sonora, Mexico. Environ Res A 78:19–24.
Xuan XZ, Lubin JH, Li JY, 1993. A cohort study in southern China of tin miners exposed to radon and radon decay products. Health Phys 64(2):120–131.8449705
Yager JW, Wiencke JK. 1993. Enhancement of chromosomal damage by arsenic: Implications for mechanism. Environ Health Perspect 101(Suppl 3):79–82.
Yager JW, Wiencke JK. 1997. Inhibition of poly(ADP-ribose) polymerase by arsenite. Mutat Res 386(3):345–351.9219571
Yager JW, Hicks JB, Fabianova E. 1997. Airborne arsenic and urinary excretion of arsenic metabolites during boiler cleaning operations in a Slovak coal-fired power plant. Environ Health Perspect 105(8):836–842.9347899
Yamamoto A, Hisanaga A, Ishinishi N. 1987. Tumorigenicity of inorganic arsenic compounds following intratracheal instillations to the lungs of hamsters. Int J Cancer 40:220–223.3610389
Yamamoto S, Konishi Y, Matsuda T, 1995. Cancer induction by an organic arsenic compound, dimethylarsinic acid (cacodylic acid), in F344/DuCrj rats after pretreatment with five carcinogens. Cancer Res 55(6):1271–1276.7882321
*Yamamoto S, Wanibuchi H, Hori T, 1997. Possible carcinogenic potential of dimethylarsinic acid as assessed in rat in vivo models: A review. Mutat Res 386(3):353–361.9219572
Yamanaka K, Okada S. 1994. Induction of lung-specific DNA damage by metabolically methylated arsenics via the production of free radicals. Environ Health Perspect 102(Suppl 3)37–40.
Yamanaka K, Hasegawa A, Sawamura R, 1989a. Dimethylated arsenics induce DNA strand breaks in lung via the production of active oxygen in mice. Biochem Biophys Res Commun 165(1):43–50.2590239
Yamanaka K, Hayashi H, Kato K, 1995. Involvement of preferential formation of apurinic/apyrimidinic sites in dimethylarsenic-induced DNA strand breaks and DNA-protein crosslinks in cultured alveolar epithelial cells. Biochem Biophys Res Commun 207(1):244–249.7857272
Yamanaka K, Hayashi H, Kato K, 1997. DNA single-strand breaks in L-132 cells resulting from inhibition of repair polymerization shortly after exposure to dimethylarsinic acid. Biol Pharm Bull 20(2):163–167.9057979
Yamanaka K, Ohba H, Hasegawa A, 1989b. Mutagenicity of dimethylated metabolites of inorganic arsenics. Chem Pharm Bull 37(10):2753–2756.
*Yamanaka K, Ohtsubo K, Hasegawa A, 1996. Exposure to dimethylarsinic acid, a main metabolite of inorganic arsenics, strongly promotes tumorigenesis initiated by 4-nitroquinoline 1-oxide in the lungs of mice. Carcinogenesis 17(4):767–770.8625489
Yamanaka K, Takabayashi F, Mizoi M, 2001. Oral exposure of dimethylarsinic acid, a main metabolite of inorganic arsenics, in mice leads to an increase in 8-oxo-2'-deoxyguanosine level, specifically in the target organs for arsenic carcinogenesis. Biochem Biophys Res Commun 287(1):66–70.11549254
Yamanaka K, Tezuka M, Kato K, 1993. Crosslink formation between DNA and nuclear proteins by in vivo and in vitro exposure of cells to dimethylarsinic acid. Biochem Biophys Res Commun 191(3):1184–1191.8466494
Yamauchi H, Yamamura Y. 1984. Metabolism and excretion of orally administered dimethylarsinic acid in the hamster. Toxicol Appl Pharmacol 74:134–140.6729818
Yamauchi H, Yamamura Y. 1985. Metabolism and excretion of orally administered arsenic trioxide in the hamster. Toxicology 34:113–121.3969684
Yamauchi H, Kaise T, Yamamura Y. 1986. Metabolism and excretion of orally administered arsenobetaine in the hamster. Bull Environ Contam Toxicol 36:350–355.3955245
Yamauchi H, Takahashi K, Mashiko M, 1989. Biological monitoring of arsenic exposure of gallium arsenide- and inorganic arsenic-exposed workers by determination of inorganic arsenic and its metabolites in urine and hair. Am Ind Hyg Assoc J 50(11):606–612.2596400
Yamauchi H, Yamato N, Yamamura Y. 1988. Metabolism and excretion of orally and intraperitoneally administered methylarsonic acid in the hamster. Bull Environ Contam Toxicol 40:280–286.3349200
Yan-Chu H. 1994. Arsenic distribution in soils. In: Nriagu JO, ed. Arsenic in the environment, part 1: Cycling and characterization. New York, NY: John Wiley & Sons, Inc., 17–49.
Yang CY, Chang CC, Tsai SS, 2003. Arsenic in drinking water and adverse pregnancy outcome in an arseniasis-endemic area in northeastern Taiwan. Environ Res 91(1):29–34.12550085
Yang JL, Chen MF, Wu CW, 1992. Posttreatment with sodium arsenite alters the mutational spectrum induced by ultraviolet light irradiation in Chinese hamster ovary cells. Environ Mol Mutagen 20(3)156–164.1396606
Yang L, Wang W, Hou S, 2002. Effects of selenium supplementation on arsenism: An intervention trial in inner Mongolia. Environ Geochem Health 24:359–374.
Yee-Chien L, Haimei H. 1996. Lowering extracellular calcium content protects cells from arsenite-induced killing and micronuclei formation. Mutagenesis 11(1):75–78.8671719
Yih LH, Ho IC, Lee TC. 1997. Sodium arsenite disturbs mitosis and induces chromosome loss in human fibroblasts. Cancer Res 57(22):5051–5059.9371502
Yokel J, Delistraty DA. 2003. Arsenic, lead, and other trace elements in soils contaminated with pesticide residues at the Hanford site (USA). Environ Toxicol 18(2):104–114.12635098
Yoshida K, Inoue Y, Kuroda K, 1998. Urinary excretion of arsenic metabolites after long-term oral administration of various arsenic compounds to rats. J Toxicol Environ Health A 54:179–192.9643871
Yoshida K, Kuroda K, Inoue Y, 2001. Metabolism of dimethylarsinic acid in rats: Production of unidentified metabolites in vivo. Appl Organomet Chem 15:539–547.
Yost LJ, Schoof RA, Aucoin R. 1998. Intake of inorganic arsenic in the North American diet. Human Ecol Risk Assess 4(1):137–152.
Yost LJ, Tao SH, Egan SK, 2004. Estimation of dietary intake of inorganic arsenic in U.S. children. Hum Ecol Risk Assess 10:473–483.
Yu D. 1998a. A realistic risk assessment of inorganic arsenic. J Environ Sci Health Part A 33(6):1149–1170.
Yu D. 1998b. Uncertainties in a pharmacokinetic modeling for inorganic arsenic. J Environ Sci Health Part A 33(7):1369–1390.
Yu D. 1999a. A physiologically based pharmacokinetic model of inorganic arsenic. Regul Toxicol Pharmacol 29:128–141.10341143
Yu D. 1999b. A pharmacokinetic modeling of inorganic arsenic: A short-term oral exposure model for humans. Chemosphere 39(15):2737–2747.10633549
Yu HS, Chang KL, Wang CM, 1992. Alterations of mitogenic responses of mononuclear cells by arsenic in arsenical skin cancers. J Dermatol 19(11):710–714.1293158
Yu HS, Sheu HM, Ko SS, 1984. Studies on blackfoot disease and chronic arsenism in southern Taiwan: With special reference to skin lesions and fluorescent substances. J Dermatol 11:361–370.6392382
Zadorozhnaja TD, Little RE, Miller RK, 2000. Concentrations of arsenic, cadmium, copper, lead, mercury, and zinc in human placentas from two cities in Ukraine. J Toxicol Environ Health A 61:255–263.11071319
Zakharyan R, Wu Y, Bogdan GM, 1995. Enzymatic methylation of arsenic compounds: Assay, partial purification, and properties of arsenite methyltransferase and monomethylarsonic acid methyltransferase of rabbit liver. Chem Res Toxicol 8(8):1029–1038.8605285
Zakharyan RA, Wildfang E, Aposhian HV. 1996. Enzymatic methylation of arsenic compounds. III. The marmoset and tamarin, but not the Rhesus, monkeys are deficient in methyltransferases that methylate inorganic arsenic. Toxicol Appl Pharmacol 140(1):77–84.
Zaldívar R. 1974. Arsenic contamination of drinking water and foodstuffs causing endemic chronic poisoning. Beitr Pathol 151:384–400.4838015
Zaldívar R. 1977. Ecological investigations on arsenic dietary intake and endemic chronic poisoning in man: Dose-response curve. Zentralbl Bakteriol Hyg 164:481–484.
Zaldívar R, Guillier A. 1977. Environmental and clinical investigations on endemic chronic arsenic poisoning in infants and children. Zentralbl Bakteriol Hyg 165:226–234.
Zaldívar R, Prunés L, Ghai G. 1981. Arsenic dose in patients with cutaneous carcinomata and hepatic haemangio-endothelioma after environmental and occupational exposure. Arch Toxicol 47:145–154.7271443
Zanzoni F, Jung EG. 1980. Arsenic elevates the sister chromatid exchange (SCE) rate in human lymphocytes in vitro. Arch Dermatol Res 267:91–95.7387181
Zartarian VG, Xue J, Ozkaynak H, 2006. A probabilistic arsenic exposure assessment for children who contact CCA-treated playsets and decks, Part 1: Model methodology, variability results, and model evaluation. Risk Anal 26(2):515–531.16573637
*Zhang X, Cornelis R, De Kimpe J, 1996. Accumulation of arsenic species in serum of patients with chronic renal disease. Clin Chem 42(8 Pt 1):1231–1237.8697582
*Zhang X, Cornelis R, De Kimpe J, 1997. Speciation of arsenic in serum, urine, and dialysate of patients on continuous ambulatory peritoneal dialysis. Clin Chem 43(2):406–408.9023150
Zheng Y, Wu J, Ng JC, 2002. The absorption and excretion of fluoride and arsenic in humans. Toxicol Lett 133(1):77–82.12076512
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372
Zierler S, Theodore M, Cohen A, 1988. Chemical quality of maternal drinking water and congenital heart disease. Int J Epidemiol 17(3):589–594.3209340
Zierold KM, Knobeloch L, Anderson H. 2004. Prevalence of chronic diseases in adults exposed to arsenic-contaminated drinking water. Am J Public Health 94(11):1936–1937.15514231
Zomber G, Nyska A, Waner T, 1989. Cacodylic acid 52-week oral toxicity study in beagle dogs. Luxembourg Industries (Pamol) Ltd. Submitted to the U.S. Environmental Protection Agency. MRID41490901.