# UPDATE STATEMENT

A Toxicological Profile for Arsenic, Draft for Public Comment was released in September 2005. This edition supersedes any previously released draft or final profile.

Toxicological profiles are revised and republished as necessary. For information regarding the update status of previously released profiles, contact ATSDR at:

- Agency for Toxic Substances and Disease Registry
- Division of Toxicology and Environmental Medicine/Applied Toxicology Branch
- 1600 Clifton Road NE
- Mailstop F-32
- Atlanta, Georgia 30333