# 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 5.1 PRODUCTION

Arsenic is presently obtained as a byproduct of the smelting of copper, lead, cobalt, and gold ores. Arsenic trioxide is volatilized during smelting and accumulates in the flue dust, which may contain up to 30% arsenic trioxide. The crude flue dust is further refined by mixing with small amounts of galena or pyrite to prevent the formation of arsensites and roasting to yield arsenic trioxide of 90–95% purity. By successive sublimations, a purity of 99% can be obtained. Elemental arsenic can be prepared by the reduction of arsenic oxide with charcoal. Demand for elemental arsenic is limited and thus, about 95% of arsenic is marketed and consumed in combined form, principally as arsenic trioxide, which is subsequently converted to arsenic acid (Carapella 1992; Hanusch et al. 1985; USGS 2006a).

Since 1985, when the ASARCO smelter in Tacoma, Washington ceased operation, there has been no domestic production of arsenic trioxide or elemental arsenic and consequently, the United States remains entirely dependent on imports (U.S. Bureau of Mines 1988, 1990; USGS 2006a). Prior to its cessation, U.S. production of arsenic trioxide had been 7,300 metric tons in 1983, 6,800 metric tons in 1984, and 2,200 metric tons in 1985 (U.S. Bureau of Mines 1988). In 2005, arsenic trioxide was obtained from the treatment of nonferrous ores or concentrates in 14 countries. In 2005, the world’s largest producer of arsenic trioxide was China, followed by Chile and Peru. China is the world leader in the production of commercial-grade arsenic followed by Japan. The United States, with an apparent demand of 8,800 metric tons in 2005, is the world's leading consumer of arsenic, mainly for CCA. This is an increase over 2004 with an apparent demand of 6,800 metric tons, but far less than that of 2003, 21,600 metric tons (USGS 2006a).

Tables 5-1 and 5-2 list facilities in each state that manufacture or process arsenic and arsenic compounds, respectively, as well as the intended use and the range of maximum amounts of arsenic or arsenic compounds that are stored on site. In 2004, there were 58 and 361 reporting facilities that produced, processed, or used arsenic and arsenic compounds, respectively, in the United States. The data listed in Tables 5-1 and 5-2 are derived from the Toxics Release Inventory (TRI04 2006). Only certain types of facilities were required to report. Therefore, this is not an exhaustive list. Current U.S. manufacturers of selected arsenic compounds are given in Table 5-3.

Table 5-1 Facilities that Produce, Process, or Use Arsenic

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AK | 1 | 1,000,000 | 9,999,999 | 1, 13
AL | 18 | 0 | 9,999,999 | 1, 2, 3, 5, 7, 8, 11, 12, 13, 14
AR | 4 | 1,000 | 999,999 | 7, 8
AZ | 9 | 0 | 99,999 | 1, 3, 4, 5, 8, 12, 13
CA | 31 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13
CO | 8 | 0 | 999,999 | 2, 7, 8, 11, 12
FL | 10 | 1,000 | 999,999 | 1, 3, 5, 7, 8, 11, 12
GA | 16 | 100 | 49,999,999 | 2, 3, 4, 6, 7, 8, 11, 12, 13, 14
HI | 1 | 10,000 | 99,999 | 8
IA | 4 | 100 | 99,999 | 6, 7, 8
ID | 7 | 0 | 49,999,999 | 1, 2, 3, 5, 6, 7, 9, 12, 13
IL | 16 | 0 | 999,999 | 1, 3, 4, 5, 6, 7, 8, 12, 14
IN | 17 | 0 | 999,999 | 1, 3, 5, 6, 7, 8, 9, 12, 13
KY | 9 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 11
LA | 8 | 0 | 999,999 | 1, 2, 3, 7, 8, 12, 13
MA | 5 | 1,000 | 999,999 | 3, 7, 8
MD | 9 | 0 | 999,999 | 1, 2, 4, 5, 6, 7, 8
MI | 10 | 0 | 999,999 | 3, 7, 8, 12, 13
MN | 5 | 100 | 99,999 | 1, 7, 8, 13
MO | 6 | 100 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8
MS | 9 | 1,000 | 49,999,999 | 2, 3, 4, 7, 8, 9
NC | 21 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13, 14
ND | 2 | 0 | 99,999 | 8
NE | 1 | 0 | 99 | 8
NJ | 9 | 0 | 99,999 | 1, 2, 3, 5, 7, 8, 9
NM | 2 | 10,000 | 999,999 | 7, 12
NV | 6 | 1,000 | 99,999,999 | 1, 2, 4, 5, 6, 7, 8, 11, 12, 13
NY | 4 | 0 | 99,999 | 7, 8, 12
OH | 15 | 0 | 999,999 | 1, 2, 3, 4, 5, 8, 9, 12, 13
OK | 9 | 0 | 99,999 | 1, 2, 5, 6, 7, 9, 11, 12, 13
OR | 6 | 10,000 | 999,999 | 1, 5, 7, 8, 12
PA | 24 | 0 | 999,999 | 1, 2, 3, 5, 6, 7, 8, 10, 11, 12, 13
PR | 3 | 1,000 | 99,999 | 8, 11
SC | 9 | 0 | 9,999,999 | 1, 2, 3, 5, 6, 8, 12
SD | 1 | 10,000,000 | 49,999,999 | 1, 7, 11, 13
TN | 11 | 0 | 999,999 | 1, 2, 3, 6, 7, 8, 11, 12, 14
TX | 29 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 10, 11, 12, 13, 14
VA | 8 | 0 | 999,999 | 2, 3, 7, 8, 10
WA | 3 | 0 | 99,999 | 5, 7, 8
WI | 9 | 0 | 99,999 | 1, 2, 3, 4, 5, 6, 7, 8, 12
WV | 19 | 100 | 999,999 | 1, 2, 3, 5, 7, 8, 10, 11, 12
WY | 1 | 100 | 999 | 1, 13

a Post office state abbreviations used

b Amounts on site reported by facilities in each state

c Activities/Uses:

1. Produce

2. Import

3. Onsite use/processing

4. Sale/Distribution

5. Byproduct

6. Impurity

7. Reactant

8. Formulation Component

9. Article Component

10. Repackaging

11. Chemical Processing Aid

12. Manufacturing Aid

13. Ancillary/Other Uses

14. Process Impurity

Source: TRI04 2006 (Data are from 2004)

Table 5-2 Facilities that Produce, Process, or Use Arsenic Compounds

State^a^ | Number of facilities | Minimum amount on site in pounds^b^ | Maximum amount on site in pounds^b^ | Activities and uses^c^
AK | 6 | 1,000 | 49,999,999 | 1, 5, 7, 12, 13, 14
AL | 37 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 7, 8, 9, 11, 12, 13
AR | 20 | 1,000 | 99,999,999 | 1, 2, 3, 7, 8, 9, 11, 12, 13, 14
AZ | 29 | 100 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
CA | 40 | 100 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
CO | 9 | 1,000 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12
DE | 1 | 10,000 | 99,999 | 1, 5, 9
FL | 30 | 0 | 999,999 | 1, 3, 4, 5, 7, 8, 9, 11, 12, 13, 14
GA | 50 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
HI | 6 | 1,000 | 99,999 | 7, 8, 11
IA | 22 | 0 | 9,999,999 | 1, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13
ID | 6 | 10,000 | 9,999,999 | 1, 3, 5, 6, 7, 8, 9, 12, 13
IL | 44 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
IN | 54 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
KS | 14 | 0 | 999,999 | 1, 3, 4, 5, 6, 7, 8, 12, 13, 14
KY | 29 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
LA | 32 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13
MA | 9 | 0 | 999,999 | 1, 4, 5, 6, 7, 8
MD | 19 | 0 | 999,999 | 1, 4, 5, 7, 8, 9, 11, 12, 13
ME | 2 | 1,000 | 99,999 | 7
MI | 32 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
MN | 13 | 0 | 999,999 | 1, 3, 4, 5, 7, 8, 9, 11, 12, 13
MO | 32 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
MS | 28 | 1,000 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13
MT | 8 | 1,000 | 10,000,000,000 | 1, 2, 3, 4, 5, 6, 7, 12, 13, 14
NC | 65 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12, 13, 14
ND | 11 | 1,000 | 99,999 | 1, 5, 8, 9, 11, 12, 13, 14
NE | 6 | 1,000 | 999,999 | 1, 2, 3, 4, 5, 6, 8, 9, 12, 13
NH | 2 | 1,000 | 99,999 | 8, 11
NJ | 35 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13
NM | 11 | 1,000 | 499,999,999 | 1, 5, 7, 12, 13
NV | 31 | 1,000 | 10,000,000,000 | 1, 2, 3, 5, 6, 7, 9, 11, 12, 13, 14
NY | 27 | 0 | 9,999,999 | 1, 2, 3, 4, 5, 7, 8, 9, 12, 13
OH | 50 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
OK | 14 | 100 | 9,999,999 | 1, 2, 3, 4, 5, 6, 8, 12, 13, 14
OR | 12 | 100 | 99,999 | 1, 2, 3, 7, 8, 12
PA | 53 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
PR | 8 | 1,000 | 99,999 | 1, 2, 3, 5, 8, 11
RI | 7 | 100 | 99,999 | 7, 8
SC | 34 | 0 | 49,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
SD | 6 | 1,000 | 99,999,999 | 1, 5, 6, 7, 8, 11, 12, 13
TN | 29 | 0 | 99,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 10, 11, 12
TX | 54 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11, 12, 13, 14
UT | 23 | 0 | 499,999,999 | 1, 3, 4, 5, 6, 7, 8, 9, 10, 12, 13
VA | 24 | 0 | 499,999,999 | 1, 2, 3, 4, 5, 7, 8, 9, 11, 12, 13, 14
WA | 14 | 0 | 999,999 | 1, 2, 3, 4, 5, 7, 8, 9, 11, 12, 13
WI | 13 | 100 | 99,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 11
WV | 26 | 0 | 999,999 | 1, 2, 3, 4, 5, 6, 7, 8, 9, 12, 13, 14
WY | 9 | 1,000 | 99,999 | 1, 3, 4, 5, 7, 8, 9, 12, 13

a Post office state abbreviations used

b Amounts on site reported by facilities in each state

c Activities/Uses:

1. Produce

2. Import

3. Onsite use/processing

4. Sale/Distribution

5. Byproduct

6. Impurity

7. Reactant

8. Formulation Component

9. Article Component

10. Repackaging

11. Chemical Processing Aid

12. Manufacturing Aid

13. Ancillary/Other Uses

14. Process Impurity

Source: TRI04 2006 (Data are from 2004)

Table 5-3 Current U.S. Manufacturers of Selected Arsenic Compounds^a^

Company | Location(s)
Arsenic acid
Arch Wood Protection, Inc. | Conley, Georgia
Osmose Wood Preserving, Inc. | Millington, Tennessee
Arsanilic acid
Fleming Laboratories, Inc. | Charlotte, North Carolina
Copper Chromated Arsenic (CCA)
Arch Wood Protection, Inc. | Conley, Georgia; Kalama, Washington; Smyrna, Georgia^b^; Valparaiso, Indiana
Chemical Specialties, Inc.^b^ | Charlotte, North Carolina
Osmose Wood Preserving, Inc.^b^ | Buffalo, New York
Calcium acid methanearsonate (CAMA)
Drexel Chemical Company (formulator)^c^ | No information provided
Disodium methanearsonate (DSMA)
Drexel Chemical Company | Tunica, Mississippi
Monosodium methyl arsonate (MSMA)
Drexel Chemical Company | Tunica, Mississippi
Gallium arsenide
Atomergic Chemetals Corporation | Farmingdale, New York

a Derived from Stanford Research Institute (SRI 2006), except where otherwise noted. SRI reports production of chemicals produced in commercial quantities (defined as exceeding 5,000 pounds or $10,000 in value annually) by the companies listed.

b USGS 2006a

c Meister et al. 2006

## 5.2 IMPORT/EXPORT

Since U.S. production ceased in 1985, all arsenic consumed in the United States is imported. Imports of arsenic (metal and compounds combined) have increased substantially since the mid-1980s, reaching 8,810 metric tons (as arsenic content) in 2005, of which 812 metric tons was as elemental arsenic. In 2005, 11,000 metric tons of arsenic trioxide was imported into the United States. China is the major import source for elemental arsenic from 2001 to 2004, supplying 81%, followed by Japan (15%) and Hong Kong (2%). China is also the major import source in 2001–2004 for arsenic trioxide, supplying 59% to the United States, followed by Morocco (22%), Chile (7%), and Mexico (5%) (USGS 2006a, 2006b).

U.S. exports of elemental arsenic were 220 metric tons in 2004 and are estimated to be 200 metric tons in 2005 (USGS 2006b). In 2005, U.S. import of arsenic was approximately 8.1×10^5^ kilograms (810 metric tons) (ITA 2007a, 2007b).

## 5.3 USE

In 2003, the United States was the world's largest consumer of arsenic, with an apparent demand of 21,600 metric tons. In 2005, the Unites States was still the world’s largest consumer of arsenic, mainly for CCA. Production of wood preservatives, primarily CCA, CrO_3_•CuO•As_2_O_5_, accounted for >90% of domestic consumption of arsenic trioxide prior to 2004. In 2005, about 65% of domestic consumption of arsenic trioxide was used for the production of CCA. The remainder was used for the production of agricultural chemicals, including herbicides, and insecticides. The major U.S. producers of CCA in 2005 included Arch Wood Protection, Inc., Smyrna Georgia; Chemical Specialties Inc., Charlotte, North Carolina; and Osmose Wood Preserving, Inc., Buffalo, New York (USGS 2006a). CCA is the most widely used wood preservative in the world. Wood treated with CCA is referred to as ‘pressure treated’ wood (American Wood Preservers Association 2007; Page and Loar 1993). In 1997, approximately 727.8 million cubic feet (20.6 million cubic meters) of wood products were pressure treated in the United States. CCA is a water-based product that protects several commercially available species of western lumber from decay and insect attack. It is widely used in treating utility poles, building lumber, and wood foundations. CCA comes in three types, A, B, and C, which contain different proportions of chromium, copper, and arsenic oxides. Type C, the most popular type, contains CrO_3_, CuO, and As_2_O_5_ in the proportions 47.5, 18.5, and 34.0%, respectively. The retention levels are 0.25 pounds per cubic feet (pcf) for above ground use such as fencing and decking, 0.40 pcf for lumber used in ground contact such as fence posts and deck posts, and 0.60 pcf for all weather wood foundations (Chicago Flameproof 2000; Permapost 2000). Piling used for fresh and saltwater contact should contain 0.80 and 2.5 pcf of CCA, respectively. Ammoniacal copper zinc arsenate (ACZA) is another arsenic containing preservative used to treat wood; however, it is not as widely used as CCA–C (Lebow et al. 2000).

In 2003, U.S. manufacturers of arsenical wood preservatives began a voluntary transition from CCA to other wood preservatives in wood products for certain residential uses, such as play structures, picnic tables, decks, fencing, and boardwalks. This phase out was completed on December 31, 2003; wood treated prior to this date could still be used and structures made with CCA-treated wood would not be affected. CCA-treated wood products continue to be used in industrial applications (EPA 2003a).

Elemental arsenic is used as an alloying element in ammunition and solders, as an anti-friction additive to metals used for bearings, and to strengthen lead-acid storage battery grids. In the past, the predominant use of arsenic was in agriculture. The uses of lead arsenate as a growth regulator on citrus, calcium arsenate as an herbicide on turf, sodium arsenite as a fungicide on grapes, and arsenic acid as a desiccant on okra for seed and cotton were voluntarily cancelled in the late 1980s and the early 1990s (EPA 2006). The herbicides, MSMA and DSMA, are registered for weed control on cotton, for turf grass and lawns, and under trees, vines, and shrubs; calcium acid methanearsonate (CAMA) is registered for postemergent weed control on lawns. Cacodylic acid, a defoliant and herbicide, is registered for weed control under nonbearing citrus trees, around buildings and sidewalks, and for lawn renovation (EPA 2006). Approximately 3 million pounds of MSMA or DSMA, and 100,000 pounds of cacodylic acid are applied in the U.S. annually based on EPA’s Screening Level Use Analysis data. Data were not available for CAMA. Application to cotton and turf (residential and golf courses) are the major uses of organic arsenical herbicides. Currently, there are approximately 90, 25, 4, and 35 end-use products containing MSMA, DSMA, CAMA, and cacodylic acid, respectively (EPA 2006).

Other organic arsenicals used in agriculture include arsanilic acid, sodium arsanilate, and 3-nitro-4-hydroxyphenylarsonic acid (roxarsone), which are antimicrobials used in animal and poultry feeds (Beerman 1994). While the U.S. Food and Drug Administration (FDA) has authorized the used of these compounds as medicinal feed additives, only one of the arsenical compounds may be used at a time as the sole source of organic arsenic in the feed (EPA 1998k). In 1999–2000, about 70% of the broiler industry added roxarsone to broiler poultry feed; concentrations of roxarsone in feed range from 22.7 to 45.4 g/ton (Garbarino et al. 2003).

From the mid-nineteenth century to the introduction of organic pesticides in the 1940s, inorganic arsenic compounds were the dominant pesticides available to farmers and fruit growers. Calcium arsenate was formerly used to control the boll weevil and cotton worm and was used as an herbicide. Lead arsenate was used on apple and other fruit orchards as well as on potato fields. Sodium arsenite was used to control weeds on railroad right-of-ways, potato fields, and in industrial areas, as well as in baits and to debark trees. Sodium arsenate had some application in ant traps. The use of inorganic arsenic compounds in agriculture has virtually disappeared beginning around the 1960s (Azcue and Nriagu 1994; Meister 1987; Merwin et al. 1994; Sanok et al. 1995). Food uses were voluntarily cancelled in 1993 as was the use of arsenic acid as a defoliant on cotton plants; inorganic arsenic’s remaining allowable uses are in ant baits and wood preservatives (EPA 1999h). In 1987, EPA issued a preliminary decision to cancel the registration of most inorganic arsenicals used as nonwood pesticides (Loebenstein 1994) (see Chapter 8). According to the California Department of Pesticide Regulation, arsenic acid, arsenic pentoxide, and arsenic trioxide are registered currently as pesticides in the United States; there are no active registrants listed for calcium arsenate, lead arsenate, or sodium arsenite (NPIRS 2007).

High-purity arsenic (99.9999%) is used by the electronics industry for gallium-arsenide semiconductors for telecommunications, solar cells, and space research (USGS 2006b). Arsenic trioxide and arsenic acid were used as a decolorizer and fining agent in the production of bottle glass and other glassware (Carapella 1992).

Arsenic compounds have a long history of use in medicine. Inorganic arsenic was used as a therapeutic agent through the mid-twentieth century, primarily for the treatment of leukemia, psoriasis, and chronic bronchial asthma; organic arsenic antibiotics were extensively used in the treatment of spirochetal and protozoal disease (NRC 1999). The availability of inorganic arsenicals in Western medicines ended in the 1970s, although they may still be encountered in non-Western traditional medicines. By the 1980s, the only remaining medicinal organic arsenical was melarsoprol for treatment of the meningoencephalitic stage of African trypanosomiasis. There has been renewed interest in arsenic as a therapeutic agent, namely the use of arsenic trioxide in the treatment of acute promyelocytic leukemia (APL) (Gallagher 1998; Kroemer and de Thé 1999; Miller 1998; Wang 2001). In 2000, the FDA approved arsenic trioxide for this use (FDA 2000).

## 5.4 DISPOSAL

Wastes containing arsenic are considered hazardous wastes, and as such, their treatment, storage, and disposal are regulated by law (see Chapter 8). The main route of disposal of solid wastes containing arsenic is landfilling. EPA has promulgated rules and treatment standards for landfilling liquid arsenical wastes (EPA 1990e). Arsenic-containing electronic components such as relays, switches, and circuit boards are disposed of at hazardous waste sites, and the elemental arsenic is not reclaimed. Process water at wood treatment plants that contained arsenic contained was reused. Gallium-arsenide scrap from the manufacture of semiconductor devices was reprocessed for arsenic recovery. Arsenic was not recovered from arsenical residues and dusts at domestic nonferrous smelters (USGS 2006b).

CCA-treated wood is classified as nonhazardous waste under the Federal Resource Conservation and Recovery Act (RCRA). CCA-treated wood is disposed of with regular municipal trash (i.e., municipal solid waste, not yard waste). It should not be burned in open fires, stoves, residential boilers, or fire places and should not be composted or used as mulch. Treated wood from commercial or industrial applications may only be burned in commercial or industrial incinerators in accordance with state and federal regulations (Adobe Lumber 2002; EPA 2005a).

Arsenic is listed as a toxic substance under Section 313 of the Emergency Planning and Community Right to Know Act (EPCRA) under Title III of the Superfund Amendments and Reauthorization Act (SARA) (EPA 1995c). Disposal of wastes containing arsenic is controlled by a number of federal regulations (see Chapter 8).