# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of arsenic and some common inorganic and organic arsenic compounds are located in Tables 4-1 and 4-2, respectively.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of arsenic and some common inorganic and organic arsenic compounds is located in Tables 4-3 and 4-4, respectively.

Arsenic appears in Group 15 (V) of the periodic table, below nitrogen and phosphorus. Arsenic is classified chemically as a metalloid, having both properties of a metal and a nonmetal; however, it is frequently referred to as a metal. Elemental arsenic, which is also referred to as metallic arsenic, (As(0)) normally occurs as the α-crystalline metallic form, which is a steel gray and brittle solid. The β-form is a dark gray amorphous solid. Other allotropic forms of arsenic may also exist. In compounds, arsenic typically exists in one of three oxidation states, −3, +3, and +5 (Carapella 1992). Arsenic compounds can be categorized as inorganic, compounds without an arsenic-carbon bond, and organic, compounds with an arsenic-carbon bond.

Table 4-1 Chemical Identity of Arsenic and Selected Inorganic Arsenic Compounds^a^

Characteristic | Arsenic | Arsenic acid | Arsenic pentoxide | Arsenic trioxide
Synonym(s) | Arsenic black; colloidal arsenic; gray arsenic, metallic arsenic | Orthoarsenic acid | Arsenic(V) oxide; arsenic acid anhydride; diarsenic pentoxide | Arsenic(III) oxide; arsenious acid; arsenious oxide; white arsenic
Registered trade name(s) | No data | Zotox; Hi-Yield Desiccant H-10; Desiccant L-10; Crab Grass Killer | No data | White Arsenic; Arsenicum Album
Chemical formula | As | H_3_AsO_4_ | As_2_O_5_ | As_2_O_3_
Chemical structure | As | [image] | [As^5+^]_2_ [O^2−^]_5_ | [As^3+^]_2_ [O^2−^]_3_
Identification numbers:
CAS registry | 7440-38-2 | 7778-39-4 | 1303-28-2 | 1327-53-3
NIOSH RTECS^b^ | CG0525000 | CG0700000 | CG2275000 | CG3325000
EPA hazardous waste | D004 | D004, P010 | D004, P011 | D004, P012
OHM/TADS | No data | No data | No data | No data
DOT/UN/NA/IMDG shipping | UN1558/IMDG 6.1 | UN1553 (liquid)/UN1554 (solid)/IMDG 6.1 (liquid and solid) | UN1559/IMDG 6.1 | UN1561/IMDG 6.1
HSDB | 509 | 431 | 429 | 419
EINECS | 231-148-6 | 231-901-9 | 215-116-9 | 215-481-4
NCI | No data | No data | No data | No data
Characteristic | Calcium arsenate | Gallium arsenide | Sodium arsenate | Sodium arsenite
Synonym(s) | Calcium orthoarsenate; arsenic acid, calcium salt | Gallium monoarsenide | Disodium arsenate, dibasic; disodium hydrogen arsenate; arsenic acid, disodium salt | Arsenenous acid, sodium salt; sodium meta-arsenite
Registered trade name(s) | Pencal; Security; Turf-Cal; Chip-Cal; SPRA-Cal | No data | No data | Atlas “A”; Penite; Kill-All; Chem-Sen 56; Chem Pels C; Progalumnol Double
Chemical formula | Ca_3_(AsO_4_)_2_ | GaAs | Na_2_HAsO_4_ | NaAsO_2_
Chemical structure | [image] | Ga:As | [image] | [image]
Identification numbers:
CAS registry | 7778-44-1 | 1303-00-0 | 7778-43-0 | 7784-46-5
NIOSH RTECS^b^ | CG0830000 | LW8800000 | CG0875000 | CG3675000
EPA hazardous waste | D004 | D004 | D004 | D004
OHM/TADS | No data | No data | No data | 7800057
DOT/UN/NA/IMDG shipping | UN1573/IMDG 6.1 | UN 2803; Gallium/IMDG 8.0; Gallium | UN 1685/IMDG 6.1 | UN1686 (aqueous solution)/UN2027 (solid)/IMDG 6.1
HSDB | 1433 | 4376 | 1675 | 693
EINECS | 233-287-8 | 215-114-8 | 231-902-4 | 232-070-5
NCI | No data | No data | No data | No data

a All information obtained from HSDB 2007 and CHEMIDplus 2007, except where noted.

b RTECS 2007

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Chemical Identity of Selected Organic Arsenic Compounds^a^

Characteristic | Arsanilic acid | Arsenobetaine | Dimethylarsinic acid
Synonym(s) | (4-Aminophenyl)arsonic acid; antoxylic acid; atoxylic acid, Pro-Gen | Arsonium, (carboxymethyl)-trimethyl-, hydroxide, inner salt | Cacodylic acid; hydroxydimethyl-arsine oxide; DMA; DMAA
Registered trade name(s) | No data | No data | 510; Arsan; Phytar 560; Rad-E-Cate 35
Chemical formula | C_6_H_8_AsNO_3_ | C_5_H_11_AsO_2_ | C_2_H_7_AsO_2_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 98-50-0 | 64436-13-1 | 75-60-5
NIOSH RTECS^b^ | CF7875000 | CH9750000 | CH7525000
EPA hazardous waste | D004 | No data | U136/D004
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | UN1572/IMDG 6.1
HSDB | 432 | No data | 360
EINECS | 202-674-3 | No data | 200-883-4
NCI | No data | No data | No data
Characteristic | Disodium methanearsonate | Methanearsonic acid | 3-Nitro-4-hydroxy-phenylarsonic acid
Synonym(s) | DSMA; disodium monomethane arsonate | Arsonic acid, methyl-; monomethylarsonic acid | Roxarsone; 3-nitro-4-hydroxyphenylarsonic acid; 3-Nitro-10
Registered trade name(s) | Ansar 8100; Arrhenal; Ansar DSMA Liquid; Dinate; Crab-E-Rad; Chipco Crab Kleen; Arsinyl; Sodar; Methar; Drexel DSMA Liquid; Di-Tac; Ansar 184; Weed-E-Rad; Versar DSMA-LQ; Calar-E-Rad; Dal-E-Rad; Jon-Trol; Namate | No data | No data
Chemical formula | CH_3_AsO_3_Na_2_ | CH_5_AsO_3_ | C_6_H_6_AsNO_6_
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 144-21-8 | 124-58-3 | 121-19-7
NIOSH RTECS^b^ | PA2275000 | PA1575000 | CY5250000
EPA hazardous waste | D004 | D004 | D004
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | No data | No data | No data
HSDB | 1701 | 845 | 4296
EINECS | 205-620-7 | 204-705-6 | 204-453-7
NCI | No data | No data | C5608
Characteristic | Sodium arsanilate | Sodium dimethylarsinate | Sodium methanearsonate
Synonym(s) | (4-Aminophenyl)arsonic acid sodium salt; arsanilic acid sodium salt; arsamin; atoxyl; soamin; trypoxyl | Sodium cacodylate; cacodylic acid, sodium salt; sodium dimethylarsonate | Arsonic acid, methyl-, monosodium salt; monosodium acid metharsonate; MSMA
Registered trade name(s) | No data | Ansar 160; Ansar 560; Bolls-Eye; Chemaid; Phytar 560, component of (with 012501); Rad-E-Cate 25. | Ansar 529; Ansar 170; Target MSMA; Phyban H.C.; Deconate; Mesamate; Bueno; Monate Merge 823; Dal-E-Rad; Weed-S-Rad; Arsanote liquid; Silvisar 550.
Chemical formula | C_6_H_7_AsNO_3_Na | C_2_H_6_AsO_2_Na | CH_4_AsO_3_Na
Chemical structure | [image] | [image] | [image]
Identification numbers:
CAS registry | 127-85-5 | 124-65-2 | 2163-80-6
NIOSH RTECS^b^ | CF9625000 | CH7700000 | PA2625000
EPA hazardous waste | D004 | D004 | D004
OHM/TADS | No data | No data | No data
DOT/UN/NA/IMDG shipping | UN2473/IMDG 6.1 | UN1688/IMDG 6.1 | No data
HSDB | 5189 | 731 | 754
EINECS | 204-869-9 | 204-708-2 | 218-495-9
NCI | C61176 | No data | C60071

a All information obtained from HSDB 2007 and CHEMIDplus 2007, except where noted.

b RTECS 2007

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Dept. of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-3 Physical and Chemical Properties of Arsenic and Selected Inorganic Arsenic Compounds^a^

Property | Arsenic | Arsenic acid | Arsenic pentoxide | Arsenic trioxide
Molecular weight | 74.9216 | 141.944 | 229.840 | 197.841
Color | Silver-gray or tin-white | White^b^ | White | White
Physical state | Solid | Solid^b^ | Solid | Solid
Melting point | 817 °C (triple point) | 35 °C | Decomposes at ~300 °C | 313 °C (claudetite); 274 °C (arsenolite)
Boiling point | 614 °C sublimes | Loses H_2_O at 160 °C ^b^ | No data | 460 °C
Density | 5.778 g/cm^3^ at 25 °C | ~2.2 g/cm^3^ | 4.32 g/cm^3^ | 3.865 g/cm^3^ (cubes); 4.15 g/cm^3^ (rhombic crystals)
Odor | Odorless | No data | No data | Odorless
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | Insoluble | 302 g/L at 12.5 °C^b^ | 2,300 g/L at 20 °C | 17 g/L at 16 °C
Organic solvent(s) | No data | Soluble in alcohol, glycerol^b^ | Soluble in alcohol | Practically insoluble in alcohol, chloroform, ether; soluble in glycerol
Other | Insoluble in caustic and nonoxidizing acids | No data | Soluble in acid, alkali | Soluble in dilute hydrochloric acid, alkali hydroxide, carbonate solution
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
pK_a_ | No data | pK_a1_=2.22; pK_a2_=6.98 pK_a3_=11.53^c^ | No data | No data
Vapor pressure | 7.5×10^−3^ mmHg at 280 °C | No data | No data | 2.47×10^−4^ mmHg at 25 °C
Autoignition temperature | No data | No data | No data | Not flammable
Flashpoint | No data | No data | No data | No data
Flammability limits in air | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data
Property | Calcium arsenate | Gallium arsenide | Disodium arsenate | Sodium arsenite
Molecular weight | 398.072 | 144.64 | 185.91 | 130.92
Color | Colorless | Dark gray | Colorless^d^ | White to gray-white
Physical state | Solid | Solid | Solid^d^ | Solid
Melting point | Decomposes on heating | 1,238 °C | 57 °C^d^ | No data
Boiling point | No data | No data | No data | No data
Density | 3.620 g/cm^3^ | 5.3176 g/cm^3^ at 25 °C | 1.87 g/cm^d^ | 1.87 g/cm^3^
Odor | Odorless | Garlic odor | Odorless^d^ | No data
Odor threshold:
Water | No data | No data | No data | No data
Air | No data | No data | No data | No data
Solubility:
Water | 0.13 g/L at 25 °C | <1 mg/mL at 20 °C | Soluble 1:3 parts in water^d^ | Freely soluble in water
Organic solvents | Insoluble | <1 mg/mg dimethyl sulfoxide, ethanol, methanol, acetone | Slightly soluble in alcohol; soluble in glycerol^d^ | Slightly soluble in alcohol
Other | Soluble in dilute acids | Soluble in hydrochloric acid | Slightly soluble in alkaline solution^d^ | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data
pK_a_ | No data | No data
Vapor pressure | ~0 mmHg at 20 °C | No data | No data | No data
Autoignition temperature | Not combustible | No data | No data | Not combustible
Flashpoint | No data | No data | No data | No data
Flammability limits in air | No data | No data | No data | No data
Conversion factors | No data | No data | No data | No data
Explosive limits | No data | No data | No data | No data

a All information from HSDB 2007, except where noted.

b Value for arsenic acid hemihydrate

c NRC 1999

d Value for disodium arsenate heptahydrate

Table 4-4 Physical and Chemical Properties of Selected Organic Arsenic Compounds^a^

Property | Arsenilic acid | Arsenobetaine | Dimethylarsinic acid
Molecular weight | 217.06 | 196.1^b^ | 138.00
Color | White | No data | Colorless
Physical state | Solid | Solid^b^ | Solid
Melting point | 232 °C | 203–210 °C (decomposes)^b^ | 195 °C
Boiling point | | No data | >200 °C
Density | 1.9571 g/cm^3^ at 10 °C | No data | No data
Odor | Practically odorless | No data | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | Slightly soluble in cold water; soluble in hot water | No data | 2,000 g/L at 25 °C
Organic solvent(s) | Slightly soluble in alcohol; soluble in amyl alcohol; insoluble in ether, acetone, benzene, chloroform | No data | Soluble in alcohol; insoluble in diethyl ether
Acids | Slightly soluble in acetic acid; soluble in alkaki carbonates; moderately soluble in concentrated mineral acids; insoluble in dilute mineral acids | No data | Soluble in acetic acid
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
pK_a_ | No data | 2.2^c^ | 1.57
Vapor pressure | No data | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability | No data | No data | Nonflammable
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Methanearsonic acid | 3-Nitro-4-hydroxy-phenylarsonic acid | Sodium arsanilate
Molecular weight | 139.97 | 263.03 | 239.04
Color | White | Pale yellow | White or creamy white
Physical state | Solid | Solid | Solid
Melting point | 160.5 °C | No data | No data
Boiling point | No data | No data | No data
Density | No data | No data | No data
Odor | No data | No data | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 256 g/L at 20 °C | Slightly soluble in cold water; soluble in about 30 parts boiling water | Soluble 1 part in 3 parts water
Organic solvents | Soluble in ethanol | Soluble in methanol, ethanol, acetone; insoluble in ether, ethyl acetate | Soluble 1 part in 150 parts alcohol; practically insoluble in chloroform, ether
Acids | No data | Soluble in acetic acid, alkalies; sparingly soluble in dilute mineral acids | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data
Log K_oc_ | No data | No data | No data
pK_a_ | pK_a1_=4.1; pK_a2_=9.02 | No data | No data
Vapor pressure at 25 °C | <7.5×10^−8^ mmHg | No data | No data
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability | No data | No data | No data
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data
Property | Disodium methanearsonate | Sodium dimethylarsinate | Sodium methanearsonate
Molecular weight | 183.93 | 159.98 | 161.95
Color | White | Colorless to light yellow | White
Physical state | Solid | Solid | Solid
Melting point | >355 °C | 200 °C | 130–140 °C
Boiling point | No data | No data | No data
Density | 1.04 g/cm^3^ | >1 g/cm^3^ at 20 °C | 1.55 g/mL^d^
Odor | No data | Odorless | Odorless
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Solubility:
Water | 432 g/L at 25 °C | 200 g/L at 25 °C | 580 g/L at 20 °C
Organic solvents | Soluble in methanol; practically insoluble in most organic solvents | No data | Insoluble in most organic solvents
Acids | No data | No data | No data
Partition coefficients:
Log K_ow_ | <1 | No data | −3.10
Log K_oc_ | No data | No data | No data
pK_a_ | pK_a1_=4.1; pK_a2_=8.94 | 6.29 | pK_a1_=4.1; pK_a2_=9.02
Vapor pressure at 25 °C | 10^−7^ mmHg | No data | 7.8×10^−8^ mmHg
Henry’s law constant | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability | Nonflammable | No data | Nonflammable
Conversion factors | No data | No data | No data
Explosive limits | No data | No data | No data

a All information from HSDB 2007, except where noted.

b Cannon et al. 1981 (arsenobetaine as monohydrate)

c Teräsahde et al. 1996

d Value for Ansar 6.6