# APPENDIX A ATSDR MINIMAL RISK LEVEL AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Inorganic Arsenic Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Inorganic Arsenic
CAS Number: | 7440-38-2
Date: | August 2007
Profile Status: | Post-Public Comment, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [X] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 29
Species: | Human

[underlined: Minimal Risk Level]: 0.005 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Mizuta N, Mizuta M, Ito F, et al. 1956. An outbreak of acute arsenic poisoning caused by arsenic-contaminated soy-sauce (shōyu): A clinical report of 220 cases. Bull Yamaguchi Med Sch 4(2–3):131–149.

[underlined: Experimental design]: Mizuta et al. (1956) summarized findings from 220 poisoning cases associated with an episode of arsenic contamination of soy sauce in Japan. The soy sauce was contaminated with approximately 0.1 mg As/mL, probably as calcium arsenate. Arsenic intake in the cases was estimated by the researchers to be 3 mg/day (0.05 mg/kg/day, assuming 55 kg average body weight for this Asian population). Duration of exposure was 2–3 weeks in most cases. Clinical symptoms were recorded. Seventy patients were examined opthalmologically. Laboratory tests were performed on some patients and included hematology, urinalysis, fecal exam, occult blood in gastric and duodenal juice, biochemical examination of blood, liver function tests, electrocardiograph, and liver biopsy.

[underlined: Effects noted in study and corresponding doses]: The primary symptoms were edema of the face, and gastrointestinal and upper respiratory symptoms initially, followed in some patients by skin lesions and neuropathy. Other effects included mild anemia and leukopenia, mild degenerative liver lesions and hepatic dysfunction, abnormal electrocardiogram, and ocular lesions. For derivation of the acute oral MRL, facial edema and gastrointestinal symptoms (nausea, vomiting, diarrhea), which were characteristic of the initial poisoning and then subsided, were considered to be the critical effects.

[underlined: Dose and end point used for MRL derivation]: 0.05 mg As/kg/day

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty factors used in MRL derivation]: [ ] 1 [ ] 3 [X] 10 (for use of a LOAEL) [ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans) [X] 1 [ ] 3 [ ] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Not applicable. [underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable. [underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The MRL is supported by the case of a man and wife in upstate New York who experienced gastrointestinal symptoms (nausea, diarrhea, abdominal cramps) starting almost immediately after beginning intermittent consumption of arsenic-tainted drinking water at an estimated dose of 0.05 mg As/kg/day (Franzblau and Lilis 1989). Gastrointestinal symptoms have been widely reported in other acute arsenic poisoning reports as well, although in some cases, the doses were higher and effects were severe, and in other cases, dose information was not available. The UF of 1 for intrahuman variability reflects the fact that the database includes persons of various ethnicities and age groups, including infants.

[underlined: Agency Contact (Chemical Manager)]: Selene Chou, Ph.D and Carolyn Harper, Ph.D.

## Inorganic Arsenic Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Inorganic Arsenic
CAS Number: | 7440038-2
Date: | August 2007
Profile Status: | Post-Public Comment, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 134
Species: | Human

[underlined: Minimal Risk Level]: 0.0003 [X] mg/kg/day [ ] ppm

[underlined: References]: Tseng, WP, Chu HM, How SW, et al. 1968. Prevalence of skin cancer in an endemic area of chronic arsenicism in Taiwan. J Natl Cancer Inst 40:453–463.

Tseng, WP. 1977. Effects and dose-response relationships of cancer and Blackfoot disease with arsenic. Environ Health Perspect 19:109–119.

[underlined: Experimental design]: Tseng et al. (1968) and Tseng (1977) investigated the incidence of Blackfoot disease and dermal lesions (hyperkeratosis and hyperpigmentation) in a large number of poor farmers (both male and female) exposed to high levels of arsenic in well water in Taiwan. A control group consisting of 17,000 people was identified. The authors stated that the incidence of dermal lesions increased with dose, but individual doses were not provided. However, incidence data were provided based on stratification of the exposed population into low (<300 μg/L), medium (300–600 μg/L), or high (>600 μg/L) exposure levels. Doses were calculated from group mean arsenic concentrations in well water, assuming the intake parameters described by Abernathy et al. (1989). Accordingly, the control, low-, medium-, and high-exposure levels correspond to doses of 0.0008, 0.014, 0.038, and 0.065 mg As/kg/day, respectively. The NOAEL identified by Tseng (1977) (0.0008 mg As/kg/day) was limited by the fact that the majority of the population was <20 years of age and the incidence of skin lesions increased as a function of age, and because the estimates of water intake and dietary arsenic intake are highly uncertain. Schoof et al. (1998) estimated that dietary intakes of arsenic from rice and yams may have been 15–211 μg/day (mean 61 μg/day), based on arsenic analyses of foods collected in Taiwan in 1993–1995. Use of the 50 μg/day estimate would result in an approximate doubling of the NOAEL (0.0016 mg/kg/day).

[underlined: Effects noted in study and corresponding doses]: A clear dose-response relationship was observed for characteristic skin lesions:

0.0008 mg As/kg/day = control group (NOAEL) 0.014 mg As/kg/day = hyperpigmentation and keratosis of the skin (less serious LOAEL) 0.038–0.065 mg As/kg/day = increased incidence of dermal lesions

[underlined: Dose and end point used for MRL derivation]: 0.0008 mg As/kg/day

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty factors used in MRL derivation]: [ ] 1 [ ] 3 [ ] 10 (for use of a LOAEL) [ ] 1 [ ] 3 [ ] 10 (for extrapolation from animals to humans)

[ ] 1 [x] 3 [ ] 10 (for human variability)

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? The arithmetic mean concentration of arsenic in well water for the control group (0.009 mg/L) was converted to a NOAEL of 0.0008 mg As/kg/day as described below:

[((0.009 m g)/(L) × (4.5 L)/(d a y)) + (0.002 m g)/(d a y)] ÷ 55 k g = 0.0008 m g A s / k g / d a y

This NOAEL conversion assumed a water intake of 4.5 L/day and a body weight of 55 kg, and includes an estimation of arsenic intake of 0.002 mg As/kg/day from food. These assumptions are detailed in Abernathy et al. (1989). This approach to deriving a chronic oral MRL is identical to EPA’s approach to deriving a chronic oral RfD.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The MRL is supported by a number of well conducted epidemiological studies that identify reliable NOAELs and LOAELs for dermal effects. EPA (1981b) identified a NOAEL of 0.006–0.007 mg As/kg/day for dermal lesions in several small populations in Utah. Harrington et al. (1978) identified a NOAEL of 0.003 mg As/kg/day for dermal effects in a small population in Alaska. Guha Mazumder et al. (1988) identified a NOAEL of 0.009 mg As/kg/day and a LOAEL of 0.006 mg As/kg/day for pigmentation changes and hyperkeratosis in a small population in India. Haque et al. (2003) identified a LOAEL of 0.0043 mg As/kg/day for hyperpigmentation and hyperkeratosis in a case-control study in India. Cebrían et al. (1983) identified a NOAEL of 0.0004 mg As/kg/day and a LOAEL of 0.022 mg As/kg/day in two regions in Mexico. Borgoño and Greiber (1972) and Zaldívar (1974) identified a LOAEL of 0.02 mg As/kg/day for abnormal skin pigmentation in patients in Chile, and Borgoño et al. (1980) identified a LOAEL of 0.01 mg As/kg/day for the same effect in school children in Chile. Valentine et al. (1985) reported a NOAEL of 0.02 mg As/kg/day for dermal effects in several small populations in California. Collectively, these studies indicate that the threshold dose for hyperpigmentation and hyperkeratosis is approximately 0.002 mg As/kg/day.

[underlined: Agency Contacts (Chemical Managers)]: Selene Chou, Ph.D and Carolyn Harper, Ph.D.

## Monomethylarsonic acid (MMA) Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Monomethylarsonic acid (MMA)
CAS Number: | 124-58-3
Date: | August 2007
Profile Status: | Post-Public Comment, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [ ] Chronic
Graph Key: | 12
Species: | Rat

[underlined: Minimal Risk Level]: 0.1 [X] mg MMA/kg/day [ ] ppm

[underlined: References]: Arnold LL, Eldan M, van Gemert M, et al. 2003. Chronic studies evaluating the carcinogenicity of monomethylarsonic acid in rats and mice. Toxicology 190:197–219.

Crown S, Nyska A, Waner T. 1990. Methanearsonic acid: Combined chronic feeding and oncogenicity study in the rat. Conducted by Life Science Research Israel Ltd., Ness Ziona Israel. Submitted to EPA Office of Pesticide Programs (MRID 41669001).

[underlined: Experimental design]: Groups of 60 male and 60 female Fischer 344 rats were exposed to 0, 50, 400, or 1,300 ppm MMA in the diet for 104 weeks. Using the average doses for weeks 1–50 reported in an unpublished version of this study (Crown et al. 1990), doses of 0, 3.5, 30.2, and 106.9 mg MMA/kg/day and 0, 4.2, 35.9, and 123.3 mg MMA/kg/day were calculated for males and females, respectively. Body weights, food consumption, and water intake were monitored regularly. Blood was taken at 3, 6, and 12 months for clinical chemistry measurements, and urine samples were collected at the same interval.

[underlined: Effects noted in study and corresponding doses]: Mortality was increased in high-dose males and females during the first 52 weeks of the study. Body weights were decreased in the mid- and high-dose groups of both sexes; however, at 51 weeks, only the body weight for the high-dose males was <10% of the control weight (14.5%). Food and water consumption was increased in the mid- and high-dose groups. Diarrhea was observed in 100% of the high-dose males and females and in 16.7 and 40% of the mid-dose males and females during the first 52 weeks of exposure. Diarrhea first occurred after 3 weeks of exposure to the high dose and 4 weeks of exposure to the mid-dose group; the severity of the diarrhea was dose-related. The gastrointestinal system was the primary target in animals dying early; numerous macroscopic and histological alterations were observed.

[underlined: Dose and end point used for MRL derivation]: Benchmark dose analysis of the dose-response data (Table A-1) for diarrhea in male and female rats exposed to MMA in the diet for 1–52 weeks (incidence data reported in Crown et al. 1990) was conducted. All available dichotomous models in EPA’s Benchmark Dose Software (version 1.4.1) were fit to the data. Predicted doses associated with a 10% extra risk were calculated. As assessed by the chi-square goodness-of-fit statistic, all models, with the exception of the quantal linear model for male incidence data and the quantal linear model for female incidence data, provided an adequate fit (X^2^ p>0.1) (Table A-2). Comparing across models, a better fit is generally indicated by a lower Akaike’s Information Criteria (AIC). As assessed by AIC, the gamma model for the males (Figure A-1) and the 2-degree polynomial multi-stage model for the females (Figure A-2) provide the best fit to the data. The predicted BMD_10_ and BMDL_10_ are 28.25 mg MMA/kg/day and 22.99 mg MMA/kg/day for the male rat incidence data and 16.17 mg MMA/kg/day, and 12.38 mg MMA/kg/day for the female rat incidence data.

Table A-1 Incidences of Diarrhea in Rats Exposed to MMA in the Diet for 1–52 Weeks

Dietary concentration (ppm) | Dose (mg MMA/kg/day) | Incidence
Male rats
0 | 0 | 2/60
50 | 3.5 | 0/60
400 | 30.2 | 10/60
1,300 | 106.9 | 60/60
Female rats
0 | 0 | 0/60
50 | 4.2 | 0/60
400 | 35.9 | 24/60
1,300 | 123.3 | 60/60

Sources: Arnold et al. 2003; Crown et al. 1990

Table A-2 Modeling Predictions for the Incidence of Diarrhea in Rats Exposed to MMA in the Diet for 1–52 Weeks

| BMD_10_ | BMDL_10_
Model | (mg MMA/kg/day) | (mg MMA/kg/day) | x^2^ p-value | AIC
Male rats
Gamma^a^ | 28.25 | 22.99 | 0.36 | 78.41
Logistic | 24.60 | 20.19 | 0.16 | 79.59
Log-logistic^b^ | 29.32 | 24.73 | 0.15 | 80.41
Multi-stage^c^ | 25.74 | 19.90 | 0.35 | 78.51
Probit | 23.11 | 18.67 | 0.11 | 80.02
Log-probit^b^ | 28.79 | 24.47 | 0.15 | 80.41
Quantal linear | 6.317 | 5.079 | 0.00 | 123.06
Weibull^a^ | 27.99 | 20.66 | 0.15 | 80.41
Female rats
Gamma^a^ | 26.81 | 15.18 | 1.00 | 84.76
Logistic | 32.85 | 21.49 | 1.00 | 84.76
Log-logistic^b^ | 31.97 | 20.16 | 1.00 | 84.76
Multi-stage^c^ | 16.17 | 12.38 | 0.90 | 83.88
Probit | 29.89 | 19.11 | 1.00 | 84.76
Log-probit^b^ | 28.95 | 18.87 | 1.00 | 84.76
Quantal linear | 5.33 | 4.33 | 0.00 | 106.52
Weibull^a^ | 27.83 | 13.58 | 1.00 | 84.76

Sources: Arnold et al. 2003; Crown et al. 1990

a Restrict power ≥1.

b Slope restricted to >1.

c Restrict betas ≥0; lowest degree polynomial with an adequate fit is reported; degree of polynomial=3.

d Restrict betas ≥0; lowest degree polynomial with an adequate fit is reported; degree of polynomial=2.

Figure A-1 Predicted and Observed Incidence of Diarrhea in Male Rats Exposed to MMA in the Diet for 1–52 Weeks*

*BMDs and BMDLs indicated are associated with a 10% extra risk change from the control, and are in units of mg MMA/kg/day.

Figure A-2 Predicted and Observed Incidence of Diarrhea in Female Rats Exposed to MMA in the Diet for 52 Weeks*

*BMDs and BMDLs indicated are associated with a 10% extra risk change from the control, and are in units of mg MMA/kg/day.

The BMDL_10_ of 12.38 mg MMA/kg/day for female rats was selected as the point of departure for deriving the intermediate-duration oral MRL because it was lower than the BMDL_10_ (22.99 mg MMA/kg/day) calculated using the male incidence data.

[ ] NOAEL [ ] LOAEL [X] BMDL

[underlined: Uncertainty factors used in MRL derivation]: 100

[ ] 10 for use of a LOAEL [X] 10 for extrapolation from animals to humans [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Doses calculated using the average of the achieved doses for weeks 1–50 reported in Crown et al. (1990): 0, 3.5, 30.2, and 106.9 mg MMA/kg/day for males and 0, 4.2, 35.9, and 123.3 mg MMA/kg/day for females.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: Increases in the incidence of diarrhea has also been observed in dogs administered via capsule 2 mg MMA/kg/day for 52 weeks (Waner and Nyska 1988); the increased incidence of diarrhea started during weeks 25–28. At 35 mg MMA/kg/day, vomiting was also observed in the dogs. Diarrhea has also been observed in rats and mice exposed to MMA for 2 years (Arnold et al. 2003); the LOAELs are 25.7 and 67.1 mg MMA/kg/day, respectively.

[underlined: Agency Contacts (Chemical Managers)]: Selene Chou, Ph.D and Carolyn Harper, Ph.D.

## Monomethylarsonic acid (MMA) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Monomethylarsonic acid (MMA)
CAS Number: | 124-58-3
Date: | August 2007
Profile Status: | Post-Public Comment, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 21
Species: | Mouse

[underlined: Minimal Risk Level]: 0.01 [X] mg MMA/kg/day [ ] ppm

[underlined: References]: Arnold LL, Eldan M, van Gemert M, et al. 2003. Chronic studies evaluating the carcinogenicity of monomethylarsonic acid in rats and mice. Toxicology 190:197–219.

Gur E, Piraic H, Waner T. 1991. Methanearsonic acid: Combined oncogenicity study in the mouse. Conducted by Life Science Research Israel Ltd., Ness Ziona Israel. Submitted to EPA Office of Pesticide Programs (MRID 42173201).

[underlined: Experimental design]: Groups of 52 male and 52 female B6C3F_1_ mice were exposed to 0, 10, 50, 200, or 400 ppm of MMA in the diet for 104 weeks. The reported MMA doses were 0, 1.2, 6.0, 24.9, and 67.1 mg MMA/kg/day (males) and 0, 1.4, 7.0, 31.2, and 101 mg MMA/kg/day (females). Body weights, food consumption, and water intake were monitored regularly. Blood was taken at 3, 6, 12, 18, and 24 months for white cell counts. At sacrifice, complete necropsies were performed, including histological examination of at least 13 organs.

[underlined: Effects noted in study and corresponding doses]: No treatment-related increases in mortality were observed. Significant decreases in body weights were observed in males and females exposed to 32.2 or 48.5 mg As/kg/day, respectively; at week 104, the males weighed 17% less than controls and females weighed 23% less. Food consumption was increased in females exposed to 101 mg MMA/kg/day, and water consumption was increased in 67.1 mg MMA/kg/day males and 31.2 and 101 mg MMA/kg/day females. Loose and mucoid feces were noted in mice exposed to 67.1/101 mg MMA/kg/day. No changes were seen in white cell counts of either sex. Small decreases in the weights of heart, spleen, kidney, and liver were seen in some animals, but the decreases were not statistically significant. Squamous metaplasia of the cecum, colon, and rectum was observed at 67.1/101 mg MMA/kg/day. The incidences of metaplasia in the cecum, colon, and rectum were 29/49, 14/49, and 39/49 in males and 38/52, 17/52, and 42/52 in females; metaplasia was not observed in other groups of male or female mice. An increased incidence of progressive glomerulonephropathy (incidence of 25/52, 27/52, 38/52, 39/52, and 46/52 in the 0, 1.2, 6.0, 24.9, and 67.1 mg MMA/kg/day) was observed in males; the incidence was significantly higher (Fisher Exact Test) than controls at ≥6.0 mg MMA/kg/day. Significant increases in the incidence of nephrocalcinosis was observed in the males at 24.9 and 67.1 mg MMA/kg/day (Fisher Exact Test) (incidence of 25/52, 30/52, 30/52, 45/522 45/51 and 0/52, 1/52, 1/52, 2/52, and 5/52 in males and females, respectively). The investigators noted that the kidney lesions were consistent with the normal spectrum of spontaneous renal lesions and there was no difference in character or severity of the lesions between groups. A reduction in the incidence of cortical focal hyperplasia in the adrenal gland of male mice exposed to 67.1 mg MMA/kg/day was possibly related to MMA exposure; the toxicological significance of this effect is not known.

[underlined: Dose and end point used for MRL derivation]: Benchmark dose analysis of the dose-response data (Table A-3) for progressive glomerulonephropathy in male mice exposed to MMA in the diet for 2 years (incidence data reported in Gur et al. 1991) was conducted. All available dichotomous models in EPA’s Benchmark Dose Software (version 1.4.1) were fit to the data. Predicted doses associated with a 10% extra risk were calculated. As assessed by the chi-square goodness-of-fit statistic, all models, with the exception of the log-probit model, provided an adequate fit (X^2^ p>0.1) (Table A-4). Comparing across models, a better fit is generally indicated by a lower Akaike’s Information Criteria (AIC). As assessed by AIC, the log-logistic model (Figure A-3) provided the best fit to the data. The predicted BMD_10_ and BMDL_10_ for the incidence data are 2.09 and 1.09 mg MMA/kg/day.

Table A-3 Incidence of Progressive Glomerulonephropathy in Male Mice Exposed to MMA in the Diet for 2 Years

Dietary Concentration (ppm) | Dose (mg MMA/kg/day) | Incidence
0 | 0 | 25/52
10 | 1.2 | 27/52
50 | 6.0 | 38/52
200 | 24.9 | 39/52
400 | 67.1 | 46/52

Sources: Arnold et al. 2003; Gur et al. 1991

Table A-4 Modeling Predictions for the Incidence of Progressive Glomerulonephropathy in Male Mice Exposed to MMA in the Diet for 2 Years

| BMD_10_ | BMDL_10_
Model | (mg MMA/kg/day) | (mg MMA/kg/day) | x^2^ p-value | AIC
Gamma^a^ | 4.60 | 3.15 | 0.18 | 309.33
Logistic | 6.09 | 4.45 | 0.13 | 310.15
Log-logistic ^ b ^ | 2.09 | 1.09 | 0.38 | 307.47
Multi-stage^c^ | 4.60 | 3.15 | 0.18 | 309.33
Probit | 6.62 | 5.00 | 0.11 | 310.43
Log-probit^b^ | 8.54 | 5.50 | 0.08 | 311.11
Quantal linear | 4.60 | 3.15 | 0.18 | 309.33
Weibull^a^ | 4.60 | 3.15 | 0.18 | 309.33

Sources: Arnold et al. 2003; Gur et al. 1991

a Restrict power ≥1.

b Slope restricted to >1.

c Restrict betas ≥0; lowest degree polynomial with an adequate fit is reported; degree of polynomial=1.

Figure A-3 Predicted and Observed Incidence of Progressive Glomerulonephropathy in Male Mice Exposed to MMA*

*BMDs and BMDLs indicated are associated with a 10% extra risk change from the control, and are in units of mg MMA/kg/day.

The BMDL_10_ of 1.09 mg MMA/kg/day for male mice was selected as the point of departure for deriving the chronic-duration oral MRL.

[ ] NOAEL [ ] LOAEL [X] BMDL

[underlined: Uncertainty factors used in MRL derivation]: 100

[ ] 10 for use of a LOAEL [X] 10 for extrapolation from animals to humans [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Doses calculated using the average of the achieved doses reported in Gur et al. (1991): 0, 1.2, 6.0, 24.9, and 67.1 mg MMA/kg/day for males and 0, 1.4, 7.0, 31.2, and 101 mg MMA/kg/day for females.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: An exacerbation of chronic progressive nephropathy (an increase in the severity of the nephropathy) has also been observed in rats exposed to ≥33.9 mg MMA/kg/day for 2 years (Arnold et al. 2003).

[underlined: Agency Contacts (Chemical Managers)]: Selene Chou, Ph.D and Carolyn Harper, Ph.D.

## Dimethylarsinic acid (DMA) Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dimethylarsinic acid (DMA)
CAS Number: | 75-60-5
Date: | August 2007
Profile Status: | Post-Public Comment, Final Draft
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 35
Species: | Mouse

[underlined: Minimal Risk Level]: 0.02 [X] mg DMA/kg/day [ ] ppm

[underlined: References]: Arnold LL, Eldan M, Nyska A, et al. 2006. Dimethylarsinic acid: Results of chronic toxicity/oncogenicity studies in F344 rats and B6C3F_1_ mice. Toxicology 223:82–100.

Gur E, Nyska A, Pirak M, et al. 1989b. Cacodylic acid: Oncogenicity study in the mouse. Conducted by Life Science Research Israel Ltd., Ness Ziona Israel. Submitted to EPA Office of Pesticide Programs (MRID 41914601).

[underlined: Experimental design]: Groups of 56 male and 56 female B6C3F_1_ mice were exposed to 0, 8, 40, 200, or 500 ppm DMA in the diet for 2 years. The investigators reported the dietary doses were equivalent to approximately 0, 1.3, 7.8, 37, and 94 mg DMA/kg/day. The following parameters were used to assess toxicity: clinical observations, body weight, food consumption, water consumption, differential leukocyte levels measured at 12, 18, and 24 months in mice in the control and 94 mg DMA/kg/day groups, organ weights (brain, kidneys, liver, and testes), and histopathological examination of major tissues and organs.

[underlined: Effects noted in study and corresponding doses]: No deaths were observed. Decreases in body weight gain were observed in the male mice exposed to 94 mg DMA/kg/day; the difference was <10% and was not considered adverse. An increase in water consumption was observed in males exposed to 94 mg DMA/kg/day during weeks 60–96. No treatment-related clinical signs were observed. In the female mice exposed to 94 mg DMA/kg/day, a statistically significant decrease in lymphocytes and increase in monocytes were observed at 24 months. Treatment related nonneoplastic alterations were observed in the urinary bladder and kidneys. In the urinary bladder, increases in the vacuolization of the superficial cells of the urothelium were observed in males exposed to 37 or 94 mg DMA/kg/day (0/44, 1/50, 0/50, 36/45, 48/48) and in females exposed to 7.8, 37, or 94 mg DMA/kg/day (1/45, 1/48, 26/43, 47/47, 43/43); incidence data reported in Gur et al. (1989b). An increased incidence of progressive glomerulonephropathy was observed in males at 37 mg DMA/kg/day (16/44, 22/50, 17/50, 34/45, 30/50) and an increased incidence of nephrocalcinosis was also observed in male mice at 94 mg DMA/kg/day (30/44, 25/50, 27/50, 29/50, 45/50). Neoplastic alterations were limited to an increased incidence of fibrosarcoma of the skin in females exposed to 94 mg DMA/kg/day; the incidence was 3/56, 0/55, 1/56, 1/56, and 6/56 in the 0, 1.3, 7.8, 37, and 94 mg DMA/kg/day groups, respectively; however it was concluded that this lesion was not related to DMA exposure.

[underlined: Dose and end point used for MRL derivation]: Benchmark dose analysis of the dose-response data (Table A-5) for vacuolization of the urothelium in the urinary bladder in female mice exposed to DMA in the diet for 2 years (incidence data reported in Gur et al. 1989b) was conducted. All available dichotomous models in EPA’s Benchmark Dose Software (version 1.4.1) were fit to the data. Predicted doses associated with a 10% extra risk were calculated. As assessed by the chi-square goodness-of-fit statistic, all models, with the exception of the quantal linear model, provided an adequate fit (X^2^ p>0.1) (Table A-6). Comparing across models, a better fit is generally indicated by a lower AIC. The AIC

values were similar for the logistic, multi-stage, and probit models; of these three models, the multi-stage had the lowest BMD_10_ and was selected for the analysis (see Figure A-4). The predicted BMD_10_ and BMDL_10_ for the incidence data are 2.68 and 1.80 mg DMA/kg/day.

Table A-5 Incidence of Vacuolization of Urotheium in Urinary Bladder of Female Mice Exposed to DMA in the Diet for 2 Years

Dietary Concentration (ppm) | Dose (mg MMA/kg/day) | Incidence
0 | 0 | 1/45
8 | 1.3 | 1/48
40 | 7.8 | 26/43
200 | 37 | 47/47
500 | 94 | 43/43

Sources: Arnold et al. 2006; Gur et al. 1989b

Table A-6. Modeling Predictions for the Incidence of Vacuolization in of Urothelium in Urinary Bladder of Female Mice Exposed to DMA in the Diet for 2 Years

| BMD_10_ | BMDL_10_
Model | (mg DMA/kg/day) | (mg DMA/kg/day) | x^2^ p-value | AIC
Gamma^a^ | 5.01 | 1.85 | 1.00 | 83.03
Logistic | 3.66 | 2.78 | 0.95 | 81.37
Log-logistic^b^ | 6.23 | 2.34 | 1.00 | 83.03
Multi-stage ^c^ | 2.68 | 1.80 | 0.90 | 81.69
Probit | 3.20 | 2.46 | 0.89 | 81.60
Log-probit^b^ | 5.03 | 2.00 | 1.00 | 83.03
Quantal linear | 0.98 | 0.76 | 0.07 | 91.75
Weibull^a^ | 4.77 | 1.88 | 1.00 | 83.03

Sources: Arnold et al. 2006; Gur et al. 1989b

a Restrict power ≥1.

b Slope restricted to >1.

c Restrict betas ≥0; lowest degree polynomial with an adequate fit is reported; degree of polynomial=2.

Figure A-4 Predicted and Observed Incidence of Vacuolization of Urothelium in Urinary Bladder of Female Mice*

*BMDs and BMDLs indicated are associated with a 10% extra risk change from the control, and are in units of mg DMA/kg/day.

Source: Arnold et al. 2006

The BMDL_10_ of 1.80 mg DMA/kg/day for female mice was selected as the point of departure for deriving the chronic-duration oral MRL.

[ ] NOAEL [ ] LOAEL [X] BMDL

[underlined: Uncertainty factors used in MRL derivation]: 100

[ ] 10 for use of a LOAEL [X] 10 for extrapolation from animals to humans [X] 10 for human variability

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Doses reported in Gur et al. (1989b): 0, 1.3, 7.8, 37, and 94 mg DMA/kg/day.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: One other study has investigated the chronic toxicity of DMA in species other than rats. In this study, administration of 16 mg DMA/kg/day via a capsule for 52 weeks resulted in increases in the incidence of diarrhea; no histological alterations were observed (Zomber et al. 1989).

[underlined: Agency Contacts (Chemical Managers)]: Selene Chou, Ph.D and Carolyn Harper, Ph.D.