# 9 REFERENCES

ACGIH. 2014. Arsenic [7440–38-2] and inorganic compounds, as As. In: TLVs and BEIs based on the documentation of the threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 12.
Afridi HI, Kazi TG, Kazi AG, 2011. Levels of arsenic, cadmium, lead, manganese and zinc in biological samples of paralysed steel mill workers with related to controls. Biol Trace Elem Res 144(1–3):164–182.21547399
Agency for Toxic Substances Disease Registry. 2007. Toxicological profile for arsenic (Update). U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/toxprofiles/tp2-p.pdf. January 23, 2015.
Agency for Toxic Substances and Disease Registry. 2009. Health consultation: Sutherlin Valley groundwater arsenic study. Sutherlin, Douglas County, Oregon. Atlanta, GA: Agency for Toxic Substances and Disease Registry, U.S. Department of Health and Human Services. http://www.atsdr.cdc.gov/HAC/pha/SutherlinValley/SutherlinValleyGroundwaterArsenicStudy7-17-09.pdf. January 29, 2015.
Agusa T, Iwata H, Fujihara J, 2009. Genetic polymorphisms in AS3MT and arsenic metabolism in residents of the Red River Delta, Vietnam. Toxicol Appl Pharmacol 236(2):131–141.19371612
Agusa T, Kunito T, Tue NM, 2012. Individual variations in arsenic metabolism in Vietnamese: The association with arsenic exposure and GSTP1 genetic polymorphism. Metallomics 4(1):91–100.22028001
Ahmed S, Ahsan KB, Kippler M, 2012. In utero arsenic exposure is associated with impaired thymic function in newborns possibly via oxidative stress and apoptosis. Toxicol Sci 129(2):305–314.22713597
Ahmed S, Moore SE, Kippler M, 2014. Arsenic exposure and cell-mediated immunity in preschool children in rural Bangladesh. Toxicol Sci 141(1):166–175.24924402
Ahsan H, Chen Y, Kibriya MG, 2007. Arsenic metabolism, genetic susceptibility, and risk of premalignant skin lesions in Bangladesh. Cancer Epidemiol Biomarkers Prev 16(6):1270–1278.17548696
AIHA. 2014. Current ERPG Values (2014). Fairfax, VA: American Industrial Hygiene Association. https://www.aiha.org/get-involved/AIHAGuidelineFoundation/EmergencyResponsePlanningGuidelines/Documents/2014%20ERPG%20Values.pdf. September 9, 2014.
Akram Z, Jalali S, Shami SA, 2010. Adverse effects of arsenic exposure on uterine function and structure in female rat. Exp Toxicol Pathol 62(4):451–459.19726171
Ali N, Hoque MA, Haque A, 2010. Association between arsenic exposure and plasma cholinesterase activity: A population based study in Bangladesh. Environ Health 9:36.20618979
Antonelli R, Shao K, Thomas DJ, 2014. AS3MT, GSTO, and PNP polymorphisms: Impact on arsenic methylation and implications for disease susceptibility. Environ Res 132:156–167.24792412
Aposhian HV, Gurzau ES, Le XC, 2000. Occurrence of monomethylarsonous acid in urine of humans exposed to inorganic arsenic. Chem Res Toxicol 13:693–697.10956055
Argos M, Kalra T, Pierce BL, 2011. A prospective study of arsenic exposure from drinking water and incidence of skin lesions in Bangladesh. Am J Epidemiol 1742(2):185–194.
Argos M, Parvez F, Rahman M, 2014. Arsenic and lung disease mortality in Bangladeshi adults. Epidemiology 25(4):536–543.24802365
Arita A, Costa M. 2009. Epigenetics in metal carcinogenesis: Nickel, arsenic, chromium and cadmium. Metallomics 1(3):222–228.20461219
Ayotte JD, Belaval M, Olson SA, 2015. Factors affecting temporal variability of arsenic in groundwater used for drinking water supply in the United States. Sci Total Environ 505:1370–1379.24650751
Baba K, Arao T, Yamaguchi N, 2014. Chromatographic separation of arsenic species with pentafluorophenyl column and application to rice. J Chromatogr A 1354:109–116.24947890
Bailey K, Fry RC. 2014a. Long-term health consequences of prenatal arsenic exposure: Links to the genome and the epigenome. Rev Environ Health 29(1–2):9–12.24552957
Bailey KA, Fry RC. 2014b. Arsenic-associated changes to the epigenome: What are the functional consequences? Curr Environ Health Rep 1:22–34.24860721
Banerjee M, Banerjee N, Bhattacharjee P, 2013. High arsenic in rice is associated with elevated genotoxic effects in humans. Sci Rep 3:2195. http://www.nature.com/srep/2013/130722/srep02195/full/srep02195.html. January 28, 2015.23873074
Barati AH, Maleki A, Alasvand M. 2010. Multi-trace elements level in drinking water and the prevalence of multi-chronic arsenical poisoning in the west area of Iran. Sci Total Environ 408(7):1523–1529.20092875
Barringer JL, Szabo Z, Wilson TP, 2011. Distribution and seasonal dynamics of arsenic in a shallow lake in northwestern New Jersey, USA. Environ Geochem Health 33(1):1–22.
Bartolotta SA, Pacskowski MG, Hick A, 2011. Micronuclei assay in exfoliated buccal cells from individuals exposed to arsenic in Argentina. Arch Environ Contam Toxicol 61(2):337–343.20957353
Basta NT, Foster JN, Dayton EA, 2007. The effect of dosing vehicle on arsenic bioaccessibility in smelter-contaminated soils. J Environ Sci Health A Tox Hazard Subst Environ Eng 42(9):1275–1281.17654147
Basu A, Som A, Ghoshal S, 2005. Assessment of DNA damage in peripheral blood lymphocytes of individuals susceptible to arsenic induced toxicity in West Bengal, India. Toxicol Lett 159(1):100–112.15953701
Beesley L, Moreno-Jimenez E, Clemente R, 2010. Mobility of arsenic, cadmium and zinc in a multi-element contaminated soil profile assessed by in-situ soil pore water sampling, column leaching and sequential extraction. Environ Pollut 158(1):155–160.19683374
Bhattacharjee P, Banerjee M, Giri AK. 2013a. Role of genomic instability in arsenic-induced carcinogenicity. A review. Environ Int 53:29–40.23314041
Bhattacharjee P, Chatterjee D, Singh KK, 2013b. Systems biology approaches to evaluate arsenic toxicity and carcinogenicity: An overview. Int J Hyg Environ Health 216(5):574–586.23340121
Bradham KD, Scheckel KG, Nelson CM, 2011. Relative bioavailability and bioaccessibility and speciation of arsenic in contaminated soils. Environ Health Perspect 119(11):1629–1634.21749965
Brattin W, Casteel S. 2013. Measurement of arsenic relative bioavailability in swine. J Toxicol Environ Health A 76(7):449–457.23611183
Brattin W, Drexler J, Lowney Y, 2013. An in vitro method for estimation of arsenic relative bioavailability in soil. J Toxicol Environ Health A 76(7):458–478.23611184
Bruce S, Noller B, Matanitobua V, 2007. In vitro physiologically based extraction test (PBET) and bioaccessibility of arsenic and lead from various mine waste materials. J Toxicol Environ Health A 70(19):1700–1711.17763089
Buchet JP, Lauwerys R, Roels H. 1981a. Comparison of the urinary excretion of arsenic metabolites after a single oral dose of sodium arsenite, monomethylarsonate, or dimethylarsinate in man. Int Arch Occup Environ Health 48:71–79.6894292
Buchet JP, Lauwerys R, Roels H. 1981b. Urinary excretion of inorganic arsenic and its metabolites after repeated ingestion of sodium metaarsenite by volunteers. Int Arch Occup Environ Health 48:111–118.6894910
Burchiel SW, Mitchell LA, Lauer F, 2009. Immunotoxicity and biodistribution analysis of arsenic trioxide in C57Bl/6 mice following a 2-week inhalation exposure. (Corrigendum in: Toxicol Appl Pharmacol 246(3):188). Toxicol Appl Pharmacol 241(3):253–259.19800901
Burchiel SW, Mitchell LA, Lauer FT, 2010. Corrigendum to "Immunotoxicity and biodistribution analysis of arsenic trioxide in C57B1/6 mice following a 2-week inhalation exposure" [Toxicol Appl Pharmacol 241 (2009) 253–259]. Toxicol Appl Pharmacol 246(3):188.21103386
Bustaffa E, Stoccoro A, Bianchi F, 2014. Genotoxic and epigenetic mechanisms in arsenic carcinogenicity. Arch Toxicol 88(5):1043–1067.24691704
CDC. 2015. Fourth national report on human exposure to environmental chemicals, updated tables (February 2015). Centers for Disease Control and Prevention. http://www.cdc.gov/biomonitoring/pdf/FourthReport_UpdatedTables_Feb2015.pdf. March 10, 2015.
Chatterjee A, Chatterji U. 2010. Arsenic abrogates the estrogen-signaling pathway in the rat uterus. Reprod Biol Endocrinol 8:80.20598115
Chen G, Chen T. 2014. SPE speciation of inorganic arsenic in rice followed by hydride-generation atomic fluorescence spectrometric quantification. Talanta 119:202–206.24401405
Chen CL, Chiou HY, Hsu LI, 2010b. Arsenic in drinking water and risk of urinary tract cancer: A follow-up study from northeastern Taiwan. Cancer Epidemiol Biomarkers Prev 19(1):101–110.20056628
Chen CL, Chiou HY, Hsu LI, 2010c. Ingested arsenic, characteristics of well water consumption and risk of different histological types of lung cancer in northeastern Taiwan. Environ Res 110(5):455–462.19735913
Chen JW, Chen HY, Li WF, 2011a. The association between total urinary arsenic concentration and renal dysfunction in a community-based population from central Taiwan. Chemosphere 84(1):17–24.21458841
Chen JW, Wang SL, Wang YH, 2012a. Arsenic methylation, GSTO1 polymorphisms, and metabolic syndrome in an arseniasis endemic area of southwestern Taiwan. Chemosphere 88(4):432–438.22440634
Chen SC, Chen CC, Kuo CY, 2012b. Elevated risk of hypertension induced by arsenic exposure in Taiwanese rural residents: Possible effects of manganese superoxide dismutase (MnSOD) and 8-oxoguanine DNA glycosylase (OGG1) genes. Arch Toxicol 86(6):869–878.22193621
Chen Y, Ahsan H, Slavkovich V, 2010a. No association between arsenic exposure from drinking water and diabetes mellitus: A cross-sectional study in Bangladesh. Environ Health Perspect 118(9):1299–1305.20813654
Chen Y, Graziano JH, Parvez F, 2011b. Arsenic exposure from drinking water and mortality from cardiovascular disease in Bangladesh: Prospective cohort study. BMJ 342:d2431. http://www.bmj.com/content/342/bmj.d2431.long. January 28, 2015.21546419
Chen Y, Wu F, Graziano JH, 2013a. Arsenic exposure from drinking water, arsenic methylation capacity, and carotid intima-media thickness in Bangladesh. Am J Epidemiol 178(3):372–381.23788675
Chen Y, Wu F, Parvez F, 2013b. Arsenic exposure from drinking water and QT-interval prolongation: Results from the health effects of arsenic longitudinal study. Environ Health Perspect 121(4):427–432.23384555
Chung CJ, Huang YL, Huang YK, 2013a. Urinary arsenic profiles and the risks of cancer mortality: A population-based 20-year follow-up study in arseniasis-endemic areas in Taiwan. Environ Res 122:25–30.23276485
Chung CJ, Huang CY, Pu YS, 2013b. The effect of cigarette smoke and arsenic exposure on urothelial carcinoma risk is modified by glutathione S-transferase M1 gene null genotype. Toxicol Appl Pharmacol 266(2):254–259.23159782
Chung CJ, Pu YS, Chen YT, 2011. Protective effects of plasma alpha-tocopherols on the risk of inorganic arsenic-related urothelial carcinoma. Sci Total Environ 409(6):1039–1045.21227482
Chung CJ, Pu YS, Su CT, 2010. Polymorphisms in one-carbon metabolism pathway genes, urinary arsenic profile, and urothelial carcinoma. Cancer Causes Control 21(10):1605–1613.20532609
Coronado-González JA, Del Razo LM, García-Vargas G, 2007. Inorganic arsenic exposure and type 2 diabetes mellitus in Mexico. Environ Res 104(3):383–389.17475235
Dauphine DC, Ferreccio C, Guntur S, 2011. Lung function in adults following in utero and childhood exposure to arsenic in drinking water: Preliminary findings. Int Arch Occup Environ Health 84:591–600.20972800
Daus B, Hempel M, Wennrich R, 2010. Concentrations and speciation of arsenic in groundwater polluted by warfare agents. Environ Pollut 158(11):3439–3444.20667635
Davis MA, Mackenzie TA, Cottingham KL, 2012. Rice consumption and urinary arsenic concentrations in U.S. children. Environ Health Perspect 120(10):1418–1424.23008276
Del Razo LM, Garcia-Vargas GG, Valenzuela OL, 2011. Exposure to arsenic in drinking water is associated with increased prevalence of diabetes: A cross-sectional study in the Zimapan and Lagunera regions in Mexico. Environ Health 10:73. http://www.ehjournal.net/content/10/1/73. January 30, 2015.21864395
Denys S, Caboche J, Tack K, 2012. In vivo validation of the unified BARGE method to assess the bioaccessibility of arsenic, antimony, cadmium, and lead in soils. Environ Sci Technol 46(11):6252–6260.22606949
DOE. 2012. Table 3: Protective action criteria (PAC) Rev 27 based on applicable 60-minute AEGLs, ERPGs, or TEELs (chemicals listed by CASRN). Oak Ridge, TN: U.S. Department of Energy and Subcommittee on Consequence Assessment and Protective Actions (SCAPA). http://www.atlintl.com/DOE/teels/teel/Table3.pdf. September 9, 2014.
Druwe IL, Vaillancourt RR. 2010. Influence of arsenate and arsenite on signal transduction pathways: An update. Arch Toxicol 84(8):585–596.20502880
El-Masri HA, Kenyon EM. 2008. Development of a human physiologically based pharmacokinetic (PBPK) model for inorganic arsenic and its mono- and di-methylated metabolites. J Pharmacokinet Pharmacodyn 35(1):31–68.17943421
Engstrom K, Nermell B, Concha G, 2009. Arsenic metabolism is influenced by polymorphisms in genes involved in one-carbon metabolism and reduction reactions. Mutat Res 667(1–2):4–14.18682255
Engstrom K, Vahter M, Mlakar SJ, 2011. Polymorphisms in arsenic(+III oxidation state) methyltransferase (AS3MT) predict gene expression of AS3MT as well as arsenic metabolism. Environ Health Perspect 119(2):182–188.21247820
EPA. 1983. Method 206.4. Arsenic (spectrophotometric, SDDC). In: Methods for chemical analysis of water and wastes. U.S. Environmental Protection Agency. EPA600479020.
EPA. 1998a. Appendix A. Chemical substances subject to proposed or final TSCA rules or orders. Washington, DC: U.S. Environmental Protection Agency. Office of Prevention Pesticides and Toxic Substances. A-1 to A-10. EPA749B98001. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=700004YF.txt. September 24, 2014.
EPA. 1998b. RCRA waste minimization PBT priority chemical list. U.S. Environmental Protection Agency. Federal Register 63 FR 60332. http://www.gpo.gov/fdsys/pkg/FR-1998-11-09/pdf/98-29952.pdf. September 10, 2014.
EPA. 2006. List of lists. Consolidated list of chemicals subject to the Emergency Planning and Community Right-to-Know Act (EPCRA) and Section 112(r) of the Clean Air Act. Washington, DC: U.S. Environmental Protection Agency. Office of Solid Waste and Emergency Response. EPA550B01003. http://www.epa.gov/emergencies/docs/chem/title3_Oct_2006.pdf. September 24, 2014.
EPA. 2008. Reregistration eligibility decision for chromated arsenicals. U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/reregistration/REDs/cca_red.pdf. January 27, 2015.
EPA. 2009. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. September 10, 2014.
EPA. 2012a. Compilation and review of data on relative bioavailablity of arsenic in soil. U.S. Environmental Protection Agency. OSWER 9200.1–113. http://www.epa.gov/superfund/bioavailability/pdfs/Arsenic%20Bioavailability%20SCIENCE%20Report_SRC%2009-20-12.pdf. January 27, 2015.
EPA. 2012b. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2012.pdf. September 9, 2014.
EPA. 2013a. National priorities list (NPL). U.S. Environmental Protection Agency. http://www.epa.gov/superfund/sites/npl/. January 28, 2015.
EPA. 2013b. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 117.3, Subpart A. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol23/pdf/CFR-2013-title40-vol23-part117-subpartA.pdf. September 9, 2014.
EPA. 2013c. Designation, reportable quantities, and notifications. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-sec302–4.pdf. September 10, 2014.
EPA. 2013d. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 372.65, Subpart D. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part372.pdf. September 10, 2014.
EPA. 2013e. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol29/pdf/CFR-2013-title40-vol29-part355-appA.pdf. September 10, 2014.
EPA. 2013f. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations 40 CFR 116.4. http://www.gpo.gov/fdsys/pkg/CFR-2013-title40-vol23/pdf/CFR-2013-title40-vol23-sec116–4.pdf. September 9, 2014.
EPA. 2014a. Draft development materials for the Integrated Risk Information System (IRIS) Toxicological Review of inorganic arsenic. [CASRN 7440–38-2]. Bimonthly public meeting: June 2014. U.S. Environmental Protection Agency. EPA630R14101. http://www.epa.gov/iris/publicmeeting/iris_bimonthly-jun2014/iA-preliminary_draft_materials.pdf. January 23, 2015.
EPA. 2014b. The Clean Air Act amendments of 1990 list of hazardous air pollutants. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/ttn/atw/orig189.html. September 9, 2014.
EPA. 2014c. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://water.epa.gov/scitech/swguidance/standards/criteria/current/index.cfm. January 08, 2014.
EPA. 2014d. Compiled AEGL values. Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/compiled_aegls_update_03oct2014.pdf. January 29, 2015.
Erickson ML, Barnes RJ. 2005. Glacial sediment causing regional-scale elevated arsenic in drinking water. Ground Water 43(6):796–805.16324001
Ettinger AS, Zota AR, Amarasiriwardena CJ, 2009. Maternal arsenic exposure and impaired glucose tolerance during pregnancy. Environ Health Perspect 117(7):1059–1064.19654913
Evans MV, Dowd SM, Kenyon EM, 2008. A physiologically based pharmacokinetic model for intravenous and ingested dimethylarsinic acid in mice. Toxicol Sci 104(2):250–260.18430741
Ezeh PC, Lauer FT, Mackenzie D, 2014. Arsenite selectively inhibits mouse bone marrow lymphoid progenitor cell development in vivo and in vitro and suppresses humoral immunity in vivo. PLoS ONE 9(4):e93920. http://journals.plos.org/plosone/article?id=10.1371/journal.pone.0093920. January 30, 2015.24714590
Faita F, Cori L, Bianchi F, 2013. Arsenic-induced genotoxicity and genetic susceptibility to arsenic-related pathologies. Int J Environ Res Public Health 10:1527–1546.23583964
Farzan SF, Korrick S, Li Z, 2013. In utero arsenic exposure and infant infection in a United States cohort: A prospective study. Environ Res 126:24–30.23769261
Fatmi Z, Abbasi IN, Ahmed M, 2013. Burden of skin lesions of arsenicosis at higher exposure through groundwater of taluka Gambat district Khairpur, Pakistan: A cross-sectional survey. Environ Geochem Health 35(3):341–346.23111830
Fatmi Z, Azam I, Ahmed F, 2009. Health burden of skin lesions at low arsenic exposure through groundwater in Pakistan. Is river the source? Environ Res 109:575–581.19419713
FDA. 2013a. Quantitative assessment of inorganic arsenic in apple juice. U.S. Food and Drug Administration. http://www.fda.gov/downloads/Food/FoodScienceResearch/RiskSafetyAssessment/UCM360016.pdf. January 29, 2015.
FDA. 2013b. Subpart B - Requirements for specific standardized beverages. Bottled water. Code of Federal Regulations. U.S. Food and Drug Administration.Vol. 21 CFR 165.110, 574–593. http://www.gpo.gov/fdsys/pkg/CFR-2013-title21-vol2/pdf/CFR-2013-title21-vol2-sec165-110.pdf. January 28, 2015.
Feki-Tounsi M, Olmedo P, Gil F, 2013. Low-level arsenic exposure is associated with bladder cancer risk and cigarette smoking: A case-control study among m en in Tunisia. Environ Sci Pollut Res Int 20(6):3923–3931.23184132
Ferreccio C, Sancha AM. 2006. Arsenic exposure and its impact on health in Chile. J Health Popul Nutr 24(2):164–175.17195557
Ferreccio C, Smith AH, Duran V, 2013a. Case-control study of arsenic in drinking water and kidney cancer in uniquely exposed Northern Chile. Am J Epidemiol 178(5):813–818.23764934
Ferreccio C, Yuan Y, Calle J, 2013b. Arsenic, tobacco smoke, and occupation associations of multiple agents with lung and bladder cancer. Epidemiology 24(6):898–905.24036609
Fillol C, Dor F, Labat L, 2010. Urinary arsenic concentrations and speciation in residents living in an area with naturally contaminated soils. Sci Total Environ 408(5):1190–1194.20004003
Gamino-Gutierrez SP, Gonzalez-Perez CI, Gonsebatt ME, 2013. Arsenic and lead contamination in urban soils of Villa de la Paz (Mexico) affected by historical mine wastes and its effect on children's health studied by micronucleated exfoliated cells assay. Environ Geochem Health 35(1):37–51.22736102
Garcia-Esquinas E, Pollan M, Umans JG, 2013. Arsenic exposure and cancer mortality in a US-based prospective cohort: the strong heart study. Cancer Epidemiol Biomarkers Prev 22(11):1944–1953. 10.1158/1055–9965.epi-13–0234-t.23800676
Gentry PR, Covington TR, Mann S, 2004. Physiologically based pharmacokinetic modeling of arsenic in the mouse. J Toxicol Environ Health A 67:43–71.14668111
Ghosh P, Banerjee M, De Chaudhuri S, 2007. Comparison of health effects between individuals with and without skin lesions in the population exposed to arsenic through drinking water in West Bengal, India. J Expo Sci Environ Epidemiol 17(3):215–223.16835595
Gilbert-Diamond D, Cottingham KL, Gruber JF, 2011. Rice consumption contributes to arsenic exposure in US women. Proc Natl Acad Sci U S A 108(51):20656–20660.22143778
Gilbert-Diamond D, Li Z, Perry AE, 2013. A population-based case-control study of urinary arsenic species and squamous cell carcinoma in New Hampshire, USA. Environ Health Perspect 121(10):1154–1160.23872349
Gribble MO, Howard BV, Umans JG, 2012. Arsenic exposure, diabetes prevalence, and diabetes control in the strong heart study. Am J Epidemiol 176(10):865–874.23097256
Guan H, Piao F, Zhang X, 2012. Prenatal exposure to arsenic and its effects on fetal development in the general population of Dalian. Biol Trace Elem Res 149(1):10–15.22451376
Guha Mazumder D, Purkayastha I, Ghose A, 2012. Hypertension in chronic arsenic exposure: A case control study in West Bengal. J Environ Sci Health A Tox Hazard Subst Environ Eng 47(11):1514–1520.22702810
Guo JX, Hu L, Yand PZ, 2007. Chronic arsenic poisoning in drinking water in Inner Mongolia and its associated health effects. J Environ Sci Health A Tox Hazard Subst Environ Eng 42(12):1853–1858.17952786
Hamadani JD, Grantham-McGregor SM, Tofail F, 2010. Pre- and postnatal arsenic exposure and child development at 18 months of age: A cohort study in rural Bangladesh. Int J Epidemiol 39(5):1206–1216.20085967
Hamadani JD, Tofail F, Nermell B, 2011. Critical windows of exposure for arsenic-associated impairment of cognitive function in pre-school girls and boys: A population-based cohort study. Int J Epidemiol 40(6):1593–1604.22158669
Hamula C, Wang Z, Zhang H, 2006. Chromium on the hands of children after playing in playgrounds built from chromated copper arsenate (CCA)-treated wood. Environ Health Perspect 114(3):460–465.16507472
Harari F, Engstrom K, Concha G, 2013. N-6-adenine-specific DNA methyltransferase 1 (N6AMT1) polymorphisms and arsenic methylation in Andean women. Environ Health Perspect 121(7):797–803.23665909
Hashim JH, Radzi RSM, Aljunid SM, 2013. Hair arsenic levels and prevalence of arsenicosis in three Cambodian provinces. Sci Total Environ 463–464:1210–1216.
Hawkesworth S, Wagatsuma Y, Kippler M, 2013. Early exposure to toxic metals has a limited effect on blood pressure or kidney function in later childhood, rural Bangladesh. Int J Epidemiol 42(1):176–185.23243118
Heck JE, Andrew AS, Onega T, 2009. Lung cancer in a U.S. population with low to moderate arsenic exposure. Environ Health Perspect 117:1718–1783.20049123
Hensley AR, Scott A, Rosenfeld PE, 2007. Attic dust and human blood samples collected near a former wood treatment facility. Environ Res 105(2):194–199.17517389
Hernandez-Zavala A, Matousek T, Drobna Z, 2008. Speciation analysis of arsenic in biological matrices by automated hydride generation-cryotrapping-atomic absorption spectrometry with multiple microflame quartz tube atomizer (multiatomizer). J Anal Atom Spectrom 23:342–351.
Hill DS, Wlodarczyk BJ, Finnell RH. 2008. Reproductive consequences of oral arsenate exposure during pregnancy in a mouse model. Birth Defects Res B Dev Reprod Toxicol 83(1):40–47.18186108
Hsieh RL, Huang YL, Shiue HS, 2014. Arsenic methylation capacity and developmental delay in preschool children in Taiwan. Int J Hyg Environ Health 217(6):678–686.24698386
Hsieh YC, Hsieh FI, Lien LM, 2008b. Risk of carotid atherosclerosis associated with genetic polymorphisms of apolipoprotein E and inflammatory genes among arsenic exposed residents in Taiwan. Toxicol Appl Pharmacol 227(1):1–7.18022660
Hsu LI, Chen GS, Lee CH, 2013a. Use of arsenic-induce3d palmoplantar hyperkeratosis and skin cancers to predict risk of subsequent internal malignancy. Am J Epidemiol 177(3):202–212.23299695
Hsu LI, Wang YH, Chiou HY, 2013b. The association of diasbetes mellitus with subsequent internal cancers in the arsenic-exposed area of Taiwan. J Asian Earth Sci 73:452–459.
Huang CY, Chu JS, Pu YS, 2011. Effect of urinary total arsenic level and estimated glomerular filtration rate on the risk of renal cell carcinoma in a low arsenic exposure area. J Urol 185(6):2040–2044.21496841
Huang CY, Su CT, Chung CJ, 2012. Urinary total arsenic and 8-hydroxydeoxyguanosine are associated with renal cell carcinoma in an area without obvious arsenic exposure. Toxicol Appl Pharmacol 262(3):349–354.22659136
Huang YK, Huang YL, Hsueh YM, 2008a. Arsenic exposure, urinary arsenic speciation, and the incidence of urothelial carcinoma: A twelve-year follow-up study. Cancer Causes Control 19(8):829–839.18351295
Huang YK, Pu YS, Chung CJ, 2008b. Plasma folate level, urinary arsenic methylation profiles, and urothelial carcinoma susceptibility. Food Chem Toxicol 46(3):929–938.18054417
Hudak PF. 2008. Distribution of arsenic concentrations in groundwater of the Seymour Aquifer, Texas, USA. Int J Environ Health Res 18(1):79–82.18231948
Hughes MF, Kenyon EM. 1998. Dose-dependent effects on the disposition of monomethylarsonic acid and dimethylarsinic acid in the mouse afte intravenous administration. J Toxicol Environ Health A 53:95–112.9444314
Hughes MF, Devesa V, Adair BM, 2005. Tissue dosimetry, metabolism and excretion of pentavalent and trivalent monomethylated arsenic in mice after oral administration. Toxicol Appl Pharmacol 208(2):186–197.16183392
Hughes MF, Devesa V, Adair BM, 2008. Tissue dosimetry, metabolism and excretion of pentavalent and trivalent dimethylated arsenic in mice after oral administration. Toxicol Appl Pharmacol 227(1):26–35.18036629
IARC. 2012. Arsenic, metals, fibres, and dusts. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 100(Pt C):11–465.
IARC. 2014. Agents classified by the IARC monographs. Volumes 1–111. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsCASOrder.pdf. September 9, 2014.
IRIS. 2003. Arsenic, inorganic (CASRN 7440–38-2). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0278.htm. January 27, 2015.
Islam MR, Khan I, Attia J, 2012a. Association between hypertension and chronic arsenic exposure in drinking water: A cross-sectional study in Bangladesh. Int J Environ Res Public Health 9(12):4522–4536.23222207
Islam R, Khan I, Hassan SN, 2012b. Association between type 2 diabetes and chronic arsenic exposure in drinking water: A cross sectional study in Bangladesh. Environ Health 11:38. http://www.ehjournal.net/content/11/1/38. January 29, 2015.22676249
Jackson BP, Taylor VF, Punshon T, 2012. Arsenic concentration and speciation in infant formulas and first foods. Pure Appl Chem 84(2):215–223.22701232
James KA, Marshall JA, Hokanson JE, 2013. A case-cohort study examining lifetime exposure to inorganic arsenic in drinking water and diabetes mellitus. Environ Res 123:33–38.23507312
Jin L, Zhang L, Li Z, 2013. Placental concentrations of mercury, lead, cadmium, and arsenic and the risk of neural tube defects in a Chinese population. Reprod Toxicol 35:25–31.23164984
Jones GW, Pichler T. 2007. Relationship between pyrite stability and arsenic mobility during aquifer storage and recovery in southwest central Florida. Environ Sci Technol 41(3):723–730.17328175
Jones MR, Tellez-Plaza M, Sharrett AR, 2011. Urine arsenic and hypertension in US adults: The 2003–2008 National Health and Nutrition Examination Survey. Epidemiology 22(2):153–161.21206367
Juhasz AL, Herde P, Herde C, 2014a. Validation of the predictive capabilities of the SBrc-G ub vitro assay for estimating arsenic relative bioavailability in contaminated soils. Environ Sci Technol 48(21):12962–12969.25310703
Juhasz AL, Smith E, Nelson C, 2014b. Variability associated with As in vivo-in vitro correlations when using different bioaccessibility methodologies. Environ Sci Technol 48(19):11646–11653.25157927
Juhasz AL, Smith E, Weber J, 2006. In vivo assessment of arsenic bioavailability in rice and its significance for human health risk assessment. Environ Health Perspect 114(12):1826–1831.17185270
Juhasz AL, Smith E, Weber J, 2007a. Comparison of in vivo and in vitro methodologies for the assessment of arsenic bioavailability in contaminated soils. Chemosphere 69:961–966.17585998
Juhasz AL, Smith E, Weber J, 2007b. In vitro assessment of arsenic bioaccessibility in contaminated (anthropogenic and geogenic) soils. Chemosphere 69:69–78.17532365
Juhasz AL, Smith E, Weber J, 2008. Application of an in vivo swine model for the determination of arsenic bioavailability in contaminated vegetables. Chemosphere 71(10):1963–1969.18262220
Juhasz AL, Weber J, Smith E, 2009. Assessment of four commonly employed in vitro arsenic bioaccessibility assays for predicting in vivo relative arsenic bioavailability in contaminated soils. Environ Sci Technol 43(24):9487–9494.20000545
Juhasz AL, Weber J, Smith E. 2011. Predicting arsenic relative bioavailability in contaminated soils using meta analysis and relative bioavailability-bioaccessibility regression models. Environ Sci Technol 45(24):10676–10683.22059522
Juskelis R, Li W, Nelson J, 2013. Arsenic speciation in rice cereals for infants. J Agric Food Chem 61(45):10670–10676.24079539
Kenyon EM, Del Razo LM, Hughes MF. 2005a. Tissue distribution and urinary excretion of inorganic arsenic and its methylated metabolites in mice following acute oral administration of arsenate. Toxicol Sci 85(1):468–475.15703264
Kenyon EM, Del Razo LM, Hughes MF, 2005b. An integrated pharmacokinetic and pharmacodynamic study of arsenite action. 2. Heme oxygenase induction in mice. Toxicology 206:389–401.15588929
Khan K, Wasserman GA, Liu X, 2012. Manganese exposure from drinking water and children's academic achievement. Neurotoxicology 33(1):91–97.22182530
Khlifi R, Olmedo P, Gil F, 2014. Risk of laryngeal and nasopharyngeal cancer associated with arsenic and cadmium in the Tunisian population. Environ Sci Pollut Res Int 21(3):2032–2042.24022098
Kim Y, Lee BK. 2011. Association between urinary arsenic and diabetes mellitus in the Korean general population according to KNHANES 2008. Sci Total Environ 409(19):4054–4062.21723589
Kim EJ, Yoo JC, Baek K. 2014. Arsenic speciation and bioaccessibility in arsenic-contaminated soils: Sequential extraction and mineralogical investigation. Environ Pollut 186:29–35.24361561
Kim NH, Mason CC, Nelson RG, 2013. Arsenic exposure and incidence of type 2 diabetes in southwestern American Indians. Am J Epidemiol 177(9):962–969.23504692
Kippler M, Wagatsuma Y, Rahman A, 2012. Environmental exposure to arsenic and cadmium during pregnancy and fetal size: A longitudinal study in rural Bangladesh. Reprod Toxicol 34(4):504–511.22985739
Kopittke PM, de Jonge MD, Wang P, 2014. Laterally resolved speciation of arsenic in roots of wheat and rice using fluorescence-XANES imaging. New Phytol 201(4):1251–1262.24206613
Krishnan K, Haddad S, Pelekis M. 1995. A simple index for representing the discrepancy between simulations of physiological pharmacokinetic models and experimental data. Toxicol Ind Health 11(4):413–421.8748422
Kumagai Y, Sumi D. 2007. Arsenic: Signal transduction, transcription factor, and biotransformation involved in cellular response and toxicity. Annu Rev Pharmacol Toxicol 47:243–262.17002598
Kunrath J, Gurzau E, Gurzau A, 2013. Blood pressure hyperreactivity: An early cardiovascular risk in normotensive men exposed to low-to-moderate inorganic arsenic in drinking water. J Hypertens 31(2):361–369.23203141
Lantz RC, Chau B, Sarihan P, 2009. In utero and postnatal exposure to arsenic alters pulmonary structure and function. Toxicol Appl Pharmacol 235(1):105–113.19095001
Lei M, Tie B, Zeng M, 2013. An arsenic-contaminated field trial to assess the uptake and translocation of arsenic by genotypes of rice. Environ Geochem Health 35(3):379–390.23149722
Leonardi G, Vahter M, Clemens F, 2012. Inorganic arsenic and basal cell carcinoma in areas of Hungary, Romania, and Slovakia: A case-control study. Environ Health Perspect 120(5):721–726.22436128
Li WF, Sun CW, Cheng TJ, 2009. Risk of carotid atherosclerosis is associated with low serum paraoxonase (PON1) activity among arsenic exposed residents in Southwestern Taiwan. Toxicol Appl Pharmacol 236(2):246–253.19371607
Li X, Li B, Xi S, 2013a. Prolonged environmental exposure of arsenic through drinking water on the risk of hypertension and type 2 diabetes. Environ Sci Pollut Res Int 20(11):8151–8161.23649600
Li X, Li B, Xi S, 2013b. Association of urinary monomethylated arsenic concentration and risk of hypertension: A cross-sectional study from arsenic contaminated areas in northwestern China. Environ Health. 12:37. http://www.ehjournal.net/content/12/1/37. January 15, 2015.23602086
Li Y, Wang M, Piao F, 2012. Subchronic exposure to arsenic inhibits spermatogenesis and downregulates the expression of ddx3y in testis and epididymis of mice. Toxicol Sci 128(2):482–489.22581830
Li Y, Xia Y, He L, 2006. Neurosensory effects of chronic exposure to arsenic via drinking water in Inner Mongolia: I. Signs, symptoms and pinprick testing. J Water Health 4(1):29–37.16604836
Liao YT, Chen CJ, Li WF, 2012. Elevated lactate dehydrogenase activity and increased cardiovascular mortality in the arsenic-endemic areas of southwestern Taiwan. Toxicol Appl Pharmacol 262(3):232–237.22569360
Lin W, Wang SL, Wu HJ, 2008. Associations between arsenic in drinking water and pterygium in southwestern Taiwan. Environ Health Perspect 116(7):952–955.18629320
Lindberg AL, Rahman M, Persson LA, 2008. The risk of arsenic induced skin lesions in Bangladeshi men and women is affected by arsenic metabolism and the age at first exposure. Toxicol Appl Pharmacol 230(1):9–16.18336856
Loska K, Wiechula D, Korus I, 2005. Application of various methods for assessment of background arsenic concentration in farming soil. Bull Environ Contam Toxicol 74(4):732–739.16094888
Lowney YW, Wester RC, Schoof RA, 2007. Dermal absorption of arsenic from soils as measured in the rhesus monkey. Toxicol Sci 100(2):381–392.17872898
Maher W, Foster S, Krikowa F, 2013. Measurement of inorganic arsenic species in rice after nitric acid extraction by HPLC-ICPMS: Verification using XANES. Environ Sci Technol 47(11):5821–5827.23621828
Majumdar KK, Mazumder DNG, Ghose N, 2009. Systemic manifestations in chronic arsenic toxicity in absence of skin lesions in West Bengal. Indian J Med Res 129:75–82.19287062
Makris KC, Quazi S, Nagar R, 2008. In vitro model improves the prediction of soil arsenic bioavailability: Worst-case scenario. Environ Sci Technol 42(16):6278–6284.18767699
Mandal BK, Ogra Y, Suzuki KT. 2001. Identification of dimethylarsinous and monomethylarsonous acids in human urine of the arsenic-affected areas in West Bengal, India. Chem Res Toxicol 14:371–378.11304125
Mann S, Droz PO, Vahter M. 1996a. A physiologically based pharmacokinetic model for arsenic exposure. 1. Development in hamsters and rabbits. Toxicol Appl Pharmacol 137:8–22.8607145
Mann S, Droz PO, Vahter M. 1996b. A physiologically based pharmacokinetic model for arsenic exposure. II. Validation and application in humans. Toxicol Appl Pharmacol 140:471–486.8887465
Marafant E, Vahter M, Norin H, 1987. Biotransformation of dimethylarsinic acid in mouse, hamster, and man. J Appl Toxicol 7(2):111–117.3624766
Marcos R, Martinez V, Hernandez A, 2006. Metabolic profile in workers occupationally exposed to arsenic: Role of GST polymorphisms. J Occup Environ Med 48(3):334–341.16531839
Martínez V, Creus A, Venegas W, 2005. Micronuclei assessment in buccal cells of people environmentally exposed to arsenic in northern Chile. Toxicol Lett 115(2):319–327.
Martinez VD, Vucic EA, Adonis M, 2011. Arsenic biotransformation as a cancer promoting factor by inducing DNA damage and disruption of repair mechanisms. Mol Biol Int 2011:718974.22091411
Melaku S, Morris V, Raghavan D, 2008. Seasonal variation of heavy metals in ambient air and precipitation at a single site in Washington, DC. Environ Pollut 155(1):88–98.18069104
Meliker JR, Slotnick MJ, Avruskin GA, 2009. Influence of groundwater recharge and well characteristics on dissolved arsenic concentrations in southeastern Michigan groundwater. Environ Geochem Health 31(1):147–157.18496757
Melkonian S, Argos M, Pierce BL, 2011. A prospective study of the synergistic effects of arsenic exposure and smoking, sun exposure, fertilizer use, and pesticide use on risk of premalignant skin lesions in Bangladeshi men. Am J Epidemiol 173(2):183–191.21098630
Mendez-Gomez J, Garcia-Vargas GG, Lopez-Carrillo L, 2008. Genotoxic effects of environmental exposure to arsenic and lead on children in region Lagunera, Mexico. Ann N Y Acad Sci 1140:358–367.18991935
Moon KA, Guallar E, Umans JG, 2013. Association between exposure to low to moderate arsenic levels and incident cardiovascular disease. A prospective cohort study. Ann Intern Med 159(10):649–659.24061511
Morales KH, Ryan L, Kuo TL, 2000. Risk of internal cancers from arsenic in drinking water. Environ Health Perspect 108:655–661.10903620
Mordukhovich I, Wright RO, Amarasiriwardena C, 2009. Association between low-level environmental arsenic exposure and QT interval duration in a general population study. Am J Epidemiol 170(6):739–746.19700500
Mostafa MG, Cherry N. 2013. Arsenic in drinking water and renal cancers in rural Bangladesh. Occup Environ Med 70(11):768–773.24143018
Munera-Picazo S, Burlo F, Carbonell-Barrachina AA. 2014a. Arsenic speciation in rice-based food for adults with celiac disease. Food Addit Contam Part A Chem Anal Control Expo Risk Assess 31(8):1358–1366.24919988
Munera-Picazo S, Ramirez-Gandolfo A, Burlo F, 2014b. Inorganic and total arsenic contents in rice-based foods for children with celiac disease. J Food Sci 79(1):T122–T128.24313911
Nafees AA, Kazi A, Fatmi Z, 2011. Lung function decrement with arsenic exposure to drinking groundwater along River Indus: A comparative cross-sectional study. Environ Geochem Health 33(2):203–216.20632073
Nahar MN, Inaoka T, Fujimura M, 2014. Arsenic contamination in groundwater and its effects on adolescent intelligence and social competence in Bangladesh with special reference to daily drinking/cooking water intake. Environ Health Prev Med 19(2):151–158.24254803
Narukawa T, Matsumoto E, Nishimura T, 2014. Determination of sixteen elements and arsenic species in brown, polished and milled rice. Anal Sci 30(2):245–250.24521911
Naujokas MF, Anderson B, Ahsan H, 2013. The broad scope of health effects from chronic arsenic exposure: Update on a worldwide public health problem. Environ Health Perspect 121(3):295–302.23458756
Navas-Acien A, Silbergeld EK, Pastor-Barriuso R, 2008. Arsenic exposure and prevalence of type 2 diabetes in U.S. adults. JAMA 300(7):814–822.18714061
Navas-Acien A, Silbergeld EK, Pastor-Barriuso R, 2009. Arsenic exposure and prevalence of type 2 diabetes: Updated findings from the National Health Nutrition and Examination Survey, 2003–2006. Epidemiology 20(6):e816–e820.
Nicolis I, Curis E, Deschamps P, 2009. Arsenite medicinal use, metabolism, pharmacokinetics and monitoring in human hair. Biochimie 91:1260–1267.19527769
NIOSH. 1992. Appendix V. Categories of pesticides. In: Recommendations for Occupational Safety and Health. Compendium of policy documents and statements. Cincinnati, OH: U.S. Department of Health and Human Services. Public Health Service. Centers for Disease Control. National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/pdfs/92-100.pdf. September 24, 2014.
NIOSH. 2010. Arsenic (inorganic compounds, as As). NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/npgd0038.html. January 27, 2015.
NLM. 2014. Arsenic. TOXMAP classic. Environment health maps. U.S. National Library of Medicine.
NPIRS. 2015. Arsenic acid. Active ingredient information. National Pesticide Information Retrieval System: http://npirspublic.ceris.purdue.edu/ppis/chemical.aspx. January 19, 2015.
NRC. 2013. Appendix B to Part 20 - Annual limits on intake (ALIs) and derived air concentrations (DACs) of radionuclides for occupational exposure; effluent concentrations; concentrations for release to sewerage. Code of Federal Regulations 10 CFR 20, Appendix B:379–434. http://www.gpo.gov/fdsys/pkg/CFR-2013-title10-vol1/pdf/CFR-2013-title10-vol1-part20-appB.pdf. October 1, 2014.
NTP. 2014. Arsenic and inorganic arsenic compounds. 13th report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/content/profiles/arsenic.pdf. January 29, 2015.
Odstrcil Adel C, Carino SN, Ricci JC, 2010. Effect of arsenic in endochondral ossification of experimental animals. Exp Toxicol Pathol 62(3):243–249.19447590
OEHHA. 2015. Arsenic. Chemicals biomonitored in California. California Department of Public Health, Department of Toxic Substances Control, Office of Environmental Health Hazard Assessment http://www.biomonitoring.ca.gov/results/chemical/all?field_chemical_name_target_id_selective[0]=71. January 12, 2015.
OSHA. 2013a. Toxic and hazardous substances. Air contaminants. Table Z-1-Limits for air contaminants. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1000, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol6/pdf/CFR-2013-title29-vol6-sec1910–1000.pdf. September 9, 2014.
OSHA. 2013b. Inorganic arsenic. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.1018. http://www.gpo.gov/fdsys/pkg/CFR-2014-title29-vol6/pdf/CFR-2014-title29-vol6-sec1910–1018.pdf. January 27, 2015.
OSHA. 2013c. Gases, vapors, fumes, dusts, and mists. Threshold limit values of airborne contaminants for construction. Code of Federal Regulations. Occupational Safety and Health Standards.Vol. 29 CFR 1926.55 App A, 36–49. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol8/pdf/CFR-2013-title29-vol8-sec1926–55.pdf. September 11, 2014.
OSHA. 2013d. List of highly hazardous chemicals, toxics, and reactives (mandatory). Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1910.119, Subpart H, Appendix A. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol5/pdf/CFR-2013-title29-vol5-sec1910-119.pdf. September 9, 2014.
OSHA. 2013d. Inorganic arsenic. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1926.1118. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol8/pdf/CFR-2013-title29-vol8-sec1926–1118.pdf. January 27, 2015.
OSHA. 2013e. Toxic and hazardous substances. Air contaminants. Table Z - Shipyards. Code of Federal Regulations. Occupational Safety and Health Standards.Vol. 29 CFR 1915.1000, Subpart Z, 120–133. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol7/pdf/CFR-2013-title29-vol7-sec1915-1000.pdf. September 29, 2014.
OSHA. 2013f. Inorganic arsenic. Occupational Safety and Health Standards. Code of Federal Regulations 29 CFR 1915.1018, Subpart Z. http://www.gpo.gov/fdsys/pkg/CFR-2013-title29-vol7/pdf/CFR-2013-title29-vol7-sec1915–1018.pdf. January 27, 2015.
Osorio-Yanez C, Ayllon-Vergara JC, Aguilar-Madrid G, 2013. Carotid intima-media thickness and plasma asymmetric dimethylarginine in Mexican children exposed to inorganic arsenic. Environ Health Perspect 121:1090–1096.23757599
Pachnanda R, Singh SP. 2012. Histopathological alterations in testicular tissue of male rats exposed to arsenic. J Appl Nat Sci 4(2):247–251.
Paiva L, Martinez V, Creus A, 2006. Sister chromatid exchange analysis in smelting plant workers exposed to arsenic. Environ Mol Mutagen 47(4):230–235.16395693
Paiva L, Martinez V, Creus A, 2008. Evaluation of micronucleus frequencies in blood lymphocytes from smelting plant workers exposed to arsenic. Environ Mol Mutagen 49(3):200–205.18240160
Pan WC, Seow WJ, Kile ML, 2013. Association of low to moderate levels of arsenic exposure with risk of type 2 diabetes in Bangladesh. Am J Epidemiol 178(10):1563–1570.24049161
Park D, Yang H, Jeong J, 2010. A comprehensive review of arsenic levels in the semiconductor manufacturing industry. Ann Occup Hyg 54(8):869–879.20724556
Parvez F, Chen Y, Brandt-Rauf PW, 2010. A prospective study of respiratory symptoms associated with chronic arsenic exposure in Bangladesh: Findings from the Health Effects of Arsenic Longitudinal Study (HEALS). Thorax 65(6):528–533.20522851
Parvez F, Chen Y, Yunus M, 2013. Arsenic exposure and impaired lung function. Findings from a large population-based prospective cohort study. Am J Respir Crit Care Med 188(7):813–819.23848239
Parvez F, Wasserman GA, Factor-Litvak P, 2011. Arsenic exposure and motor function among children in Bangladesh. Environ Health Perspect 119(11):1665–1670.21742576
Paul S, Bhattacharjee P, Mishra PK, 2013a. Human urothelial micronucleus assay to assess genotoxic recovery by reduction of arsenic in drinking water: A cohort study in West Bengal, India. Biometals 26(5):855–862.23907726
Paul S, Das N, Bhattacharjee P, 2013b. Arsenic-induced toxicity and carcinogenicity: A two-wave cross-sectional study in arsenicosis individuals in West Bengal, India. J Expo Sci Environ Epidemiol 23(2):156–162.22990472
Pawlak Z, Rauckyte T, Zak S, 2008. Study of arsenic content in mine groundwater commonly used for human consumption in Utah. Environ Technol 29(2):217–224.18613620
Pearce DC, Dowling K, Gerson AR, 2010. Arsenic microdistribution and speciation in toenail clippings of children living in a historic gold mining area. Sci Total Environ 408(12):2590–2599.20067849
Pei Q, Ma N, Zhang J, 2013. Oxidative DNA damage of peripheral blood polymorphonuclear leukocytes, selectively induced by chronic arsenic exposure, is associated with extent of arsenic-related skin lesions. Toxicol Appl Pharmacol 266(1):143–149.23142755
Pesola GR, Parvez F, Chen Y, 2012. Arsenic exposure from drinking water and dyspnoea risk in Araihazar, Bangladesh: A population-based study. Eur Respir J 39(5):1076–1083.22088973
Pierce BL, Argos M, Chen Y, 2011. Arsenic exposure, dietary patterns, and skin lesion risk in bangladesh: A prospective study. Am J Epidemiol 173(3):345–354.21178101
Pichler T, Brinkmann R, Scarzella GI. 2008. Arsenic abundance and variation in golf course lakes. Sci Total Environ 394(2–3):313–320.18314159
Pollack AZ, Louis GM, Chen Z, 2013. Trace elements and endometriosis: The ENDO study. Reprod Toxicol 42:41–48.23892002
Porter KE, Basu A, Hubbard AE, 2010. Association of genetic variation in cystathionine-beta-synthase and arsenic metabolism. Environ Res 110(6):580–587.20670920
Presley SM, Abel MT, Austin GP, 2010. Metal concentrations in schoolyard soils from New Orleans, Louisiana before and after Hurricanes Katrina and Rita. Chemosphere 80(1):67–73.20385401
Rahman A, Persson LA, Nermell B, 2010. Arsenic exposure and risk of spontaneous abortion, stillbirth, and infant mortality. Epidemiology 21(6):797–804.20864889
Rahman A, Vahter M, Ekström EC, 2007. Association of arsenic exposure during pregnancy with fetal loss and infant death: A cohort study in Bangladesh. Am J Epidemiol 165(12):1389–1396.17351293
Rahman A, Vahter M, Ekstrom EC, 2011. Arsenic exposure in pregnancy increases the risk of lower respiratory tract infection and diarrhea during infancy in Bangladesh. Environ Health Perspect 119(5):719–724.21147604
Rahman A, Vahter M, Smith AH, 2009. Arsenic exposure during pregnancy and size at birth: A prospective cohort study in Bangladesh. Am J Epidemiol 169(3):304–312.19037006
Rahman M, Sohel N, Yunus M, 2014. A prospective cohort study of stroke mortality and arsenic in drinking water in Bangladeshi adults. BMC Public Health 14:174. http://www.biomedcentral.com/1471-2458/14/174. January 29, 2015.24548416
Ramsey KA, Bosco A, McKenna KL, 2013a. In utero exposure to arsenic alters lung development and genes related to immune and mucociliary function in mice. Environ Health Perspect 121(2):244–250.23221970
Ramsey KA, Larcombe AN, Sly PD, 2013b. In utero exposure to low dose arsenic via drinking water impairs early life lung mechanics in mice. BMC Pharmacol Toxicol 14(1):13.tp://www.biomedcentral.com/2050-6511/14/13. January 29, 2015.23419080
Raqib R, Ahmed S, Sultana R, 2009. Effects of in utero arsenic exposure on child immunity and morbidity in rural Bangladesh. Toxicol Lett 185(3):197–202.19167470
Rasmussen RR, Qian Y, Sloth JJ. 2013. SPE HG-AAS method for the determination of inorganic arsenic in rice--results from method validation studies and a survey on rice products. Anal Bioanal Chem 405(24):7851–7857.23604416
Rehman K, Naranmandura H. 2012. Arsenic metabolism and thioarsenicals. Metallomics 4(9):881–892.22358131
Reilly MP, Saca JC, Hamilton A, 2013. Prepubertal exposure to arsenic(III) suppresses circulating insulin-like growth factor-1 (IGF-1) delaying sexual maturation in female rats. Reprod Toxicol 44:41–49.24090629
Rhee SY, Hwang YC, Woo JT, 2013. Arsenic exposure and prevalence of diabetes mellitus in Korean adults. J Korean Med Sci 28(6):861–868.23772150
Roberts SM, Munson JW, Lowney YW, 2007. Relative oral bioavailability of arsenic from contaminated soils measured in the cynomolgus monkey. Toxicol Sci 95(1):281–288.17005634
Roberts SM, Weimar WR, Vinson JRT, 2002. Measurement of arsenic bioavailability in soil using a primate model. Toxicol Sci 67:303–310.12011490
Rodrigues EG, Kile M, Hoffman E, 2012. GSTO and AS3MT genetic polymorphisms and differences in urinary arsenic concentrations among residents in Bangladesh. Biomarkers 17(3):240–247.22339537
Rodriguez RR, Basta NT, Casteel SW, 1999. An in vitro gastrointestinal method to estimate bioavailable arsenic in contaminated soils and solid media. Environ Sci Technol 33(4):642–649.
Root TL, Gotkowitz MB, Bahr JM, 2010. Arsenic geochemistry and hydrostratigraphy in Midwestern U.S. glacial deposits. Ground Water 48(6):903–912.19840125
Roy A, Kordas K, Lopez P, 2011. Association between arsenic exposure and behavior among first-graders from Torreon, Mexico. Environ Res 111(5):670–676.21439564
Ruby MV, Davis A, Schoof R, 1996. Estimation of lead and arsenic bioavailability using a physiologically based extraction test. Environ Sci Technol 30(2):422–430.
Rudnai T, Sandor J, Kadar M, 2014. Arsenic in drinking water and congenital heart anomalies in Hungary. Int J Hyg Environ Health 217:813–818.24916166
Saha KK, Engstrom A, Hamadani JD, 2012. Pre- and postnatal arsenic exposure and body size to 2 years of age: A cohort study in rural Bangladesh. Environ Health Perspect 120(8):1208–1214.22504586
Salnikow K, Zhitkovich A. 2008. Genetic and epigenetic mechanisms in metal carcinogenesis and cocarcinogenesis: Nickel, arsenic, and chromium. Chem Res Toxicol 21(1):28–44.17970581
Sawada N, Iwasaki M, Inoue M, 2013. Dietary arsenic intake and subsequent risk of cancer: The Japan Public Health Center-based (JPHC) prospective study. Cancer Causes Control 24(7):1403–1415.23666560
See LC, Chiou HY, Lee JS, 2007. Dose-response relationship between ingested arsenic and cataracts among residents in Southwestern Taiwan. J Environ Sci Health A Tox Hazard Subst Environ Eng 42(12):1843–1851.17952785
Serbula SM, Miljkovic D, Kovacevic RM, 2012. Assessment of airborne heavy metal pollution using plant parts and topsoil. Ecotoxicol Environ Saf 76(2):209–214.22018546
Shen J, Wanibuchi H, Waalkes MP, 2006. A comparative study of the sub-chronic toxic effects of three organic arsenical compounds on the urothelium in F344 rats; gender-based differences in response. Toxicol Appl Pharmacol 210(3):171–180.15950995
Shi T, Liu H, Wang J, 2014. Monitoring arsenic contamination in agricultural soils with reflectance spectroscopy of rice plants. Environ Sci Technol 48(11):6264–6272.24804926
Singh PK, Singh J, Gupta AK, 2011. Effects of ground water arsenic on the testes of albino rats. J Ecophysiol Occup Health 11(1/2):33.
Smith AH, Steinmaus CM. 2009. Health effects of arsenic and chromium in drinking water: Recent human findings. Annu Rev Public Health 30:107–122.19012537
Smith AH, Ercumen A, Yuan Y, 2009. Increased lung cancer risks are similar whether arsenic is ingested or inhaled. J Expo Sci Environ Epidemiol 19:343–348. 10.1038/jes.2008.73.19190673
Smith AH, Marshall G, Liaw J, 2012. Mortality in young adults following in utero and childhood exposure to arsenic in drinking water. Environ Health Perspect 120(11):1527–1531.22949133
Smith AH, Marshall G, Yuan Y, 2006. Increased mortality from lung cancer and bronchiectasis in young adults after exposure to arsenic in utero and in early childhood. Environ Health Perspect 114(8):1293–1296.16882542
Smith AH, Yunus M, Khan AF, 2013. Chronic respiratory symptoms in children following in utero and early life exposure to arsenic in drinking water in Bangladesh. Int J Epidemiol 42(4):1077–1086.24062297
Sommella A, Deacon C, Norton G, 2013. Total arsenic, inorganic arsenic, and other elements concentrations in Italian rice grain varies with origin and type. Environ Pollut 181:38–43.23810819
Sorg TJ, Chen AS, Wang L. 2014. Arsenic species in drinking water wells in the USA with high arsenic concentrations. Water Res 48:156–169.24094730
Spayd S, Robson MG, Xie R, 2012. Importance of arsenic speciation in populations exposed to arsenic in drinking water. Hum Ecol Risk Assess 18(6):1271–1291.
Stanek EJ 3rd, Calabrese EJ, Barnes RM, 2010. Bioavailability of arsenic in soil: pilot study results and design considerations. Hum Exp Toxicol 29(11):945–960.20237175
Steinmaus C, Yuan Y, Liaw J, 2009. Low-level population exposure to inorganic arsenic in the United States and diabetes mellitus: A reanalysis. Epidemiology 20(6):807–815.19652600
Steinmaus CM, Ferreccio C, Romo JA, 2013. Drinking water arsenic in northern chile: High cancer risks 40 years after exposure cessation. Cancer Epidemiol Biomarkers Prev 22(4):623–630.23355602
Sumi D, Himeno S. 2012. Role of arsenic (+3 oxidation state) methyltransferase in arsenic metabolism and toxicity. Biol Pharm Bull 35:1870–1875.23123458
Syed EH, Melkonian S, Poudel KC, 2013. Arsenic exposure and oral cavity lesions in Bangladesh. J Occup Environ Med 55(1):59–66.23201591
Taylor M, Lau BP, Feng SY, 2013. Effects of oral exposure to arsenobetaine during pregnancy and lactation in Sprague-Dawley rats. J Toxicol Environ Health A 76(24):1333–1345.24283475
Tellez-Plaza M, Gribble MO, Voruganti VS, 2013. Heritability and preliminary genome-wide linkage analysis of arsenic metabolites in urine. Environ Health Perspect 121(3):345–351.23322787
Tofail F, Vahter M, Hamadani JD, 2009. Effect of arsenic exposure during pregnancy on infant development at 7 months in rural Matlab, Bangladesh. Environ Health Perspect 117(2):288–293.19270801
Tokar EJ, Diwan BA, Thomas DJ, 2012a. Tumors and proliferative lesions in adult offspring after maternal exposure to methylarsonous acid during gestation in CD1 mice. Arch Toxicol 86(6):975–982.22398986
Tokar EJ, Diwan BA, Waalkes MP. 2012b. Renal, hepatic, pulmonary and adrenal tumors induced by prenatal inorganic arsenic followed by dimethylarsinic acid in adulthood in CD1 mice. Toxicol Lett 209(2):179–185.22230260
Torrance K, Keenan H, Munk L, 2012. Arsenic speciation and mobility in surface water at Lucky Shot Gold Mine, Alaska. Environ Geochem Health 34(6):711–723.23001470
Tseng HP, Wang YH, Wu MM, 2006. Association between chronic exposure to arsenic and slow nerve conduction velocity among adolescents in Taiwan. J Health Popul Nutr 24(2):182–189.17195559
Tsuji JS, Van Kerkhove MD, Kaetzel RS, 2005. Evaluation of exposure to arsenic in residential soil. Environ Health Perspect 113(12):1735–1740.16330356
USDA. 2013. Nonsynthetic substances prohibited for use in organic crop production. U.S. Department of Agriculture. Code of Federal Regulations 7 CFR 205.602, Subgroup G. http://www.gpo.gov/fdsys/pkg/CFR-2013-title7-vol3/pdf/CFR-2013-title7-vol3-sec205-602.pdf. January 28, 2015.
USGS. 2006. Biota, sediment, and soil samples using collision/reaction cell inductively coupled plasma–mass spectrometry. Chapter 1, Section B, Methods of the national water quality laboratory. Book 5, Laboratory analysis. U.S. Geological Survey. http://pubs.usgs.gov/tm/2006/tm5b1/PDF/TM5-B1.pdf. January 27, 2015.
USGS. 2011a. Arsenic, metals, and nutrients in runoff from two detention basins to Raccoon Creek, New Jersey Coastal Plain, 2008. U.S. Geological Survey. http://pubs.usgs.gov/sir/2011/5017/. January 30, 2015.
USGS. 2011b. Arsenic and uranium in water from private wells completed in bedrock of east-central Massachusetts-concentrations, correlations with bedrock units, and estimated probability maps. U.S. Geological Survey. http://pubs.usgs.gov/sir/2011/5013/pdf/sir2011-5013.pdf. January 30, 2015.
USGS. 2014. Arsenic. Mineral commidity summaries. Volume 1. Metals and minerals. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/arsenic/mcs-2014-arsen.pdf. January 27, 2015.
Valenzuela OL, Borja-Aburto VH, Garcia-Vargas GG, 2005. Urinary trivalent methylated arsenic species in a population chronically exposed to inorganic arsenic. Environ Health Perspect 113(3):250–254.15743710
Vall O, Gomez-Culebras M, Garcia-Algar O, 2012. Assessment of prenatal exposure to arsenic in Tenerife Island. PLoS ONE 7(11):e50463. 10.1371/journal.pone.0050463. January 29, 2015.23209747
Verdon CP, Caldwell KL, Fresquez MR, 2009. Determination of seven arsenic compounds in urine by HPLC-ICP-DRC-MS: A CDC population biomonitoring method. Anal Bioanal Chem 393:939–947.19082583
Vuyyuri SB, Ishaq M, Kuppala D, 2006. Evaluation of micronucleus frequencies and DNA damage in glass workers exposed to arsenic. Environ Mol Mutagen 47(7):562–570.16795086
WA DOH. 2015. High arsenic area study: South Widbey Island. Biomonitoring in Washington State. Washington State Department of Health. http://www.doh.wa.gov/DataandStatisticalReports/EnvironmentalHealth/Biomonitoring/Projects/HighArsenicArea. January 20, 2015.
Waalkes MP, Qu W, Tokar EJ, 2014. Lung tumors in mice induced by "whole life" inorganic arsenic exposure at human-relevant doses. Arch Toxicol 88:1619–1629.25005685
Wade TJ, Xia Y, Wu K, 2009. Increased mortality associated with well-water arsenic exposure in Inner Mongolia, China. Int J Environ Res Public Health 6(3):1107–1123.19440436
Wang A, Wolf DC, Sen B, 2009b. Dimethylarsinic acid in drinking water changed the morphology of urinary bladder but not the expression of DNA repair genes of bladder transitional epithelium in F344 rats. Toxicol Pathol 37(4):425–437.19387086
Wang CH, Chen CL, Hsiao CK, 2009a. Increased risk of QT prolongation associated with atherosclerotic diseases in arseniasis-endemic area in southwestern coast of Taiwan. Toxicol Appl Pharmacol 239(3):320–324.19573547
Wang SL, Li WF, Chen CJ, 2011. Hypertension incidence after tap-water implementation: A 13-year follow-up study in the arseniasis-endemic area of southwestern Taiwan. Sci Total Environ 409(21):4528–4535.21872294
Warren C, Duzgoren-Aydin NS, Weston J, 2012. Trace element concentrations in surface estuarine and marine sediments along the Mississippi Gulf Coast following Hurricane Katrina. Environ Monit Assess 184(2):1107–1119.21494829
Wasserman GA, Liu X, Loiacono NJ, 2014. A cross-sectional study of well water arsenic and child IQ in Maine schoolchildren. Environ Health 13(1):23. http://www.ehjournal.net/content/13/1/23. January 29, 2015.24684736
Wasserman GA, Liu X, Parvez F, 2007. Water arsenic exposure and intellectual function in 6-year-old children in Araihazar, Bangladesh. Environ Health Perspect 115(2):285–289.17384779
Wasserman GA, Liu X, Parvez F, 2011. Arsenic and manganese exposure and children's intellectual function. Neurotoxicology 32(4):450–457.21453724
Watanabe T, Hirano S. 2013. Metabolism of arsenic and its toxicological relevance. Arch Toxicol 87(6):969–979.22811022
Wei Y, Zhu J, Nguyen A. 2014. Rice consumption and urinary concentrations of arsenic in US adults. Int J Environ Health Res 24(5):459–470.24236891
WHO. 2000. Air quality guidelines for Europe. WHO Regional Publications, European Series, No. 91. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0005/74732/E71922.pdf. January 26, 2015.
WHO. 2011a. Safety evaluation of certain contaminants in food. WHO food additives series: 63. FAO JECFA Monographs 8. World Health Organization, Food and Agriculture Organization of the United Nations. http://whqlibdoc.who.int/publications/2011/9789241660631_eng.pdf. January 27, 2015.
WHO. 2011b. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://whqlibdoc.who.int/publications/2011/9789241548151_eng.pdf?ua=1. September 9, 2014.
Wildfang E, Zakharyan RA, Aposhian HV. 1998. Enzymatic methylation of arsenic compounds. VI. Characterization of hamster liver arsenite and methylarsonic acid methyltransferase activities in vitro. Toxicol Appl Pharmacol 152:366–375.9853005
Wragg J, Cave M, Basta N, 2011. An inter-laboratory trial of the unified BARGE bioaccessibility method for arsenic, cadmium and lead in soil. Sci Total Environ 409(19):4016–4030.21703664
Wu CC, Huang YK, Chung CJ, 2013. Polymorphism of inflammatory genes and arsenic methylation capacity are associated with urothelial carcinoma. Toxicol Appl Pharmacol 272:30–36.23727622
Wu CC, Su CT, Lee HL, 2012. Joint effect of arsenic methylation profile and NNK metabolites on urothelial carcinoma. J Urol 188(5):1701–1705.22998908
Wu J, Zhang C, Pei L, 2014. Association between risk of birth defects occurring level and arsenic concentrations in soils of Lvliang, Shanxi province of China. Environ Pollut 191:1–7.24769413
Wu MM, Chiou HY, Chen CL, 2010. GT-repeat polymorphism in the heme oxygenase-1 gene promoter is associated with cardiovascular mortality risk in an arsenic-exposed population in northeastern Taiwan. Toxicol Appl Pharmacol 248(3):226–233.20708634
Xia Y, Wade TJ, Wu K, 2009. Well water arsenic exposure, arsenic induced skin-lesions and self-reported morbidity in Inner Mongolia. Int J Environ Res Public Health 6:1010–1025.19440430
Xu W, Bao H, Liu F, 2012. Environmental exposure to arsenic may reduce human semen quality: Associations derived from a Chinese cross-sectional study. Environ Health 11:46. http://www.ehjournal.net/about/access. January 29, 2015.22776062
Xu XY, McGrath SP, Meharg AA, 2008. Growing rice aerobically markedly decreases arsenic accumulation. Environ Sci Technol 42(15):5574–5579.18754478
Yu D. 1998a. A realistic cancer risk assessment of inorganic arsenic. J Environ Sci Health A Environ Sci Eng Toxic Hazard A 33(6):1149–1170.
Yu D. 1998b. Uncertainties in a pharmacokinetic modeling for inorganic arsenic. J Environ Sci Health A Tox Hazard Subst Environ Eng A 33:1369–1370.
Yu D. 1999a. A physiologically based pharmacokinetic model of inorganic arsenic. Regul Toxicol Pharmacol 29:128–141.10341143
Yu D. 1999b. A pharmacokinetic modeling of inorganic arsenic: A short-term oral exposure model for humans. Chemosphere 39(15):2737–2747.10633549
Yuan Y, Marshall G, Ferreccio C, 2010. Kidney cancer mortality: Fifty-year latency patterns related to arsenic exposure. Epidemiology 21(1):103–108.20010213
Zakharyan RA, Ayala-Fierro F, Cullen WR, 1999. Enzymatic methylation of arsenic compounds. VII. Monomethylarsonous acid (MMAIII) is the substrate for MMA methyltransferase of rabbit liver and human hepatocytes. Toxicol Appl Pharmacol 158(1):9–15.10387927
Zavala YJ, Gerads R, Gorleyok H, 2008. Arsenic in rice: II. Arsenic speciation in USA grain and implications for human health. Environ Sci Technol 42(10):3861–3866.18546735