# 8 REGULATIONS AND ADVISORIES

Table 8-1 Regulations and Guidelines Applicable to Arsenic and Arsenic Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]; Guidelines:
IARC | Carcinogenicity classification | | IARC 2014
| Arsenic and inorganic arsenic compounds | Group 1^a^
WHO | Air quality guidelines | | WHO 2000
| Arsenic | 1.5×10^−3^ unit risk^b^
| Drinking water quality guidelines | | WHO 2011b
| Arsenic | 0.01 mg/L^c^
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | | | ACGIH 2014
| Arsenic and inorganic compounds | 0.01 mg/m^3^
AIHA | ERPGs | No data | AIHA 2014
NIOSH | REL (15-minute ceiling limit) | | NIOSH 2010
| Arsenic (inorganic compounds, as As)^d^ | 0.002 mg/m^3^
DOE | PACs^e^ | | DOE 2012
| Arsenic
| PAC-1 | 0.03 mg/m^3^
| PAC-2 | 0.58 mg/m^3^
| PAC-3 | 100 mg/m^3^
| Arsenic acid
| PAC-1 | 0.057 mg/m^3^
| PAC-2 | 0.54 mg/m^3^
| PAC-3 | 190 mg/m^3^
| Arsenic pentoxide
| PAC-1 | 0.73 mg/m^3^
| PAC-2 | 8 mg/m^3^
| PAC-3 | 150 mg/m^3^
| Arsenic trioxide
| PAC-1 | 0.27 mg/m^3^
| PAC-2 | 3.0 mg/m^3^
| PAC-3 | 9.1 mg/m^3^
| Calcium arsenate
| PAC-1 | 0.91 mg/m^3^
| PAC-2 | 10 mg/m^3^
| PAC-3 | 270 mg/m^3^
| Sodium arsenite
| PAC-1 | 0.91 mg/m^3^
| PAC-2 | 10 mg/m^3^
| PAC-3 | 170 mg/m^3^
| Dimethylarsinic acid
| PAC-1 | 0.5 mg/m^3^
| PAC-2 | 0.5 mg/m^3^
| PAC-3 | 130 mg/m^3^
| Sodium dimethylarsinate
| PAC-1 | 1.1 mg/m^3^
| PAC-2 | 4 mg/m^3^
| PAC-3 | 510 mg/m^3^
EPA | AEGLs | | EPA 2014d
| Arsenic pentoxide; Arsenic trioxide | Holding status^f^
| AEGL 1 | Not recommended^g^
| AEGL 2
| 10- and 30-minute | 3.7 mg/m^3^
| 60-minute | 3.0 mg/m^3^
| 4-hour | 1.9 mg/m^3^
| 8-hour | 1.2 mg/m^3^
| AEGL 3
| 10- and 30-minute | 11 mg/m^3^
| 60-minute | 9.1 mg/m^3^
| 4-hour | 5.7 mg/m^3^
| 8-hour | 3.7 mg/m^3^
| Hazardous Air Pollutants | Yes | EPA 2014b
| Arsenic and inorganic compounds, including arsine
OSHA | PEL (8-hour TWA) for general industry | | OSHA 2013a
| Arsenic, organic compounds (as As) | 0.5 mg/m^3^ | 29 CFR 1910.1000, Table Z-1
| Inorganic arsenic | 10 μg/m^3^ | OSHA 2013b29 CFR 1910.1018
| PEL (8-hour TWA) for construction | | OSHA 2013c
| Arsenic, organic compounds (as As) | 0.5 mg/m^3^ | 29 CFR 1926.55 Appendix A
| Inorganic arsenic | 10 μg/m^3^ | OSHA 2013d 29 CFR 1926.1118
| PEL (8-hour TWA) for shipyards | | OSHA 2013e
| Arsenic, organic compounds (as As) | 0.5 mg/m^3^ | 29 CFR 1915.1000 Table Z
| Inorganic arsenic | 10 μg/m^3^ | OSHA 2013f 29 CFR 1915.1018
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act | Yes | EPA 2013f; 40 CFR 116.4
| Arsenic pentoxide, arsenic trioxide, calcium arsenate, and sodium arsenite
| Drinking water standards and health advisories for arsenic | | EPA 2012
| DWEL | 0.01 mg/L
| RfD | 0.0003 mg/kg/day
| National primary drinking water regulations for arsenic | | EPA 2009
| MCL | 0.01 mg/L
| MCLG | Zero
EPA | National recommended water quality criteria for inorganic arsenic | | EPA 2014c
| Water + organism | 0.018 μg/L^h^
| Organism only | 0.14 μg/L^h^
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act | | EPA 2013b
| Arsenic pentoxide, arsenic trioxide, calcium arsenate, sodium arsenite | 1 pound
c. Food
FDA | Allowable levels for contaminants in bottled water for arsenic; proposed action level for inorganic arsenic in apple juice | 0.010 mg/L | FDA 2013b; 21 CFR 165.110
USDA | Nonsynthetic substances prohibited for use in organic crop production | Arsenic | USDA 2013; 7 CFR 205.602
d. Other
ACGIH | Carcinogenicity classification
| Arsenic and inorganic compounds | A1^i^ | ACGIH 2014
| BEI for inorganic arsenic plus methylated metabolites in urine at the end of the work week | 35 μg As/L
EPA | Carcinogenicity classification | | IRIS 2003
| Inorganic arsenic | Group A^j^
| Oral slope factor | 1.5 per mg/kg/day
| Inhalation unit risk | 4.3×10–3 μg/m^3^
| RfD | 3×10–4 mg/kg/day
| Superfund, emergency planning, and community right-to-know
| Designated CERCLA hazardous substance and reportable quantity | | EPA 2013c; 40 CFR 302.4
| Arsenic, arsenic acid, arsenic pentoxide, arsenic trioxide, dimethyl arsenic acid, calcium arsenate, sodium arsenate, and sodium arsenite
| Final RQ pounds | 1
| Effective date of toxic chemical release reporting | | EPA 2013d; 40 CFR 372.65
| Arsenic | 1/1/87
| Extremely hazardous substances and its threshold planning quantity (pounds) | | EPA 2013e; 40 CFR 355, Appendix A
| Arsenic pentoxide, arsenous oxide, sodium cacodylate | 100/10,000
| Calcium arsenate, sodium arsenite | 500/10,000
| Sodium arsenate sodium | 1,000/10,000
DHHS | Carcinogenicity classification | | NTP 2014
| Arsenic and inorganic arsenic compounds | Known to be human carcinogens

a Group 1: Carcinogenic to humans.

b Cancer risk estimates for lifetime exposure to a concentration of 1 μg/m^3^.

c Provisional guideline value: as there is evidence of a hazard, but the available information on health effects is limited.

d NIOSH potential occupational carcinogen.

e Based on applicable 60-minute AEGLs, ERPGs, or TEELs.

f Holding status AEGLs have been reviewed by the NAC/AEGL Committee and are under further review.

g Due to insufficient data.

h This criterion is based on carcinogenicity of 10^−6^ risk.

i A1: Confirmed human carcinogen.

j Group A: Human carcinogen.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = acute exposure guideline levels; AIHA = American Industrial Hygiene Association; BEI = biological exposure indices; CERCLA = Comprehensive Environmental Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; DHHs = Department of Health and Human Services; DOE = Department of Energy; DWEL = Drinking water equivalent level; EPA = Environmental Protection Agency; ERPG = emergency response planning guidelines; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; MCL = maximum contaminant level; NAAQS = National Ambient Air Quality Standards; NAC = National Advisory Committee; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; RCRA = Resource Conservation and Recovery Act; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; RQ = reportable quantity; TEEl = temporary emergency exposure limit; TLV = threshold limit values; TSCA = Toxic Substances Control Act; TWA = time-weighted average; WHO = World Health Organization