# 7 ANALYTICAL METHODS

## 7.1 BIOLOGICAL SAMPLES

Inorganic arsenic and organic arsenic exhibit distinctly different toxic health effects. Speciation of arsenic in tissues and body fluids improves the evaluation of arsenic exposure. Seven arsenic compounds are able to be determined in urine using one method (Verdon et al. 2009). HPLC-ICP-MS with dynamic reaction cell (DRC) has been used to separate and quantify arsenobetaine, arsenocholine, TMAO, As(V), As(III), monomethylarsonate, and dimethylarsinate. Interconversion of arsenic species is minimized by freezing samples until analysis, followed by treatment with a slightly acidified buffer solution. Samples are prepared with 0.1 M ammonium acetate (pH 5) and centrifuged at 4°C. The clarified supernatant is placed in a capped auto-sampler vial for analysis. Post column addition of arsenic internal standard improves the distinction of monoisotopic elements. The DCR mode minimizes interferences from the carrier gas. Detection limits for the selected species are As(V)=1.0, As(III)=1.2, DMA=1.7, MMA=0.9, arsenobetaine=0.4, arsenocholine=0.6, and TMAO=1.0, reported in μg As/L.

Development of the hydride-generation cryotrapping-AAS (HG-CT-AAS) technique for the analysis of major arsenic human metabolites, including dimethylmonothioarsinic acid, in biological samples was made to improve performance and lower detection limits (see Table 7-1; Hernandez-Zavala et al. 2008). Sample preparation involves generation of arsines from As(III) using a buffered mixture of tris-HCl and sodium borohydride, along with generation of arsines from both As(III) and As(V) by reduction using L-cysteine. The detection limits range from 9 to 20 pg arsenic for trivalent species and from 8 to 20 pg arsenic for pentavalent species.

Table 7-1 Analytical Methods for Determining Arsenic in Biological Samples

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Human, rat, mouse tissues | Reduction to arsines; cryotrapping | Atomic absorption spectrometry | 8–20 pg arsenic [16–40 pg/mL (0.5-mL sample)] | 73–117 | Hernandez-Zavala et al. 2008

Analysis of hair is used in arsenic biomonitoring studies. Synchrotron radiation-based X-ray fluorescence (XRF) spectroscopy is used to quantify arsenic exposure in relation to time (Nicolis et al. 2009). In addition, micro-XRF cartography and micro- fluorescence-X-ray absorption near-edge spectroscopy (XANES) spectra was used to show the location and species of arsenic in hair samples. Exogenous absorption from external arsenic exposure would complicate hair biomonitoring results.

## 7.2 ENVIRONMENTAL SAMPLES

Dietary exposure to inorganic arsenic is of greater concern compared with exposure to organic arsenic compounds. Analytical methods for the speciation of arsenic in foods evaluate specific arsenic compounds rather than total arsenic (see Table 7-2).

Table 7-2 Analytical Methods for Determining Arsenic

Sample matrix | Preparation method | Analytical method | Sample detection limit | Percent recovery | Reference
Water | Reduction to arsine in acid solution; reaction with SDDC | EPA Method 206.4; SDDC colorimetric spectrophotometry at 535 nm | 10 μg/L | 100 | EPA 1983
Water, biota, sediment, and soil digestates | SPE | HPLC-ICP-MS USGS method I-2020–05 | 0.06 μg/L | NR | USGS 2006
Wheat and rice | Seal between polyimide films | Fluorescence-XANES | NR | NR | Kopittke et al. 2014
Rice | Extraction with 2% v/v nitric acid | HPLC-ICP-MS | 0.003 μg/g | 94(±8)–11(±19)% | Maher et al. 2013
Rice | SPE | HG-AAS | 0.02 mg/kg (0.02 μg/g) | 101–106 | Rasmussen et al. 2013

HG-AAS = hydride-generation atomic absorption; spectrometry; HPLC-ICP-MS = high-performance liquid chromatography = inductively coupled plasma-mass spectrometry; NR = not reported; SDDC = silver diethyldithiocarbamate; SPE = solid phase extractions; USGS = U.S. Geological Survey; XANES = X-ray absorption near-edge spectroscopy

The USGS National Water Quality laboratories have updated analytical methods for the determination of elements in environmental media, including arsenic (USGS 2006). A new ICP-MS method using collision/reaction cell technology was developed to improve accuracy in the analysis of aqueous matrices. The method is valid for both speciated and unspeciated arsenic evaluation.

Nitric acid extraction is a common technique employed for the successful separation of inorganic arsenic in rice samples (Baba et al. 2014; Maher et al. 2013; Rasmussen et al. 2013). Baba et al. (2014) and Maher et al. (2013) have validated the measurement and speciation of arsenic in rice using HPLC-ICP-MS. Baba et al. (2014) optimized a rapid speciation analysis of arsenic in rice using HPLC-ICP-MS. Arsenous acid, arsenic acid, methylarsonic acid, and dimethylarsinic acid were determined with the use of silica-based pentafluorophenyl (PFP) HPLC columns with an isocratic mobile phase of formic acid and methanol in 5 minutes. Arsenic species are extracted from finely ground rice samples using 0.15 M nitric acid. The LOD is reported as 0.002 mg arsenic/kg (0.002 μg/g).

Chen and Chen (2014) reported a LOD of 1.3 ng/g using solid phase extraction (SPE). Arsenic is extracted from rice samples via microwave assisted digestion with nitric acid-hydrogen peroxide. As(III) is oxidized to As(V) during digestion. Silica-based anion exchange cartridges separate As(V) form organic arsenic compounds and quantification is achieved with hydride-generation atomic fluorescence spectrometry (HG-AFS).

XANES has been employed for arsenic speciation in rice. Kopittke et al. (2014) developed a method to illustrate the accumulation and transformation of arsenic within root tissues. Roots are sealed between two 8-μm thick polyimide films and analyzed continuously using X-ray fluorescence microscopy.

Visible and near-infrared diffuse reflectance spectroscopy (VNIRS) has been used for rapid monitoring of arsenic contamination in soils. Using the reflectance spectra of rice plants, arsenic concentrations in soils can be calculated using regression analysis methods (Shi et al. 2014). The method and techniques require optimization and validation.