# 6 POTENTIAL FOR HUMAN EXPOSURE

## 6.1 OVERVIEW

Arsenic has been identified in at least 860 of the 1,754 proposed (47), final (1,322), and deleted (385) hazardous waste sites listed on the EPA Superfund National Priorities List (NPL) (EPA 2013a; NLM 2014). However, the number of sites evaluated for arsenic is not known.

Exposure to the general population occurs through contaminated groundwater and can also occur from the ingestion of foods containing arsenic compounds. Exposure from drinking water, water used for food preparation, or water used in crop (especially rice) irrigation, is a source of concern, as elevated concentrations have been reported.

## 6.2 RELEASES TO THE ENVIRONMENT

Of the 20,853 Toxics Release Inventory (TRI) facilities reporting nationwide, elemental arsenic has been reported in 40 on site-releases and inorganic arsenic compounds have been reported in no on-site releases, for the reporting year 2012 (NLM 2014).

## 6.4 LEVELS MONITORED OR ESTIMATED IN THE ENVIRONMENT

### 6.4.1 Air

Ambient air and precipitation samples were collected at a site in Washington, DC (Melaku et al. 2008). The ambient air samples collected every 6 days over 7 months had total arsenic concentrations ranging of from 0.800 to 15.7 ng/m^3^. Wet deposition samples collected every 6 days for 1 year resulted in total arsenic concentrations ranging from 0.20 to 1.3 μg/L.

### 6.4.2 Water

A Washington State Environmental Biomonitoring Survey was conducted with tap water samples from 82 households in South Whidbey from July to September 2011. Results indicated that 54% of the water samples exceeded the EPA drinking water standard (maximum contaminant level [MCL]=10 μg/L) (WA DOH 2015).

Wasserman et al. (2014) measured kitchen tap water in Maine households; the average value found was 9.88 μg/L. Close to one-third of the water samples exceeded the EPA drinking water standard (MCL=10 μg/L). The highest level found was 115.3 μg/L.

In September and October 2005, samples from eight sites located in Lake Mohawk, a man-made body of water in New Jersey, were assessed for arsenic concentrations (Barringer et al. 2011). Shallow and deep lake water and sediment samples were collected. Lakes depths ranged from 1 to 7 m. The source water for the lake is predominantly groundwater. The lake is surrounded by approximately 2,200 homes and a golf course located on the western shore. It was reported that in the mid-20^th^ century, an estimated 300,000 kg of arsenical pesticides were applied to the lake. Concentrations of arsenic in sediment cores ranged from 91 to 460 mg/kg (91–460 μg/g). Concentrations in filtered (27.5–31.5 μg/L) and unfiltered (23–26 μg/L) water samples appeared to be evenly distributed in the lake.

In 2006, arsenic concentrations were measured in samples of runoff water, from two detention basins in Raccoon Creek, New Jersey (USGS 2011a). Arsenic concentrations in water samples collected in September, 2006 upstream of the outfall of basin one, at the basin, and at the outfall reported for detention basin one were 0.663, 2.56, and 2.44 μg/L, respectively, for filtered samples and 2.28, 2.68, and 2.45 μg/L, respectively, for unfiltered samples. Arsenic concentrations in water samples collected in May, 2006 up stream of the outfall of basin two, at the basin, and at the outfall reported for detention basin two were 0.872, 1.54, and 2.10 μg/L, respectively, for filtered samples and 1.39, 1.63, and 2.21 μg/L, respectively, for unfiltered samples. Arsenic concentrations in water samples collected in September, 2006 upstream of the outfall of basin two, at the basin, and at the outfall reported for detention basin two were 1.00, 4.35, and 3.11 μg/L, respectively, for filtered samples and 3.10, 4.35, and 3.71 μg/L, respectively, for unfiltered samples.

In Sutherlin, Oakland, and Yoncalla, Oregon, naturally occurring arsenic in groundwater was studied by the Environmental Health Assessment Program (EHAP), a part of the Oregon Department of Human Services (DHS) Office of Environmental Public Health (Agency for Toxic Substances and Disease Registry 2009). Well water analysis was performed for 124 samples collected from 114 private wells between June 9 and June 18, 2008. Arsenic was detected in 29 of the wells at concentrations ranging from 1 to 460 ppb (0.001–0.460 μg/L). Water samples that exceeded the EPA drinking water standard (MCL=10 μg/L) occurred in 13 of the wells located in areas east of Sutherlin, 11 of which were intended for domestic use.

Arsenic in groundwater has been correlated to the geology of the region, including aquifer characteristics, pH, redox conditions, and concentrations of inorganic minerals (Jones and Pilcher 2007; Meliker et al. 2009; Root et al. 2010; USGS 2011b). Aquifer recharge and aquifer storage and recovery (ASR) are processes employed in storing available water in aquifers and using the water when it is needed. Arsenic mobilization was investigated in Southwest Central Florida (Jones and Pilcher 2007) and southeastern Michigan groundwater (Meliker et al. 2009). From 300 core samples of 19 wells, a mean concentration of 3.5 μg/L arsenic was found in the Limestone of wells, in Southwest Central Florida region, used in groundwater recharge. Study results confirmed that arsenic is released from minerals containing arsenic, such as pyrite. Pyrite becomes unstable and dissolves when redox conditions shift towards a more oxidizing environment, increasing the potential of leaching arsenic into the stored water. Conditions in the Suwannee Limestone were reducing; therefore, low levels of arsenic were found. Arsenic concentrations in well water from 13 of the 19 wells were <0.02 μg/L; 6 of the 19 samples had levels ranging from 0.022 to 0.036 μg/L (Jones and Pilcher 2007). The spatial relationships in groundwater recharge wells, well characteristics, and dissolved arsenic in unconsolidated and bedrock aquifers of southeastern Michigan were studied (Meliker et al. 2009). Total arsenic concentrations in water from 641 bedrock wells in the Southeastern Michigan region ranged from not detectable to 161 μg/L; the mean total arsenic concentration was 4 μg/L and the median was 3 μg/L (Meliker et al. 2009). Total arsenic concentrations in water from 71 unconsolidated wells in the Southeastern Michigan region ranged from not detectable to 46 μg/L; the mean total arsenic concentration was 11 μg/L and the median was 17 μg/L.

During the spring and summer of 2009 in east-central Massachusetts, 478 private bedrock wells were sampled for analysis of arsenic concentrations by the U.S. Geological Survey (USGS 2011b). In 24% of the samples, arsenic concentrations were below the method detection limit of 0.2 μg/L. Concentrations up to 1,540 μg/L were reported. Concentrations >10 μg/L were found in 13–15% of samples. Correlations with bedrock units were made in order to calculate the probability of elevated arsenic in area wells. It was estimated that 5,741 wells in the State of Massachusetts may contain arsenic concentrations >10 μg/L.

Arsenic concentrations in mine groundwater and sediment from the Judge Tunnel, a water treatment facility in Park City, Utah, were measured. Total arsenic concentrations of 0.009–0.010 mg/L (9–10 μg/L) and <5 μg/L were reported in unfiltered and filtered water samples, respectively. The total arsenic concentrations in sediments collected from water storage tanks was 320 mg/kg (320 μg/g) (Pawlak et al. 2008). In one area of the Park City distribution system, hydrant-flushed water had elevated arsenic concentrations of 21.2–151 μg/L.

Arsenopyrite and pyrite, present in gold-bearing quartz veins of the Lucky Shot Gold Mine in Alaska, were attributed to the elevated arsenic concentrations in mine tailings and drainage water (Torrance et al. 2012). The mine was in operation from 1920 to 1942, producing 252,000 ounces of gold. Water samples were collected in August 2010 and September 2011 from 17 established monitoring wells. Total arsenic concentrations ranged from <1.0 μg/L found downstream to 752.5 μg/L found in water seeping from mine tailings. The main source of arsenic was found to be discharge from the mine adits. Less than half of the monitoring wells (five total) had total arsenic concentrations >10 μg/L. Arsenite accounted for close to 100% of the total arsenic present in the majority of the wells. A <2% difference in arsenic concentrations from filtered versus unfiltered samples indicated that the majority of arsenic present was in aqueous form.

In 2008, speciation of arsenic was performed in groundwater samples of a former ammunition depot and filling station in Germany operating in the 1940s (Daus et al. 2010). Remediation of the site was performed in 2005 by soil excavation. In June 2008, samples were taken at the source 2.0–15 m below the surface. Total arsenic reported in this study includes the summation of arsenite, arsenate, phenylarsonic acid, phenylarsine oxide, and diphenylarsinic acid. The highest concentration of total arsenic in source samples of groundwater was reported as 16 mg/L (16,000 μg/L), detected 4.4–5.4 m below the surface. Concentrations >1 mg/L (1,000 μg/L) were typically confined to depths ≤10 m. In November 2008, groundwater samples were taken 1 km from the source in the flow direction of the groundwater, at depths ranging from 4.8 to 25.0 m below the surface. Total arsenic concentrations were <400 μg/L. The species found here included arsenite, arsenate, phenylarsonic acid, phenylarsine oxide, and diphenylarsinic acid. Proportions of the species changed with the sampling depth.

Ayotte et al. (2015) analyzed five datasets containing arsenic concentrations in wells in the United States. Data were compiled for 1,245 public and private drinking water wells. The two most recent samples available for each well were used for this analysis. Data from filtered samples of 312 public and private wells collected from 1993 to 2008 at aquifers across the United States were obtained from the USGS National Water-Quality Assessment (NAWQA) Program dataset. Samples in New England were obtained from 607 public bedrock wells sampled from 1995 to 2008. A dataset for the Lamprey River basin was compiled from unfiltered water samples from 148 domestic wells across the basin in 2004 and 2005. The Lamprey River basin samples were analyzed at the New Hampshire Department of Environmental Services (NHDES) Laboratory, an EPA contract laboratory, and the EPA National Air and Radiation Environmental Laboratory. Unfiltered samples from 35 private bedrock wells near the Mottolo Superfund site sampled from 2009 to 2010 and analyzed at the NHDES laboratory and 143 domestic bedrock wells sampled from 2002 to 2012 by homeowners and analyzed by EPA laboratory were also included. Concentrations of arsenic in a specific well did not vary greatly over time: <±4 μg/L variability in 87% of the wells considered in this analysis. Variability in arsenic concentrations occurred more often in public water supplies compared to private wells. Variability was dependent upon multiple factors including geochemical parameters. Data indicated a weak correlation to seasonal variability in the New England area but not in California; concentrations in New England during the first half of the year were lower than arsenic concentrations in the second half of the year. Variability in California wells appeared to be a result of geochemical processes as well as aquifer storage and recovery practices, including groundwater recharge methods.

Speciation tests were performed in 65 wells from 59 sites across the United States with naturally occurring arsenic (Sorg et al. 2014). The sites chosen for the study were either part of the EPA Arsenic Demonstration Program (ADP) (n=50), proposed sites for the ADP program (n=5), or EPA research project sites (n=4). Analysis was conducted monthly for up to 3 years in select wells. Arsenate was found as the dominant species in 31 wells, arsenite was the dominant species in 29 wells, and almost equal amounts of the two species were found in 5 wells. Overall concentrations of arsenic species in a specific well did not vary greatly over time. The average iron content was 29, 1,544, 30, and 129 μg/L for the wells located in the East, Midwest, West, and Farwest regions, respectively. The average oxidation/reduction potentials were 244, -17, 179, and 213 mV for the wells located in the East, Midwest, West, and Farwest regions, respectively. The average pH of the wells in this assessment ranged from 7.4 to 7.9 in all four regions. On average, 92–100% of arsenic in the samples was in soluble form, and arsenate occurred as the dominant species in the East, West, and Farwest wells. Sites in the East region included wells in Maine, New Hampshire, Vermont, Rhode Island, Connecticut, Delaware, Maryland, New York, and Pennsylvania. In the East region, the average concentration of total arsenic found was 27.6 μg/L, the average particulate concentration was 0.3 μg/L, the average soluble arsenic concentration was 27.8 μg/L, and the average concentrations of arsenate and arsenite were 19.8 and 8.0 μg/L, respectively. Sites in the West region included wells in Texas, South Dakota, Nebraska, New Mexico, Arizona, and Montana. In the West region, the average concentration of total arsenic found was 36.3 μg/L, the average particulate concentration was 1.5 μg/L, the average soluble arsenic concentration was 35.0 μg/L, and the average concentrations of arsenate and arsenite were 30.4 and 5.2 μg/L, respectively. Sites in the Farwest region included wells in California, Oregon, Washington, Idaho, Nevada, and Utah. The average concentration of total arsenic found was 34.1 μg/L, the average particulate concentration was 1.3 μg/L, the average soluble arsenic concentration was 33.1 μg/L, and the average concentrations of arsenate and arsenite were 28.2 and 4.8 μg/L, respectively. Arsenite occurred as the dominant species in anoxic Midwest wells with elevated iron concentrations. Sites in the Midwest region included wells in Ohio, Michigan, Indiana, Illinois, Wisconsin, Minnesota, and Louisiana. The average concentration of total arsenic found was 28.6 μg/L, the average particulate concentration was 2.6 μg/L, the average soluble arsenic concentration was 26.1 μg/L, and the average concentrations of arsenate and arsenite were 2.3 and 24.1 μg/L, respectively.

Erikson and Barnes (2005) evaluated arsenic concentrations in public water systems located inside (1,764 wells) and outside (2,182 wells) an area where glacial sediment had been deposited, known as the northwest provenance Wisconsin-aged drift. Bedrock and glacial drift wells in North Dakota, South Dakota, Minnesota, and Iowa were also investigated. The study found that inside the drift, 12.0% of public water systems exceed 10 μg/L, while only 2.4% of public water systems exceed 10 μg/L outside the area. Of the wells located inside the drift, 1.5% exceeded 10 μg/L arsenic bedrock with well depths ranging from 800 to 186 m (n=132), 3.8% exceeded 10 μg/L arsenic with well depths ranging from 185 to 92 m (n=263), and 22.1% exceeded 10 μg/L arsenic with well depths ranging from 91 to 4 m (n=131). Of the wells located inside the drift, 8.5% exceeded 10 μg/L with well depths ranging from 157 to 65 m (n=120), 27.0% exceeded 10 μg/L arsenic with well depths ranging from 64 to 28 m (n=236), and 7.4% exceeded 10 μg/L arsenic depths ranging from 28 to 7 m (n=118).

Pichler et al. (2008) investigated arsenic concentrations and seasonal variations in 28 golf course lakes at four golf courses in Hillsborough County, Florida. Each of the four sites studied used private wells as their water source and applied monosodium methanearsonate as an herbicide. Surface water samples were collected monthly from February 2001 through January 2002. Total arsenic concentrations detected in lake samples ranged from 0 to 124 μg/L and an annual mean of 10.9 μg/L was reported for all lakes. The most recently renovated course had the lowest levels of total arsenic.

Hudak et al. (2008) compiled data on arsenic concentrations in 64 wells supplied by the Seymour Aquifer. Data were obtained from the Ground Water Database of the Texas Water Development Board sampled during 2001 and 2004. The median concentrations of arsenic in water were 3.5, 2.7, and <2.0 μg/L in irrigation wells, domestic wells, and public wells, respectively. Well depths ranged from 7.3 to 55.5 m, with a median value of 16.8 m. No statistically significant correlation was found between arsenic concentrations and well depths.

### 6.4.3 Sediment and Soil

Background concentrations of total arsenic in farming soils collected from Poland ranged from 4.98 to 17.40 mg/kg (4.98–17.40 μg/g) soil, with an average arsenic concentration of 8.83 mg/kg (8.83 μg/g) soil (Loska et al. 2005). Xu et al. (2008) evaluated growing practices (aerobic and flooded) and their effects on soil arsenic concentrations using soil from the upper layer (0–20 cm) of a field on the Rothamsted farm, Southeast England. The initial total arsenic concentration of the soil was reported as 15.1 mg/kg (15.1 μg/g). It was shown that flooding practices result in soil solutions with higher overall arsenic concentrations, arsenite was the predominant species. In samples collected between 12 and 97 days after flooding treatments, arsenite accounted for 81–95% of the total arsenic. In aerobic practices arsenate was the predominant species, accounting for >88% of the total arsenic. In soils under flooded conditions, the concentration of total arsenic (mainly arsenite) increased from 4 to 16.9 μg/L from day 3 to 97, while in soils under aerobic treatment, total arsenic levels decreased from 3.3 to 1.0 μg/L. In two soil samples in which 10 mg/kg (10 μg/g) arsenic was added to the soil, total arsenic concentrations remained at an elevated level (between 35 and 60 μg/L) from day 3 to 97 during the flooded treatment, but decreased during the aerobic treatment from 23–27 to 4 μg/L. Soil samples from 10 sites in Serbia, where high levels of arsenic had been found in suspended particles in the air, were analyzed with inductively coupled plasma-atomic emission spectroscopy (ICP-AES) and atomic absorption spectroscopy (AAS) to evaluate airborne heavy metal contamination (Serbula et al. 2012). Arsenic levels ranged from 16.8 to 95.5 mg/kg soil. The highest concentrations of arsenic were located in the urban industrial sampling zone and the lowest concentrations were located in the rural sampling zone. The control sample from Sumrakovac, Serbia had an arsenic concentration of 9 mg/kg soil.

Presley et al. (2010) reported measured concentrations of arsenic in New Orleans, Louisiana soils before Hurricane Katrina (June 2005) and after Hurricane Rita (January 2006). A total of 39 sites were sampled, 37 of which were schoolyards. Total arsenic concentration ranged from 1.20 to 11.30 mg/kg (1.20–11.30 μg/g) in four soil samples collected before Hurricane Katrina. Total arsenic concentration ranged from below reliable detection limits up to 24.30 mg/kg (24.30 μg/g) in 18 soil samples collected after Hurricane Rita. The 17 soil samples collected both before and after Hurricane Katrina had a geometric mean arsenic concentration of 4.73 μg/g before and 6.99 μg/g after. Warren et al. (2012) reported measured concentrations of arsenic in surface estuarine and marine sediments from 10 sites along the Mississippi Gulf Coast in New Orleans, Louisiana after Hurricane Katrina, from September 2005 to 2006. ICP-mass spectrometry (MS) was used to detect concentrations of arsenic ranging from 0.37 to 7.43 μg/g for the <2 mm particle size fractions and 2.50–17.1 μg/g for the <63 μm particle size fractions.

At an arsenic contaminated site in Kidsgrove, Staffordshire, soil sampled at 0–30, 30–70, and 70–100 cm depth had arsenic detected at concentrations of 280, 200, and 96 mg/kg soil, respectively, when the soil samples were microwave digested in concentrated 14 M nitric acid (Beesley et al. 2010). Arsenic-contaminated soil samples from a former nonferrous metal refinery plant and an abandoned mine tailing site in Korea were collected from 0- to 30-cm depths (Kim et al. 2014). A mean arsenic concentration of 61.2 mg/kg soil was detected from the smelter location samples and 82,300 mg/kg soil from the mine location samples. X-ray photoelectron spectroscopy was used to determine that As(V)-O was the major chemical form of arsenic at both sites investigated.

In 2006, arsenic concentrations were measured in soils, sediments, clay, and grab samples of runoff water, from two detention basins in Raccoon Creek, New Jersey (USGS 2011a). Soil and sediment samples collected in October at basin one had total arsenic concentrations ranging from 3.0 to 16.1 mg/kg (3.0–16.1 μg/g). Soil and sediment samples collected in June and July at basin two had total arsenic concentrations ranging from 12.0 to 45.4 mg/kg (12.0–45.4 μg/g). Total arsenic concentrations in soil from Victoria, Australia, collected in areas with a history of gold mining activity, ranged from 3.3 to 130 μg/g; the geometric mean was 11.5 μg/g (Pearce et al. 2010). Tsuji et al. (2005) analyzed total arsenic and arsenic species in urine, toenails, and soil of Middleport, New York residents. The range of total arsenic detected in urine was 2.1–773 μg/L in all participants. The arsenic concentration levels in soil and dust averaged 18.8 and 10.6 mg/kg (18.8 and 10.6 μg/g), respectively.

### 6.4.4 Other Environmental Media

Total arsenic levels in rice have shown notable variations with geographical region, cultivation methods, rice strain, and degree of polishing/milling practices. In addition, arsenic speciation can vary in different rice strains (Gilbert-Diamond 2011; Lei et al. 2013; Sommella 2013; Zavala et al. 2008). In a field study conducted in Chenzhou City Hunan, China, 34 rice genotypes grown in arsenic-contaminated fields had arsenic concentrations ranging from 9.07 to 25.26 g/dry weight plant (Lei et al. 2013). Rice grown and cultivated using flooded conditions contained 10–15-fold higher levels of arsenic species, specifically in the form of DMA, compared to rice grown under aerobic (i.e., non-flooded, well drained) conditions (Xu et al. 2008). Grain samples from flooded treatments had total arsenic concentrations ranging from 1 to 2.5 mg/kg (1–2.5 μg/g). Narukawa et al. (2014) evaluated 10 brown rice samples from six regions in Japan. The study found that the species of arsenic in the samples was directly related to the degree of polishing and milling; the concentrations of DMA in milled rice tended to be lower than polished rice. The concentration of inorganic arsenic decreased with increased milling and the concentration of inorganic arsenic in milled rice was higher than that in polished rice.

Rice grown in the south-central region of the United States tends to contain a higher average concentration of total arsenic (0.30 μg/g) compared to rice grown in California (0.17 μg/g) (Gilbert-Diamond 2011). Sommella et al. (2013) performed a survey of commercial rice purchased in Italian stores. Based on analysis of eight varieties from four different regions, it was confirmed that arsenic concentrations are not homogeneous. The highest mean concentration of total arsenic was 0.28 mg/kg found in Emilia, while the lowest mean concentration was 0.11 mg/kg (0.11 μg/g) found in Calabria. A study and review of rice crops in the United States, Australia, China, Asia, and Europe showed that the percentage of total arsenic in rice is dominated by either DMA or inorganic arsenic. Rice in the United States, Italy, and China was found to be dominated by the DMA species. Speciation of arsenic was assessed in U.S. commercially produced rice (Zavala et al. 2008). Of the 24 samples evaluated, 2 brown rice samples contained the highest concentrations of 0.45 and 0.71 mg/kg (0.45–0.71 μg/g). White rice samples had total arsenic concentrations of 0.162–0.383 mg/kg (0.162–0.383 μg/g) and brown rice samples had total arsenic concentrations of 0.201–0.71 mg/kg (0.201–0.71 μg/g). In general, brown rice had overall higher levels of As(III); As(III) concentrations ranged from 0.097 to 0.168 mg/kg (0.097–0.168 μg/g). White rice samples had As(III) concentrations of 0.049–0.122 mg/kg (0.049–0.122 μg/g). The total arsenic concentrations reported for 3 types of rice grain cultivated in Arkansas ranged from 0.253 to 0.356 mg/kg (0.253–0.356 μg/g), for 5 types of rice grain cultivated in California ranged from 0.162 to 0.345 mg/kg (0.160–0.710 μg/g) and for 16 types of rice grain cultivated in Texas ranged from 0.190 to 0.710 mg/kg (0.190–0.710 μg/g) (Zavala et al. 2008). Table 6-1 provides the concentrations of arsenic speciation in the U.S. commercial rice samples from the study.

Food products purchased both over the internet and from stores in the Hanover, New Hampshire area were evaluated for arsenic concentrations. Organic brown rice syrup (OBRS) and products containing OBRS, such as toddler formula, cereal and energy bars, were included. Total arsenic in three rice syrups tested ranged from 78 to 406 ng/g (0.08–0.4 μg/g). Inorganic arsenic accounted for 80–90% of the total arsenic in two of the syrups and 50% in the third. The third, however, had the highest concentration of arsenic overall at 406 ng/g. Fifteen of the 17 baby formulas evaluated did not have OBRS as an ingredient and contained levels of arsenic ranging from 2 to 12 ng/g (0.002–0.012 μg/g). OBRS was listed as an ingredient in 2 of the 17 baby formulas. Levels of inorganic arsenic in these two reconstituted formulas were 8–9 μg/L for dairy-based formulas and approximately 15–25 μg/L for soy-based formulas. Total arsenic concentrations in 100 cereal and energy bars tested ranged from 8 to 128 ng/g (0.08–0.128 μg/g). Analysis of 12 of the bars containing rice had an average of 70% inorganic arsenic (Jackson et al. 2012).

Table 6-1 Speciation of Arsenic in U.S. Commercial Rice

Rice color/state of production | Total arsenic (HNO_3_/H_2_O_2_) | Species (TFA extraction) (μg/g) | | | | Species recovery percent total arsenic^a^
Rice color/state of production | Total arsenic (HNO_3_/H_2_O_2_) | DMA | As(III) | As(V) | Sum | Species recovery percent total arsenic^a^
Brown
Arkansas | 0.253 | 0.068 | 0.133 | 0.012 | 0.212 | 84
California | 0.201±0.005 | 0.036 | 0.115 | 0.013 | 0.164 | 81
California | 0.236 | 0.067 | 0.145 | 0.009 | 0.221 | 94
California | 0.354 | 0.186 | 0.097 | 0.006 | 0.289 | 82
California | 0.273 | 0.171 | 0.102 | ≤0.005 | 0.273 | 100
Texas^b^ | 0.710±0.028 | 0.572 | 0.168 | ≤0.005 | 0.769 | 108
Texas | 0.450±0.021 | 0.320 | 0.116 | ≤0.005 | 0.437 | 97
Texas | 0.241±0.003 | 0.068 | 0.157 | 0.011 | 0.236 | 98
Texas | 0.258 | 0.069 | 0.142 | 0.008 | 0.218 | 85
White
Arkansas | 0.287 | 0.142 | 0.081 | 0.008 | 0.231 | 80
Arkansas | 0.356±0.008 | 0.190 | 0.066 | ≤0.005 | 0.256 | 72
California | 0.162±0.006 | 0.040 | 0.112 | 0.017 | 0.169 | 104
Texas | 0.242 | 0.171 | 0.049 | 0.023 | 0.242 | 100
Texas^c^ | 0.253±0.002 | 0.138 | 0.076 | 0.095 | 0.312 | 123
Texas^d^ | 0.383±0.003 | 0.302 | 0.071 | 0.003 | 0.382 | 100
Texas | 0.369±0.008 | 0.221 | 0.069 | 0.013 | 0.302 | 82
Texas | 0.190±0.002 | 0.061 | 0.122 | 0.008 | 0.192 | 101
Texas | 0.203±0.005 | 0.095 | 0.094 | 0.013 | 0.201 | 99
Texas | 0.195±0.017 | 0.106 | 0.086 | 0.014 | 0.207 | 106
Texas | 0.270±0.020 | 0.179 | 0.098 | 0.008 | 0.285 | 106
Texas | 0.256 | 0.128 | 0.118 | 0.014 | 0.259 | 101
Texas | 0.351 | 0.239 | 0.078 | 0.007 | 0.323 | 92
Texas | 0.240±0.014 | 0.171 | 0.081 | 0.013 | 0.265 | 111
Texas | 0.222 | 0.143 | 0.084 | 0.003 | 0.230 | 104

a Values >100% represent experimental error between two different analytical methods.

b Contained MMA at 0.013 and an unidentified arsenic species at 0.017 μg/g.

c Contained MMA at 0.003 μg/g.

d Contained MMA at 0.006 μg/g.

DMA = dimethylarsinic acid; MMA = monomethylarsonic acid; TFA = trifluoroacectic acid

Source: Zavala et al. 2008

Jackson et al. (2012) analyzed 15 infant formulas and 41 first foods for arsenic concentrations and found that rice-containing products had elevated levels of total arsenic. Of the formulas that were speciated, inorganic arsenic accounted for 100% of the total arsenic present. The highest concentrations of total arsenic reported for rice-based formula and first food puree in pears/raspberries were 11.89±0.64 ng/g (0.01189 μg/g) and 20.20 ng/g (0.02020 μg/g), respectively. Tables 6-2 and 6-3 summarize the results.

Table 6-2 Total Arsenic Concentrations for Main Brand Infant Formulas

Total arsenic (μg/g) | Dairy | Rice | Percent inorganic arsenic
0.00536 ±0.00021 | Yes | No | Not speciated
0.01127±0.00035 | No | No | 100%
0.00929±0.00043 | No | No | 100%
0.01189±0.00064 | No | Yes | 100%
0.00576±0.0004 | Yes | No | Not speciated
0.00695±0.00043 | No | No | 100%
0.01143±0.00109 | No | No | 100%
0.00602±0.00026 | Yes | Yes | Not speciated
0.00819±0.00063 | Yes | Yes | 100%
0.00814±0.00077 | Yes | No | 100%
0.00938±0.00031 | Yes | No | 100%
0.00292±0.00033 | Yes | No | Not speciated
0.00962±0.00135 | No | No | 100%
0.00342±0.0002 | Yes | No | Not speciated
0.0026±0.00044 | Yes | No | Not speciated

Source: Jackson et al. 2012

Table 6-3 Total Arsenic Concentration in First-Food Purees

Ingredients | Total arsenic (μg/g)
Apples | 0.00069–0.00674
Apples and apricots | 0.00148
Apples and blueberries | 0.00093
Apples and plums | 0.00097
Apple and strawberries | 0.0012
Applesauce | 0.00065
Bananas | 0.00032–0.00399
Carrots | 0.00168–0.00175
Corn and butternut squash | 0.00048
First prunes | 0.00125
Green beans | 0.0009–0.00321
Peaches | 0.00334
Pears | 0.00317–0.01752
Pears and mango | 0.01501
Pears and raspberries | 0.02020
Pears and wild blueberries | 0.00100
Peas | 0.00314
Prunes | 0.00201
Prunes and oatmeal | 0.00174
Select prunes | 0.00163
Select sweet potatoes | 0.00781
Squash | 0.00048–0.00190
Sweet carrots | 0.00207
Sweet peas | 0.00074–0.00106
Sweet potatoes | 0.00145–0.00503
Winter squash | 0.00068

Source: Jackson et al. 2012

A review done by the World Health Organization (WHO 2011a) reported that washing rice with water can eliminate up to 23% of arsenic, with As(III) being the species with the highest elimination potential. In addition, cooking methods such as boiling and baking may remove arsenic from foods such as vegetables, cereals, and seafood. The majority of studies conducted have been on rice boiling, and results indicate that large volumes of water are required to remove total arsenic (up to 35%) and inorganic arsenic (up to 45%) (WHO 2011a). Cooking with arsenic-contaminated water, however, has been shown to increase arsenic concentrations.

Arsenic speciation in 31 infant rice cereals sold in U.S. stores was performed via ICP-MS-high performance liquid chromatography (HPLC) (Juskelis et al. 2013). Mixed grain, single grain, whole grain, organic, white, and brown rice cereals were assessed. Cereals were purchased in Illinois, Texas, California, and North Dakota. The average concentrations of total arsenic and inorganic arsenic found were 174.4–101.4 μg/kg (0.1744–0.1014 μg/g). Total inorganic arsenic concentrations ranged from 55.5 to 158.0 μg/kg (0.0555–0.1580 μg/g). The major organic arsenic species detected was DMA; MMA was not typically detected unless at trace amounts. There were no notable differences in the inorganic arsenic concentrations of organic cereals versus conventional rice cereals. The lowest concentrations of inorganic arsenic were found in mixed-grain cereals. The levels of inorganic arsenic per serving ranged from 0.8 (mixed grain cereal) to 2.4 μg (organic whole grain cereal).

Arsenic concentrations were analyzed for 32 gluten-free food products purchased in Spain (Munera-Picazo et al. 2014a). The gluten-free foods products evaluated in this study, such as baking flour, breadcrumbs, pasta, breads, pastries, beer, and rice milk, had a rice content of 5–100%. The pastas contained the highest levels of total arsenic (0.109–0.120 μg/g) and inorganic arsenic (0.0730–0.0842 μg/g).

Dust samples were analyzed near a former wood treatment facility in southern Alabama (Hensley et al. 2007). Attic dust samples from 11 buildings located in a 1-mile radius of the facility had an average total arsenic concentration of 29.8 mg/kg (29.8 μg/g). The range was from 2.0 to 261.0 μg/g.

Speciation of arsenic in several mid-Atlantic fish and shellfish samples was achieved via ICP-MS (Green and Crecelius 2006). Summer flounder, Atlantic croaker, and Hard clam samples were collected from Delaware Inland Bays in 2002. Striped bass samples were collected from the Delaware Estuary and lower to mid Delaware Bay. Total arsenic concentrations in all 27 samples ranged from 0.36 to 3.33 μg/g (limit of detection [LOD] of 0.04 μg/g). Inorganic arsenic concentrations were reported as detected above the blank but less than the detection limit in 5 samples and not detected in 22 samples (LOD=0.03 μg/g). MMA concentrations were not detected in 10 samples and reported as detected above the blank but less than the detection limit in 17 samples (LOD=0.01 μg/g). DMA was reported as detected above the blank but less than the detection limit in 20 samples, below the LOD in 1 sample, and in concentrations ranging from 0.0412 to 0.528 in 6 samples(LOD=0.04 μg/g).

## 6.5 GENERAL POPULATION AND OCCUPATIONAL EXPOSURE

The Updated Fourth National Report on Human Exposures to Environmental Chemicals, published and updated by the Centers for Disease Control and Prevention (CDC 2015), reported 2003–2012 data from the National Health and Nutrition Examination Survey (NHANES). These data are summarized in Tables 6-4 through 6-19. Total arsenic levels in the urine (see Table 6-4) and urine, creatinine corrected (see Table 6-5) were evaluated for various ages and ethnicities. In addition values were reported of concentrations in urine for arsenic(V) acid, arsenobetaine, arsenocholine, arsenous (III) acid, DMA(V), monomethylarsonic acid (MMA(V)), and TMAO. Mean values of total arsenic (creatinine corrected) in the urine were 8.24 and 9.15 μg/g for 2,557 members of the general U.S. population sampled during 2003–2004 and 2,576 members of the general U.S. population sampled during 2005–2006, respectively. Mean values of total arsenic (creatinine corrected) in the urine were 8.46 and 9.90 μg/g for 2,605 members of the general U.S. population sampled during 2007–2008 and 2,860 members of the general U.S. population sampled during 2009–2010, respectively. The mean value for toal arsenic (creatinine corrected) in the urine for 2,502 members of the general U.S. population sampled during was 7.77 μg/g. The two highest geometric means (creatinine corrected) during 2009–2010 of 10.8 and 10.6 μg/g resulted from 2,028 samples from participants ≥20 years old and 1,459 samples from female participants, respectively. Throughout all survey years, females had a higher geometric mean of total arsenic (creatinine corrected) than males and the age group of ≥20 years had higher means than the 6–11-year-old group, which had higher means than ages 12–19 years (CDC 2015). Concentrations of arsenic(V) acid (corrected for creatinine) throughout all NHANES survey years were below the detection limits of the analytical methods (1.0 μg/L). Concentrations of arsenous (III) acid (corrected for creatinine) were below the dectection limits of the analytical methods (1.2 μg/L) for reporting years 2003–2010, but were at detectable levels for the reporting years 2011–2012 (Table 6-13).

Table 6-4 Geometric Mean and Selected Percentiles of Urinary Total Arsenic (in μg/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 8.30 (7.19–9.57) | 7.70 (6.90–8.90) | 16.0 (14.1–18.7) | 37.4 (31.6–43.5) | 65.4 (48.7–83.3) | 2,557
Total | 2005–2006 | 9.29 (8.05–10.7) | 8.65 (7.48–9.99) | 17.1 (14.9–20.6) | 41.1 (33.3–49.7) | 66.7 (53.7–87.0) | 2,576
Total | 2007–2008 | 8.10 (7.44–8.83) | 7.49 (6.90–8.12) | 14.9 (13.2–17.0) | 33.3 (29.8–38.7) | 50.8 (42.3–65.1) | 2,605
Total | 2009–2010 | 9.28 (8.47–10.2) | 8.15 (7.20–8.98) | 18.0 (15.3–20.8) | 44.6 (39.0–55.1) | 85.6 (64.7–114) | 2,860
Total | 2011–2012 | 6.85 (5.85–8.02) | 6.09 (5.22–7.12) | 13.0 (10.9–16.6) | 32.0 (25.9–39.0) | 52.5 (41.9–66.2) | 2,504
Age group
6–11 years | 2003–2004 | 7.08 (5.66–8.84) | 6.80 (5.90–7.70) | 10.9 (8.90–14.2) | 24.6 (13.8–61.8) | 46.9 (17.5–178) | 290
6–11 years | 2005–2006 | 7.19 (5.81–8.90) | 6.96 (5.32–8.88) | 11.5 (9.19–16.0) | 19.6 (13.1–51.5) | 34.1 (19.6–58.5) | 355
6–11 years | 2007–2008 | 6.85 (5.98–7.83) | 6.40 (5.74–7.23) | 10.8 (9.75–12.3) | 22.5 (16.9–34.7) | 41.0 (21.1–52.8) | 390
6–11 years | 2009–2010 | 6.63 (5.74–7.66) | 5.94 (5.14–7.19) | 10.8 (9.37–12.5) | 26.0 (18.2–33.4) | 37.7 (27.8–65.6) | 378
6–11 years | 2011–2012 | 6.02 (5.03–7.19) | 5.50 (4.58–6.56) | 10.5 (7.93–14.1) | 30.1 (16.7–46.5) | 53.0 (37.5–70.3) | 399
12–19 years | 2003–2004 | 8.55 (7.34–9.97) | 8.10 (6.80–9.40) | 15.2 (12.2–17.8) | 30.5 (23.1–40.4) | 46.1 (32.9–62.5) | 725
12–19 years | 2005–2006 | 8.19 (6.87–9.77) | 7.92 (6.37–9.50) | 14.0 (11.6–18.1) | 28.2 (22.9–32.9) | 41.9 (32.7–48.0) | 701
12–19 years | 2007–2008 | 7.09 (6.17–8.14) | 6.87 (5.88–7.86) | 11.4 (9.41–13.7) | 20.4 (16.1–26.6) | 38.2 (21.6–53.3) | 373
12–19 years | 2009–2010 | 6.45 (5.58–7.47) | 6.11 (5.26–6.89) | 10.8 (8.59–13.7) | 25.9 (16.2–32.9) | 38.8 (27.8–55.1) | 454
12–19 years | 2011–2012 | 6.01 (4.45–8.11) | 5.26 (3.95–7.47) | 10.9 (7.74–16.9) | 25.9 (16.6–44.0) | 44.0 (25.9–153) | 390
≥20 years | 2003–2004 | 8.41 (7.25–9.77) | 7.90 (7.00–9.10) | 17.0 (15.0–19.7) | 40.5 (34.9–46.2) | 66.2 (51.2–93.1) | 1,542
≥20 years | 2005–2006 | 9.76 (8.43–11.3) | 9.12 (7.85–10.4) | 18.9 (15.8–22.9) | 44.2 (35.2–56.1) | 71.4 (57.7–98.3) | 1,520
≥20 years | 2007–2008 | 8.43 (7.70–9.22) | 7.94 (7.09–8.67) | 16.2 (14.5–18.6) | 35.2 (30.4–42.3) | 59.0 (44.2–75.6) | 1,842
≥20 years | 2009–2010 | 10.2 (9.14–11.3) | 8.75 (7.95–9.81) | 20.4 (17.2–24.1) | 52.1 (42.4–66.1) | 93.1 (74.2–127) | 2,028
≥20 years | 2011–2012 | 7.09 (6.03–8.33) | 6.31 (5.32–7.45) | 13.6 (11.3–18.3) | 33.2 (26.7–39.5) | 52.5 (41.9–77.3) | 1,715
Gender
Males | 2003–2004 | 9.50 (8.34–10.8) | 8.90 (7.70–9.80) | 17.6 (15.2–20.1) | 41.6 (32.5–52.8) | 65.8 (48.7–95.4) | 1,281
Males | 2005–2006 | 10.1 (8.61–11.8) | 8.95 (8.05–10.0) | 18.3 (15.5–22.9) | 40.8 (31.05–2.6) | 63.7 (46.4–78.7) | 1,271
Males | 2007–2008 | 9.25 (8.28–10.3) | 8.50 (7.37–9.53) | 17.0 (14.6–19.4) | 36.0 (32.1–44.2) | 62.5 (44.3–84.6) | 1,318
Males | 2009–2010 | 10.1 (9.06–11.3) | 8.80 (7.80–9.75) | 20.4 (16.1–23.9) | 47.4 (42.1–64.1) | 89.1 (71.6–114) | 1,401
Males | 2011–2012 | 7.69 (6.35–9.31) | 6.84 (5.33–8.59) | 15.4 (11.7–19.7) | 33.5 (27.7–41.9) | 56.5 (42.2–78.0) | 1,262
Females | 2003–2004 | 7.30 (6.02–8.84) | 6.90 (5.90–8.30) | 15.0 (11.3–19.5) | 33.4 (26.5–41.7) | 60.5 (40.8–77.1) | 1,276
Females | 2005–2006 | 8.60 (7.38–10.0) | 8.18 (6.64–9.97) | 15.9 (13.7–19.9) | 41.5 (32.2–53.7) | 72.6 (54.8–122) | 1,305
Females | 2007–2008 | 7.14 (6.51–7.82) | 6.54 (6.09–7.14) | 12.7 (11.6–14.4) | 30.1 (26.0–34.0) | 49.1 (40.1–57.5) | 1,287
Females | 2009–2010 | 8.55 (7.44–9.83) | 7.63 (6.45–8.62) | 15.8 (13.1–19.9) | 41.5 (31.7–55.5) | 81.5 (54.3–132) | 1,459
Females | 2011–2012 | 6.14 (5.22–7.22) | 5.42 (4.79–6.25) | 11.6 (9.85–13.7) | 29.0 (22.5–38.2) | 50.6 (37.5–79.8) | 1,242
Race/ethnicity
Mexican Americans | 2003–2004 | 9.29 (8.12–10.6) | 9.20 (8.10–10.3) | 16.2 (13.5–19.9) | 34.4 (24.0–60.5) | 68.2 (41.3–111) | 618
Mexican Americans | 2005–2006 | 9.55 (8.54–10.7) | 9.11 (7.99–10.3) | 15.6 (14.0–17.1) | 29.2 (21.4–56.8) | 67.6 (41.7–81.4) | 652
Mexican Americans | 2007–2008 | 8.98 (8.13–9.92) | 8.84 (7.80–9.48) | 15.4 (12.3–19.7) | 35.2 (25.0–46.0) | 53.0 (44.2–77.4) | 510
Mexican Americans | 2009–2010 | 8.47 (7.30–9.84) | 7.96 (6.87–9.08) | 13.9 (11.3–17.7) | 34.7 (25.0–53.2) | 60.9 (49.3–78.7) | 613
Mexican Americans | 2011–2012 | 7.12 (5.73–8.84) | 6.94 (5.34–8.70) | 12.2 (9.84–16.5) | 24.2 (18.43–5.7) | 44.0 (23.87–0.3) | 317
Non-Hispanic blacks | 2003–2004 | 11.6 (9.50–14.1) | 10.4 (7.90–11.8) | 21.5 (14.93–4.4) | 43.5 (36.2–61.8) | 78.0 (43.6–141) | 722
Non-Hispanic blacks | 2005–2006 | 11.0 (8.60–14.0) | 9.55 (6.99–13.3) | 21.9 (14.9–28.9) | 44.9 (31.1–71.4) | 82.3 (49.2–164) | 692
Non-Hispanic blacks | 2007–2008 | 10.5 (9.40–11.7) | 9.21 (8.22–10.4) | 18.4 (16.1–21.5) | 42.4 (32.9–52.8) | 65.6 (45.5–112) | 585
Non-Hispanic blacks | 2009–2010 | 10.9 (9.46–12.5) | 9.26 (7.70–11.4) | 21.7 (17.6–24.2) | 49.1 (32.2–81.7) | 84.8 (51.3–174) | 546
Non-Hispanic blacks | 2011–2012 | 9.31 (7.19–12.0) | 8.18 (6.16–10.8) | 17.9 (13.1–25.3) | 46.8 (28.8–76.5) | 82.1 (53.1–107) | 669
Non-Hispanic whites | 2003–2004 | 7.12 (6.13–8.27) | 7.00 (6.10–7.90) | 13.7 (11.3–15.8) | 29.0 (22.6–35.9) | 53.1 (38.4–65.6) | 1,074
Non-Hispanic whites | 2005–2006 | 8.66 (7.20–10.4) | 8.05 (6.52–9.66) | 16.3 (13.4–20.6) | 40.8 (29.4–50.2) | 58.5 (46.0–88.0) | 1,041
Non-Hispanic whites | 2007–2008 | 6.98 (6.31–7.71) | 6.46 (5.93–7.29) | 12.4 (11.3–14.3) | 28.3 (21.6–32.6) | 42.1 (32.3–50.0) | 1,088
Non-Hispanic whites | 2009–2010 | 8.18 (7.46–8.96) | 7.24 (6.46–8.21) | 14.8 (12.7–17.4) | 38.9 (31.7–44.4) | 66.3 (49.3–88.7) | 1,224
Non-Hispanic whites | 2011–2012 | 5.89 (4.92–7.06) | 5.08 (4.56–6.06) | 10.8 (8.48–15.5) | 26.3 (20.3–34.9) | 43.2 (34.9–56.0) | 820

CI = confidence interval

Source: CDC 2015

Table 6-5 Geometric Mean and Selected Percentiles of Urinary Total Arsenic

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 8.24 (7.07–9.59) | 7.04 (5.93–8.51) | 14.1 (11.6–17.2) | 30.4 (26.0–38.7) | 50.4 (40.3–64.5) | 2,557
Total | 2005–2006 | 9.15 (7.93–10.6) | 7.70 (6.55–8.98) | 15.2 (11.7–19.4) | 35.1 (26.5–44.7) | 62.8 (44.7–85.0) | 2,576
Total | 2007–2008 | 8.46 (7.78–9.21) | 7.06 (6.56–7.74) | 13.8 (12.5–15.2) | 28.9 (24.2–36.7) | 49.0 (38.8–70.5) | 2,605
Total | 2009–2010 | 9.90 (9.06–10.8) | 7.90 (6.98–8.97) | 17.6 (15.4–20.2) | 45.2 (36.6–53.3) | 80.8 (60.5–94.4) | 2,860
Total | 2011–2012 | 7.77 (6.85–8.81) | 6.39 (5.57–7.24) | 13.7 (11.5–16.5) | 30.8 (24.6–38.6) | 50.4 (38.2–70.1) | 2,502
Age group
6–11 years | 2003–2004 | 8.25 (6.58–10.3) | 7.18 (5.93–9.45) | 11.7 (9.10–16.3) | 22.2 (12.0–69.5) | 40.1 (14.7–188) | 290
6–11 years | 2005–2006 | 8.88 (7.05–11.2) | 7.87 (6.19–9.42) | 11.8 (9.32–18.9) | 24.5 (13.0–62.8) | 45.4 (22.9–80.9) | 355
6–11 years | 2007–2008 | 8.87 (8.06–9.77) | 7.53 (6.73–7.88) | 13.4 (10.2–16.0) | 26.7 (19.9–34.0) | 37.2 (28.6–71.4) | 390
6–11 years | 2009–2010 | 8.97 (7.93–10.2) | 7.42 (6.70–8.32) | 11.0 (9.90–14.0) | 33.5 (17.0–54.6) | 60.8 (36.6–84.9) | 378
6–11 years | 2011–2012 | 8.63 (7.26–10.3) | 6.87 (5.84–8.00) | 12.3 (9.58–15.5) | 27.7 (17.7–57.7) | 91.2 (26.2–129) | 398
12–19 years | 2003–2004 | 6.11 (5.23–7.13) | 5.06 (4.47–6.04) | 9.66 (7.44–11.2) | 17.8 (12.0–26.0) | 27.8 (20.7–35.9) | 725
12–19 years | 2005–2006 | 6.30 (5.56–7.14) | 5.19 (4.80–6.19) | 9.62 (8.12–11.1) | 19.4 (13.9–25.8) | 28.0 (21.9–33.2) | 701
12–19 years | 2007–2008 | 5.50 (4.91–6.16) | 4.96 (4.25–5.40) | 7.69 (6.09–9.31) | 16.8 (10.8–21.1) | 22.5 (16.8–29.1) | 373
12–19 years | 2009–2010 | 6.06 (5.34–6.87) | 4.95 (4.39–5.81) | 9.18 (7.00–11.0) | 19.2 (14.5–21.3) | 28.4 (20.8–35.7) | 454
12–19 years | 2011–2012 | 5.75 (4.49–7.36) | 4.69 (3.70–5.73) | 8.73 (6.26–13.3) | 22.1 (11.5–52.6) | 34.9 (21.1–159) | 390
≥20 years | 2003–2004 | 8.64 (7.38–10.1) | 7.47 (6.20–9.01) | 15.4 (12.7–18.8) | 33.8 (27.3–41.2) | 53.9 (45.4–64.5) | 1,542
≥20 years | 2005–2006 | 9.75 (8.46–11.2) | 8.22 (6.98–9.75) | 17.0 (12.8–21.3) | 41.0 (29.6–52.5) | 68.4 (52.8–89.7) | 1,520
≥20 years | 2007–2008 | 9.00 (8.20–9.88) | 7.55 (6.79–8.53) | 14.9 (13.1–17.1) | 32.5 (25.8–41.0) | 59.4 (41.0–86.2) | 1,842
≥20 years | 2009–2010 | 10.8 (9.71–12.0) | 8.73 (7.69–9.71) | 20.1 (16.5–24.2) | 50.8 (40.5–59.7) | 87.3 (70.0–105) | 2,028
≥20 years | 2011–2012 | 8.04 (7.07–9.14) | 6.52 (5.88–7.69) | 14.8 (12.1–18.8) | 32.4 (25.2–39.8) | 49.7 (38.2–70.1) | 1,714
Gender
Males | 2003–2004 | 8.00 (6.81–9.40) | 6.75 (5.66–8.35) | 13.7 (11.0–18.0) | 28.7 (25.1–36.4) | 45.6 (35.3–62.1) | 1,281
Males | 2005–2006 | 8.26 (7.09–9.63) | 7.16 (5.87–8.54) | 12.9 (10.2–18.0) | 28.8 (22.9–36.3) | 46.1 (35.1–66.5) | 1,271
Males | 2007–2008 | 8.30 (7.49–9.18) | 6.79 (6.39–7.61) | 13.2 (11.8–15.2) | 28.9 (23.5–38.5) | 47.7 (35.7–68.1) | 1,318
Males | 2009–2010 | 9.21 (8.55–9.93) | 7.22 (6.43–8.67) | 17.0 (14.9–18.6) | 41.8 (35.4–47.9) | 66.9 (52.0–81.5) | 1,401
Males | 2011–2012 | 7.20 (6.15–8.43) | 6.13 (5.18–7.23) | 12.5 (10.5–15.2) | 28.3 (20.2–34.9) | 50.4 (33.3–69.6) | 1,261
Females | 2003–2004 | 8.47 (7.12–10.1) | 7.33 (6.10–8.75) | 14.4 (11.7–17.7) | 32.3 (24.2–46.6) | 58.4 (42.8–75.0) | 1,276
Females | 2005–2006 | 10.1 (8.72–11.7) | 8.29 (7.23–9.87) | 17.4 (13.0–21.4) | 43.8 (29.2–61.5) | 74.1 (55.0–96.2) | 1,305
Females | 2007–2008 | 8.63 (7.91–9.41) | 7.13 (6.53–8.33) | 14.1 (12.3–16.9) | 27.9 (24.1–37.0) | 51.4 (39.7–83.3) | 1,287
Females | 2009–2010 | 10.6 (9.36–12.0) | 8.38 (7.40–9.41) | 18.6 (14.9–23.9) | 50.8 (35.1–72.9) | 87.8 (66.8–109) | 1,459
Females | 2011–2012 | 8.35 (7.40–9.42) | 6.64 (6.12–7.37) | 15.0 (12.2–19.1) | 33.1 (26.1–41.4) | 50.7 (39.8–79.0) | 1,241
Race/ethnicity
Mexican Americans | 2003–2004 | 8.61 (7.33–10.1) | 7.76 (6.30–9.44) | 12.6 (10.2–15.9) | 24.0 (17.7–34.8) | 42.4 (24.8–62.4) | 618
Mexican Americans | 2005–2006 | 8.98 (7.89–10.2) | 7.48 (6.72–8.87) | 12.8 (11.0–16.3) | 28.1 (21.1–35.5) | 49.1 (31.0–108) | 652
Mexican Americans | 2007–2008 | 8.88 (7.71–10.2) | 7.38 (6.51–8.63) | 14.1 (10.6–17.8) | 28.6 (22.5–35.3) | 48.2 (31.1–75.7) | 510
Mexican Americans | 2009–2010 | 8.88 (7.87–10.0) | 7.62 (6.69–8.45) | 13.2 (10.7–17.2) | 31.4 (23.7–38.5) | 49.8 (37.5–68.9) | 613
Non-Hispanic blacks | 2003–2004 | 8.31 (6.99–9.88) | 6.88 (5.66–8.41) | 13.8 (11.5–17.0) | 27.6 (17.9–56.0) | 54.3 (27.5–120) | 722
Non-Hispanic blacks | 2005–2006 | 7.96 (6.40–9.92) | 6.48 (5.21–8.30) | 13.4 (10.0–18.6) | 32.5 (18.7–66.5) | 71.4 (35.6–98.8) | 692
Non-Hispanic blacks | 2007–2008 | 7.72 (6.98–8.54) | 6.60 (6.01–7.56) | 13.4 (11.5–15.4) | 25.7 (22.1–30.0) | 42.7 (31.4–60.3) | 585
Non-Hispanic blacks | 2009–2010 | 8.67 (7.54–9.98) | 7.26 (5.96–9.02) | 15.6 (12.4–21.3) | 38.7 (31.5–48.7) | 63.9 (43.1–102) | 546
Non-Hispanic blacks | 2011–2012 | 8.00 (6.85–9.36) | 6.91 (6.07–7.98) | 11.9 (9.05–14.6) | 26.1 (16.7–39.4) | 40.8 (24.0–70.1) | 317
Non-Hispanic whites | 2003–2004 | 7.50 (6.25–9.01) | 6.32 (5.28–7.96) | 12.5 (9.86–17.1) | 26.8 (21.8–32.0) | 40.0 (31.3–53.9) | 1,074
Non-Hispanic whites | 2005–2006 | 9.01 (7.57–10.7) | 7.68 (6.18–9.56) | 14.3 (11.1–20.8) | 31.9 (24.1–46.1) | 59.4 (37.9–96.2) | 1,041
Non-Hispanic whites | 2007–2008 | 7.82 (7.05–8.68) | 6.72 (6.00–7.54) | 12.5 (11.1–13.9) | 24.6 (19.6–32.3) | 43.1 (29.1–64.0) | 1,088
Non-Hispanic whites | 2009–2010 | 9.14 (8.35–10.0) | 7.10 (6.43–8.06) | 15.8 (13.7–18.4) | 40.9 (30.4–50.8) | 66.4 (50.9–90.0) | 1,224
Non-Hispanic whites | 2011–2012 | 7.24 (5.51–9.51) | 5.83 (4.65–7.96) | 13.5 (9.02–19.0) | 28.8 (21.5–46.3) | 55.4 (31.6–87.1) | 669

CI = confidence interval

Source: CDC 2015

Table 6-6 Geometric Mean and Selected Percentiles of Urinary Arsenic(V) Acid (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | 1.10 (<LOD-1.50) | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.06 (<LOD-1.43) | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,852
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,517
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.10 (<LOD-1.30) | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 379
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.20 (<LOD-1.60) | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.00 (<LOD-1.30) | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 453
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.10 (<LOD-1.50) | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.09 (<LOD-1.71) | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,020
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,724
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | 1.20 (≤LOD–1.50) | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.14 (≤LOD–1.71) | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,396
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,264
Females | 2003–2004 | * | <LOD | <LOD | <LOD | 1.10 (≤LOD–1.30) | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.01 (≤LOD–1.22) | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | 1.20 (≤LOD–1.60) | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | 1.20 (≤LOD–1.80) | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 543
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | 1.10 (≤LOD–1.50) | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.10 (≤LOD–1.74) | 1,050
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,210
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-7 Geometric Mean and Selected Percentiles of Urinary Arsenic(V) Acid (Creatinine Corrected) (in μg As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | 3.04 (<LOD–3.50) | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | 3.23 (<LOD–3.55) | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,851
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | 2.80 (<LOD–4.00) | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 378
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.75 (<LOD–2.41) | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.69 (<LOD–2.73) | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 453
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | 3.18 (<LOD–3.70) | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | 3.38 (<LOD–3.94) | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,020
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,723
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | 2.61 (<LOD–3.18) | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 2.14 (<LOD–2.73) | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,395
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,263
Females | 2003–2004 | * | <LOD | <LOD | <LOD | 3.33 (<LOD–3.89) | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 3.55 (<LOD–4.44) | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | 2.69 (<LOD–3.50) | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | 1.75 (<LOD–2.19) | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 542
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | 3.33 (<LOD–3.95) | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | 3.38 (<LOD–3.80) | 1,210
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,210
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 824

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-8 Geometric Mean and Selected Percentiles of Urinary Arsenobetaine (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 1.55 (1.31–1.83) | 1.00 (0.800–1.40) | 5.20 (4.00–6.50) | 16.8 (12.7–22.3) | 35.0 (27.6–44.6) | 2,568
| 2005–2006 | 1.86 (1.43–2.41) | 1.53 (0.98–02.26) | 6.73 (4.80–8.91) | 22.6 (16.5–30.3) | 40.6 (30.7–59.4) | 2,588
| 2007–2008 | * | 0.670 (0.510–0.910) | 4.26 (3.53–4.88) | 16.6 (12.5–20.2) | 29.5 (22.8–37.1) | 2,576
| 2009–2010 | 1.59 (1.38–1.83) | 0.940 (0.720–1.26) | 6.18 (4.67–7.87) | 23.5 (19.8–30.1) | 50.4 (35.7–63.2) | 2,870
| 2011–2012 | * | <LOD | 4.62 (3.25–6.25) | 18.0 (13.7–23.2) | .5 (25.7–51.9) | 2,517
Age group
6–11 years | 2003–2004 | * | <LOD | 1.80 (0.800–4.00) | 8.80 (3.90–29.9) | 29.9 (6.20–190) | 292
| 2005–2006 | * | <LOD | 2.22 (0.620–5.35) | 7.14 (2.34–29.9) | 18.9 (5.46–45.0) | 354
| 2007–2008 | * | <LOD | 1.24 (0.780–2.42) | 6.71 (3.37–8.38) | 13.0 (7.22–25.2) | 390
| 2009–2010 | * | <LOD | 1.20 (0.590–3.12) | 7.98 (5.20–15.7) | 19.4 (9.25–47.9) | 380
| 2011–2012 | * | <LOD | 1.58 (<LOD-4.12) | 15.2 (6.60–35.6) | 49.6 (20.0–60.1) | 401
12–19 years | 2003–2004 | * | 0.600 (0.400–0.800) | 3.20 (2.00–4.70) | 13.9 (7.20–25.1) | 31.8 (17.2–35.8) | 728
| 2005–2006 | * | 0.550 (<LOD-1.14) | 3.76 (1.95–7.16) | 12.4 (9.15–20.4) | 25.6 (16.4–32.4) | 703
| 2007–2008 | * | <LOD | 1.72 (0.780–2.62) | 4.88 (3.49–9.17) | 10.4 (6.81–23.6) | 366
| 2009–2010 | * | <LOD | 2.07 (1.26–3.60) | 11.0 (5.35–16.7) | 17.8 (12.8–24.0) | 455
| 2011–2012 | * | <LOD | 1.82 (<LOD-8.46) | 17.6 (6.92–26.5) | 32.6 (15.3–100) | 392
≥20 years | 2003–2004 | 1.74 (1.48–2.05) | 1.30 (1.00–1.60) | 6.10 (4.90–7.10) | 18.5 (14.0–23.5) | 35.5 (26.8–50.5) | 1,548
| 2005–2006 | 2.20 (1.71–2.84) | 1.89 (1.41–2.64) | 8.14 (5.86–10.4) | 27.6 (18.7–35.7) | 43.9 (36.0–67.9) | 1,531
| 2007–2008 | 1.46 (1.28–1.67) | 0.960 (0.750–1.22) | 5.08 (4.30–6.20) | 19.1 (14.3–23.7) | 31.7 (23.9–46.1) | 1,820
| 2009–2010 | 1.92 (1.63–2.26) | 1.33 (0.960–1.91) | 7.60 (6.06–9.90) | 28.2 (21.9–34.9) | 59.5 (45.7–76.7) | 2,035
| 2011–2012 | * | <LOD | 5.26 (4.07–6.58) | 18.1 (13.4–24.0) | 36.5 (24.4–53.4) | 1,724
Gender
Males | 2003–2004 | 1.66 (1.43–1.93) | 1.20 (0.900–1.50) | 5.80 (4.40–7.10) | 18.6 (13.9–23.7) | 35.0 (26.8–40.5) | 1,284
| 2005–2006 | 1.83 (1.40–2.40) | 1.44 (0.920–2.04) | 6.63 (5.06–8.66) | 23.2 (12.8–33.4) | 37.1 (28.5–51.3) | 1,276
| 2007–2008 | * | 0.910 (0.660–1.26) | 5.07 (4.01–6.81) | 19.1 (13.8–22.6) | 30.3 (22.8–46.1) | 1,289
| 2009–2010 | 1.71 (1.48–1.97) | 0.990 (0.780–1.33) | 7.14 (5.38–9.86) | 26.8 (21.5–31.8) | 57.4 (36.4–64.6) | 1,402
| 2011–2012 | * | <LOD | 5.22 (3.38–7.16) | 18.4 (13.72–5.9) | 41.7 (26.4–60.3) | 1,264
Females | 2003–2004 | 1.45 (1.17–1.80) | 0.900 (0.700–1.40) | 4.70 (3.40–6.20) | 15.6 (11.1–25.3) | 32.7 (21.1–51.3) | 1,284
| 2005–2006 | 1.88 (1.42–2.50) | 1.64 (0.950–2.51) | 6.81 (4.03–9.88) | 21.8 (17.3–30.1) | 43.3 (33.8–67.9) | 1,312
| 2007–2008 | * | 0.530 (0.410–0.650) | 3.52 (2.94–4.35) | 14.0 (10.9–17.5) | 29.5 (19.4–34.0) | 1,287
| 2009–2010 | 1.49 (1.20–1.84) | 0.890 (0.590–1.35) | 5.54 (3.56–7.74) | 21.2 (14.7–32.7) | 47.1 (32.5–76.4) | 1,468
| 2011–2012 | * | <LOD | 4.18 (2.84–6.11) | 17.0 (10.6–22.7) | 33.5 (22.1–53.1) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | 1.19 (0.871–1.62) | 0.800 (0.500–1.30) | 3.20 (1.80–5.20) | 10.2 (6.70–21.4) | 31.4 (16.3–39.1) | 621
Mexican Americans | 2005–2006 | 1.44 (1.23–1.69) | 1.04 (0.770–1.35) | 3.90 (3.03–5.06) | 16.8 (11.1–32.0) | 41.4 (23.4–57.9) | 651
Mexican Americans | 2007–2008 | * | 0.560 (<LOD-0.910) | 3.27 (2.00–5.65) | 16.9 (9.73–20.8) | 29.6 (19.3–40.5) | 513
Mexican Americans | 2009–2010 | * | 0.640 (0.440–0.800) | 3.58 (1.80–5.89) | 15.5 (7.83–24.6) | 31.9 (18.7–44.7) | 617
Mexican Americans | 2011–2012 | * | <LOD | 3.78 (1.93–5.84) | 12.5 (6.11–17.6) | 19.3 (12.93–4.7) | 317
Non-Hispanic blacks | 2003–2004 | 2.29 (1.60–3.28) | 2.00 (1.20–3.50) | 7.70 (5.00–12.0) | 23.7 (13.2–38.7) | 45.6 (25.1–94.0) | 725
Non-Hispanic blacks | 2005–2006 | 2.55 (1.64–3.99) | 2.42 (1.15–4.58) | 8.74 (6.01–14.4) | 23.8 (15.9–48.9) | 59.6 (30.5–121) | 695
Non-Hispanic blacks | 2007–2008 | 1.58 (1.31–1.90) | 1.11 (0.750–1.60) | 5.88 (4.12–8.13) | 21.9 (16.4–24.9) | 35.9 (25.4–47.7) | 586
Non-Hispanic blacks | 2009–2010 | 1.99 (1.60–2.47) | 1.79 (1.05–2.41) | 7.61 (5.34–10.0) | 25.5 (15.4–37.6) | 51.2 (31.0–90.9) | 546
Non-Hispanic blacks | 2011–2012 | * | 1.19 (<LOD-2.91) | 7.09 (3.79–13.4) | 30.2 (17.2–51.9) | 57.9 (36.1–81.5) | 672
Non-Hispanic whites | 2003–2004 | 1.37 (1.11–1.68) | 0.800 (0.700–1.20) | 4.30 (2.50–6.30) | 13.3 (9.70–21.4) | 29.3 (21.4–35.5) | 1,078
Non-Hispanic whites | 2005–2006 | 1.74 (1.27–2.40) | 1.41 (0.750–2.27) | 6.40 (3.93–9.04) | 22.4 (14.1–30.1) | 38.4 (27.8–66.8) | 1,050
Non-Hispanic whites | 2007–2008 | * | 0.530 (<LOD-0.780) | 3.63 (3.06–4.38) | 12.6 (9.08–17.1) | 24.3 (17.6–30.3) | 1,063
Non-Hispanic whites | 2009–2010 | 1.43 (1.24–1.65) | 0.800 (0.610–1.18) | 5.40 (3.77–7.27) | 20.6 (17.7–24.5) | 41.3 (30.6–59.5) | 1,226
Non-Hispanic whites | 2011–2012 | * | <LOD | 4.07 (2.39–6.12) | 16.7 (9.30–22.5) | 30.0 (23.2–47.0) | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-9 Geometric Mean and Selected Percentiles of Urinary Arsenobetaine (Creatinine Corrected) (in μg As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 1.54 (1.30–1.82) | 1.16 (0.95–91.43) | 5.00 (3.62–6.91) | 16.2 (12.5–20.3) | 29.4 (24.0–36.4) | 2,568
| 2005–2006 | 1.82 (1.40–2.37) | 1.64 (1.10–2.41) | 6.64 (4.48–8.79) | 20.3 (14.5–28.1) | 37.0 (27.5–58.3) | 2,588
| 2007–2008 | * | 1.00 (0.850–1.18) | 4.07 (3.36–4.98) | 14.7 (11.1–17.8) | 27.7 (18.9–45.4) | 2,576
| 2009–2010 | 1.69 (1.45–1.97) | 1.23 (0.980–1.47) | 6.48 (4.90–8.00) | 23.6 (18.5–30.7) | 49.6 (36.6–61.3) | 2,869
| 2011–2012 | * | <LOD | 5.63 (4.42–7.22) | 18.0 (13.8–26.1) | 36.9 (26.9–45.6) | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | 2.00 (1.15–4.83) | 12.2 (4.13–39.7) | 29.6 (6.80–153) | 292
| 2005–2006 | * | <LOD | 2.88 (1.04–6.25) | 8.77 (2.88–40.5) | 23.6 (6.86–74.8) | 354
| 2007–2008 | * | <LOD | 2.11 (1.27–3.79) | 8.98 (4.76–14.8) | 16.4 (8.98–23.8) | 390
| 2009–2010 | * | <LOD | 1.70 (1.21–3.02) | 9.52 (5.08–20.7) | 24.9 (9.81–50.7) | 379
| 2011–2012 | * | <LOD | 4.35 (<LOD-6.46) | 16.0 (8.00–39.5) | 69.0 (16.0–102) | 401
12–19 years | 2003–2004 | * | .531 (0.40–0.638) | 2.14 (1.39–3.51) | 9.29 (4.29–14.7) | 17.3 (10.4–28.7) | 728
| 2005–2006 | * | .620 (<LOD-.800) | 2.82 (1.58–4.77) | 10.5 (7.03–13.7) | 15.4 (11.8–22.3) | 703
| 2007–2008 | * | <LOD | 1.28 (0.650–1.72) | 5.17 (2.31–6.53) | 9.88 (5.72–16.0) | 366
| 2009–2010 | * | <LOD | 2.25 (1.17–3.76) | 8.69 (5.03–12.8) | 14.0 (9.82–15.5) | 455
| 2011–2012 | * | <LOD | 3.36 (<LOD-8.94) | 14.4 (5.56–23.8) | 25.9 (13.6–104) | 392
≥20 years | 2003–2004 | 1.79 (1.51–2.12) | 1.47 (1.15–1.88) | 5.91 (4.32–7.72) | 17.2 (13.4–21.8) | 30.1 (26.1–36.4) | 1,548
| 2005–2006 | 2.19 (1.70–2.82) | 2.13 (1.40–2.83) | 7.79 (5.38–10.2) | 24.4 (16.6–32.9) | 43.1 (30.5–71.4 | 1,531
| 2007–2008 | 1.55 (1.36–1.78) | 1.29 (1.13–1.52) | 5.27 (3.91–6.40) | 16.6 (12.2–21.6) | 33.4 (21.0–55.9) | 1,820
| 2009–2010 | 2.03 (1.70–2.42) | 1.52 (1.18–2.16) | 7.65 (6.04–10.4) | 27.7 (22.1–35.9) | 57.0 (39.7–71.9) | 2,035
| 2011–2012 | * | <LOD | 6.25 (4.78–8.46) | 19.3 (14.0–28.4) | 35.8 (26.8–44.1) | 1,723
Gender
Males | 2003–2004 | 1.40 (1.18–1.67) | 1.11 (0.909–1.28) | 4.78 (3.61–6.70) | 14.4 (11.1–18.5) | 26.5 (18.6–29.9) | 1,284
| 2005–2006 | 1.50 (1.15–1.96) | 1.25 (0.800–1.93) | 5.11 (3.41–7.54) | 15.3 (11.2–20.8) | 30.5 (19.6–44.0) | 1,276
| 2007–2008 | * | 1.04 (0.870–1.25) | 4.11 (3.16–5.30) | 14.9 (10.1–17.9) | 27.0 (17.8–49.2) | 1,289
| 2009–2010 | 1.56 (1.35–1.80) | 1.04 (0.880–1.34) | 6.20 (4.34–7.79) | 23.4 (18.7–27.6) | 39.2 (32.0–54.8) | 1,401
| 2011–2012 | * | <LOD | 4.94 (3.50–6.67) | 16.7 (12.6–25.7) | 35.7 (23.4–52.8) | 1,263
Females | 2003–2004 | 1.68 (1.37–2.05) | 1.25 (0.938–1.67) | 5.58 (3.50–7.43) | 17.2 (12.3–24.5) | 32.9 (25.6–46.3) | 1,284
| 2005–2006 | 2.20 (1.65–2.93) | 2.04 (1.30–2.92) | 7.86 (5.38–10.8) | 26.4 (16.6–35.6) | 46.2 (30.374.3) | 1,312
| 2007–2008 | * | 0.980 (0.800–1.18) | 4.06 (3.35–5.29) | 14.6 (11.1–17.8) | 29.6 (18.2–50.0) | 1,287
| 2009–2010 | 1.83 (1.48–2.26) | 1.36 (1.04–1.75) | 6.65 (4.68–9.21) | 24.1 (16.5–37.3) | 57.0 (36.3–71.3) | 1,468
| 2011–2012 | * | <LOD | 6.48 (4.79–8.60) | 18.8 (15.4–28.1) | 37.0 (26.2–46.8) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | 1.10 (0.786–1.55) | 0.877 (0.61–21.40) | 2.93 (1.78–5.21) | 8.88 (5.50–15.4) | 19.0 (9.64–29.4) | 621
| 2005–2006 | 1.35 (1.13–1.62) | 0.970 (0.810–1.19) | 4.21 (2.79–5.68) | 16.6 (10.5–21.3) | 36.9 (18.4–69.5) | 651
| 2007–2008 | * | 0.780 (<LOD-1.21) | 3.04 (1.99–5.09) | 13.7 (9.09–16.7) | 28.9 (16.2–46.7) | 513
| 2009–2010 | * | 0.790 (0.670–0.940) | 3.64 (2.28–4.41) | 13.5 (7.78–19.1) | 26.8 (16.5–42.0) | 617
| 2011–2012 | * | <LOD | 3.87 (2.80–5.76) | 12.6 (8.36–22.6) | 25.9 (13.4–40.3) | 317
Non-Hispanic blacks | 2003–2004 | 1.65 (1.19–2.30) | 1.53 (0.90–12.45) | 5.81 (4.25–7.82) | 13.6 (9.76–27.9) | 32.9 (13.4–82.1) | 725
| 2005–2006 | 1.84 (1.20–2.83) | 1.71 (0.910–2.95) | 6.07 (3.83–9.25) | 19.4 (10.4–45.2) | 47.5 (25.3–62.0) | 695
| 2007–2008 | 1.16 (0.955–1.41) | 0.830 (0.620–1.12) | 4.44 (3.23–6.58) | 14.9 (10.5–17.6) | 25.1 (17.4–40.0) | 586
| 2009–2010 | 1.59 (1.29–1.96) | 1.30 (0.850–2.04) | 5.92 (4.20–8.40) | 19.5 (13.5–27.1) | 37.9 (26.1–51.7) | 545
| 2011–2012 | * | 1.50 (<LOD-2.18) | 6.00 (2.63–12.4) | 20.3 (12.8–30.0) | 38.7 (22.6–78.2) | 672
Non-Hispanic whites | 2003–2004 | 1.44 (1.15–1.80) | 1.05 (0.83–31.36) | 4.47 (2.7–36.83) | 14.3 (10.9–18.6) | 26.5 (18.6–32.0) | 1,078
| 2005–2006 | 1.81 (1.32–2.47) | 1.65 (0.970–2.55) | 6.65 (3.95–9.34) | 19.7 (12.6–30.5) | 36.6 (25.1–71.4) | 1,050
| 2007–2008 | * | 0.970 (<LOD-1.18) | 3.56 (2.93–4.53) | 11.6 (8.98–16.6) | 23.8 (15.5–41.7) | 1,063
| 2009–2010 | 1.60 (1.36–1.87) | 1.15 (0.900–1.43) | 5.85 (4.33–7.65) | 22.8 (15.62–9.4) | 38.5 (32.0–57.0) | 1,226
| 2011–2012 | * | <LOD | 5.00 (4.06–7.55) | 16.8 (12.7–28.7) | 35.7 (21.0–45.6) | 824

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-10 Geometric Mean and Selected Percentiles of Urinary Arsenocholine (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,871
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,517
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 380
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,724
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,403
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,264
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,264
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 546
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-11 Geometric Mean and Selected Percentiles of Urinary Arsenocholine (Creatinine Corrected) (in μg As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,870
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 379
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,723
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,403
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,263
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 545
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 824

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-12 Geometric Mean and Selected Percentiles of Urinary Arsenous (III) Acid (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,871
| 2011–2012 | * | <LOD | 0.520 (<LOD–0.600) | 0.840 (0.760–0.960) | 1.11 (0.980–1.27) | 2,517
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 380
| 2011–2012 | * | <LOD | 0.540 (<LOD–0.660) | 0.870 (0.710–1.00) | 1.03 (0.820–1.22) | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.40 (<LOD–1.70) | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.20 (<LOD–1.40) | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | 0.610 (0.480–.720) | 0.920 (0.810–1.14) | 1.18 (0.980–1.43) | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | 0.500 (<LOD–0.570) | 0.830 (0.750–0.940) | 1.11 (0.980–1.27) | 1,724
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 1.26 (<LOD–1.73) | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | 1.24 (<LOD–1.50) | 1,403
| 2011–2012 | * | <LOD | 0.600 (0.520–0.680) | 0.980 (0.840–1.13) | 1.31 (1.11–1.59) | 1,264
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | >LOD | 0.760 (0.600–0.840) | 0.940 (0.810–1.07) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | 2.00 (<LOD–3.00) | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | 1.20 (<LOD–1.76) | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | 0.570 (0.490–0.660) | 0 .830 (0.770–1.03) | 1.14 (0.880–1.37) | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | 1.20 (<LOD–1.80) | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 546
| 2011–2012 | * | <LOD | 0.520 (<LOD–0.680) | 0.880 (0.700–1.10) | 1.21 (0.980–1.57) | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
| 2011–2012 | * | <LOD | <LOD | 0.800 (0.640–0.900) | 1.03 (0.830–1.18) | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-13 Geometric Mean and Selected Percentiles of Urinary Arsenous (III) Acid (Creatinine Corrected) (in μg As/g of creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,870
| 2011–2012 | * | <LOD | 0.791 (<LOD–0.850) | 1.35 (1.21–1.42) | 1.79 (1.55–1.89) | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 379
| 2011–2012 | * | <LOD | 1.03 (<LOD–1.13) | 1.54 (1.26–1.79) | 2.00 (1.55–2.62) | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | 1.95 (<LOD–2.76) | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | 2.02 (<LOD–3.04) | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | 0.709 (0.607–0.850) | 1.11 (0.971–1.31) | 1.36 (1.03–2.50) | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | 0.773 (<LOD–0.850) | 1.36 (1.19–1.48) | 1.79 (1.55–1.95) | 1,723
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | 2.43 (<LOD–3.15) | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | 2.93 (<LOD–3.54) | 1,402
| 2011–2012 | * | <LOD
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | 0.708 (0.645–0.756) | 1.12 (0.981–1.25) | 1.48 (1.28–1.70) | 1,263
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | 3.08 (<LOD–4.44) | 621
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
| 2007–2008 | * | <LOD | <LOD | <LOD | 3.54 (<LOD–4.72) | 513
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
| 2011–2012 | * | <LOD | <LOD | 1.42 (1.36–1.62) | 1.89 (1.70–2.27) | 1,253
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | 2.00 (<LOD–2.29) | 725
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 545
| 2011–2012 | * | <LOD | 0.723 (0.630–0.850) | 1.13 (0.919–1.42) | 1.55 (1.13–2.20) | 317
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
| 2011–2012 | * | <LOD | 0.514 (<LOD–0.586) | 0.919 (0.739–1.06) | 1.22 (0.971–1.64) | 672

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2015

Table 6-14 Geometric Mean and Selected Percentiles of Urinary Dimethylarsinic Acid (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 3.71 (3.33–4.14) | 3.90 (3.00–4.00) | 6.00 (5.00–7.00) | 11.0 (9.20–12.0) | 16.0 (13.0–17.8) | 2,568
| 2005–2006 | 3.95 (3.59–4.35) | 3.90 (3.46–4.31) | 6.17 (5.53–7.04) | 10.3 (9.00–12.2) | 15.0 (12.2–17.8) | 2,588
| 2007–2008 | 3.67 (3.44–3.91) | 3.58 (3.44–3.84) | 5.96 (5.44–6.57) | 9.78 (8.72–11.2) | 13.3 (11.8–15.3) | 2,576
| 2009–2010 | 3.67 (3.43–3.93) | 3.50 (3.25–3.76 | 6.16 (5.59–6.73) | 11.5 (9.35–13.7) | 17.4 (14.0–21.0) | 2,871
| 2011–2012 | 3.47 (3.18–3.78) | 3.37 (3.06–3.66) | 5.81 (5.14–6.59) | 9.55 (8.4–11.2) | 14.0 (11.4–16.5) | 2,517
Age group
6–11 years | 2003–2004 | 3.73 (3.12–4.45) | 4.00 (3.00–4.00) | 6.00 (5.00–7.00) | 9.00 (7.00–12.0) | 12.0 (8.00–22.0) | 292
| 2005–2006 | 3.96 (3.49–4.49) | 3.94 (3.20–4.71) | 5.94 (5.01–7.10) | 10.5 (7.10–12.1) | 13.0 (10.7–15.3) | 354
| 2007–2008 | 3.86 (3.45–4.32) | 3.76 (3.47–4.01) | 6.10 (5.29–6.99) | 10.4 (7.57–13.9) | 15.2 (9.32–39.2) | 390
| 2009–2010 | 3.53 (3.17–4.32) | 3.27 (2.81–3.87) | 5.76 (5.07–6.53) | 10.7 (7.84–11.9) | 12.8 (11.0–14.4) | 380
| 2011–2012 | 3.43 (3.06–3.85) | 3.53 (2.81–4.05) | 5.81 (5.21–6.38) | 8.60 (7.55–9.73) | 11.4 (9.35–13.7) | 401
12–19 years | 2003–2004 | 3.85 (3.34–4.42) | 4.00 (3.00–4.00) | 6.00 (5.00–7.10) | 9.30 (7.70–12.0) | 13.0 (10.0–16.0) | 728
| 2005–2006 | 3.97 (3.46–4.55) | 3.97 (3.31–4.64) | 5.74 (5.11–7.10) | 9.43 (7.63–11.6) | 12.0 (10.7–13.9) | 703
| 2007–2008 | 3.60 (3.16–4.09) | 3.66 (3.24–4.26) | 5.53 (4.75–6.72) | 8.90 (7.33–9.95) | 10.7 (9.08–13.3) | 366
| 2009–2010 | 3.08 (2.77–3.43) | 2.89 (2.64–3.29) | 5.05 (4.44–5.77) | 7.89 (6.87–10.1) | 11.3 (8.75–13.8) | 456
| 2011–2012 | 3.27 (2.71–3.94) | 3.33 (2.49–4.20) | 5.02 (4.33–6.05) | 8.53 (6.29–11.1) | 11.6 (8.74–17.9) | 392
≥20 years | 2003–2004 | 3.69 (3.31–4.11) | 3.70 (3.00–4.00) | 6.00 (5.00–7.00) | 11.0 (10.0–12.0) | 16.0 (13.0–19.0) | 1,548
| 2005–2006 | 3.95 (3.58–4.36) | 3.87 (3.46–4.32) | 6.30 (5.59–7.28) | 10.3 (9.25–13.3) | 16.2 (12.5–19.4) | 1,531
| 2007–2008 | 3.66 (3.43–3.91) | 3.56 (3.41–3.80) | 5.97 (5.44–6.63) | 9.89 (8.72–11.4) | 13.8 (11.8–15.5) | 1,820
| 2009–2010 | 3.79 (3.51–4.09) | 3.60 (3.33–3.87) | 6.40 (5.71–7.03) | 12.1 (9.52–16.0) | 18.2 (15.8–23.6) | 2,035
| 2011–2012 | 3.51 (3.22–3.82) | 3.37 (3.05–3.67) | 5.91 (5.20–6.83) | 9.94 (8.57–11.5) | 14.1 (12.2–16.4) | 1,724
Gender
Males | 2003–2004 | 4.12 (3.60–4.71) | 4.00 (3.70–4.30) | 6.00 (5.60–7.70) | 11.0 (9.00–15.0) | 17.0 (12.1–22.0) | 1,284
| 2005–2006 | 4.17 (3.79–4.59) | 4.04 (3.68–4.43) | 6.32 (5.41–7.61) | 10.5 (8.68–13.3) | 14.8 (11.8–19.2) | 1,276
| 2007–2008 | 4.05 (3.73–4.40) | 3.96 (3.63–4.27) | 6.53 (5.77–7.15) | 10.3 (9.31–12.0) | 14.6 (11.6–20.2) | 1,289
| 2009–2010 | 3.89 (3.50–4.32) | 3.71 (3.35–4.11) | 6.33 (5.80–7.02) | 11.6 (8.80–17.3) | 19.2 (13.0–24.7) | 1,403
| 2011–2012 | 3.79 (3.40–4.239) | 3.71 (3.33–4.29) | 6.27 (5.36–7.61) | 10.3 (8.75–12.5) | 15.3 (12.5–16.7) | 1,264
Females | 2003–2004 | 3.37 (3.00–3.78) | 3.00 (3.00–4.00) | 5.50 (4.80–6.20) | 10.0 (8.00–11.0) | 14.0 (11.0–17.7) | 1,284
| 2005–2006 | 3.75 (3.37–4.18) | 3.70 (3.28–4.21) | 6.03 (5.46–6.99) | 9.95 (8.81–12.2) | 15.5 (11.6–19.0) | 1,312
| 2007–2008 | 3.34 (3.13–3.57) | 3.37 (3.15–3.53) | 5.48 (5.00–6.05) | 8.99 (7.97–10.4) | 11.9 (10.7–13.9) | 1,287
| 2009–2010 | 3.48 (3.22–3.76) | 3.28 (2.95–3.63) | 5.85 (5.21–6.69) | 11.5 (9.42–13.3) | 16.1 (13.8–17.7) | 1,468
| 2011–2012 | 3.19 (2.92–3.48) | 3.01 (2.73–3.30) | 5.30 (4.61–5.96) | 8.96 (7.72–10.5) | 12.2 (9.56–17.8) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | 4.72 (4.27–5.22) | 4.80 (4.00–5.00) | 7.00 (6.00–9.00) | 12.0 (10.0–16.0) | 17.0 (12.0–25.0) | 621
| 2005–2006 | 4.43 (4.15–4.72) | 4.66 (4.26–5.13) | 6.93 (6.38–7.58) | 9.51 (8.70–11.1) | 13.1 (10.3–15.1) | 651
| 2007–2008 | 4.36 (4.05–4.69) | 4.62 (4.07–5.07) | 7.14 (6.23–7.76) | 9.67 (8.39–10.8) | 11.7 (9.96–17.6) | 513
| 2009–2010 | 3.90 (3.45–4.40) | 3.98 (3.18–4.63) | 6.53 (5.61–7.15) | 10.7 (8.95–13.2) | 16.2 (13.1–19.2) | 618
| 2011–2012 | 3.67 (3.33–4.04) | 3.58 (3.27–4.18) | 5.82 (5.24–6.47) | 9.05 (7.91–10.0) | 12.1 (9.61–17.4) | 317
Non-Hispanic blacks | 2003–2004 | 4.27 (3.71–4.92) | 4.00 (3.50–5.00) | 7.00 (6.00–8.00) | 11.6 (9.00–15.0) | 16.0 (14.0–18.7) | 725
| 2005–2006 | 4.28 (3.68–4.98) | 4.02 (3.37–4.82) | 6.42 (5.31–7.36) | 10.9 (8.22–13.1) | 15.2 (11.5–27.1) | 695
| 2007–2008 | 4.19 (3.92–4.49) | 3.98 (3.63–4.27) | 6.69 (5.80–7.43) | 11.2 (10.1–12.5) | 14.7 (12.1–19.2) | 586
| 2009–2010 | 4.09 (3.63–4.61) | 3.93 (3.31–4.36) | 7.13 (5.99–8.63) | 12.3 (10.1–17.0) | 18.2 (13.7–27.8) | 546
| 2011–2012 | 4.05 (3.46–4.74) | 4.05 (3.35–4.65) | 6.78 (5.46–8.21) | 12.0 (10.01–4.2) | 17.4 (14.2–19.8) | 672
Non-Hispanic whites | 2003–2004 | 3.27 (2.95–3.62) | 3.00 (3.00–3.80) | 5.00 (4.60–6.00) | 9.00 (7.00–10.0) | 12.0 (9.50–15.0) | 1,078
| 2005–2006 | 3.69 (3.28–4.15) | 3.60 (3.19–4.08) | 5.66 (5.10–6.70) | 9.62 (8.11–11.8) | 13.9 (10.6–17.8) | 1,050
| 2007–2008 | 3.23 (3.01–3.48) | 3.34 (3.04–3.53) | 5.14 (4.77–5.59) | 8.27 (7.48–9.07) | 10.5 (9.25–13.2) | 1,063
| 2009–2010 | 3.21 (3.07–3.37) | 3.12 (2.91–3.29) | 5.32 (5.00–5.66) | 8.65 (7.23–10.1) | 12.0 (10.1–14.4) | 1,226
| 2011–2012 | 3.06 (2.82–3.33) | 2.97 (2.72–3.29) | 4.95 (4.39–5.77) | 7.98 (6.92–9.02) | 10.5 (8.71–13.0) | 825

CI = confidence interval

Source: CDC 2015

Table 6-15 Geometric Mean and Selected Percentiles of Urinary Dimethylarsinic Acid (Creatinine Corrected) (in μg As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | 3.69 (3.24–4.19) | 3.37 (2.94–3.91) | 5.71 (4.69–6.74) | 9.09 (7.61–11.5) | 13.0 (10.7–16.0) | 2,568
| 2005–2006 | 3.88 (3.57–4.22) | 3.66 (3.39–3.93) | 5.71 (5.10–6.43) | 9.57 (7.95–10.9) | 12.3 (10.6–15.0) | 2,588
| 2007–2008 | 3.83 (3.60–4.07) | 3.62 (3.37–3.93) | 5.80 (5.33–6.32) | 9.01 (8.00–9.97) | 11.6 (9.97–14.4) | 2,576
| 2009–2010 | 3.90 (3.64–4.18) | 3.53 (3.30–3.80) | 6.03 (5.36–6.62) | 10.2 (9.15–11.8) | 14.9 (12.3–19.2) | 2,870
| 2011–2012 | 3.92 (3.69–4.16) | 3.65 (3.47–3.91) | 5.92 (5.40–6.49) | 9.86 (8.68–11.3) | 13.1 (11.5–15.2) | 2,516
Age group
6–11 years | 2003–2004 | 4.34 (3.57–5.28) | 4.03 (3.20–4.80) | 6.32 (4.65–8.33) | 10.3 (7.00–13.9) | 13.9 (7.86–21.8) | 292
| 2005–2006 | 4.89 (4.22–5.65) | 4.31 (3.64–5.69) | 6.85 (5.71–7.69) | 10.0 (7.54–14.7) | 14.7 (10.0–18.8) | 354
| 2007–2008 | 5.07 (4.56–5.64) | 4.54 (4.08–4.82) | 6.90 (6.14–7.76) | 12.0 (8.39–17.1) | 20.9 (12.0–40.8) | 390
| 2009–2010 | 4.77 (4.34–5.23) | 4.48 (4.12–4.85) | 6.41 (5.66–6.82) | 10.0 (7.63–15.3) | 16.5 (9.33–27.0) | 379
| 2011–2012 | 4.86 (4.54–5.21) | 4.44 (4.10–4.70) | 6.82 (6.15–7.69) | 9.77 (8.65–11.5) | 13.8 (10.3–15.0) | 401
12–19 years | 2003–2004 | 2.74 (2.39–3.14) | 2.55 (2.27–2.94) | 3.77 (3.17–4.44) | 5.88 (4.65–6.67) | 7.18 (6.16–11.7) | 728
| 2005–2006 | 3.05 (2.78–3.34) | 2.92 (2.55–3.29) | 4.25 (3.87–4.84) | 6.68 (5.49–8.06) | 9.08 (7.11–10.6) | 703
| 2007–2008 | 2.80 (2.54–3.09) | 2.69 (2.37–2.93) | 3.91 (3.46–4.56) | 6.27 (4.72–8.21) | 8.21 (5.77–10.1) | 366
| 2009–2010 | 2.89 (2.61–3.20) | 2.60 (2.36–2.86) | 4.08 (3.43–4.80) | 6.67 (5.71–8.57) | 10.0 (7.61–12.6) | 456
| 2011–2012 | 3.13 (2.68–3.64) | 3.02 (2.48–3.34) | 4.51 (3.49–5.62) | 7.03 (5.08–10.8) | 10.8 (6.13–18.1) | 392
≥20 years | 2003–2004 | 3.79 (3.34–4.31) | 3.48 (3.00–4.00) | 5.95 (4.86–7.05) | 9.45 (8.00–12.0) | 13.5 (11.1–18.6) | 1,548
| 2005–2006 | 3.93 (3.62–4.27) | 3.71 (3.42–4.02) | 5.82 (5.22–6.47) | 9.74 (8.00–11.2) | 12.6 (10.9–15.8) | 1,531
| 2007–2008 | 3.89 (3.64–4.16) | 3.69 (3.44–4.02) | 5.96 (5.47–6.58) | 9.10 (8.00–10.0) | 11.6 (9.74–14.5) | 1,820
| 2009–2010 | 4.00 (3.70–4.32) | 3.61 (3.33–3.90) | 6.25 (5.57–6.88) | 10.8 (9.23–12.9) | 16.1 (12.6–22.2) | 2,035
| 2011–2012 | 3.96 (3.75–4.19) | 3.73 (3.52–3.94) | 6.05 (5.45–6.68) | 10.1 (8.97–11.3) | 13.1 (11.51–5.5) | 1,723
Gender
Males | 2003–2004 | 3.48 (2.95–4.10) | 3.16 (2.70–3.82) | 5.46 (4.17–6.90) | 8.59 (6.92–12.0) | 12.3 (8.84–18.9) | 1,284
| 2005–2006 | 3.43 (3.13–3.75) | 3.24 (2.91–3.63) | 5.11 (4.25–6.08) | 7.90 (6.65–9.77) | 11.0 (9.29–13.0) | 1,276
| 2007–2008 | 3.63 (3.41–3.85) | 3.44 (3.22–3.68) | 5.33 (5.00–5.82) | 8.31 (7.21–10.1) | 12.1 (9.73–14.9) | 1,289
| 2009–2010 | 3.54 (3.29–3.80) | 3.20 (3.04–3.38) | 5.31 (4.80–5.99) | 9.24 (7.80–10.8) | 13.3 (10.3–16.5) | 1,402
| 2011–2012 | 3.55 (3.27–3.86) | 3.34 (3.11–3.69) | 5.32 (4.75–6.06) | 8.47 (7.35–9.73) | 11.0 (9.45–14.1) | 1,263
Females | 2003–2004 | 3.89 (3.49–4.34) | 3.57 (3.13–4.06) | 5.78 (4.95–6.67) | 9.32 (8.00–11.5) | 13.7 (10.61–8.6) | 1,284
| 2005–2006 | 4.37 (4.03–4.75) | 4.03 (3.72–4.51) | 6.26 (5.71–6.84) | 10.0 (8.50–12.6) | 14.4 (11.2–19.3) | 1,312
| 2007–2008 | 4.02 (3.75–4.32) | 3.80 (3.46–4.26) | 6.15 (5.58–7.06) | 9.23 (8.11–10.1) | 10.9 (9.52–14.9) | 1,287
| 2009–2010 | 4.28 (3.96–4.63) | 4.00 (3.62–4.32) | 6.55 (5.98–7.14) | 11.0 (9.64–13.2) | 17.2 (13.22–4.4) | 1,468
| 2011–2012 | 4.30 (4.06–4.56) | 4.10 (3.85–4.35) | 6.68 (5.93–7.36) | 10.8 (9.77–12.4) | 14.9 (12.4–17.0) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | 4.38 (3.80–5.05) | 4.11 (3.29–4.90) | 6.25 (4.84–8.15) | 10.3 (8.00–11.8) | 12.9 (11.1–15.2) | 621
| 2005–2006 | 4.16 (3.83–4.52) | 4.00 (3.65–4.36) | 5.94 (5.40–6.49) | 8.69 (7.23–9.65) | 10.2 (9.52–13.2) | 651
| 2007–2008 | 4.34 (3.87–4.88) | 4.19 (3.66–4.83) | 6.23 (5.31–7.44) | 9.14 (8.00–11.0) | 12.1 (10.1–15.1) | 513
| 2009–2010 | 4.06 (3.63–4.54) | 3.95 (3.33–4.44) | 6.32 (5.36–7.10) | 9.23 (8.10–10.6) | 11.7 (10.2–14.8) | 618
| 2011–2012 | 4.12 (3.83–4.44) | 4.10 (3.43–4.59) | 5.77 (5.29–6.37) | 8.06 (7.49–9.54) | 10.5 (8.70–14.8) | 317
Non-Hispanic blacks | 2003–2004 | 3.08 (2.69–3.52) | 2.86 (2.60–3.24) | 4.34 (3.82–5.05) | 7.81 (5.82–9.45) | 10.4 (7.61–16.9) | 725
| 2005–2006 | 3.08 (2.70–3.52) | 2.91 (2.52–3.32) | 4.21 (3.75–4.91) | 7.33 (5.40–10.7) | 11.6 (7.66–17.9) | 695
| 2007–2008 | 3.08 (2.87–3.31) | 2.77 (2.56–3.13) | 4.74 (4.31–5.22) | 7.29 (6.58–8.26) | 9.67 (8.26–11.0) | 586
| 2009–2010 | 3.26 (2.90–3.66) | 2.86 (2.47–3.34) | 5.10 (4.43–6.06) | 10.0 (7.39–11.7) | 13.1 (11.1–15.2) | 545
| 2011–2012 | 3.16 (2.66–3.74) | 3.05 (2.41–3.67) | 4.98 (4.01–6.08) | 8.27 (6.68–9.70) | 11.3 (8.87–13.7) | 672
Non-Hispanic whites | 2003–2004 | 3.44 (2.97–3.98) | 3.17 (2.80–3.73) | 5.16 (4.03–6.49) | 8.00 (6.32–10.9) | 11.1 (8.00–15.4) | 1,078
| 2005–2006 | 3.82 (3.47–4.21) | 3.64 (3.30–3.93) | 5.71 (4.90–6.51) | 9.23 (7.26–10.6) | 11.6 (9.93–13.9) | 1,050
| 2007–2008 | 3.62 (3.38–3.87) | 3.48 (3.20–3.76) | 5.38 (4.95–5.80) | 8.00 (7.28–8.86) | 10.0 (8.96–11.1) | 1,063
| 2009–2010 | 3.58 (3.36–3.81) | 3.31 (3.09–3.49) | 5.30 (4.87–5.75) | 8.12 (7.06–9.21) | 11.5 (9.43–14.3) | 1,226
| 2011–2012 | 3.68 (3.44–3.93) | 3.47 (3.31–3.63) | 5.32 (5.04–5.93) | 9.07 (7.47–10.3) | 11.5 (9.87–13.1) | 824

CI = confidence interval

Source: CDC 2014

Table 6-16 Geometric Mean and Selected Percentiles of Urinary Monomethyl- arsonic Acid (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | 1.20 (1.00–1.30) | 1.90 (1.60–2.10) | 2.40 (2.00–2.80) | 2,567
| 2005–2006 | * | <LOD | 1.19 (1.05–1.34) | 1.72 (1.51–1.94) | 2.12 (1.79–2.70) | 2,588
| 2007–2008 | * | <LOD | 1.11 (1.00–1.20) | 1.61 (1.51–1.69) | 2.09 (1.91–2.26) | 2,576
| 2009–2010 | * | <LOD | 1.02 (.920–1.10) | 1.64 (1.41–1.83) | 2.01 (1.82–2.28) | 2,871
| 2011–2012 | * | <LOD | <LOD | 1.36 (1.17–1.55) | 1.83 (1.57–2.07) | 2,517
Age group
6–11 years | 2003–2004 | * | <LOD | 1.00 (<LOD-1.40) | 1.80 (1.30–2.60) | 2.30 (1.70–2.90) | 292
| 2005–2006 | * | <LOD | 1.03 (<LOD-1.37) | 1.54 (1.37–2.12) | 2.12 (1.51–2.73) | 354
| 2007–2008 | * | <LOD | 1.05 (<LOD-1.28) | 1.60 (1.32–1.83) | 2.04 (1.64–2.86) | 390
| 2009–2010 | * | <LOD | <LOD | 1.38 (1.00–1.84) | 1.81 (1.26–2.13) | 380
| 2011–2012 | * | <LOD | <LOD | 1.21 (0.970–1.40) | 1.42 (1.24–1.54) | 401
12–19 years | 2003–2004 | * | <LOD | 1.50 (1.10–1.80) | 2.20 (1.70–3.00) | 2.90 (2.20–3.60) | 728
| 2005–2006 | * | <LOD | 1.31 (1.09–1.46) | 1.99 (1.62–2.23) | 2.41 (2.04–2.89) | 703
| 2007–2008 | * | <LOD | 1.26 (1.11–1.35) | 1.83 (1.54–2.22) | 2.31 (1.87–2.90) | 366
| 2009–2010 | * | <LOD | 1.10 (0.910–1.25) | 1.62 (1.33–1.92) | 2.03 (1.74–2.30) | 456
≥20 years | 2003–2004 | * | <LOD | 1.20 (1.00–1.30) | 1.80 (1.50–2.10) | 2.30 (2.00–2.60) | 1,547
| 2005–2006 | * | <LOD | 1.20 (1.05–1.33) | 1.70 (1.48–1.90) | 2.06 (1.74–2.75) | 1,531
| 2007–2008 | * | <LOD | 1.08 (0.970–1.17) | 1.58 (1.44–1.71) | 1.98 (1.82–2.21) | 1,820
| 2009–2010 | * | <LOD | 1.02 (0.930–1.11) | 1.65 (1.42–1.86) | 2.03 (1.81–2.35) | 2,035
| 2011–2012 | * | <LOD | <LOD | 1.41 (1.15–1.67) | 1.88 (1.58–2.08) | 1,724
Gender
Males | 2003–2004 | * | <LOD | 1.30 (1.10–1.60) | 2.00 (1.80–2.40) | 2.60 (2.10–3.00) | 1,283
| 2005–2006 | * | <LOD | 1.31 (1.12–1.49) | 1.79 (1.57–2.09) | 2.23 (1.85–2.86) | 1,276
| 2007–2008 | * | <LOD | 1.24 (1.13–1.35) | 1.78 (1.63–1.94) | 2.33 (1.97–2.71) | 1,289
| 2009–2010 | * | <LOD | 1.07 (0.970–1.23) | 1.77 (1.47–2.01) | 2.19 (1.83–2.68) | 1,403
| 2011–2012 | * | <LOD | 0.900 (<LOD-1.09) | 1.28 (1.09–1.57) | 1.59 (1.26–3.30) | 392
Females | 2003–2004 | * | <LOD | 1.00 (<LOD-1.20) | 1.60 (1.30–1.90) | 2.10 (1.70–2.60) | 1,284
| 2005–2006 | * | <LOD | 1.08 (0.920–1.24) | 1.57 (1.36–1.90) | 2.04 (1.67–2.50) | 1,312
| 2007–2008 | * | <LOD | 0.970 (<LOD-1.06) | 1.42 (1.30–1.57) | 1.81 (1.68–1.90) | 1,287
| 2009–2010 | * | <LOD | 0.950 (<LOD-1.06) | 1.52 (1.27–1.74) | 1.89 (1.66–2.12) | 1,468
| 2011–2012 | * | <LOD | <LOD | 1.15 (1.02–1.40) | 1.57 (1.41–1.79) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | 1.50 (1.20–1.90) | 2.20 (1.70–2.80) | 2.80 (2.00–4.40) | 621
| 2005–2006 | * | <LOD | 1.19 (1.10–1.32) | 1.73 (1.51–1.97) | 2.04 (1.67–2.51) | 651
| 2007–2008 | * | <LOD | 1.22 (1.02–1.35) | 1.69 (1.43–2.12) | 2.32 (1.75–2.85) | 513
| 2009–2010 | * | <LOD | 1.02 (<LOD-1.37) | 1.65 (1.38–1.90) | 2.02 (1.65–2.33) | 618
| 2011–2012 | * | <LOD | >LOD | 1.25 (1.04–1.65) | 1.85 (1.25–3.26) | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | 1.10 (<LOD-1.30) | 1.80 (1.40–2.00) | 2.20 (1.70–2.70) | 725
| 2005–2006 | * | <LOD | 1.02 (.950–1.07) | 1.35 (1.29–1.44) | 1.70 (1.50–1.88) | 695
| 2007–2008 | * | <LOD | 1.21 (1.09–1.33) | 1.79 (1.61–2.05) | 2.32 (2.15–2.63) | 586
| 2009–2010 | * | <LOD | 1.02 (<LOD-1.18) | 1.51 (1.36–1.84) | 1.88 (1.73–2.24) | 546
| 2011–2012 | * | <LOD | <LOD | 1.26 (1.01–1.55) | 1.65 (1.34–2.02) | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | 1.10 (.900–1.30) | 1.80 (1.40–2.00) | 2.10 (1.80–2.50) | 1,077
| 2005–2006 | * | <LOD | 1.22 (1.02–1.39) | 1.75 (1.42–2.12) | 2.14 (1.72–2.93) | 1,050
| 2007–2008 | * | <LOD | 1.04 (.930–1.15) | 1.50 (1.37–1.63) | 1.91 (1.69–2.09) | 1,063
| 2009–2010 | * | <LOD | 0.940 (<LOD-1.04) | 1.45 (1.24–1.76) | 1.90 (1.65–2.12) | 1,226
| 2011–2012 | * | <LOD | <LOD | 1.24 (1.03–1.49) | 1.71 (1.34–2.04) | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2014

Table 6-17 Geometric Mean and Selected Percentiles of Urinary Monomethyl- arsonic Acid (Creatinine Corrected) (in μg As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | 1.33 (1.18–1.54) | 2.22 (1.82 2.57) | 2.86 (2.40 3.53) | 2,567
| 2005–2006 | * | <LOD | 1.28 (1.14–1.52) | 2.37 (1.94–2.78) | 3.13 (2.67–3.76) | 2,588
| 2007–2008 | * | <LOD | 1.31 (1.23–1.42) | 2.24 (2.00–2.56) | 3.19 (2.78–3.58) | 2,576
| 2009–2010 | * | <LOD | 1.36 (1.25–1.45) | 2.16 (2.00–2.29) | 2.91 (2.67–3.15) | 2,870
| 2011–2012 | * | <LOD | <LOD | 2.21 (2.03–2.42) | 2.86 (2.63–3.32) | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | 1.63 (<LOD-1.81) | 2.31 (1.88–2.50) | 2.52 (2.31–3.07) | 292
| 2005–2006 | * | <LOD | 1.44 (<LOD-1.83) | 2.37 (1.65–3.20) | 3.13 (2.29–4.92) | 354
| 2007–2008 | * | <LOD | 1.69 (<LOD-2.06) | 2.46 (2.09–2.91) | 3.20 (2.56–4.32) | 390
| 2009–2010 | * | <LOD | <LOD | 2.37 (2.07–2.78) | 3.16 (2.55–3.76) | 379
| 2011–2012 | * | <LOD | <LOD | 2.55 (2.17–3.15) | 3.32 (2.52–4.50) | 401
12–19 years | 2003–2004 | * | <LOD | 1.10 (0.853–1.23) | 1.53 (1.30–1.85) | 2.07 (1.71–2.22) | 728
| 2005–2006 | * | <LOD | 1.05 (0.930–1.14) | 1.56 (1.49–1.73) | 1.97 (1.78–2.13) | 703
| 2007–2008 | * | <LOD | 0.970 (.880–1.07) | 1.45 (1.19–1.73) | 1.97 (1.49–2.34) | 366
| 2009–2010 | * | <LOD | 1.21 (1.02–1.45) | 1.98 (1.60–2.56) | 2.56 (1.94–4.57) | 456
| 2011–2012 | * | <LOD | 1.07 (<LOD-1.24) | 1.75 (1.30–2.42) | 2.52 (1.62–7.00) | 392
≥20 years | 2003–2004 | * | <LOD | 1.36 (1.18–1.58) | 2.28 (1.82–2.79) | 3.00 (2.43–3.53) | 1,547
| 2005–2006 | * | <LOD | 1.31 (1.13–1.58) | 2.46 (2.00–2.91) | 3.20 (2.78–3.81) | 1,531
| 2007–2008 | * | <LOD | 1.32 (1.23–1.45) | 2.35 (2.02–2.67) | 3.38 (2.78–3.83) | 1,820
| 2009–2010 | * | <LOD | 1.36 (1.25–1.45) | 2.18 (2.00–2.29) | 2.91 (2.78–3.20) | 2,035
| 2011–2012 | * | <LOD | <LOD | 2.25 (2.00–2.42) | 2.74 (2.52–3.32) | 1,723
Gender
Males | 2003–2004 | * | <LOD | 1.20 (1.05–1.36) | 1.88 (1.53–2.34) | 2.50 (2.07–3.45) | 1,283
| 2005–2006 | * | <LOD | 1.11 (.950–1.28) | 1.78 (1.47–2.29) | 2.46 (1.88–3.32) | 1,276
| 2007–2008 | * | <LOD | 1.18 (1.07–1.26) | 2.06 (1.85–2.34) | 2.71 (2.46–3.37) | 1,289
| 2009–2010 | * | <LOD | 1.16 (1.07–1.25) | 1.79 (1.64–1.99) | 2.29 (2.08–2.78) | 1,402
| 2011–2012 | * | <LOD | 1.13 (<LOD-1.24) | 1.72 (1.58–1.85) | 2.31 (1.92–2.67) | 1,263
Females | 2003–2004 | * | <LOD | 1.50 (<LOD-1.77) | 2.40 (1.96–2.86) | 3.00 (2.61–3.53) | 1,284
| 2005–2006 | * | <LOD | 1.58 (1.36–1.76) | 2.78 (2.29–3.20) | 3.56 (3.05–4.35) | 1,312
| 2007–2008 | * | <LOD | 1.45 (<LOD-1.60) | 2.41 (1.94–2.91) | 3.56 (2.78–4.27) | 1,287
| 2009–2010 | * | <LOD | 1.56 (<LOD-1.73) | 2.46 (2.29–2.62) | 3.37 (2.91–3.56) | 1,468
| 2011–2012 | * | <LOD | <LOD | 2.52 (2.27–2.74) | 3.32 (2.74–3.94) | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | 1.46 (1.11–1.93) | 2.30 (1.84–3.00) | 3.16 (2.40–3.85) | 621
| 2005–2006 | * | <LOD | 1.19 (1.08–1.35) | 1.92 (1.60–2.13) | 2.53 (2.06–2.91) | 651
| 2007–2008 | * | <LOD | 1.28 (1.10–1.60) | 2.27 (1.64–2.71) | 3.05 (2.35–3.76) | 513
| 2009–2010 | * | <LOD | 1.31 (<LOD-1.49) | 2.00 (1.73–2.56) | 3.05 (2.29–3.56) | 618
| 2011–2012 | * | <LOD | <LOD | 1.95 (1.54–2.25) | 2.63 (1.85–3.32) | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | 0.816 (<LOD-0.985) | 1.37 (1.14–1.61) | 1.88 (1.46–2.17) | 725
| 2005–2006 | * | <LOD | 0.790 (0.720–0.880) | 1.11 (0.980–1.34) | 1.57 (1.23–1.98) | 695
| 2007–2008 | * | <LOD | 0.920 (0.840–1.06) | 1.45 (1.33–1.73) | 2.09 (1.73–2.56) | 586
| 2009–2010 | * | <LOD | 0.970 (<LOD-1.08) | 1.73 (1.39–1.94) | 2.29 (1.83–2.91) | 545
| 2011–2012 | * | <LOD | <LOD | 1.38 (1.21–1.62) | 1.97 (1.75–2.33) | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | 1.33 (1.15–1.62) | 2.28 (1.73–2.86) | 2.86 (2.35–3.75) | 1,077
| 2005–2006 | * | <LOD | 1.35 (1.16–1.64) | 2.50 (2.00–3.05) | 3.20 (2.78–3.81) | 1,050
| 2007–2008 | * | <LOD | 1.35 (1.23–1.52) | 2.37 (2.04–2.78) | 3.37 (2.78–4.00) | 1,063
| 2009–2010 | * | <LOD | 1.36 (<LOD-1.52) | 2.21 (1.99–2.37) | 2.91 (2.67–3.20) | 1,226
| 2011–2012 | * | <LOD | >LOD | 2.33 (2.03–2.52) | 2.86 (2.52–3.50) | 824

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2014

Table 6-18 Geometric Mean and Selected Percentiles of Urinary Trimethylarsine Oxide (in μg As/L) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,871
Age group | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,517
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 380
| 2011–2012 | * | <LOD | <LOD | <LOD | 0.300 (<LOD-0.960 | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,724
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,403
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,264
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 621
Mexican Americans | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
Mexican Americans | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
Mexican Americans | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
Mexican Americans | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 725
Non-Hispanic blacks | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
Non-Hispanic blacks | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
Non-Hispanic blacks | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 546
Non-Hispanic blacks | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
Non-Hispanic whites | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
Non-Hispanic whites | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
Non-Hispanic whites | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
Non-Hispanic whites | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 825

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2014

Table 6-19 Geometric Mean and Selected Percentiles of Urinary Trimethylarsine Oxide (Creatinine Corrected) (in μ As/g of Creatinine) for the U.S. Population from the National Health and Nutrition Examination Survey (NHANES)

| Survey years | Geometric mean (95% CI) | Selected percentiles (95% CI) | | | | Sample size
| Survey years | Geometric mean (95% CI) | 50^th^ | 75^th^ | 90^th^ | 95^th^ | Sample size
Total | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 2,568
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 2,588
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 2,576
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,870
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 2,516
Age group
6–11 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 292
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 354
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 390
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 379
| 2011–2012 | * | <LOD | <LOD | <LOD | 1.06 (<LOD-1.39 | 401
12–19 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 728
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 703
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 366
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 456
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 392
≥20 years | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,548
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,531
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,820
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 2,035
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,723
Gender
Males | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,276
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,289
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,403
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,263
Females | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,284
| 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,312
| 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,287
| 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,468
| 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 1,253
Race/ethnicity
Mexican Americans | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 621
Mexican Americans | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 651
Mexican Americans | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 513
Mexican Americans | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 618
Mexican Americans | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 317
Non-Hispanic blacks | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 725
Non-Hispanic blacks | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 695
Non-Hispanic blacks | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 586
Non-Hispanic blacks | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 545
Non-Hispanic blacks | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 672
Non-Hispanic whites | 2003–2004 | * | <LOD | <LOD | <LOD | <LOD | 1,078
Non-Hispanic whites | 2005–2006 | * | <LOD | <LOD | <LOD | <LOD | 1,050
Non-Hispanic whites | 2007–2008 | * | <LOD | <LOD | <LOD | <LOD | 1,063
Non-Hispanic whites | 2009–2010 | * | <LOD | <LOD | <LOD | <LOD | 1,226
Non-Hispanic whites | 2011–2012 | * | <LOD | <LOD | <LOD | <LOD | 824

<LOD means less than the limit of detection, which may vary for some chemicals by year and by individual sample.

* Not calculated: proportion of results below limit of detection was too high to provide a valid result.

CI = confidence interval

Source: CDC 2014

MMA and DMA are excreted methylated metabolites commonly assessed to aid in evaluation of exposure (WHO 2011a). Concentrations of MMA throughout all NHANES survey years reported in the updated Fourth National report were below the detection limits of the methods (0.9 μg/L) (CDC 2014). The two highest geometric means (creatinine corrected) of DMA reported during 2009–2010 of 4.77 and 4.28 μg/g resulted from 379 samples from 6–11 year olds and 1,468 samples from female participants, respectively. Throughout all survey years, females had a higher geometric mean of DMA (creatinine corrected) than males. The age group 6–11 years had the highest mean of DMA (creatinine corrected) each period compared to 12–19- and 20-year-old groups. Mean values ranged from 4.34 to 5.07 μg/g for the 6–11-year-old age group (CDC 2014).

The NHANES data from 2003 to 2006 were analyzed to evaluate the correlation between rice consumption and concentrations of total urinary arsenic and urinary DMA in 3,027 and 2,653 U.S. adult participants, respectively, 20–85 years of age (Wei et al. 2014). The study took into consideration factors such as demographic variables, fish consumption, and drinking water. The study found a distinct relationship of increased total urinary arsenic and urinary DMA concentrations (both creatinine corrected) of participants who consumed rice more than twice per week compared to a reference group. Participants who consumed rice and grain less than twice per week had mean levels of 2.21 (total arsenic) μg/g creatinine and 1.32 (DMA) μg/g creatinine. Participants who consumed rice and grain at least twice per week had mean total arsenic levels of 2.42 μg/g creatinine and 1.58 (DMA) μg/g creatinine.

A Washington State Environmental Biomonitoring Survey was conducted with 172 participants and tap water samples from 82 households in South Whidbey from July to September 2011. Results indicated that the average urine levels (28.4 μg/g creatinine corrected) for total arsenic of the participants were higher than statewide and national levels. Urine arsenic levels were above the CDC’s reporting level (50 μg/L) among 28% of the participants and 54% of the water samples were above the EPA’s drinking water standard (MCL=10 μg/L) (WA DOH 2015).

In an ongoing study by the Maternal and Infant Environmental Exposure Project measures chemical exposures in pregnant women at the San Francisco General Hospital, a geometric mean of 7.71 μg/L arsenic was reported for 89 urine samples from pregnant women collected from 2010 to 2011 (LOD=0.158 μg/L) (OEHHA 2015).

In 2009, 229 pregnant women were evaluated for urinary arsenic excretion and recent rice consumption in an area of the United States with known elevated levels of arsenic in well waters (Gilbert-Diamond et al. 2011). A multiple regression model accounting for age, urinary creatinine, rice consumption, and water exposure was employed. Of the 229 pregnant women, 73 consumed rice and 156 did not consume rice. A range of total urinary arsenic levels from 2.86 to 8.72 μg/L (median=5.27 μg/L) was detected for the rice-consuming women, while 1.64–5.39 μg/L (median=3.38 μg/L) was detected for women who did not eat rice. The women who ate rice had a range of inorganic arsenic between 0.13 and 0.51 μg/L (median=0.28 μg/L), while the non-rice eaters had a range of inorganic arsenic between 0.13 and 0.36 μg/L (median=0.21 μg/L).

Occupational exposure to arsenic in the semiconductor manufacturing industry was reviewed (Park et al. 2010). A statistical analysis of air and wipe samples was used to classify fabrication workers with respect to observed arsenic levels in their surroundings. The study review concluded that people involved with maintenance work have higher potential for exposure than people in charge of routine production work. Maintenance processes result in arsenic-containing compounds being deposited on surrounding surfaces. These particles may become airborne or may accumulate on surfaces increasing the potential for exposure. Afridi et al. (2011) collected whole blood, urine, and hair samples from 42 steel mill production workers and 33 steel mill quality control workers aged 25–55 years who were affected by paralysis, and 62 non-paralyzed steel mill workers. A control group of 75 non-paralyzed male subjects was also included. Mean arsenic concentrations in hair samples from the control group, non-paralyzed steel mill workers, paralyzed quality control workers, and paralyzed production workers were 1.06±0.09, 1.67±0.17, 2.89±0.3, and 3.99±0.5 μg/g, respectively. Mean arsenic concentrations in whole blood samples from the control group, non-paralyzed steel mill workers, paralyzed quality control workers, and paralyzed production workers were 1.7±0.4, 2.56±0.3, 4.07±0.38, and 5.48±0.39 μg/L, respectively. Mean arsenic concentrations in urine samples from the control group, non-paralyzed steel mill workers, paralyzed quality control workers, and paralyzed production workers were 4.4±1.5, 5.3±0.84, 8.7±01.7, and 11.5±1.3 μg/L, respectively.

## 6.6 EXPOSURES OF CHILDREN

The NHANES data from 2003 to 2008 were analyzed to evaluate the correlation between rice consumption and dietary arsenic exposure in 2,323 participants under 18 years of age (Davis et al. 2012). The study took into consideration factors such as fish consumption and metabolic rates according to age. Results indicated that total urinary arsenic and urinary DMA concentrations were higher among the participants who had reported consumption of ≥0.25 cups of rice within 24 hours of the sampling time. The total urinary arsenic concentration of children who had consumed rice was 8.9 μg/L, while the concentration was 5.5 μg/L among children who had not (Davis et al. 2012). The evaluation suggests that rice consumption has the potential to increase exposure to arsenic for U.S. children.

Munera-Picazo et al. (2014b) investigated Spanish gluten-free food products intended for young children and found levels of arsenic as high as 256 μg/kg. Rice-based pasta samples had the highest concentration of inorganic arsenic. Control samples for each food group had levels reported as not detected or below the limit of quantification for the method (6 μg/kg). Foods with a higher percentage of rice content typically contained higher levels of total arsenic and inorganic arsenic. A daily intake of inorganic arsenic for children ≤5 years old was found to range between 0.61 and 0.78 μg/kg body weight.

Wasserman et al. (2014) investigated arsenic exposure and intelligence in 272 children residing in Maine with an average age of 9.67 years. In 248 of the children, a notable correlation of nail arsenic concentrations and arsenic concentrations in household tap water was found. However, it was added that nail concentrations may be less accurate for children due to rapid growth of other systems. Measured household kitchen tap water had an average value of 9.88 μg/L, almost a third of samples exceeded the EPA MCL (10 μg/L). The studied concluded that children residing in homes with arsenic water concentration ≥5 μg/L demonstrated reduced Full Scale IQ scores compared to households with concentrations <5 μg/L.

A maximum amount of 4 μg arsenic was detected in hand washing samples for 66 children from eight playgrounds. Children’s hands were rinsed immediately after playing on playground equipment constructed with CCA-treated wood in Edmonton, Alberta (Hamula et al. 2006).

Exposure to arsenic via contaminated soils has been investigated. Pearce et al. (2010) analyzed the concentration of arsenic in children's toenail clippings and household soils from areas with a history of gold mining activity in Victoria, Australia. The arsenic concentrations in children’s toenails ranged from 0.15 to 2.1 μg/g; the geometric mean was 0.49 μg/g. The arsenic concentrations in soil ranged from 3.3 to 130 μg/g; the geometric mean was 11.5 μg/g. The distribution of arsenic in the nail clippings suggested periodic exposure patterns and a positive correlation between the nail concentrations, and soil concentrations indicated that contaminated soils can contribute to arsenic uptake by children.

Tsuji et al. (2005) analyzed total arsenic and arsenic species in urine from 77 children <7 years old, in urine from 362 subjects >7 years old, and in toenails from 67 subjects >7 years old living in Middleport, New York. The overall range of total arsenic detected in urine was 2.1–773 μg/L. The arsenic concentrations in toenail samples were <1 mg/kg. Household soil and dust arsenic levels were also measured; the arsenic concentration levels averaged 18.8 and 10.6 mg/kg, respectively.

Children may be exposed to arsenic via consumption of apple juices. Exposure of children to arsenic from apple juice consumption was investigated (FDA 2013a). Based on data from NHANES, children aged 0–6 years consume an estimated 4.1 g/kg/day of apple juice. Monitoring data from the Toxic Elements Program (TEP) and an apple juice survey (AJS) were evaluated. Total arsenic concentrations are reported noting that levels of organic arsenic species were below the level of quantification, suggesting that inorganic arsenic accounts for the arsenic present in the samples. For TEP survey years 2008–2011, there were 153 samples ranging in concentrations ranging from not detected up to 45 ppb (0.045 μg/g) with an average concentration of 4.7 ppb (0.0047 μg/g). The average total arsenic concentrations reported for 2008, 2009, 2010, and 2011 were 8.8, 7.8, 6.6, and 2.7 ppb, respectively (0.0088, 0.0078, 0.0066, and 0.0027 μg/g). For AJS survey year 2011, there were 94 samples ranging in concentrations from not detected up to 36 ppb (0.036 μg/g), with an average concentration of 4.4 ppb (0.0044 μg/g).

## 6.7 POPULATIONS WITH POTENTIALLY HIGH EXPOSURES

An ongoing study by the Firefighter Occupational Exposures Project measures chemical exposures in firefighters in Southern California. A geometric mean of 10.8 μg/L arsenic was reported for 101 urine samples collected from 2010 to 2011; the detection frequency was 100% (LOD=0.158 μg/L) (OEHHA 2015).

Medicinal use of arsenite results in direct exposure of arsenic for patients who are administered this type of therapy. A study by Nicolis et al. (2009) analyzed the hair of two patients receiving arsenic trioxide treatments. High arsenic levels in the patient’s hair directly corresponded to treatment and decreased accordingly when treatment ceased.

Children and adults with celiac disease who consume a gluten-free diet tend to eat more rice-based foods; additionally, people who reside with children or adults with celiac disease may consume a similar diet. Food manufactured for people with celiac disease often contains rice and elevated levels of inorganic arsenic (Munera-Picazo et al. 2014a, 2014b).

Urine samples from 322 residents of an area in France with naturally high arsenic levels in soil were analyzed for arsenic (Fillol et al. 2010). The residents included adults and children >7 years of age. Urinary arsenic concentrations ranged from below the limit of quantification to 28.2 μg/g creatinine and a geometric mean arsenic concentration of 4.4 μg/g creatinine. Two urine samples contained arsenate, half of the samples contained arsenite, MMA was in 19% of the samples, and DMA was the only arsenic species detected in all samples containing arsenic.

## 6.8 ADEQUACY OF THE DATA BASE

### 6.8.1 Identification of Data Needs

Children are exposed to arsenic by the same exposure routes as adults (e.g., ingestion of food and water) as well as possible exposure in utero. Data from the NHANES survey discussed in Section 6.5 indicated that higher urinary levels of DMA, a metabolite of arsenic exposure, were typically observed in children 6–11 years old as compared to adults. Continued monitoring of levels in children is needed.

Continued species-specific monitoring of rice, soil, and water sources would add value to exposure assessments.

### 6.8.2 Ongoing Studies

Biomonitoring programs in United States include the Minnesota Biomonitoring Program (http://www.health.state.mn.us/biomonitoring), Rocky Mountain Biomonitoring Consortium (https://www.colorado.gov/pacific/cdphe/rocky-mountain-biomonitoring-consortium), California Environmental Contaminant Biomonitoring Program (http://www.biomonitoring.ca.gov/), and Washington Environmental Biomonitoring Survey (http://www.doh.wa.gov/DataandStatisticalReports/EnvironmentalHealth/Biomonitoring).