# 5 PRODUCTION, IMPORT/EXPORT, USE, AND DISPOSAL

## 5.1 PRODUCTION

U.S. production of metallic arsenic and arsenic trioxide ceased in 1985; limited quantities of metallic arsenic, however, may be recovered from gallium arsenide semiconductor scrap (USGS 2014).

## 5.2 IMPORT/EXPORT

China was the major import source for elemental arsenic during the years 2009–2012, supplying 87%, followed by Japan (12%) and others (1%). Morocco was the major import source for arsenic trioxide during the years 2009–2012, supplying 67%, followed by China (20%), Belgium (12%), and others (1%) (USGS 2014).

U.S. exports of elemental arsenic were 354 metric tons in 2009, 481 metric tons in 2010, 705 metric tons in 2011, and 439 metric tons in 2012, and are estimated to be 1,750 metric tons in 2013 (USGS 2014).

## 5.3 USE

According to the National Pesticide Information Retrieval System (NPIRS), arsenic acid, arsenic pentoxide, and sodium methanearsonate are currently registered as pesticides in the United States; there are no active registrants listed for arsenic trioxide, calcium arsenate, lead arsenate, sodium arsenite, arsanilic acid, dimethylarsinic acid, disodium methanearsonate, methanearsonic acid, or sodium dimethylarsinate (NPIRS 2015).

The EPA issued a reregistration eligibility decision (RED) for wood preservatives containing chromated arsenicals, including chromated copper arsenate (CCA) and ammoniacal copper arsenate (ACA) (EPA 2008). Based on the results of the RED, the EPA concluded that current registered uses of chromated arsenicals are eligible for reregistration upon meeting specific risk mitigation procedures, proper end-use, and labeling. Active ingredients containing arsenic evaluated in the assessment include arsenic acid and arsenic oxide.

Gallium-arsenide (GaAs) is used in third- and fourth-generation “smartphones” (USGS 2014).

## 5.4 DISPOSAL

As of February 2014, both metallic arsenic from gallium arsenide semiconductor manufacturing and arsenic contained in the process water of wood treatment plants using CCA were recycled (USGS 2014). However, metallic arsenic was not recovered during metal recycling of electronic circuit boards, relays, and switches, which may contain arsenic, nor was metallic arsenic recovered from arsenic-containing residues or dust generated at nonferrous smelters in the United States (USGS 2014).

Wastes generated from the treatment of wood are regulated under the Resource Conservation and Recovery Act (RCRA). Waste water generated from wood preservation is listed as Hazardous Waste number F035 (EPA 2008).

CCA-treated wood is commonly disposed of in construction or demolition landfills, municipal solid waste landfills, or industrial nonhazardous waste landfills. Existing federal hazardous waste regulations require testing procedures to evaluate if a representative sample of the waste leaches arsenic above a certain threshold concentration. This value determines whether wastes containing arsenic are defined as hazardous waste. Some CCA-treated wood may meet this definition; however, because of an existing exemption by the federal register (40 CFR 261.4(b)(9)), CCA-treated wood is generally not defined as a hazardous waste (EPA 2008). Disposal may occur with household trash, where the disposal would be defined by state and local waste management authorities (EPA 2008).