# CHAPTER 8 REFERENCES

+ Cited in supplemental document

Adams JB, Holloway CE, George F, 2006. Analyses of toxic metals and essential minerals in the hair of Arizona children with autism and associated conditions, and their mothers. Biol Trace Elem Res 110(3):193–209. http://doi.org/10.1385/BTER:110:3:193. 16845157
Adams JB, Audhya T, McDonough-Means S, 2013. Toxicological status of children with autism vs. neurotypical children and the association with autism severity. Biol Trace Elem Res 151(2):171–180. http://doi.org/10.1007/s12011-012-9551-1. 23192845
+Ainsworth N. 1988. Distribution and biological effects of antimony in contaminated grasslands. Sunderland Polytechnic, University of Liverpool, Liverpool, U.K., 152–159.
Ainsworth N, Cooke JA, Johnson MS. 1990. Distribution of antimony in contaminated grassland: 2. Small mammals and invertebrates. Environ Pollut 65:79–87.15092279
Ainsworth N, Cooke JA, Johnson MS. 1991. Behavior and toxicity of antimony in the short-tailed field vole (Microtus agrestis). Ecotoxicol Environ Saf 21(2):165–170.2065629
AlKhawajah AM, Jain S, Larbi EB. 1996. Effects of antimony compounds on foetal development in rats. J Appl Anim Res 10(1):15–24.
AlKhawajah A, Larbi EB, Jain S, 1992. Subacute toxicity of pentavalent antimony compounds in rats. Hum Exp Toxicol 11(4):283–288.1354978
Alvarez M, Malecot CO, Gannier F, 2005. Antimony-induced cardiomyopathy in guinea-pig and protection by L-carnitine. Br J Pharmacol 144(1):17–27. http://doi.org/10.1038/sj.bjp.0706030. 15644865
Amereih S, Meisel T, Scholger R, 2005. Antimony speciation in soil samples along two Austrian motorways by HPLC-ID-ICP-MS. J Environ Monit 7(12):1200–1206. http://doi.org/10.1039/b510321e. 16307072
Anawar HM, Freitas MC, Canha N, 2011. Arsenic, antimony, and other trace element contamination in a mine tailings affected area and uptake by tolerant plant species. Environ Geochem Health 33(4):353–362. http://doi.org/10.1007/s10653-011-9378-2. 21424773
Andersen EM, Cruz-Saldarriaga M, Llanos-Cuentas A, 2005. Comparison of meglumine antimoniate and pentamidine for Peruvian cutaneous leishmaniasis. Am J Trop Med Hyg 72(2):133–137.15741547
Andreae MO. 1983. The determination of the chemical species of the "hydribe elements" (arsenic, antimony, tin and germanium) in seawater: Methodogy and results. In: Wong CS, Boyle E, Bruland KW, , eds. Trace metal in sea water. New York, NY: Plenum Press, 1–19.
Andreae MO, Froelich PN. 1984. Arsenic, antimony, germanium biogeochemistry in the Baltic Sea. Tellus B 36B:101–117.
+Angrisani E, Lampa E, Lisa M, 1988. Vasomotor reactivity and postnatal exposure to antimony trichloride. Curr Ther Res Clin Exp 43(1):153–159.
Arimoto R, Duce RA. 1987. Air-sea transfer of trace elements. In: Sources and fates of aquatic pollutants. First ed. Washington DC: American Chemical Society, 131–150.
Asakura K, Satoh H, Chiba M, 2009. Genotoxicity studies of heavy metals: Lead, bismuth, indium, silver and antimony. J Occup Health 51(6):498–512.19851040
Asta MP, Kirk Nordstrom D, Blaine McCleskey R. 2012. Simultaneous oxidation of arsenic and antimony at low and circumneutral pH, with and without microbial catalysis. Appl Geochem 27(1):281–291. http://doi.org/http://dx.doi.org/10.1016/j.apgeochem.2011.09.002.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register. Agency for Toxic Substances and Disease Registry. Vol. 54, 37618–37634.
ATSDR. 2017. Antimony. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry, Centers for Disease Control and Prevention. http://www.atsdr.cdc.gov/SPL/resources/index.html. December 13, 2018.
Austin LS, Millward GE. 1988. Simulated effects of tropospheric emissions on the global antimony cycle. Atmos Environ 22(7):1395–1403.
Avento JM, Touval I. 1980. Flame retardants (antimony). In: Kirk-Othmer encyclopedia of chemical technology. Vol. 10, 3rd ed. New York, NY: John Wiley and Sons, Inc., 355–356.
Baceva K, Stafilov T, Matevski V. 2014. Bioaccumulation of heavy metals by endemic Viola species from the soil in the vicinity of the As-Sb-Tl mine "Allchar" Republic of Macedonia. Int J Phytoremediation 16(4):347–365. http://doi.org/10.1080/15226514.2013.783551. 24912236
Bailly R, Lauwerys R, Buchet JP, 1991. Experimental and human studies on antimony metabolism: Their relevance for the biological monitoring of workers exposed to inorganic antimony. Br J Ind Med 48(2):93–97.1998614
Bannon DI, Drexler JW, Fent GM, 2009. Evaluation of small arms range soils for metal contamination and lead bioavailability. Environ Sci Technol 43(24):9071–9076. http://doi.org/10.1021/es901834h. 20000496
Barbieri FL, Gardon J, Ruiz-Castell M, 2016. Toxic trace elements in maternal and cord blood and social determinants in a Bolivian mining city. Int J Environ Health Res 26(2):158–174. http://doi.org/10.1080/09603123.2015.1061114. 26179629
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barrera C, Lopez S, Aguilar L, 2016. Pentavalent antimony uptake pathway through erythrocyte membranes: Molecular and atomic fluorescence approaches. Anal Bioanal Chem 408(11):2937–2944. http://doi.org/10.1007/s00216-015-9188-y. 26586161
+Basinger M, Jones M. 1981. Structural requirements for chelate antidotal efficacy in acute antimony (III) intoxication. Res Commun Chem Pathol Pharmacol 32(2):355–363.6264554
+Belyaeva AP. 1967. [The effect of antimony on reproduction.]. Gig Tr Prof Zabol 11:32–37. (Russian)
Belzile N, Chen Y, Filella M. 2011. Human exposure to antimony: I. Sources and intake. Crit Rev Environ Sci 41:1309–1373.
Bentley R, Chasteen TG. 2002. Microbial methylation of metalloids: Arsenic, antimony, and bismuth. Microbiol Mol Biol Rev 66(2):250–271.12040126
+Berman JD, Gallalee JF, Gallalee JV. 1988. Pharmacokinetics of pentavalent antimony (Pentostam) in hamsters. Am J Trop Med Hyg 39:41–45.2840834
+Bio/Dynamics. 1985. A three month inhalation toxicity study of antimony trioxide in the rat followed by a recovery period. Prepared by Bio/dynamics, Inc., E. Millstone, NJ for the Antimony Oxide Industry Association, Washington, DC.
+Bio/Dynamics. 1990. A one year inhalation toxicity study of antimony trioxide in the rat (with a one year recovery period); Volume III. Project No. 83–7647.
Blaurock-Busch E, Amin OR, Rabah T. 2011. Heavy metals and trace elements in hair and urine of a sample of Arab children with autistic spectrum disorder. Maedica (Buchar) 6(4):247–257. http://www.ncbi.nlm.nih.gov/pubmed/22879836.
Bloom MS, Buck Louis GM, Sundaram R, 2015. Birth outcomes and background exposures to select elements, the Longitudinal Investigation of Fertility and the Environment (LIFE). Environ Res 138:118–129. http://doi.org/10.1016/j.envres.2015.01.008. 25707016
Bodek I, Lyman WJ, Reehl W, 1988. Environmental inorganic chemistry: Properties, processes, and estimation methods. New York, NY: Pergamon Press., 7.1–1.
Boex TJ, Padgham C, Nurse PA, 1998. Antimony and sudden infant death syndrome. Lancet 351(9109):1102–1103.
+Bradley WR, Fredrick WG. 1941. The toxicity of antimony. Ind Med 10:15–22.
+Brieger H, Semisch CW, Stasney J, 1954. Industrial antimony poisoning. Ind Med Surg:521–523.13211006
+Bromberger-Barnea B, Stephens NL. 1965. Effects of antimony on myocardial performance in isolated and intact canine hearts. Am Ind Hyg Assoc J 26:404–408.5854678
Carapella SC. 1978. Antimony and antimony alloys. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 3. 3rd ed. New York, NY: John Wiley and Sons, Inc., 96–105.
Cavallo D, Iavicoli I, Setini A, 2002. Genotoxic risk and oxidative DNA damage in workers exposed to antimony trioxide. Environ Mol Mutagen 40(3):184–189. http://doi.org/10.1002/em.10102. 12355552
+CDC. 2019. Fourth national report on human exposure to environmental chemicals, updated tables. January 2019. Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. 17–22, 27. https://www.cdc.gov/exposurereport/. May 5, 2019.
Chapa-Martinez CA, Hinojosa-Reyes L, Hernandez-Ramirez A, 2016. An evaluation of the migration of antimony from polyethylene terephthalate (PET) plastic used for bottled drinking water. Sci Total Environ 565:511–518. http://doi.org/10.1016/j.scitotenv.2016.04.184. 27192700
Charles River Laboratories. 2006. Clinical laboratory parameters for Crl:CD(SD) rats. March, 2006. http://www.criver.com/files/pdfs/rms/cd/rm_rm_r_clinical_parameters_cd_rat_06.aspx. Sepember 13, 2016.
Chen YW, Deng TL, Filella M, 2003. Distribution and early diagenesis of antimony species in sediments and porewaters of freshwater lakes. Environ Sci Technol 37(6):1163–1168.12680670
+Chulay JD, Fleckenstein L, Smith DH. 1988. Pharmacokinetics of antimony during treatment of visceral leishmaniasis with sodium stibogluconate or meglumine antimoniate. Trans R Soc Trop Med Hyg 82:69–72.2845611
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Coelho DR, De-Carvalho RR, Rocha RC, 2014a. Effects of in utero and lactational exposure to SbV on rat neurobehavioral development and fertility. Reprod Toxicol 50:98–107. http://doi.org/10.1016/j.reprotox.2014.10.016. 25461908
Coelho DR, Miranda ES, Saint’Pierre TD, 2014b. Tissue distribution of residual antimony in rats treated with multiple doses of meglumine antimoniate. Mem Inst Oswaldo Cruz 109(4):420–427.25075781
+Colak EH, Yomralioglu T, Nisanci R, 2015. Geostatistical analysis of the relationship between heavy metals in drinking water and cancer incidence in residential areas in the Black Sea region of Turkey. J Environ Health 77(6):86–93.25619041
Cole RH, Frederick RE, Healy RP, 1984. Preliminary findings of the priority pollutant monitoring project of the National Urban Runoff Program. J Water Pollut Control Fed 56(7):898–908.
+Cooper DA, Pendergrass EP, Vorwald AJ, 1968. Pneumoconiosis among workers in an antimony industry. Am J Roentgenol Radium Ther Nucl Med 103:495–601.
+Cotten MD, Logan ME. 1966. Effects of antimony on the cardiovascular system and intestinal smooth muscle. J Pharmacol Exp Ther 151(1):7–22.5902182
Cotton FA, Wilkinson G. 1966. Nontransition elements. In: Advanced inorganic chemistry. A comprehensive text. New York, NY: Interscience Publishers, 498–503.
Cruz A, Rainey PM, Herwaldt BL, 2007. Pharmacokinetics of antimony in children treated for leishmaniasis with meglumine antimoniate. J Infect Dis 195(4):602–608. http://doi.org/10.1086/510860. 17230422
Cullen A, Kiberd B, Matthews T, 1998. Antimony in blood and urine of infants. J Clin Pathol 51(3):238–240.9659268
Cullen A, Kiberd B, Devaney D, 2000. Concentrations of antimony in infants dying from SIDS and infants dying from other causes. Arch Dis Child 82(3):244–247.10685932
Cutter GA. 1992. Kinetic controls on metalloid speciation in seawater. Mar Chem 40(1–2):65–80. http://doi.org/http://dx.doi.org/10.1016/0304-4203(92)90048-F.
Dams R, Vandecasteele C, Desmet B, 1988. Element concentrations in the air of an indoor shooting range. Sci Total Environ 77:1–13.3232073
+Dancaster CP, Duckworth WC, Matthews REP. 1966. Stokes-Adams attacks following sodium antimonylgluconate (triostam). S Afr Med J 40:1029–1030.5926116
de Doncker K, Dumarey R, Dams R, 1983. Determination of antimony in atmospheric particulate matter by hydride generation and atomic absorption spectrometry. Anal Chim Acta 153:33–40.
de la Calle-Guntinas MB, Madrid Y, Camara C. 1991. Determination of antimony(III) and antimony(V) in water by selective extraction with lactic acid-Malachite Green followed by graphite furnace atomic absorption spectrometry. Anal Chim Acta 247(1):7–12.
Dernehl CU, Stead FM, Nau CA. 1944. Arsine, stibine, and hydrogen sulfide: Accidental generation in a metal refinery. Am Ind Hyg Assoc Q 5(2):361–362. http://doi.org/10.1080/00968204409344172.
+Dernehl CU, Nau CA, Sweets HH. 1945. Animal studies on the toxicity of inhaled antimony trioxide. J Ind Hyg Toxicol 27:256–262.21007120
Dezateux C, Delves HT, Stocks J, 1997. Urinary antimony levels in infants are low and unrelated to age or passive smoking. Arch Dis Child 23(5):423–424.
Dieter MP, Jameson CW, Elwell MR, 1991. Comparative toxicity and tissue distribution of antimony potassium tartrate in rats and mice dosed by drinking water or intraperitoneal injection. J Toxicol Environ Health 34(1):51–82. http://doi.org/10.1080/15287399109531548. 1890693
DOE. 2009a. Analysis of background distributions of metals in the soil at Lawrence Berkeley National Laboratory. U.S. Department of Energy. LBNL-1782E. http://www2.lbl.gov/ehs/erp/assets/pdfs/Background%20Metals%20in%20Soil%20Report0409.pdf. March 18, 2016.
DOE. 2009b. A review of metal concentrations measured in surface soil samples collected on and around the Hanford Site. U.S. Department of Energy: 1-32. PNNL-18577. http://www.pnl.gov/main/publications/external/technical_reports/PNNL-18577.pdf. March 15, 2016.
DOE. 2018a. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/. July 26, 2018.
DOE. 2018b. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. June 2018. Oak Ridge, TN: U.S. Department of Energy. https://sp.eota.energy.gov/pac/docs/Revision_29A_Table3.pdf. July 26, 2018.
+Dorea JG, Merchan-Hamann E, Ryan DE, 1989. Retention of antimony in hair during leishmaniasis treatment. Clin Chim Acta 179:341–346.2714007
+Drummond GS, Kappas A. 1981. Potent heme-degrading action of antimony and antimony-containing parasiticidal agents. J Exp Med 153:245–246.6894611
+Dunn JT. 1928. A curious case of antimony poisoning. Analyst 53:532–533.
Dutkiewicz VA, Parekh PP, Husain L. 1987. An evaluation of regional elemental signatures relevant to the northeastern United States. Atmos Environ 21:1033–1044.
Eckel WP, Langley WD. 1988. A background-based ranking technique for assessment of elemental enrichment in soils at hazardous waste sites. Superfund ’88: Proceedings of the 9th National Conference, November 28-30, 1988. Washington, DC: The Hazardous Materials Control Research Institute.
Eckel WP, Jacob TA. 1989. Ambient concentrations of 25 "dissolved" and "total" metals in U.S. surface waters. Alexandria, VA: Viar and Company, 1–14.
+Edel J, Marafante E, Sabbioni E, 1983. Metabolic behaviour of inorganic forms of antimony in the rat. Heavy Met Environ Int Conf 4th 1:574–577.
Elinder CG, Friberg L. 1986. Antimony. In: Handbook on the toxicology of metals. Vol. II. 2nd ed. Amsterdam: Elsevier Science Publishers, 26–42.
Elliott BM, Mackay JM, Clay P, 1998. An assessment of the genetic toxicology of antimony trioxide. Mutat Res 415(1–2):109–117.9711267
EPA. 1979. Antimony. Water-related environmental fate of 129 priority pollutants. Vol. 1. Washington, DC: U.S. Environmental Protection Agency. 5-1 to 5-8. EPA440479029a.
EPA. 1980. Ambient water quality criteria for antimony. Washington, DC: U.S. Environmental Protection Agency. EPA440580020. PB91117319.
EPA. 1982. Seattle distribution system corrosion control study: Volume III: Potential for drinking water contamination from tin/antimony solder. Washington, DC: U.S. Environmental Protection Agency. EPA600282013; PB82231242.
EPA. 1983. Antimony metal, antimony trioxide, and antimony sulfide response to the Interagency Testing Committee. Federal Register. U.S. Environmental Protection Agency. 48:717–725.
EPA. 1988. Analysis of clean water act effluent guidelines pollutants: Summary of the chemicals regulated by industrial point source category. Washington DC: U.S. Environmental Protection Agency. 40 CFR Parts 400-475.
EPA. 1989. Antimony. Acquire database. Duluth, MN: U.S. Environmental Protection Agency, 1–11.
EPA. 2000. National air pollutant emission trends, 1900–1998. U.S. Environmental Protection Agency. EPA454R00002. http://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000ETJA.txt. March 17, 2016.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency, Office of Environmental Information. EPA260B05001.
EPA. 2009. National primary drinking water regulations. Washington, DC: U.S. Environmental Protection Agency. EPA816F090004. http://water.epa.gov/drink/contaminants/upload/mcl-2.pdf. March 4, 2015.
EPA. 2015. Air quality system (AQS). Data files. Annual summary data. U.S. Environmental Protection Agency. http://aqsdr1.epa.gov/aqsweb/aqstmp/airdata/download_files.html. December 2, 2015.
EPA. 2016a. Air emissions inventories. 2011 National Emissions Inventory (NEI) data. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2011-national-emissions-inventory-nei-data. March 21, 2016.
EPA. 2016b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2016-03/documents/compiled_aegl_update_.pdf. September 8, 2017.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. July 25, 2018.
EPA. 2018b. About Acute Exposure Guideline Levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
FDA. 2017. Subpart B - Requirements for specific standardized beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. Washington, DC: https://www.gpo.gov/fdsys/pkg/CFR-2017-title21-vol2/pdf/CFR-2017-title21-vol2-sec165-110.pdf. September 7, 2017.
FDA. 2018. Substances Added to Food. Washington, DC: U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances. July 26, 2018.
+Felicetti SW, Thomas RG, McClellan RO. 1974a. Retention of inhaled antimony-124 in the beagle dog as a function of temperature of aerosol formation. Health Phys 26:525–531.
+Felicetti SW, Thomas RG, McClellan RO. 1974b. Metabolism of two valence states of inhaled antimony in hamsters. Am Ind Hyg Assoc J 35:292–300.4208632
Fido A, Al-Saad S. 2005. Toxic trace elements in the hair of children with autism. Autism 9(3):290–298. http://doi.org/10.1177/1362361305053255. 15937043
Filella M, Belzile N, Chen Y-W. 2002. Antimony in the environment: A review focused on natural waters: II. Relevant solution chemistry. Earth Sci Rev 59(1–4):265–285. http://doi.org/http://dx.doi.org/10.1016/S0012-8252(02)00089-2.
Filella M, Williams PA, Belzile N. 2009a. Antimony in the environment: Knowns and unknowns. Environ Chem 6(2):95–105. http://doi.org/10.1071/EN09007.
Filella M, Philippo S, Belzile N, 2009b. Natural attenuation processes applying to antimony: A study in the abandoned antimony mine in Goesdorf, Luxembourg. Sci Total Environ 407(24):6205–6216. http://doi.org/http://dx.doi.org/10.1016/j.scitotenv.2009.08.027. 19775729
Fleming AJ. 1938. The toxicity of antimony trioxide. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS215027.
Fløtre CH, Varsi K, Helm T, 2017. Predictors of mercury, lead, cadmium and antimony status in Norwegian never-pregnant women of fertile age. PLoS ONE 12(12):e0189169. http://doi.org/10.1371/journal.pone.0189169. 29206878
Freedman LD, Doak GO, Long GG. 1978. Antimony compounds. In: Kirk-Othmer encyclopedia of chemical technology. Vol. 3. 3rd ed. New York, NY: John Wiley and Sons, Inc., 105–128.
Friedrich K, Vieira FA, Porrozzi R, 2012. Disposition of antimony in rhesus monkeys infected with Leishmania braziliensis and treated with meglumine antimoniate. J Toxicol Environ Health A 75(2):63–75. http://doi.org/10.1080/15287394.2012.624826. 22129235
Garboś S, Bulska E, Hulanicki A, 2000. Determination of total antimony and antimony(V) by inductively coupled plasma mass spectrometry after selective separation of antimony(III) by solvent extraction with N-benzoyl-N-phenylhydroxylamine. Spectrochim Acta Part B At Spectrosc 55(7):795–802. http://doi.org/10.1016/s0584-8547(00)00212-3.
Gebel T, Claussen K, Dunkelberg H. 1998b. Human biomonitoring of antimony. Int Arch Occup Environ Health 71(3):221–224.9591164
Gebel T, Birkenkamp P, Luthin S, 1998a. Arsenic(III), but not antimony(III), induces DNA-protein crosslinks. Anticancer Res 18(6A):4253–4257.9891475
+Gellhorn A, van Dyke HB. 1946. The correlation between distribution of antimony in tissues and chemotherapeutic effect in experimental leishmaniasis. J Pharmacol Exp Ther 88(2):162–176.20274538
+Gellhorn A, Tupikova NA, van DHB. 1946. The tissue-distribution and excretion of four organic anitmonials after single or repeated administration to normal hamsters. J Pharmacol Exp Ther 87:169–180.20989229
+Gerber GB, J, Eykens B. 1982. Transfer of antimony and arsenic to the developing organism. Arch Toxicol 49:159–168.7059282
+Gerhardsson L, Brune D, Nordberg GF, 1982. Antimony in lung, liver and kidney tissue from deceased smelter workers. Scand J Work Environ Health 8:201–208.7156939
+Ghaleb HA, Shoeb HA, el-Gawhary N, 1979. Acute toxicity studies of some new organic trivalent antimonials. J Egypt Med Assoc 62:45–62.262475
Gladney ES, Perrin DR, Robinson RD, 1984. Multitechnique determination of elemental concentrations in NBS urban air particulate SRM 1648 and evaluation of its use for quality assurance. J Radioanal Nucl Chem 83(2):379–386.
Glorennec P, Lucas JP, Mercat AC, 2016. Environmental and dietary exposure of young children to inorganic trace elements. Environ Int 97:28–36. http://doi.org/10.1016/j.envint.2016.10.009. 27770708
+Goodwin, Page JE. 1943. A study of the extraction of organic antimonials using a polarographic procedure. Biochem J 37:198–209.16747617
+Gross P, Brown JHU, Hatch TF. 1952. Experimental endogenous lipoid pneumonia. Am J Pathol 28:211–221.14903052
+Gross P, Brown J, Westrick ML, 1955. Toxicologic study of calcium halophosphate phosphors and antimony trioxide. I. Acute and chronic toxicity and some pharmacologic aspects. AMA Arch Ind Health 11:473–478.14375403
+Groth DH, Stettler LE, Burg JR, 1986. Carcinogenic effects of antimony trioxide and antimony ore concentrate in rats. J Toxicol Environ Health 18:607–626.3735460
Grund SC, Hanusch K, Breunig HJ, 2012. Antimony and antimony compounds. In: Ullman’s encyclopedia of industrial chemistry. Hoboken, NJ: John Wiley & Sons, Inc., http://doi.org/10.1002/14356007.a03_055.pub2.
Guo J, Su L, Zhao X, 2016. Relationships between urinary antimony levels and both mortalities and prevalence of cancers and heart diseases in general U.S. population, NHANES 1999–2010. Sci Total Environ 571:452–460. http://doi.org/10.1016/j.scitotenv.2016.07.011. 27396316
Gurnani N, Sharma A, Talukder G. 1992a. Comparison of the clastogenic effects of antimony trioxide on mice in vivo following acute and chronic exposure. Biometals 5(1):47–50.1392472
Gurnani N, Sharma A, Talukder G. 1992b. Cytotoxic effects of antimony trichloride on mice in vivo. Cytobios 70(281):131–136.1451533
Gurnani N, Sharma A, Talukder G. 1993. Comparison of clastogenic effects of antimony and bismuth as trioxides on mice in vivo. Biol Trace Elem Res 37(2–3):281–292. http://doi.org/10.1007/bf02783802. 7688540
Haldar AK, Sen P, Roy S. 2011. Use of antimony in the treatment of leishmaniasis: Current status and future directions. Mol Bio Int 2011:571242. http://doi.org/10.4061/2011/571242. 22091408
Hansen C, Tsirigotaki A, Bak SA, 2010. Elevated antimony concentrations in commercial juices. J Environ Monit 12(4):822–824. http://doi.org/10.1039/b926551a. 20383361
Hantson P, Leonard ED, Crutzen-Fayt MC, 1996. Cytogenetic observations after meglumine antimoniate therapy for visceral leishmaniasis. Pharmacotherapy 16(5):869–871.8888081
Han-Wen S, Xiao-Quan S, Zhe-Ming N. 1982. Selective separation and differential determination of antimony (III) and antimony (V) by solvent extraction with N-benzoyl-N-phenylhydroxylamine and graphite-furnace atomic-absorption spectrometry using a matrix-modification technique. Talanta 29(7):589–593.18963190
+Harris JW. 1956. Studies on the mechanism of a drug-induced hemolytic anemia. J Lab Clin Med 47(5):760–775.13319885
Herbst KA, Rose G, Hanusheh K, 1985. Antimony and antimony compounds. In: Ullmann’s encyclopedia of industrial chemistry. Vol. A3. Weinheim, Germany: Wiley-VCH, 55–76.
+Hext PM, Pinto PJ, Rimmel BA. 1999. Subchronic feeding study of antimony trioxide in rats. J Appl Toxicol 19(3):205–209.10362272
Hillamo R, Pacyna JM, Bartonova A. 1988. Characterization of aerosols during long-range transport episodes of air pollution to Norway. J Aerosol Sci 19:1257–1261.
+Hiraoka N. 1986. The toxicity of organ-distribution of antimony after chronic administration to rats. Kyoto Furitsu Ika Daigaku Zasshi 95:997–1017.
Hockmann K, Lenz M, Tandy S, 2014. Release of antimony from contaminated soil induced by redox changes. J Hazard Mater 275:215–221. http://doi.org/10.1016/j.jhazmat.2014.04.065. 24862348
+Honey M. 1960. The effects of sodium antimony tartrate on the myocardium. Br Heart J 22:601–616.13715657
Hopper JF, Barrie LA. 1988. Regional and background aerosol trace elemental composition observed in eastern Canada. Tellus 40B:446–462.
+Horton JR, Gawroski CL, Newton PE, 1986. Evaluation of the acute toxicity, irritation, sensitization, and subchronic dermal toxicity of antimony thioantimonate lubricant. University of California, Irvine, 1-20. ADA166873.
+Houpt K, Zgoda JC, Stahlbaum CC. 1984. Use of taste repellents and emetics to prevent accidental poisoning of dogs. Am J Vet Res 45:1501–1503.6476561
HSDB. 2005a. Antimony, elemental. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
HSDB. 2005b. Antimony trichloride. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
HSDB. 2009a. Antimony sulfide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
HSDB. 2009b. Stibine. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
HSDB. 2013. Antimony trioxide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
HSDB. 2014. Antimony potassium tartrate. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. June 22, 2015.
Huang H, Shu SC, Shih JH, 1998. Antimony trichloride induces DNA damage and apoptosis in mammalian cells. Toxicology 129(2–3):113–123.9772090
Huang Y, Ni W, Chen Y, 2015. Levels and risk factors of antimony contamination in human hair from an electronic waste recycling area, Guiyu, China. Environ Sci Pollut Res Int 22(9):7112–7119. http://doi.org/10.1007/s11356-014-3941-1. 25501644
IARC. 1989. Antimony trioxide and antimony trisulfide. IARC Monographs on the evaluation of carcinogenic risks to humans. Volume 47. Some organic solvents, resin monomers and related compounds, pigments and occupational exposures in paint manufacture and painting. Lyon, France: International Agency for Research on Cancer. https://monographs.iarc.fr/wp-content/uploads/2018/06/mono47-16.pdf. May 6, 2019.
IARC. 2015. Agents classified by the IARC monographs. Volumes 1–114. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications_Vol1-114.pdf. November 9, 2015.
Iavicoli I, Caroli S, Alimonti A, 2002. Biomonitoring of a worker population exposed to low antimony trioxide levels. J Trace Elem Med Biol 16(1):33–39. http://doi.org/10.1016/s0946-672x(02)80006-2. 11878750
ICRP. 1981. Metabolic data for antimony. Limits for intakes of radionuclides by workers (ICRP Publication 30, Part 3). International Commission on Radiological Protection. Ann ICRP 6(2/3):46–49.
Iijima A, Sato K, Fujitani Y, 2009. Clarification of the predominant emission sources of antimony in airborne particulate matter and estimation of their effects on the atmosphere in Japan. Environ Chem 6(2):122–132. http://doi.org/http://dx.doi.org/10.1071/EN08107.
IRIS. 1987. Antimony; CASRN 7440-36-0. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0006_summary.pdf. November 9, 2015.
IRIS. 1995. Antimony trioxide; CASRN 1309-64-4. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0676_summary.pdf. November 9, 2015.
Jablonska-Czapla M, Szopa S, Grygoyc K, 2014. Development and validation of HPLC-ICP-MS method for the determination inorganic Cr, As and Sb speciation forms and its application for Plawniowice reservoir (Poland) water and bottom sediments variability study. Talanta 120:475–483. http://doi.org/10.1016/j.talanta.2013.11.092. 24468399
Jenkins RO, Craig PJ, Goessler W, 1998. Antimony leaching from cot mattresses and sudden infant death syndrome (SIDS). Hum Exp Toxicol 17(3):138–139.9587780
Johnson CA, Moench H, Wersin P, 2005. Solubility of antimony and other elements in samples taken from shooting ranges. J Environ Qual 34(1):248–254.15647555
Johnson DL, Davis BL, Dzubay TG, 1984. Chemical and physical analyses of Houston aerosol for interlaboratory comparison of source apportionment procedures. Atmos Environ 18(8):1539–1553.
+Joliffe DS. 1985. Nephrotoxicity of pentavalent antimonials. Lancet 1:584.
+Jones RD. 1994. Survey of antimony workers: Mortality 1961–1992. Occup Environ Med 51(11):772–776.7849856
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
+Kanisawa M, Schroeder HA. 1969. Life term studies on the effect of trace elements on spontaneous tumors in mice and rats. Cancer Res 29(4):892–895.5777793
Katayama Y, Ishida N. 1987. Determination of antimony in nail and hair by thermal neutron activation analysis. Radioisotopes 36:103–107.3602476
Kentner M, Leinemann M, Schaller KH, 1995. External and internal antimony exposure in starter battery production. Int Arch Occup Environ Health 67(2):119–123.7672855
+Kim HA, Heo Y, Oh SY, 1999. Altered serum cytokine and immunoglobulin levels in the workers exposed to antimony. Hum Exp Toxicol 18(10):607–613.10557011
Kirkland D, Whitwell J, Deyo J, 2007. Failure of antimony trioxide to induce micronuclei or chromosomal aberrations in rat bone-marrow after sub-chronic oral dosing. Mutat Res 627(2):119–128. http://doi.org/10.1016/j.mrgentox.2006.10.012. 17174592
Kobayashi A, Ogra Y. 2009. Metabolism of tellurium, antimony and germanium simultaneously administered to rats. J Toxicol Sci 34(3):295–303.19483383
Koch B, Maser E, Hartwig A. 2017. Low concentrations of antimony impair DNA damage signaling and the repair of radiation-induced DSB in HeLa S3 cells. Arch Toxicol 91(12):3823–3833. http://doi.org/10.1007/s00204-017-2004-z. 28612261
Kopp B, Zalko D, Audebert M. 2018. Genotoxicity of 11 heavy metals detected as food contaminants in two human cell lines. Environ Mol Mutagen 59:202–210. http://doi.org/10.1002/em.22157. 29150881
Kowalczyk GS, Gordon GE, Rheingrover SW. 1982. Identification of atmospheric particulate sources in Washington, D.C., using chemical element balances. Environ Sci Technol 16:79–90.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kubo T, Urano K, Utsumi H. 2002. Mutagenicity characteristics of 255 environmental chemicals. J Health Sci 48(6):545–554.
Kuroda K, Endo G, Okamoto A, 1991. Genotoxicity of beryllium, gallium and antimony in short-term assays. Mutat Res 264(4):163–170.1723493
Kuryshev YA, Wang L, Wible BA, 2006. Antimony-based antileishmanial compounds prolong the cardiac action potential by an increase in cardiac calcium currents. Mol Pharmacol 69(4):1216–1225. http://doi.org/10.1124/mol.105.019281. 16418337
Landsberger S, Jervis RE, Kajrys G, 1983. Characterization of trace elemental pollutants in urban snow using proton induced X-ray emission and instrumental neutron activation analysis. Int J Environ Anal Chem 16(2):95–130.
Lantzsch H, Gebel T. 1997. Genotoxicity of selected metal compounds in the SOS chromotest. Mutat Res 389(2–3):191–197.9093383
Lawn SD, Armstrong M, Chilton D, 2006. Electrocardiographic and biochemical adverse effects of sodium stibogluconate during treatment of cutaneous and mucosal leishmaniasis among returned travellers. Trans R Soc Trop Med Hyg 100:264–269.16289167
Lehr CR, Kashyap DR, McDermott TR. 2007. New insights into microbial oxidation of antimony and arsenic. Appl Environ Microbiol 73(7):2386–2389. http://doi.org/10.1128/aem.02789-06. 17308197
Lewis RJ. 2012. Antimony pentoxide. AQF750. In: Sax’s dangerous properties of industrial medicine. Hoboken, NJ: John Wiley & Sons, Inc., 341–342.
Li T. 2011. Antimony and antimony alloys. In: Kirk-Othmer encyclopedia of chemical toxicology. Hoboken, NJ: John Wiley & Sons, Inc., http://doi.org/10.1002/0471238961.011420091209.a01.pub3.
Liao YH, Yu HS, Ho CK, 2004. Biological monitoring of exposures to aluminium, gallium, indium, arsenic, and antimony in optoelectronic industry workers. J Occup Environ Med 46(9):931–936.15354058
Lima MI, Arruda VO, Alves EV, 2010. Genotoxic effects of the antileishmanial drug glucantime. Arch Toxicol 84(3):227–232. http://doi.org/10.1007/s00204-009-0485-0. 19911167
+Lippincott SW, Ellerbrook LD, Rhees M, 1947. A study of the distribution and fate of antimony when used as tartar emetic and fuadin in the treatment of American soldiers with Schistosomiasis japonica. J Clin Invest 26(3):370–378.
Llewellyn TO. 1989. Antimony. In: Minerals yearbook metals and minerals 1987, Volume 1. Pittsburgh, PA: Bureau of Mines, U.S. Department of the Interior, http://digicoll.library.wisc.edu/cgi-bin/EcoNatRes/EcoNatRes-idx?id=EcoNatRes.MinYB1987v1. March 16, 2016.
+Longerich HP, Friel JK, Fraser C, 1991. Analysis of the drinking water of mothers of neural tube defect infants and of normal infants for 14 selected trace elements by inductively coupled plasma-mass spectrometry (ICP-MS). Can J Appl Spectrosc 36(1):15–21.
Lopez S, Aguilar L, Mercado L, 2015. Sb(V) reactivity with human blood components: Redox effects. PLoS ONE 10(1):e0114796. http://doi.org/10.1371/journal.pone.0114796. 25615452
Lopez-Garcia I, Sanchez-Merlos M, Hernandez-Cordoba M. 1997. Arsenic and antimony determination in soils and sediments by graphite furnace atomic absorption spectrometry with slurry sampling. Spectrochimica Acta Part B At Spectrosc 52(4):437–443.
+Ludersdorf R, Fuchs A, Mayer P, 1987. Biological assessment of exposure to antimony and lead in the glass-producing industry. Int Arch Occup Environ Health 59:469–474.3653992
Luo J, Bai Y, Liang J, 2014. Metagenomic approach reveals variation of microbes with arsenic and antimony metabolism genes from highly contaminated soil. PLoS ONE 9(10):e108185. http://doi.org/10.1371/journal.pone.0108185. 25299175
Maciaszczyk-Dziubinska E, Wawrzycka D, Wysocki R. 2012. Arsenic and antimony transporters in eukaryotes. Int J Mol Sci 13(3):3527–3548. http://doi.org/10.3390/ijms13033527. 22489166
Maher W. 1986. Measurement of total antimony in marine organisms and waters by stibine generation and atomic absorption spectrometry. Anal Lett 18(3&4):295–305.
+Mansour SE, Reese HH. 1965. Experimental antimony toxicity on lower motor neurons and muscles of mice. Exp Parasitol 13:148–187.
Mansour MM, Rasoul AA A, Schulert AR. 1967. Anti-bilharzial antimony drugs. Nature (London) New Biol 214:819–820.
Mariussen E, Johnsen IV, Stromseng AE. 2017. Distribution and mobility of lead (Pb), copper (Cu), zinc (Zn), and antimony (Sb) from ammunition residues on shooting ranges for small arms located on mires. Environ Sci Pollut Res Int 24(11):10182–10196. http://doi.org/10.1007/s11356-017-8647-8. 28265871
+Marmo E, Matera MG, Acampora R, 1987. Prenatal and postnatal metal exposure: Effect on vasomoter reactivity development of pups. Curr Ther Res Clin Exp 42:823–838.
Maynar M, Llerena F, Grijota FJ, 2017. Serum concentration of several trace metals and physical training. J Int Soc Sports Nutr 14:19. http://doi.org/10.1186/s12970-017-0178-7. 28615997
+Mendy A, Gasana J, Vieira ER. 2012. Urinary heavy metals and associated medical conditions in the US adult population. Int J Environ Health Res 22(2):105–118.21854105
Menke A, Guallar E, Cowie CC. 2016. Metals in urine and diabetes in U.S. adults. Diabetes 65(1):164–171. http://doi.org/10.2337/db15-0316. 26542316
Michalke K, Wickenheiser EB, Mehring M, 2000. Production of volatile derivatives of metal(loid)s by microflora involved in anaerobic digestion of sewage sludge. Appl Environ Microbiol 66(7):2791–2796.10877769
Miekeley N, Carneiro MTW, Silveira CLP. 1998. How reliable are human hair reference intervals for trace elements? Sci Total Environ 218(1):9–17.9718741
Migliore L, Cocchi L, Nesti C, 1999. Micronuclei assay and FISH analysis in human lymphocytes treated with six metal salts. Environ Mol Mutagen 34(4):279–284.10618176
Migon C, Mori C. 1999. Arsenic and antimony release from sediments in a Mediterranean estuary. Hydrobiologia 392(1):81–88.
Milford JB, Davidson CI. 1985. The sizes of particulate trace elements in the atmosphere- A review. J Air Pollut Control Assoc 35(12):1249–1260.3910700
Miranda ES, Miekeley N, De-Carvalho RR, 2006. Developmental toxicity of meglumine antimoniate and transplacental transfer of antimony in the rat. Reprod Toxicol 21(3):292–300. http://doi.org/10.1016/j.reprotox.2005.09.010. 16271447
Miravet R, López-Sánchez JF, Rubio R. 2006. Leachability and analytical speciation of antimony in coal fly ash. Anal Chim Acta 576(2):200–206. http://doi.org/10.1016/j.aca.2006.06.003. 17723633
Mitsunobu S, Harada T, Takahashi Y. 2006. Comparison of antimony behavior with that of arsenic under various soil redox conditions. Environ Sci Technol 40(23):7270–7276. http://doi.org/10.1021/es060694x. 17180977
Mok WM, Wal CM. 1990. Distribution and mobilization of arsenic and antimony species in the Coeur d’Alene River, Idaho. Environ Sci Technol 24:102–108.
Muramatsu Y, Parr RM. 1988. Concentrations of some trace elements in hair, liver and kidney from autopsy subjects - Relationship between hair and internal organs. Sci Total Environ 76:29–40.3238413
Murrell NE. 1987. Impact of metallic solders on water quality. Proc Annu Conf AWWA 1:39–43.
+Myers RC, Homan ER, Well CS, 1978. Antimony trioxide range-finding toxicity studies. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206062.
Nakamaru YM, Sekine K. 2008. Sorption behavior of selenium and antimony in soils as a function of phosphate ion concentration. Soil Sci Plant Nutr 54(3):332–341. http://doi.org/10.1111/j.1747-0765.2008.00247.x.
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press. 15–35.
Navas-Acien A, Silbergeld EK, Sharrett R, 2005. Metals in urine and peripheral arterial disease. Environ Health Perspect 113(2):164–169. http://doi.org/10.1289/ehp.7329. 15687053
Neves DB, Caldas ED, Sampaio RN. 2009. Antimony in plasma and skin of patients with cutaneous leishmaniasis--relationship with side effects after treatment with meglumine antimoniate. Trop Med Int Health 14(12):1515–1522. http://doi.org/10.1111/j.1365-3156.2009.02408.x. 19954451
+Newton PE, Bolte HF, Daly IW, 1994. Subchronic and chronic inhalation toxicity of antimony trioxide in the rat. Fundam Appl Toxicol 22(4):561–576.8056203
+NIOSH. 1979. Toxicity evaluation for establishing IDLH values. Cincinnati, OH: National Institute for Occupational Safety and Health. PB87229498.
NIOSH. 1985. Elements in blood or tissue. Cincinnati, OH: National Institute for Occupational Safety and Health. 8005-8001 to 8005-S. Method 8005.
NIOSH. 1989. National Occupational Exposure Survey (NOES). Washington, DC: National Institute for Occupational Safety and Health.
NIOSH. 1994a. Antimony compounds. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/7440360.html. May 8, 2019.
NIOSH. 1994b. Stibine. Immediately Dangerous to Life or Health Concentrations (IDLH). Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/idlh/7803523.html. May 8, 2019.
NIOSH. 2018a. Antimony. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0036.html. May 6, 2019.
NIOSH. 2018b. Stibine. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0568.html. May 6, 2019.
Nriagu JO. 1989. A global assessment of natural sources of atmospheric trace metals. Nature 338:47–49.
+NTP. 1992. NTP report on the toxicity studies of antimony potassium tartrate in F344/N rats and B6C3F1 mice (drinking water and intraperitoneal injection studies). Research Triangle Park, NC: NTP Tox 11. NIH Publication No. 92-3130.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments- February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. April 13, 2016.
NTP. 2015. Handbook for conducting a literature-based health assessment using OHAT approach for systematic review and evidence integration. National Toxicology Program. http://ntp.niehs.nih.gov/ntp/ohat/pubs/handbookjan2015_508.pdf. October 2, 2015.
+NTP. 2016. NTP technical report on the toxicology and carcinogenesis studies of antimony trioxide (CAS NO. 1309-64-4) in Wistar Han [Crl:WI (Han)] rats and B6C3F1/N mice. National Toxicology Program. NTP TR 590.
NTP. 2018. Report on carcinogens monograph on antimony trioxide. Research Triangle Park, NC: National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/monographs/antimony_final20181019_508.pdf. May 8, 2019.
Ohmori S, Tsujii H, Kusaka Y, 1981. Radioactivation analysis of hair a means of biological monitoring of the environment. J Radioanal Chem 63(2):269–282.
Olmez I, Kotra JP, Lowery S, 1985. Airborne lead and trace elements in an indoor shooting range: A study of the DC National Guard armory pistol range. Environ Toxicol Chem 4:447–452.
+Omura M, Tanaka A, Hirata M, 2002. Testicular toxicity evaluation of two antimony compounds, antimony trioxide and antimony potassium tartrate, in rats and mice. Environ Health Prev Med 7(1):15–18. http://doi.org/10.1007/bf02898061. 21432285
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants Code of Federal Regulations. 29 CFR 1910.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. November 28, 2018.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Code of Federal Regulations. 29 CFR 1915.1000. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. November 1, 2018.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Code of Federal Regulations 29 CFR 1926.55 Appendix A. Occupational Safety and Health Administration. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55AppA. November 1, 2018.
Pacyna JM, Pacyna EG. 2001. An assessment of global and regional emissions of trace metals to the atmosphere from anthropogenic sources worldwide. Environ Rev 9(4):269–298. http://doi.org/10.1139/a01-012.
Pacyna JM, Semb A, Hanssen JE. 1984. Emission and long-range transport of trace elements in Europe. Tellus 36B:163–178.
Palacios R, Osorio LE, Grajales LF, 2001. Treatment failure in children in a randomized clinical trial with 10 and 20 days of meglumine antimonate for cutaneous leishmaniasis due to Leishmania viannia species. Am J Trop Med Hyg 64(3–4):187–193.11442216
+Palacios N, Fitzgerald K, Roberts AL, 2014. A prospective analysis of airborne metal exposures and risk of Parkinson disease in the nurses’ health study cohort. Environ Health Perspect 122(9):933–938. http://doi.org/10.1289/ehp.1307218. 24905870
Pan X, Zhang D, Chen X, 2010. Antimony accumulation, growth performance, antioxidant defense system and photosynthesis of Zea mays in response to antimony pollution in soil. Water Air Soil Pollut 215(1):517–523. http://doi.org/10.1007/s11270-010-0496-8.
+Pandey AK, Kumar M, Thakur CP. 1988. ECG changes in prolonged treatment of kalaazar with antimony compounds [letter]. J Assoc Physicians India 36:398–399.
Paßlack N, Mainzer B, Lahrssen-Wiederholt M, 2014a. Concentrations of strontium, barium, cadmium, copper, zinc, manganese, chromium, antimony, selenium and lead in the equine liver and kidneys. SpringerPlus 3(343):1–10. http://doi.org/10.1186/2193-1801-3-343. 24422185
Paßlack N, Mainzer B, Lahrssen-Wiederholt M, 2014b. Concentrations of strontium, barium, cadmium, copper, zinc, manganese, chromium, antimony, selenium, and lead in the liver and kidneys of dogs according to age, gender, and the occurrence of chronic kidney disease. J Vet Sci 16(1):57–66. http://www.ncbi.nlm.nih.gov/pubmed/25234328. 25234328
Paßlack N, Mainzer B, Lahrssen-Wiederholt M, 2014c. Liver and kidney concentrations of strontium, barium, cadmium, copper, zinc, manganese, chromium, antimony, selenium and lead in cats. BMC Vet Res 10:163. http://doi.org/10.1186/1746-6148-10-163. 25030305
Paton GR, Allison AD. 1972. Chromosome damage in human cell cultures induced by metal salts. Mutat Res 16:332–336.5078138
Pattenden NJ, Branson JR, Fisher EMR. 1982. Trace element measurements in wet and dry deposition and airborne particulate at an urban site. Deposition of atmospheric pollutants. Boston, MA: D. Reidel Publishing Company, 173–184.
Perez-Corona T, Madrid Y, Camara C. 1997. Evaluation of selective uptake of selenium (Se(IV) and Se(VI)) and antimony (Sb(III) and Sb(V)) species by baker’s yeast cells (Saccharomyces cerevisiae). Anal Chim Acta 345(1–3):249–255.
Plunkert PA. 1982. Antimony. In: Minerals Handbook. Pittsburgh, PA: Bureau of Mines, U.S. Department of the Interior, 93–101.
+Poon R, Chu I, Lecavalier P, 1998. Effects of antimony on rats following 90-day exposure via drinking water. Food Chem Toxicol 36(1):21–35.9487361
+Potkonjak V, Pavlovich M. 1983. Antimoniosis: A particular form of pneumoconiosis. I. Etiology, clinical and x-ray findings. Int Arch Occup Environ Health 51:199–207.6222000
+Potkonjak V, Vishnjich V. 1983. Antimoniosis: A particular form of pneumoconiosis II. Experimental investigation. Int Arch Occup Environ Health 51(4):229–303.
Quiroz W, Arias H, Bravo M, 2011. Development of analytical method for determination of Sb(V), Sb(III) and TMSb(V) in occupationally exposed human urine samples by HPLC-HG-AFS. Microchem J 97(1):78–84.
Quiroz W, Aguilar L, Barria M, 2013. Sb(V) and Sb(III) distribution in human erythrocytes: speciation methodology and the influence of temperature, time and anticoagulants. Talanta 115:902-910. http://doi.org/10.1016/j.talanta.2013.06.052.
Ragaini RC, Ralston HR, Roberts N. 1977. Environmental trace metal contamination in Kellogg, Idaho, near a lead smelting complex. Environ Sci Technol 11(8):773–781.
+Rees PH, Kager PA, Keating MI, 1980. Renal clearance of pentavalent antimony (sodium stibogluconate). Lancet 2:226–229.6105394
+Renes LE. 1953. Antimony poisoning in industry. AMA Arch Ind Health 7:99–108.
RePORTER. 2019. Antimony. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. May 7, 2017.
Ribeiro RR, Ferreira WA, Martins PS, 2010. Prolonged absorption of antimony(V) by the oral route from non-inclusion meglumine antimoniate-beta-cyclodextrin conjugates. Biopharm Drug Dispos 31(2–3):109–119. http://doi.org/10.1002/bdd.695. 20014042
Richardson BA. 1994. Sudden infant death syndrome: A possible primary cause. J Forensic Sci Soc 34(3):199–204.7523575
Rooney AA, Boyles AL, Wolfe MS, 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. http://doi.org/10.1289/ehp.1307972. 24755067
+Rossi F, Acampora R, Vacca C, 1987. Prenatal and postnatal antimony exposure in rats: Effect on vasomotor reactivity development of pups. Teratog Carcinog Mutagen 7(5):491–496.2893463
RTECS. 2015. Antimony and compounds. Registry of Toxic Effects on Chemical Substances. National Institute of Occupational Safety and Health. MDL Information Systems, Inc. June 2, 2015.
+Rugemalila JB. 1980. Fatal stibocaptate toxicity. East Afr Med J 57(10):720–722.6260456
Saghazadeh A, Rezaei N. 2017. Systematic review and meta-analysis links autism and toxic metals and highlights the impact of country development status: Higher blood and erythrocyte levels for mercury and lead, and higher hair antimony, cadmium, lead, and mercury. Prog Neuropsychopharmacol Biol Psych 79(Pt B):340–368. http://doi.org/10.1016/j.pnpbp.2017.07.011.
Schaumlöffel N, Gebel T. 1998. Heterogeneity of the DNA damage provoked by antimony and arsenic. Mutagenesis 13(3):281–286.9643588
Scheinost AC, Rossberg A, Vantelon D, 2006. Quantitative antimony speciation in shooting-range soils by EXAFS spectroscopy. Geochim Cosmochim Acta 70(13):3299–3312.
+Schnorr TM, Steenland K, Thun MJ, 1995. Mortality in a cohort of antimony smelter workers. Am J Ind Med 27(5):759–770.7611310
+Schroeder HA, Mitchener M, Nason AP. 1970. Zirconium, niobium, antimony, vanadium and lead in rats: Life term studies. J Nutr 100(1):59–68.5412131
+Schroeder HA, Mitchener M, Balassa JJ, 1968. Zirconium, niobium, antimony, and fluorine in mice: Effects on growth, survival and tissue levels. J Nutr 95(1):95–101.5653281
Scinicariello F, Buser MC. 2016. Urinary antimony and leukocyte telomere length: An analysis of NHANES 1999–2002. Environ Res 150:513–518. http://doi.org/10.1016/j.envres.2016.06.044. 27423705
Scinicariello F, Buser MC, Feroe AG, 2017. Antimony and sleep-related disorders: NHANES 2005–2008. Environ Res 156:247–252. http://doi.org/10.1016/j.envres.2017.03.036. 28363141
Shacklette HT, Boerngen JG. 1984. Element concentration in soils and other surficial materials of the conterminous United States. In: U.S. Geological Survey Professional Paper 1270. Washington, DC: U.S. Department of the Interior, 1–9.
+Shirai S, Suzuki Y, Yoshinaga J, 2010. Maternal exposure to low-level heavy metals during pregnancy and birth size. J Environ Sci Health A Tox Hazard Subst Environ Eng 45:1468–1474. http://doi.org/10.1080/10934529.2010.500942. 20694885
+Shiue I. 2014. Higher urinary heavy metal, arsenic, and phthalate concentrations in people with high blood pressure: US NHANES, 2009–2010. Int J Environ Res Public Health 11(6):5989–5999. http://doi.org/10.3109/08037051.2014.925228. 24905244
+Shiue I. 2015. Relationship of environmental exposures and ankylosing spondylitis and spinal mobility: US NHANES, 2009–2010. Int J Environ Health Res 25(3):322–329. http://doi.org/10.1080/09603123.2014.945512. 25103950
+Shiue I, Hristova K. 2014. Higher urinary heavy metal, phthalate and arsenic concentrations accounted for 3–19% of the population attributable risk for high blood pressure: US NHANES, 2009–2012. Hypertens Res 37(12):1075–1081. http://doi.org/10.1038/hr.2014.121. 25077919
Smichowski P. 2008. Antimony in the environment as a global pollutant: A review on analytical methodologies for its determination in atmospheric aerosols. Talanta 75(1):2–14. http://doi.org/10.1016/j.talanta.2007.11.005. 18371839
Smith MM, White MA, Wilson HK. 1995. Determination of antimony in urine by solvent extraction and electrothermal atomization atomic absorption spectrometry for the biological monitoring of occupational exposure. J Anal Atom Spectrom 10(6):349–352.
+Smyth HF, Thompson WL. 1945. The single dose and subacute-toxicity of antimony oxide (SB2O3). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206062.
+Smyth HF, Carpenter CP. 1948. Further experience with the range finding test in the industrial toxicology laboratory. J Ind Hyg Toxicol 30:63–68.18895731
Stauffer RE, Thompson JM. 1984. Arsenic and antimony in geothermal waters of Yellowstone National Park, Wyoming, USA. Geochim Cosmochim Acta 48(12):2547–2561. http://pubs.er.usgs.gov/publication/70013582. May 16, 2019.
+Stevenson CJ. 1965. Antimony spots. In: Transactions of the St. John’s Hospital Dermatology Society. Vol. 51. London, England: St. John’s Hospital Dermatological Society, 40–43.
Stoessel RP, Michaelis W. 1986. Wet and dry deposition of metals. Proceedings of the 2nd International Conference on Environmental Contamination. Amsterdam, The Netherlands: CEP Consultants, Ltd, 85–88.
Sumino K, Hayakawa K, Shibata T, 1975. Heavy metals in normal Japanese tissues: Amount of 15 heavy metals in 30 subjects. Arch Environ Health 30:487–494.1180571
Sun H, Yan SC, Cheng WS. 2000. Interaction of antimony tartrate with the tripeptide glutathione implication for its mode of action. Eur J Biochem 267(17):5450–5457.10951203
+Sunagawa S. 1981. [Experimental studies on antimony poisoning]. Igaku Kenkyu 51:129–142. (Japanese)7331729
Sundar S, Sinha PR, Agrawal NK, 1998. A cluster of cases of severe cardiotoxicity among kala-azar patients treated with a high-osmolarity lot of sodium antimony gluconate. Am J Trop Med Hyg 59(1):139–143.9684642
Takagi Y, Matsuda S, Imai S, 1986. Trace elements in human hair: An international comparison. Bull Environ Contam Toxicol 36:793–800.3719115
Takagi Y, Matsuda S, Imai S, 1988. Survey of trace elements in human nails: An international comparison. Bull Environ Contam Toxicol 41:690–695.3233368
+Taylor PJ. 1966. Acute intoxication from antimony trichloride. Br J Ind Med 23:318–321.5224624
Telford K, Maher W, Krikowa F, 2008. Measurement of total antimony and antimony species in mine contaminated soils by ICPMS and HPLC-ICPMS. J Environ Monit 10(1):136–140. http://doi.org/10.1039/b715465h. 18175027
Thakur CP. 1998. Sodium antimony gluconate, amphotericin, and myocardial damage. Lancet 351(9120):1928–1929.9654264
+Thomas RG, Felicetti SW, Lucchino RV, 1973. Retention patterns of antimony in mice following inhalation of particles formed at different temperatures. Proc Soc Exp Biol Med 144:544–550.4746928
Tirmenstein MA, Plews PI, Walker CV, 1995. Antimony-induced oxidative stress and toxicity in cultured cardiac myocytes. Toxicol Appl Pharmacol 130(1):41–47. http://doi.org/10.1006/taap.1995.1006. 7839369
Tirmenstein MA, Mathias PI, Snawder JE, 1997. Antimony-induced alterations in thiol homeostasis and adenine nucleotide status in cultured cardiac myocytes. Toxicology 119(3):203–211.9152016
Toraason M, Wey HE, Richards DE, 1997. Altered Ca2+ mobilization during excitation contraction in cultured cardiac myocytes exposed to antimony. Toxicol Appl Pharmacol 146(1):104–115.9299602
TRI16. 2018. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Environmental Information. U.S. Environmental Protection Agency. http://www.epa.gov/triexplorer/. September 18, 2018.
Tschan M, Robinson B, Schulin R. 2008. Antimony uptake by Zea mays (L.) and Helianthus annuus (L.) from nutrient solution. Environ Geochem Health 30(2):187–191. http://doi.org/10.1007/s10653-008-9142-4. 18253841
Tschan M, Robinson BH, Schulin R. 2009. Antimony in the soil–Plant system – A review. Environ Chem 6(2):106–115. http://doi.org/10.1071/EN08111.
U.S. Bureau of Mines. 1989. Antimony in the 2nd quarter of 1989, August 23, 1989. Pittsburgh, PA: U.S. Bureau of Mines, 1–16.
USGS. 2004. Mineral commodity profiles. Antimony. U.S. Geological Survey. Open-File Report 03-019. http://pubs.usgs.gov/of/2003/of03-019/of03-019.pdf. March 17, 2016.
USGS. 2010. Water-chemistry data for selected springs, geysers, and streams in Yellowstone National Park, Wyoming, 2006–2008. U.S. Geological Survey. Open-File Report 2010-1192. Water-chemistry data for selected springs, geysers, and streams in Yellowstone National Park, Wyoming, 2006–2008. March 15, 2016.
USGS. 2011. National water-quality assessment program. Trace elements and radon in groundwater across the United States, 1992–2003. U.S. Geological Survey. Scientific Investigations Report 2011-5059. http://pubs.usgs.gov/sir/2011/5059/pdf/sir2011-5059_report-covers_508.pdf. March 22, 2016.
USGS. 2015. Mineral industry surveys. Antimony in the fourth quarter 2014. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/antimony/mis-2014q4-antim.pdf. March 17, 2016.
Van Velzen D, Langenkamp H, Herb G. 1998. Antimony, its sources, applications and flow paths into urban and industrial waste: A review. Waste Manag Res 16(1):32–40.
Vandecasteele C, Vermeir G, Dams R. 1988. Element concentrations in the air of an indoor shooting range. Environ Technol Lett 9:1287–1294.
Vasquez L, Scorza Dagert JV, Scorza JV, 2006. Pharmacokinetics of experimental pentavalent antimony after intramuscular administration in adult volunteers. Curr Ther Res Clin Exp 67(3):193–203. http://doi.org/10.1016/j.curtheres.2006.06.005. 24678095
Vigeh M, Yokoyama K, Matsukawa T, 2017. Effects of hair metals on body weight in Iranian children aged 20 to 36 months. Iran J Public Health 46(8):1018–1027.28894702
Vinas P, Lopez-Garcia I, Merino-Merono B, 2006. Liquid chromatography-hydride generation-atomic fluorescence spectrometry hybridation for antimony speciation in environmental samples. Talanta 68(4):1401–1405. http://doi.org/10.1016/j.talanta.2005.07.056. 18970479
Vong RJ, Larson TV, Zoller WH. 1988. A multivariate chemical classification of rainwater samples. Chemometr Intell Lab Syst 3:99–109.
Wang YX, Pan A, Feng W, 2019. Variability and exposure classification of urinary levels of non-essential metals aluminum, antimony, barium, thallium, tungsten and uranium in healthy adult men. Chemometr Intell Lab Syst 29:424–434. http://doi.org/10.1038/s41370-017-0002-0.
Wang YX, Sun Y, Huang Z, 2016. Associations of urinary metal levels with serum hormones, spermatozoa apoptosis and sperm DNA damage in a Chinese population. Environ Int 94:177–188. http://doi.org/10.1016/j.envint.2016.05.022. 27258659
+Watt WD. 1980. Chronic inhalation toxicity of antimony trioxide: Validation of the T.L.V.-progress report-summary of results. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS206195.
+Watt WD. 1983. Chronic inhalation toxicity of antimony trioxide: Validation of the threshold limit value. Detroit, MI: Wayne State University, 1–135.
Weast RC. 1988. The elements (continued). In: Handbook of chemistry and physics. 69th ed. Boca Raton, FL: CRC Press, B-8, B-72 to B-73.
Westerhoff P, Prapaipong P, Shock E, 2008. Antimony leaching from polyethylene terephthalate (PET) plastic used for bottled drinking water. Water Res 42(3):551–556. http://doi.org/10.1016/j.watres.2007.07.048. 17707454
+Westrick ML. 1953. Physiologic responses attending administration of antimony, alone or with simultaneous injections of thyroxin. Proc Soc Exp Biol Med 82:56–60.13037801
Wey HE, Richards D, Tirmenstein MA, 1997. The role of intracellular calcium in antimony-induced toxicity in cultured cardiac myocytes. Toxicol Appl Pharmacol 145(1):202–210. http://doi.org/10.1006/taap.1997.8175. 9221838
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. September 9, 2014.
WHO. 2017. Guidelines for drinking-water quality. Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. http://apps.who.int/iris/bitstream/10665/254637/1/9789241549950-eng.pdf?ua=1. February 28, 2017.
Wiersema JM, Wright L, Rogers B, 1984. Human exposure to potentially toxic elements through ambient air in Texas. Proceedings of the 77th Annual Meeting of the Air Pollution Control Association, 1–15.
+Wil Research Laboratories Inc. 1979. Acute eye irritation study in rabbits with antimony oxide. Sponsored by PPG Industries Inc., Pittsburgh, PA. 1–13.
Wilson SC, Lockwood PV, Ashley PM, 2010. The chemistry and behaviour of antimony in the soil environment with comparisons to arsenic: A critical review. Environ Pollut 158(5):1169–1181. http://doi.org/http://dx.doi.org/10.1016/j.envpol.2009.10.045. 19914753
Windholz M. 1983. Antimony and compounds. In: The Merck index. 10th ed. Rahway, NJ: Merck and Co., 102–104.
Wong LCK, Winston JM, Hagensen J, 1979. Study of carcinogenicity and toxicity of inhaled antimony trioxide, antimony ore concentrate and thallic oxide in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0511065.
+Wu CC, Chen YC. 2017. Assessment of industrial antimony exposure and immunologic function for workers in Taiwan. Int J Environ Res Public Health 14(7):1–9. http://doi.org/10.3390/ijerph14070689.
Wyllie S, Fairlamb AH. 2006. Differential toxicity of antimonial compounds and their effects on glutathione homeostasis in a human leukaemia monocyte cell line. Biochem Pharmacol 71(3):257–267. http://doi.org/10.1016/j.bcp.2005.10.043. 16318845
Yu RC, Rappaport SM. 1996. Relation between pulmonary clearance and particle burden: A Michaelis-Menten-like kinetic model. Occup Environ Med 53(8):567–572.8983469
+Zaki MH, Shookhoff HB, Sterman M, 1964. Astiban in Schistosomiasis mansoni: A controlled therapeutic trial in a nonendemic area. Am J Trop Med Hyg 13:803–810.14222433
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21:2–141.
+Zheng G, Zhong H, Guo Z 2014. Levels of heavy metals and trace elements in umbilical cord blood and the risk of adverse pregnancy outcomes: A population-based study. Biol Trace Elem Res 160(3):437–444. http://doi.org/10.1007/s12011-014-0057-x. 25008990
Zikovsky L, Badillo M. 1987. An indirect study of air pollution by neutron activation analysis of snow. J Radioanal Nucl Chem 114(1):147–153.