# VERSION HISTORY

Date | Description
October 2019 | Final toxicological profile released
April 2017 | Draft for public comment toxicological profile released
September 1992 | Final toxicological profile released