# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding antimony in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for antimony.

Table 7-1 Regulations and Guidelines Applicable to Antimony

Agency | Description | Information | Reference
Air
EPA | RfC | | IRIS 1995
EPA | | | IRIS 1995
EPA | Antimony trioxide | 2×10^−4^ mg/m^3^ ^a^ | IRIS 1995
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories (antimony) | | EPA 2018a
EPA | | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | 0.01 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | 0.01 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | DWEL | 0.01 mg/L | EPA 2018a
EPA | | | EPA 2018a
EPA | Lifetime health advisory | 0.006 mg/L | EPA 2018a
EPA
EPA | National primary drinking water regulations | | EPA 2009
EPA | | | EPA 2009
EPA | MCL (antimony) | 0.006 mg/L | EPA 2009
EPA
EPA | RfD (antimony) | 4×10^−4^ mg/kg/day^b^ | IRIS 1987
WHO | Drinking water quality guidelines (antimony and compounds) | | WHO 2017
WHO | | | WHO 2017
WHO | Guideline value | 0.02 mg/L | WHO 2017
WHO | | | WHO 2017
WHO | TDI | 6 μg/kg body weight | WHO 2017
FDA | Substances added to food | Not listed^c^ | FDA 2018
FDA
FDA | Allowable level for antimony in bottled water | 0.006 mg/L | FDA 2017
Cancer
HHS | Carcinogenicity classification (antimony trioxide) | Reasonably anticipated to be a human carcinogen | NTP 2018
EPA | Carcinogenicity classification | No data | IRIS 1987, 1995
IARC | Carcinogenicity classification | | IARC 1989
IARC | | | IARC 1989
IARC | Antimony trioxide | Group 2B^d^ | IARC 1989
IARC | Antimony trisulfide | Group 3^e^ | IARC 1989
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction (antimony and compounds, as Sb) | 0.5 mg/m^3^ | OSHA 2018a, 2018b, 2018c
NIOSH | REL (up to 10-hour TWA)
NIOSH
NIOSH | Antimony and compounds (as Sb) | 0.5 mg/m^3^ | NIOSH 2018a
NIOSH | Stibine | 0.1 ppm | NIOSH 2018b
NIOSH
NIOSH | IDLH
NIOSH
NIOSH | Antimony compounds (as Sb) | 50 mg/m^3^ | NIOSH 1994a
NIOSH | Stibine | 5 ppm | NIOSH 1994b
Emergency Criteria
EPA | AEGLs-air (stibine) | | EPA 2016b
EPA | | | EPA 2016b
EPA | AEGL-1^f^ | | EPA 2016b
EPA | 10-minute | NR^g^ | EPA 2016b
EPA | 30-minute | NR^g^ | EPA 2016b
EPA | 60-minute | NR^g^ | EPA 2016b
EPA | 4-hour | NR^g^ | EPA 2016b
EPA | 8-hour | NR^g^ | EPA 2016b
EPA | | | EPA 2016b
EPA | AEGL-2^f^ | | EPA 2016b
EPA | 10-minute | 4.2 ppm | EPA 2016b
EPA | 30-minute | 2.9 ppm | EPA 2016b
EPA | 60-minute | 1.5 ppm | EPA 2016b
EPA | 4-hour | 0.36 ppm | EPA 2016b
EPA | 8-hour | 0.18 ppm | EPA 2016b
EPA | | | EPA 2016b
EPA | AEGL-3^f^ | | EPA 2016b
EPA | 10-minute | 28 ppm | EPA 2016b
EPA | 30-minute | 19 ppm | EPA 2016b
EPA | 60-minute | 9.6 ppm | EPA 2016b
EPA | 4-hour | 2.4 ppm | EPA 2016b
EPA | 8-hour | 1.2 ppm | EPA 2016b
DOE | PACs-air | | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-1^h^ | | DOE 2018b
DOE | | | DOE 2018b
DOE | Antimony | 0.5 mg/m^3^ | DOE 2018b
DOE | Antimony pentasulfide | 2.5 mg/m^3^ | DOE 2018b
DOE | Antimony potassium tartrate | 1.7 mg/m^3^ | DOE 2018b
DOE | Antimony trichloride | 0.94 mg/m^3^ | DOE 2018b
DOE | Antimony trioxide | 0.6 mg/m^3^ | DOE 2018b
DOE | Stibine | 0.14 ppm | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-2^h^ | | DOE 2018b
DOE | Antimony | 0.5 mg/m^3^ | DOE 2018b
DOE | Antimony pentasulfide | 22 mg/m^3^ | DOE 2018b
DOE | Antimony potassium tartrate | 1.7 mg/m^3^ | DOE 2018b
DOE | Antimony trichloride | 0.94 mg/m^3^ | DOE 2018b
DOE | Antimony trioxide | 0.6 mg/m^3^ | DOE 2018b
DOE | Stibine | 1.5 ppm | DOE 2018b
DOE | | | DOE 2018b
DOE | PAC-3^h^ | | DOE 2018b
DOE | Antimony | 80 mg/m^3^ | DOE 2018b
DOE | Antimony pentasulfide | 130 mg/m^3^ | DOE 2018b
DOE | Antimony potassium tartrate | 220 mg/m^3^ | DOE 2018b
DOE | Antimony trichloride | 150 mg/m^3^ | DOE 2018b
DOE | Antimony trioxide | 96 mg/m^3^ | DOE 2018b
DOE | Stibine | 9.6 ppm | DOE 2018b

a The RfC is based on a calculated BMC10(HEC) of 0.074 mg/cu3 for pulmonary toxicity and chronic interstitial inflammation in rats.

b The RfD is based on a LOAEL of 0.35 mg/kg/day for effects on longevity, blood glucose, and cholesterol in rats.

c The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances "no longer FEMA GRAS."

d Group 2B: possibly carcinogenic to humans.

e Group 3: not classifiable as to its carcinogenicity to humans.

f Definitions of AEGL terminology are available from EPA (2018b).

g NR = not recommended due to insufficient data.

h Definitions of PAC terminology are available from DOE (2018a).

AEGL = acute exposure guideline levels; BMC = benchmark concentration; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association; GRAS = generally recognized as safe; HEC = human equivalent concentration; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; MCL = maximum contaminant level; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TDI = tolerable daily intake; TWA = time-weighted average; WHO = World Health Organization