# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Antimony (Sb) is in the fourth row of group 5A (IUPAC group 15) in the periodic table, residing between arsenic and bismuth. Antimony displays four oxidation states: −3, 0, +3, and +5. The most common and stable oxidation states of antimony in aqueous solutions and biological fluids are Sb(III) and Sb(V). Antimony is sometimes referred to as a metalloid, indicating that it displays both metallic and nonmetallic characteristics (Li 2011).

Table 4-1 lists the common synonyms, trade names, and other pertinent identification information for antimony and selected antimony compounds.

Table 4-1 Chemical Identity of Antimony and Compounds^a^

Characteristic | Information
Chemical name | Antimony | Antimony pentasulfide | Antimony pentoxide
Synonym(s) | Antimony black; stibium, antimony regulus | Antimonial saffron; antimonic sulfide; antimony red; antimony; golden antimony sulfide, antimony persulfide^c^ | Antimonic oxide; antimony pentaoxide; diantimony pentoxide; stibic anhydride; antimonic anhydride; antimonic acid^c^
Registered trade name(s) | No data | No data | No data
Chemical formula | Sb^b^ | S_5_Sb_2_^d^ | O_5_Sb_2_^d^
Chemical structure | Sb | No data | No data
CAS Registry Number | 7440-36-0 | 1315-04-4 | 1314-60-9
Chemical name | Ammonium potassium tartrate | | Antimony trichloride
Synonym(s) | Antimonial potassium tartrate; potassium antimonial tartrate; tartox; tartrated antimony; potassium antimony tartrate; tartar emetic | | Antimonous chloride; antimony butter; antimony(III) chloride; trichlorostibine; chloride antimony
Registered trade name(s) | No data | | No data
Chemical formula | C_8_H_4_K_2_O_12_Sb_2_·3H_2_O^d^ | | Cl_3_Sb
Chemical structure | [image] | | [image]
CAS Registry Number | 28300-74-5 | | 10025-91-9
Chemical name | Antimony trioxide | Antimony trisulfide | Stibine
Synonym(s) | Antimonious oxide; antimony oxide; diantimony trioxide^d^; flowers of antimony^d^; antimony sesquioxide^e^; senmarmontite; valentinite; antimony white; antimony peroxide; timothox; exitelite | Antimonous sulfide; antimony glance; antimony orange; 130antimony crimson; antimony sesquisulfide; antimony sulfide; antimony vermilion; stibite; antimony needles | Antimony hydride; antimony trihydride; hydrogen antimonide
Registered trade name(s) | Hd^f^; LP^f^; KR^f^; White Star^f^; White Star M^f^; KR-LTS^f^; Thermoguard S^f^; Thermoguard L^f^; H Grade^f^; L Grade^f^; Fire Shield L^f^; Montana Brand^f^ | No data | No data
Chemical formula | O_3_Sb_2_ | S_3_Sb_2_ | H_3_Sb
Chemical structure | [image] | [image] | [image]
CAS Registry Numer | 1309-64-4 | 1345-04-6 | 7803-52-3

a All information obtained from HSDB (2005a, 2005b, 2009a, 2009b, 2013, 2014) except where noted.

b Weast 1988.

c RTECS 2015.

d Windholz 1983.

e Freedman et al. 1978.

f Avento and Touval 1980.

g Cotton and Wilkinson 1966.

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

The physical and chemical properties of antimony and selected antimony compounds are given in Table 4-2. Antimony metal is stable under ordinary conditions. Antimony is a poor conductor of heat and electricity (Li 2011). Antimony forms complex ions with organic and inorganic acids. Stable complexes, such as Sb_2_S_4_^2−^, may form when antimony is in the presence of sulfur (Bodek et al. 1988). Stibine (SbH_3_) is a gaseous antimony compound in which antimony is in the −3 valence state. Stibine is formed by the action of acids on metal antimonides or antimony alloys by the reduction of antimony compounds, or by the electrolysis of acidic or basic solutions where antimony is present in the cathode. There is a danger of stibine being liberated from overcharged lead storage batteries in which antimony is alloyed into the lead. Stibine slowly decomposes into metallic antimony and hydrogen. It is readily, and sometimes violently, oxidized by air to form antimony trioxide and water (Freedman et al. 1978).

Table 4-2 Physical and Chemical Properties of Antimony and Compounds^a^

Property | Information
Chemical name | Antimony | Antimony pentasulfide | Antimony pentoxide
Molecular weight | 121.75 | 403.80 | 323.5 (anhydrous)
Color | Silvery white | Yellow | Yellow
Physical state | Solid | Solid | Solid
Valence state | 0 | +5 | +5
Melting point (°C) | 630.5 | 75 (decomposes) | 380 (decomposes)^f^
Boiling point (°C) | 1,750; 1,325^b^; 1,635^c^ | No data | No data
Density (g/cm^3^) at 20°C | 6.684 (at 25°C); 6.688^b^ | 4.12 | 3.78
Odor | No data | Odorless^c^ | No data
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Taste | No data | No data | No data
Taste threshold | No data | No data | No data
Solubility:
Water at 20°C | Insoluble | Insoluble | Very slightly soluble
Organic solvents | No data | Insoluble | No data
Partition coefficients:
Log Kow | No data | No data | No data
Log Koc | No data | No data | No data
Vapor pressure (mmHg) at 20°C | 1 (at 886°C)^d^ | No data | No data
Henry’s law constant at 25°C | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors (ppm to mg/m^3^) | None^e^ | None^e^ | None^e^
Explosive limits | No data | No data | No data
Molecular weight | 333.93 | | 228.11
Color | Colorless | | Colorless
Physical state | Solid | | Solid
Valence state | +3 | | +3
Melting point (°C) | 100 (−½ mole H2O) | | 73.4
Boiling point (°C) | No data | | 283, 222.6^g^
Density (g/cm^3^) at 20°C | 2.6 | | 3.140 (at 25°C)
Odor | Odorless^g^ | | Sharp, unpleasant
Odor threshold:
Water | No data | | No data
Air | No data | | No data
Taste | Sweetish, metallic^c^ | | No data
Taste threshold | No data | | No data
Solubility
Water at 20°C | 83 g/L (cold) | | 6,016 g/L (at 0°C)
Organic solvents | Insoluble in alcohol; soluble in glycerine | | Soluble in ABS alcohol, tartaric acid, methylene chloride, benzene, acetone
Partition coefficients
Log Kow | No data | | No data
Log Koc | No data | | No data
Vapor pressure (mmHg) at 20°C | No data | | 1 (at 49.2°C, sublimes)
Henry’s law constant at 25°C | No data | | No data
Autoignition temperature | No data | | No data
Flashpoint | No data | | No data
Flammability limits | No data | | No data
Conversion factors (ppm to mg/m^3^) | None^e^ | | None^e^
Explosive limits | No data | | No data
Chemical name | Antimony trioxide | Antimony trisulfide | Stibine
Molecular weight | 291.50 | 339.69 | 124.77
Color | White (senarmontite); colorless (valentinite) | Black (stibinite); yellow-red (amorphous) | Colorless^g^
Physical state | Solid | Solid | Gas
Valence state | +3 | +3 | −3
Melting point (°C) | 656 | 550 | −88
Boiling point (°C) | 1,550 (sublimes); 1,425^g^ | 1,150 | −17^g^
Density (g/cm^3^) at 20°C | 5.2 (senarmontite); 5.67 (valentinite) | 4.64 (stibinite); 4.12 (amorphous solid) | 2.204 (at -17°C)
Odor | Odorless | No data | Disagreeable, like hydrogen sulfide^g^
Odor threshold:
Water | No data | No data | No data
Air | No data | No data | No data
Taste | No data | No data | No data
Taste threshold | No data | No data | No data
Solubility
Water at 20°C | Very slightly soluble | 1.75 mg/L (at 18°C) | 4.1 g/L (at 0°C)
Organic solvents | Soluble in tartaric acid, acetic acid, hydrochloric acid | Soluble in alcohol; insoluble in acetic acid | Soluble in carbon disulfide, ethanol^g^
Partition coefficients
Log Kow | No data | No data | No data
Log Koc | No data | No data | No data
Vapor pressure (mmHg) at 20°C | 1 (at 574°C)^d^ | No data | No data
Henry’s law constant at 25°C | No data | No data | No data
Autoignition temperature | No data | No data | No data
Flashpoint | No data | No data | No data
Flammability limits | No data | No data | No data
Conversion factors (ppm to mg/m^3^) | None^e^ | None^e^ | 1 ppm stibine = 5.1 mg/m^3^
Explosive limits | No data | No data | No data

a All information obtained from Weast (1988) except where noted.

b Herbst et al. 1985.

c Windholz 1983.

d HSDB 2013.

e Since these substances exist in the atmosphere in the particulate state, the concentration is expressed as mg/m^3^.

f Lewis 2012.

g Freedman et al. 1978.