# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR ANTIMONY

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to antimony, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to antimony:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to antimony. The inclusion criteria used to identify relevant studies examining the health effects of antimony are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of antimony. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for antimony released for public comment in 2017. See Appendix B for the databases searched and the search strategy.

A total of 1,505 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of antimony.

Title and Abstract Screen. In the Title and Abstract Screen step, 1,505 records were reviewed; 14 studies were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of the 14 health effects studies identified in the update literature was performed. Additionally, 71 studies cited in the LSE tables for the existing profile were included in the full study screen bringing the total number of studies for the qualitative review to 85.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Antimony and overviews of the results of the inhalation, oral, and dermal exposure studies are presented in Sections 2.2–2.18 of the profile and in the Levels Significant Exposures tables in Section 2.1 of the profile (Tables 2-3, 2-4, and 2-5, respectively).

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN

Overviews of the potential health effect outcomes for antimony identified in human and animal studies are presented in Tables C-3 and C-4, respectively. The available human studies examined a limited number of endpoints and reported respiratory, cardiovascular, gastrointestinal, musculoskeletal, immunological, reproductive, and developmental effects. Animal studies examined a number of endpoints following inhalation, oral, or dermal exposure. These studies examined most systemic endpoints and reported respiratory, cardiovascular, gastrointestinal, hematological, musculoskeletal, hepatic, renal, endocrine, dermal, ocular, body weight, and metabolic effects. Additionally, animal studies have reported immunological, reproductive, and developmental effects.

Table C-3 Overview of the Health Outcomes for Antimony Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Observational | | 7 | 2 (1) | 3 | | | | | 3 | 1 | | 1 | 2 | 1 | 1 | | 2
Observational | | 5 | 2 | 3 | | | | | 3 | 1 | | 1 | 1 | 1 | 1 | | 1
Experimental
Oral studies
Observational | 1 | 1 | 5(0) | 1 | | 1 | 1 | | | | 1 | 1 | 5 | 1 | 2^a^ | 2 | 3
Observational | 0 | 0 | 3 | 1 | | 1 | 0 | | | | 0 | 1 | 1 | 0 | 0 | 1 | 1
Experimental
Dermal studies
Observational
Experimental
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Numbers in parentheses represent those studies looking at the specific cardiovascular endpoints of interest to this systematic review (damage to the myocardium and/or EKG alterations).

a One study (Zheng et al. 2014) was excluded because it measured risk of “adverse pregnancy outcome,” but did not provide information on the endpoints examined and was not considered suitable for the systematic review.

Table C-4 Overview of the Health Outcomes for Antimony Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration | 3 | 5 | 2(1) | | | | 2 | 3 | | | 2
Acute-duration | 0 | 5 | 1 | | | | 1 | 2 | | | 0
Intermediate-duration | 5 | 4 | 5 | | 5 | | 3 | 2 | | | 1 | | | 1 | 1
Intermediate-duration | 0 | 4 | 3 | | 1 | | 2 | 1 | | | 1 | | | 1 | 1
Chronic-duration | 7 | 8 | 7 | 6 | 1 | 4 | 6 | 6 | | 2 | 6 | 6 | 5 | 6 | | 4 | 7
Chronic-duration | 2 | 7 | 2 | 1 | 0 | 2 | 0 | 1 | | 2 | 0 | 3 | 0 | 0 | | 0 | 5
Oral Studies
Acute-duration | 3 | 2 | 2 | 3 | | 2 | 2 | 2 | | | 2
Acute-duration | 1 | 1 | 0 | 2 | | 0 | 1 | 0 | | | 0
Intermediate-duration | 11 | 2 | 4(2) | 3 | 7 | 1 | 4 | 3 | 1 | 1 | 2 | 1 | | 4 | 3 | 1
Intermediate-duration | 5 | 0 | 1 | 0 | 4 | 0 | 2 | 0 | 0 | 0 | 0 | 1 | | 0 | 3 | 1
Chronic-duration | 2 | | 1(0) | | | | 1 | | | | | | | | | 1 | 2
Chronic-duration | 0 | | 0 | | | | 0 | | | | | | | | | 1 | 0
Dermal studies
Acute-duration | | | | | | | | | 1 | 4 | | 1
Acute-duration | | | | | | | | | 0 | 2 | | 0
Intermediate-duration | 1 | | 1 | | | | 1 | 1 | 1 | 1 | | | | 1
Intermediate-duration | 0 | | 0 | | | | 0 | 0 | 0 | 1 | | | | 0
Chronic-duration | | | | | | | | | 4 | 3
Chronic-duration | | | | | | | | | 1 | 0
Number of studies examining endpoint | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | | | | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Numbers in parentheses represent those studies looking at the specific cardiovascular endpoints of interest to this systematic review (damage to the myocardium and/or EKG alterations).

Respiratory, cardiovascular (damage to the myocardium and/or EKG alterations), gastrointestinal, metabolic (alterations in blood glucose levels), and developmental effects were considered sensitive outcomes, i.e., effects were observed at low concentrations or doses. Eighty-five studies (published in 54 documents) examining these potential outcomes were carried through to Steps 4–8 of the systematic review.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES

### C.5.1 Risk of Bias Assessment

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (−)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias
Were the comparison groups appropriate?
Confounding bias
Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-6

Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias
Was administered dose or exposure level adequately randomized?
Was the allocation to study groups adequately concealed?
Performance bias
Were experimental conditions identical across study groups?
Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias
Were outcome data complete without attrition or exclusion from analysis?
Detection bias
Is there confidence in the exposure characterization?
Is there confidence in outcome assessment?
Selective reporting bias
Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of antimony health effects studies (observational epidemiology and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to antimony and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

Table C-8 Summary of Risk of Bias Assessment for Antimony—Observational Epidemiology Studies

| Risk of bias criteria and ratings
| Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias
Reference | Were the comparison groups appropriate? | Did the study design or analysis account for important confounding and modifying variables?^*^ | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization?^*^ | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Risk of bias tier
Outcome: Respiratory effects
Cohort studies
Jones 1994 (antimony metal and antimony trioxide) | − | − | + | NA | − | + | Second
Renes 1953 (antimony oxides) | NA | − | + | + | + | + | Second
Schnorr et al. 1995 (antimony oxides) | + | − | + | − | + | + | Second
Cross-sectional studies
Brieger et al. 1954 (antimony trisulfide) | NA | − | + | + | + | + | Second
Cooper et al. 1968 (antimony trioxide) | NA | − | + | NA | + | + | Second
Case series
Potkonjak and Pavlovich 1983 (antimony oxides) | NA | − | + | NA | + | + | Second
Taylor 1966 (antimony trichloride) | NA | − | + | − | − | + | Third
Outcome: Cardiovascular effects (myocardium damage and/or EKG alterations)
Cross Sectional studies
Brieger et al. 1954 (antimony trisulfide) | NA | − | + | + | + | + | Second
Outcome: Gastrointestinal Effects
Cohort studies
Renes 1953 (antimony oxides) | NA | − | + | + | + | + | Second
Cross-sectional studies
Brieger et al. 1954 (antimony trisulfide) | NA | − | + | + | + | + | Second
Case series
Taylor 1966 (antimony trichloride) | NA | − | + | − | − | + | Third
Outcome: Developmental Effects
Cohort studies
Belyaeva 1967 (antimony metal, antimony trioxide, antimony pentasulfide) | − | − | + | + | − | + | Second
Case-control studies
Longerich et al. 1991 (not reported) | + | − | + | − | + | + | Second
Cross-sectional studies
Bloom et al. 2015 | NA | − | + | − | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Antimony—Experimental Animal Studies

| Risk of bias criteria and ratings
| Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias
Reference | Was administered dose or exposure level adequately randomized? | Was the allocation to study groups adequately concealed? | Were experimental conditions identical across study groups? | Were the research personnel blinded to the study group during the study? | Were outcome data complete without attrition or exclusion from analysis? | Is there confidence in the exposure characterization? | Is there confidence in the outcome assessment?^*^ | Were all measured outcomes reported? | Did the study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Respiratory effects (inhalation only)
Inhalation acute exposure
Brieger et al. 1954 (rabbit) (antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
NTP 2016 (rat, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 2016 (mouse, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NIOSH 1979 (rat, stibine) | − | + | + | + | + | + | − | − | NA | Second
NIOSH 1979 (guinea pig, stibine) | − | + | + | + | + | + | − | − | NA | Second
Inhalation intermediate exposure
Belyaeva 1967 (rat, antimony trisulfide) | + | + | + | − | + | − | − | + | NA | Second
Brieger et al. 1954 (rat, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Dernehl et al. 1945 (guinea pig, antimony trioxide) | − | − | − | − | + | − | − | + | NA | Third
Newton et al. 1994 (rat, antimony trioxide) | − | + | + | − | ++ | ++ | + | + | NA | First
Inhalation chronic exposure
Gross et al. 1952 (rat, antimony trisulfide) | − | + | + | − | + | − | + | + | NA | First
Groth et al. 1986 (rat, antimony trioxide) | + | + | + | + | + | ++ | + | − | NA | First
Groth et al. 1986 (rat, antimony ore) | + | + | + | + | + | ++ | + | − | NA | First
Newton et al. 1994 (rat, antimony trioxide) | − | + | + | − | ++ | ++ | + | + | NA | First
NTP 2016 (rat, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 2016 (mouse, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Watt 1983 (rat, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Watt 1983 (pig, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Outcome: Cardiovascular effects(myocardium damage and/or EKG alterations)
Inhalation acute exposure
Brieger et al. 1954 (rabbit, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Inhalation intermediate exposure
Brieger et al. 1954 (rat, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Brieger et al. 1954 (rabbit, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Brieger et al. 1954 (dog, 7 weeks, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Brieger et al. 1954 (dog, 10 weeks, antimony trisulfide) | NA | NA | NA | NA | + | − | + | + | NA | Second
Dernehl et al. 1945 (guinea pig, antimony trioxide) | − | − | − | − | + | − | − | + | NA | Third
Newton et al. 1994 (rat, antimony trioxide) | − | + | + | − | ++ | ++ | + | + | NA | First
Inhalation chronic exposure
Groth et al. 1986 (rat, antimony trioxide) | + | + | + | + | + | ++ | + | − | NA | First
Groth et al. 1986 (rat, antimony ore) | + | + | + | + | + | ++ | + | − | NA | First
Newton et al. 1994 (rat, antimony trioxide) | − | + | + | − | ++ | ++ | + | + | NA | First
NTP 2016 (rat, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 2016 (mouse, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Watt 1983 (rat, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Watt 1983 (pigs, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Oral acute exposure
NTP 1992 (rat, antimony potassium tartrate) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 1992 (mouse, antimony potassium tartrate) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Oral intermediate exposure
Hext et al. 1999 (rat, antimony trioxide) | + | + | + | + | + | ++ | + | + | NA | First
Poon et al. 1998 (rat, antimony potassium tartrate) | + | + | ++ | + | + | ++ | + | + | NA | First
Outcome: Gastrointestinal effects
Inhalation chronic exposure
Groth et al. 1986 (rat, antimony trioxide) | + | + | + | + | + | ++ | + | − | NA | First
Groth et al. 1986 (rat, antimony ore) | + | + | + | + | + | ++ | + | − | NA | First
NTP 2016 (rat, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 2016 (mouse, antimony trioxide) | ++ | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Watt 1983 (rat, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Watt 1983 (pig, antimony trioxide) | − | + | ++ | + | ++ | + | + | ++ | NA | First
Oral acute exposure
Houpt et al. 1984 (dog, antimony potassium tartrate) | − | + | + | + | + | − | + | + | NA | First
NTP 1992 (rat, antimony potassium tartrate) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
NTP 1992 (mouse, antimony potassium tartrate) | + | + | ++ | + | ++ | ++ | ++ | ++ | NA | First
Oral intermediate exposure
Hext et al. 1999 (rat, antimony trioxide) | + | + | + | + | + | ++ | + | + | + | First
Poon et al. 1998 (rat, antimony potassium tartrate) | + | + | + | + | + | + | + | − | NA | First
Outcome: Metabolic effects (altered blood glucose levels)
Oral intermediate exposure
Poon et al. 1998 (rat, antimony potassium tartrate) | + | + | + | + | + | + | + | − | NA | First
Oral chronic exposure
Schroeder et al. 1970 (rat, antimony potassium tartrate) | + | + | + | + | + | − | + | − | NA | First
Outcome: Developmental effects
Inhalation intermediate exposure
Belyaeva 1967 (rat, antimony trisulfide) | + | + | + | − | + | − | − | + | NA | Second
Oral intermediate exposure
Angrisani et al. 1988 (rat pup CV, antimony trichloride) | + | + | + | + | + | − | + | + | NA | First
Rossi et al. 1987 (rat, antimony trichloride) | + | + | + | + | + | − | + | + | NA | First
Rossi et al. 1987 (rat pup CV, antimony trichloride) | + | + | + | + | + | − | + | + | NA | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; NA = not applicable

* Key question used to assign risk of bias tier

### C.6.1 Initial Confidence Rating

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to antimony and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions in Distiller, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human-Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining respiratory, cardiovascular, gastrointestinal, metabolic, and developmental effects observed in the observational epidemiology and animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Antimony— Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects (inhalation only)
Cohort studies
Jones 1994 (antimony metal and antimony trioxide) | | | | | Moderate
Jones 1994 (antimony metal and antimony trioxide) | No | Yes | Yes | Yes
Renes 1953 (antimony oxides) | No | Yes | Yes | No | Low
Schnorr et al. 1995 (antimony oxides) | No | Yes | Yes | Yes | Moderate
Cross-sectional studies
Brieger et al. 1954 (antimony trisulfide) | No | Yes | Yes | No | Low
Cooper et al. 1968 (antimony trioxide) | No | Yes | Yes | No | Low
Case series
Potkonjak and Pavlovich 1983 (antimony oxides) | | | | | Low
Potkonjak and Pavlovich 1983 (antimony oxides) | No | Yes | Yes | No
Taylor 1966 (antimony trichloride) | No | Yes | Yes | No | Low
Outcome: Cardiovascular effects
Cross-sectional studies
Brieger et al. 1954 (antimony trisulfide) | No | Yes | Yes | No | Low
Outcome: Gastrointestinal effects
Cohort studies
Renes 1953 (antimony oxides) | No | Yes | Yes | No | Low
Cross-sectional studies
Brieger et al. 1954 (antimony trisulfide) | No | Yes | Yes | No | Low
Case series
Taylor 1966 (antimony trichloride) | No | Yes | Yes | No | Low
Outcome: Developmental effects
Cohort studies
Belyaeva 1967 (antimony metal, antimony trioxide, antimony pentasulfide) | | | | | Low
Belyaeva 1967 (antimony metal, antimony trioxide, antimony pentasulfide) | No | No | Yes | Yes
Case-control studies
Longerich et al. 1991 (not reported) | No | No | Yes | Yes | Low

Table C-14 Presence of Key Features of Study Design for Antimony— Experimental Animal Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Respiratory effects (inhalation only)
Inhalation acute exposure
Brieger et al. 1954 (rabbit, antimony trisulfide) | Yes | No | Yes | No | Moderate
NTP 2016 (rat, antimony trioxide) | Yes | No | Yes | Yes | Moderate
NTP 2016 (mouse, antimony trioxide) | Yes | No | Yes | Yes | Moderate
NIOSH 1979 (rat, stibine) | Yes | No | Yes | No | Low
NIOSH 1979 (guinea pig, stibine) | Yes | No | Yes | No | Low
Inhalation intermediate exposure
Belyaeva 1967 (rat, antimony trisulfide) | Yes | Yes | Yes | No | Moderate
Brieger et al. 1954 (rat, antimony trisulfide) | Yes | Yes | Yes | No | Moderate
Dernehl et al. 1945 (guinea pig, antimony trioxide) | Yes | No | Yes | No | Low
Newton et al. 1994 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Inhalation chronic exposure
Gross et al. 1952 (rat, antimony trisulfide) | Yes | Yes | Yes | Yes | High
Groth et al. 1986 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Groth et al. 1986 (rat, antimony ore) | Yes | Yes | Yes | Yes | High
Newton et al. 1994 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
NTP 2016 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
NTP 2016 (mouse, antimony trioxide) | Yes | Yes | Yes | Yes | High
Watt 1983 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Watt 1983 (pig, antimony trioxide) | Yes | No | Yes | Yes | Moderate
Outcome: Cardiovascular effects (myocardium damage or altered EKG)
Inhalation acute exposure
Brieger et al. 1954 (rabbit, antimony trisulfide) | Yes | No | Yes | Yes | Moderate
Inhalation intermediate exposure
Brieger et al. 1954 (rat, antimony trisulfide) | Yes | Yes | Yes | No | Moderate
Brieger et al. 1954 (rabbit, antimony trisulfide) | Yes | No | Yes | No | Low
Brieger et al. 1954 (dog, 7 weeks, antimony trisulfide) | Yes | No | Yes | No | Low
Brieger et al. 1954 (dog, 10 weeks, antimony trisulfide) | Yes | No | Yes | No | Low
Dernehl et al. 1945 (guinea pig, antimony trioxide) | Yes | No | Yes | No | Low
Newton et al. 1994 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
Inhalation chronic exposure
Groth et al. 1986 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
Groth et al. 1986 (rat, antimony ore) | Yes | Yes | No | Yes | Moderate
Newton et al. 1994 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
NTP 2016 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
NTP 2016 (mouse, antimony trioxide) | Yes | Yes | No | Yes | Moderate
Watt 1983 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
Watt 1983 (pigs, antimony trioxide) | Yes | No | Yes | No | Low
Oral acute exposure
NTP 1992 (rat, antimony potassium tartrate) | Yes | No | No | Yes | Low
NTP 1992 (mouse, antimony potassium tartrate) | Yes | No | No | Yes | Low
Oral intermediate exposure
Hext et al. 1999 (rat, antimony trioxide) | Yes | Yes | No | Yes | Moderate
Poon et al. 1998 (rat, antimony potassium tartrate) | Yes | Yes | No | Yes | Moderate
Outcome: Gastrointestinal effects
Inhalation chronic exposure
Groth et al. 1986 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Groth et al. 1986 (rat, antimony ore) | Yes | Yes | Yes | Yes | High
NTP 2016 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
NTP 2016 (mouse, antimony trioxide) | Yes | Yes | Yes | Yes | High
Watt 1983 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Watt 1983 (pig, antimony trioxide) | Yes | No | Yes | Yes | Moderate
Oral acute exposure
Houpt et al. 1984 (dog, antimony potassium tartrate) | Yes | Yes | Yes | Yes | High
NTP 1992 (rat, antimony potassium tartrate) | Yes | No | Yes | Yes | Moderate
NTP 1992 (mouse, antimony potassium tartrate) | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Hext et al. 1999 (rat, antimony trioxide) | Yes | Yes | Yes | Yes | High
Poon et al. 1998 (rat, antimony potassium tartrate) | Yes | Yes | Yes | Yes | High
Outcome: Metabolic effects (altered blood glucose levels)
Oral intermediate exposure
Poon et al. 1998 (rat, antimony potassium tartrate) | Yes | Yes | Yes | Yes | High
Oral Chronic exposure
Schroeder et al. 1970 (rat, antimony potassium tartrate) | Yes | Yes | Yes | Yes | High
Outcome: Developmental effects
Inhalation intermediate exposure
Belyaeva 1967 (rat, antimony trisulfide) | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Angrisani et al. 1988 (rat pup CV, antimony trichloride) | Yes | Yes | Yes | Yes | High
Rossi et al. 1987 (rat, antimony trichloride) | Yes | Yes | Yes | Yes | High
Rossi et al. 1987 (rat pup CV, antimony trichloride) | Yes | Yes | Yes | Yes | High

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Antimony Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Respiratory effects
Studies finding effects
Inhalation acute exposure
Animal studies
Brieger et al. 1954 (rabbit, antimony trisulfide) | Moderate
NTP 2016 (rat, antimony trioxide) | Moderate
NTP 2016 (mouse, antimony trioxide) | Moderate | Moderate
NIOSH 1979 (rat, stibine) | Low
NIOSH 1979 (guinea pig, stibine) | Low
Inhalation intermediate exposure
Animal studies
Belyaeva 1967 (rat, antimony trisulfide) | Moderate
Brieger et al. 1954 (rat, antimony trisulfide) | Moderate | High
Dernehl et al. 1945 (guinea pig, antimony trioxide) | | Low
Newton et al. 1994 (rat, antimony trioxide) | High
Inhalation chronic exposure
Human studies
Renes 1953 (antimony oxides) | Low
Schnorr et al. 1995 (antimony oxides) | Moderate
Cooper et al. 1968 (antimony trioxide) | Low | Moderate
Potkonjak and Pavlovich 1983 (antimony oxides) | Low
Taylor 1966 (antimony trichloride) | Low
Animal studies
Gross et al. 1952 (rat, antimony trisulfide) | High
Groth et al. 1986 (rat, antimony trioxide) | High
Groth et al. 1986 (rat, antimony ore) | High
Newton et al. 1994 (rat, antimony trioxide) | High | High
NTP 2016 (rat, antimony trioxide) | | High
NTP 2016 (mouse, antimony trioxide) | High
Watt 1983 (rat, antimony trioxide) | High
Watt 1983 (pig, antimony trioxide) | Moderate
Studies finding no effects
Inhalation chronic exposure
Human studies
Brieger et al. 1954 (antimony trisulfide) | Low
Jones 1994 (antimony metal and antimony trioxide) | Moderate | Moderate
Outcome: Cardiovascular effects
Studies finding effects on myocardium and/or EKGs
Inhalation acute exposure
Animal studies
Brieger et al. 1954 (rabbit, antimony trisulfide) | Low | Low
Inhalation intermediate exposure
Animal studies
Brieger et al. 1954 (rat, antimony trisulfide) | Moderate
Brieger et al. 1954 (rabbit, antimony trisulfide) | Low | Moderate
Brieger et al. 1954 (dog, 10 weeks, antimony trisulfide) | Low
Inhalation chronic exposure
Human studies
Brieger et al. 1954 (antimony trisulfide) | Low | Low
Studies finding no effects on myocardium and/or EKGs
Inhalation intermediate exposure
Animal studies
Brieger et al. 1954 (dog, 7 weeks, antimony trisulfide) | Low
Brieger et al. 1954 (dog, 7 weeks, antimony trisulfide) | | Moderate
Dernehl et al. 1945 (guinea pig, antimony trioxide) | Low | Moderate
Newton et al. 1994 (rat, antimony trioxide) | Moderate
Inhalation chronic exposure
Animal studies
Groth et al. 1986 (rat, antimony trioxide) | Moderate
Groth et al. 1986 (rat, antimony ore) | Moderate
Newton et al. 1994 (rat, antimony trioxide) | Moderate
NTP 2016 (rat, antimony trioxide) | Moderate | Moderate
NTP 2016 (mouse, antimony trioxide) | Moderate
Watt 1983 (rat, antimony trioxide) | Moderate
Watt 1983 (pigs, antimony trioxide) | Low
Oral acute exposure
Animal studies
NTP 1992 (rat, antimony potassium tartrate) | Low | Low
NTP 1992 (mouse, antimony potassium tartrate) | Low
Oral intermediate exposure
Animal studies
Hext et al. 1999 (rat, antimony trioxide) | Moderate | Moderate
Poon et al. 1998 (rat, antimony potassium tartrate) | Moderate | Moderate
Outcome: Gastrointestinal effects
Studies finding effects
Inhalation chronic exposure
Human studies
Brieger et al. 1954 | Low
Renes 1953 | Low | Low
Taylor 1966 | Low
Animal studies
NTP 2016 (mouse, antimony trioxide) | High | High
Oral acute exposure
Animal studies
Houpt et al. 1984 (dog, antimony potassium tartrate) | High | High
NTP 1992 (mouse, antimony potassium tartrate) | Moderate
Studies finding no effects
Inhalation chronic exposure
Animal studies
Groth et al. 1986 (rat, antimony trioxide) | High
Groth et al. 1986 (rat, antimony ore) | High
NTP 2016 (rat, antimony trioxide) | High | High
Watt 1983 (rat, antimony trioxide) | High
Watt 1983 (pig, antimony trioxide) | Moderate
Oral acute exposure
Animal studies
NTP 1992 (rat, antimony potassium tartrate) | Moderate | Moderate
Oral intermediate exposure
Animal studies
Hext et al. 1999 (rat, antimony trioxide) | High | High
Poon et al. 1998 (rat, antimony potassium tartrate) | High | High
Outcome: Metabolic effects
Studies finding effects on serum glucose levels
Oral intermediate exposure
Animal studies
Poon et al. 1998 (rat, antimony potassium tartrate) | High | High
Oral chronic exposure
Animal studies
Schroeder et al. 1970 (rat, antimony potassium tartrate) | High | High
Outcome: Developmental effects
Studies finding effects
Inhalation intermediate exposure
Animal studies
Belyaeva 1967 (rat, antimony trisulfide) | Moderate | Moderate
Inhalation chronic exposure
Human studies
Belyaeva 1967 (metallic antimony, antimony trioxide, antimony pentasulfide) | Low | Low
Oral intermediate exposure
Animal studies
Angrisani et al. 1988 (rat, pup CV, antimony trichloride) | High
Rossi et al. 1987 (rat, pup CV, antimony trichloride) | High | High
Rossi et al. 1987 (rat, antimony trichloride) | High
Studies finding no effects
Inhalation chronic exposure
Human studies
Longerich et al. 1991 (not reported) | Low | Low

### C.6.2 Adjustment of the Confidence Rating

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for respiratory, cardiovascular, gastrointestinal, metabolic, and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with antimony exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Respiratory effects
Studies finding effects
Human studies | Moderate | −1 risk of bias | Low
Animal studies | High | +1 magnitude, +1 consistency | High
Studies finding no effects
Human studies | Moderate | −1 risk of bias, | Low
Outcome: Cardiovascular effects
Studies finding effects on myocardium and/or EKGs
Human studies | Low | −1 risk of bias, | Very low
Animal studies | Moderate | −1 risk of bias | Low
Studies finding no effects on myocardium and/or EKGs
Animal studies | Moderate | None | Moderate
Outcome: Gastrointestinal effects
Studies finding effects
Human studies | Low | −1 risk of bias | Very low
Animal studies | High | None | High
Studies finding no effects
Animal studies | High | None | High
Outcome: Metabolic effects
Studies finding effects on serum glucose levels
Animal studies | High | None | High
Outcome: Developmental effects
Studies finding effects
Human studies | Low | −1 risk of bias | Very low
Animal studies | High | None | High
Studies finding no effects
Human studies | Low | −1 risk of bias | Very low

Table C-17 Confidence in the Body of Evidence for Antimony

| Confidence in body of evidence
Outcome | Human studies | Animal studies
Respiratory effects
Effect | Low | High
No effect | Low | No data
Cardiovascular effects
Effects on myocardium/EKG | Very low | Low
No effect on myocardium/EKG | No data | Moderate
Gastrointestinal effects
Effect | Very low | High
No effect | No data | High
Metabolic effects
Effect | No data | High
No effect | No data | No data
Developmental effects
Effect | Very low | High
No effect | Very low | No data

- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  - No downgrade if there are no serious imprecisions
  - Downgrade one confidence level for serious imprecisions
  - Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a nonmonotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  - Upgrade one confidence level if there is a high degree of consistency in the database

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS

In the seventh step of the systematic review of the health effects data for antimony, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for antimony is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Antimony

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Respiratory effects (inhalation only)
| Low | Health effect | Low
| Low | No effect | Inadequate
Cardiovascular—myocardial and EKG alterations
| Very Low | Health effect | Inadequate
Gastrointestinal effect
| Very Low | Health effect | Inadequate
Metabolic—serum glucose alterations
| No data | – | No data
Developmental effects
| Very Low | Health effect | Inadequate
Animal studies
Respiratory effects (inhalation only)
| High | Health effect | High
Cardiovascular—myocardial and EKG alterations
| Low | Health effect | Low
| Moderate | No effect | Inadequate
Gastrointestinal effects
| High | Health effect | High
| High | No effect | Evidence of no health effect
Metabolic—serum glucose alterations
| High | Health effect | High
Developmental effects
| High | Health effect | High
| No data | – | No data

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1. Hazard Identification Scheme

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for antimony are listed below and summarized in Table C-19.

Presumed Health Effects

- Respiratory effects following inhalation exposure
  ○ Low evidence from studies of antimony workers (Cooper et al. 1968; Potkonjak and Pavlovich 1983; Renes 1953; Schnorr et al. 1995; Taylor 1966).
  ○ High level of evidence in rats, mice, rabbits, guinea pigs, and pigs from acute exposure to antimony trisulfide, antimony trioxide, and stibine (Brieger et al. 1954; NIOSH 1979; NTP 2016), intermediate exposure to antimony trisulfide and antimony trioxide (Belyaeva 1967; Brieger et al. 1954; Dernehl et al. 1945; Newton et al. 1994), and chronic exposure to antimony trisulfide, antimony trioxide, and antimony ore (Gross et al. 1952; Groth et al. 1986; Newton et al. 1994; NTP 2016; Watt 1983).
- Gastrointestinal effects
  ○ Inadequate evidence from studies of antimony workers (Brieger et al. 1954; Renes 1953; Taylor 1966).
  ○ High level of evidence for gastrointestinal irritation in dogs (Houpt et al. 1984) and mice (NTP 1992, 2016). Inhalation and oral studies in rats with initial confidences of high or moderate did not find histological alterations in the gastrointestinal tract following inhalation exposure to antimony trioxide (Groth et al. 1986; NTP 2016; Watt 1983) or antimony ore (Groth et al. 1986) or oral exposure to antimony trioxide (Hext et al. 1999) or antimony potassium tartrate (NTP 1992; Poon et al. 1998).

Suspected Health Effects

- Cardiovascular-myocardial and EKG alterations
  ○ Inadequate evidence in humans exposed to antimony trisulfide (Brieger et al. 1954)
  ○ Low evidence in rats, rabbits, and dogs exposed via inhalation to antimony trisulfide (Brieger et al. 1954) and in rats exposed to antimony potassium tartrate (Schroeder et al. 1970). No myocardial alterations were observed in rat, mouse, pig, or guinea pig antimony ore or antimony trioxide inhalation studies with initial moderate confidence levels (Dernehl et al. 1945; Groth et al. 1986; Newton et al. 1994; Watt 1983) or in antimony trioxide and antimony potassium tartrate oral studies with initial moderate confidence level (Hext et al. 1999; NTP 1992; Poon et al. 1998).
  ○ Although the hazard identification for myocardial and EKG alterations should be not classifiable based on inadequate evidence in humans and low evidence in animals, the level of the hazard identification was raised to suspected health effect based on consistent evidence of EKG alterations in patients treated with injected trivalent or pentavalent antimony compounds (Dancaster et al. 1966; Honey 1960; Lawn et al. 2006; Neves et al. 2009; Sundar et al. 1998; Thakur 1998) and in animal studies involving parenteral administration (Alvarez et al. 2005; Bromberger-Barnea and Stephens 1965; Cotten and Logan 1966).
- Metabolic effect (decreases in blood glucose levels)
  ○ No data are available on whether inhalation, oral, or dermal exposure to antimony alters blood glucose levels in humans.
  ○ High evidence in animal studies based on two studies that found decreases in blood glucose levels following intermediate (Poon et al. 1998) or chronic (Schroeder et al. 1970) oral exposure. Decreases in blood glucose levels were also found in rats following repeated intramuscular injection of two organic pentavalent compounds (Alkhawajah et al. 1992b).
  ○ Based on the high evidence found in the two animal studies, decreases in blood glucose levels should be classified as a presumed health effect. However, because blood glucose levels have only been assessed in two studies administering antimony via environmentally relevant routes of exposure, the hazard identification was downgraded to suspected health effect.
- Developmental effects
  ○ Inadequate evidence of developmental effects (decreases in infant growth) from an occupational exposure study (Belyaeva 1967).
  ○ High evidence of developmental toxicity from animal studies. An inhalation study found decreases in the number of offspring in rats exposed to antimony trioxide during gestation (Belyaeva 1967). An antimony trichloride oral exposure study found decreases in postnatal growth resulting from gestation and lactation exposure, but no effect on the number of offspring or abnormalities (Rossi et al. 1987).
  ○ Decreases in birth weight and decreases in the number of viable offspring were observed in rat studies involving gestation and/or lactation exposure to subcutaneously administered meglumine antimoniate (Coelho et al. 2014a; Miranda et al. 2006) or intramuscularly administered sodium stibogluconate, meglumine antimoniate, or antimony trichloride (Alkhawajah et al. 1992a).
  ○ Although the hazard identification for developmental effects, particularly for decreased growth, should be presumed health effect based on inadequate evidence in humans and high evidence in humans, the hazard identification was lowered to suspected health effect based on the small number of studies evaluating the developmental toxicity of antimony by environmentally relevant routes of exposure.

Table C-19 Hazard Identification Conclusions for Antimony

Outcome | Hazard identification
Respiratory effects | Presumed health effect following inhalation exposure
Cardiovascular-myocardial and EKG alterations | Suspected health effect following exposure to soluble antimony compounds
Gastrointestinal effects | Presumed health effect
Metabolic effects (decreased serum glucose levels) | Suspected health effect
Developmental effects | Suspected health effect