# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR ANTIMONY

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to antimony.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for antimony. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of antimony have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of antimony are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for antimony released for public comment in 2017. The following main databases were searched in January 2018:

- PubMed
- National Library of Medicine’s TOXLINE
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for antimony. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to antimony were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which include unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
01/2018 | ((7440-36-0[rn] OR 1315-04-4[rn] OR 1314-60-9[rn] OR 28300-74-5[rn] OR 10025-91-9[rn] OR 1309-64-4[rn] OR 1345-04-6[rn] OR 7803-52-3[rn]) AND (2014/02/01:3000[dp] OR 2015/02/01:3000[mhda])) OR ((“Antimony”[tw] OR “Antimonyl potassium tartrate”[tw] OR “Potassium antimonyl tartrate”[tw] OR “Sb2O3”[tw] OR “Senarmontite”[tw] OR “Potassium antimonyltartrate”[tw] OR “Stibine”[tw] OR “Stibium”[tw] OR “Stibnite”[tw] OR “Tartar emetic”[tw] OR “Trichlorostibine”[tw] OR “Valentinite”[tw]) NOT medline[sb]) AND (2014/02/01:3000[dp] OR 2015/02/01:3000[crdat] OR 2015/02/01:3000[edat])); (“A 1550”[tw] OR “A 1582”[tw] OR “A 1588LP”[tw] OR “A 2550”[tw] OR “AGO 40”[tw] OR “Amspec-KR”[tw] OR “AN 800”[tw] OR “Anchimonzol A 2550”[tw] OR “Antimonate(2)-, bis(mu-tartrato(4-))di-, dipotassium, trihydrate”[tw] OR “Antimonate(2-), bis(mu-(2,3- di(hydroxy-kappaO)butanedioato(4-)-kappaO1:kappaO4))di-, dipotassium, trihydrate, stereoisomer”[tw] OR “Antimonate(2-), bis(mu-(2,3-dihydroxybutanedioato(4-)-O(sup 1),O(sup 2):O(sup 3),O(sup 4)))-di-, dipotassium, trihydrate, stereoisomer”[tw] OR “Antimonate(2-), bis(u-(2,3-dihydroxybutanedioato(4-)-O1,O2,O3,O4))di-, dipotassium, trihydrate”[tw] OR “Antimonate(2-), bis[.mu.-[2,3-di(hydroxy-,kappa.O)butanedioato(4-)- .kappa.O(1):.kappa.O4]]di-, dipotassium, trihydrate, stereoisomer”[tw] OR “Antimonate(2-), bis[.mu.-[2,3-di(hydroxy-.kappa.O)butanedioato(4-)-.kappa.O1:.kappa.O4]]di-, dipotassium, trihydrate, stereoisomer”[tw] OR “Antimonial saffron”[tw] OR “Antimonic oxide”[tw] OR “Antimonic sulfide”[tw] OR “Antimonious oxide”[tw] OR “Antimonous chloride”[tw] OR “Antimonous sulfide”[tw] OR “Apox S”[tw] OR “AT 3 (fireproofing agent)”[tw] OR “AT 3B”[tw] OR “Atox B”[tw] OR “Atox F”[tw] OR “Atox R”[tw] OR “Atox S”[tw] OR “C.I. 77060”[tw] OR “C.I. Pigment Red 107”[tw] OR “C.I. Pigment White 11”[tw] OR “Chemetron fire shield”[tw] OR “CI 77060”[tw] OR “CI Pigment Red 107”[tw] OR “CI Pigment white 11”[tw] OR “Dechlorane A-O”[tw] OR “Diantimony pentaoxide”[tw] OR “Diantimony pentasulphide”[tw] OR “Diantimony pentoxide”[tw] OR “Diantimony trioxide”[tw] OR “Diantimony trisulfide”[tw] OR “Dipotassium bis(mu-(L-(+)-tartrato(4-)))diantimonate(2-) trihydrate”[tw] OR “ENT 50,434”[tw] OR “Exitelite”[tw] OR “Fireshield FSPO 405”[tw] OR “FireShield H”[tw] OR “FireShield LS-FR”[tw] OR “Flame Cut 610”[tw] OR “Flame Cut 610R”[tw] OR “Flameguard VF 59”[tw] OR “HFR 201”[tw] OR “HM 203P”[tw] OR “Hydrogen antimonide”[tw] OR “LS-FR”[tw] OR “LSB 80”[tw] OR “Microfine A 05”[tw] OR “NCI-C55152”[tw] OR “Nyacol 1550”[tw] OR “Nyacol A 1510LP”[tw] OR “Nyacol A 1530”[tw] OR “Nyacol A 1590”[tw] OR “Nyacol ADP 480”[tw] OR “Nyacol ADP 494”[tw] OR “Nyacol AGO 40”[tw] OR “Octoguard FR 10”[tw] OR “Patox C”[tw] OR “Patox H”[tw] OR “Patox L”[tw] OR “Patox M”[tw] OR “Patox S”[tw] OR “Potassium antimonyl D-tartrate”[tw] OR “Sanka Anchimonzol A 2550M”[tw] OR “Stibic anhydride”[tw] OR “Stibiox MS”[tw] OR “Sun Epoch NA 100”[tw] OR “Sun Epoch NA 3070P”[tw] OR “Sun Epoch NA 3080P”[tw] OR “Suncolloid AME 130”[tw] OR “Suncolloid AMT 130”[tw] OR “Thermoguard B”[tw] OR “Thermoguard L”[tw] OR “Thermoguard S”[tw] OR “Timonox”[tw] OR “Timonox White Star”[tw] OR “Twinkling star”[tw]) NOT medline[sb]) AND (2014/02/01:3000[dp] OR 2015/02/01:3000[crdat] OR 2015/02/01:3000[edat])
Toxline
01/2018 | ( ( 7440-36-0 [rn] OR 1315-04-4 [rn] OR 1314-60-9 [rn] OR 28300-74-5 [rn] OR 10025-91-9 [rn] OR 1309-64-4 [rn] OR 1345-04-6 [rn] OR 7803-52-3 [rn] ) OR “antimony” OR “antimonyl potassium tartrate” OR “potassium antimonyl tartrate” OR “sb2o3” OR “senarmontite” OR “potassium antimonyltartrate” OR “stibine” OR “stibium” OR “stibnite” OR “tartar emetic” OR “trichlorostibine” OR “valentinite” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]; ( “anchimonzol a 2550” OR “antimonial saffron” OR “antimonic oxide” OR “antimonic sulfide” OR “antimonious oxide” OR “antimonous chloride” OR “antimonous sulfide” OR “apox s” OR “atox b” OR “atox f” OR “atox r” OR “atox s” OR “chemetron fire shield” OR “dechlorane a o” OR “diantimony pentaoxide” OR “diantimony pentasulphide” OR “diantimony pentoxide” OR “diantimony trioxide” OR “diantimony trisulfide” OR “ent 50 434” OR “exitelite” OR “fireshield fspo 405” OR “fireshield h” OR “fireshield ls fr” OR “flame cut 610” OR “flame cut 610r” OR “flameguard vf 59” OR “hfr 201” OR “hm 203p” OR “hydrogen antimonide” OR “ls fr” OR “lsb 80” OR “microfine a 05” OR “nci c55152” OR “nyacol 1550” OR “nyacol a 1510lp” OR “nyacol a 1530” OR “nyacol a 1590” OR “nyacol adp 480” OR “nyacol adp 494” OR “nyacol ago 40” OR “octoguard fr 10” OR “patox c” OR “patox h” OR “patox l” OR “patox m” OR “patox s” OR “potassium antimonyl d tartrate” OR “sanka anchimonzol a 2550m” OR “stibic anhydride” OR “stibiox ms” OR “sun epoch na 100” OR “sun epoch na 3070p” OR “sun epoch na 3080p” OR “suncolloid ame 130” OR “suncolloid amt 130” OR “thermoguard b” OR “thermoguard l” OR “thermoguard s” OR “timonox” OR “timonox white star” OR “twinkling star” ) AND 2014:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
Toxcenter
01/2018 | FILE ‘TOXCENTER’ ENTERED AT 08:52:47 ON 10 JAN 2018; => s 7440-36-0 OR 1315-04-4 OR 1314-60-9 OR 28300-74-5 OR 10025-91-9 OR 1309- 64-4 OR 1345-04-6 OR 7803-52-3; L1 22076 7440-36-0 OR 1315-04-4 OR 1314-60-9 OR 28300-74-5 OR 10025-91-9 OR 1309-64-4 OR 1345-04-6 OR 7803-52-3; => s l1 not tscats/fs; L2 21927 L1 NOT TSCATS/FS; => s l2 not patent/dt; L3 17767 L2 NOT PATENT/DT; => s l3 and py>2014; L4 1973 L3 AND PY>2014; => s l3 and 20141201; L5 0 L3 AND 20141201; => s l3 and ed>=20141201; L6 2222 L3 AND ED>=20141201; => activate toxquery/q; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? ORSPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 O R L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 O R L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (NONHUMAN MAMMALS)/ORGN; L37 QUE L35 OR L36; L38 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L39 QUE L37 OR L38; => s l6 and l39; L40 1007 L6 AND L39; => s l40 and medline/fs; L41 141 L40 AND MEDLINE/FS; => s l40 and biosis/fs; L42 185 L40 AND BIOSIS/FS; => s l40 and caplus/fs; L43 681 L40 AND CAPLUS/FS; => s l40 not (medline/fs or biosis/fs or caplus/fs); L44 0 L40 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); => dup rem l41 l42 l43; => s l45 not medline/fs L46 141 S L45; L47 169 S L45; L48 597 S L45 3757645 MEDLINE/FS; L49 766 (L46 OR L47 OR L48) NOT MEDLINE/FS; => d scan l49

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS ^a^
01/2018 | Compounds searched: 7440-36-0; 1315-04-4; 1314-60-9; 28300-74-5; 10025-91-9; 1309-64-4; 1345-04-6; 7803-52-3
NTP
05/2019 | “antimony” “stibine” “7440-36-0” “1309-64-4”; “1315-04-4” “1314-60-9” “28300-74-5”; “10025-91-9” “1345-04-6” “7803-52-3”; “antimonyl potassium tartrate” “potassium antimonyl tartrate”; “sb2o3” “senarmontite” “potassium antimonyltartrate” “stibium”; “stibnite” “tartar emetic” “trichlorostibine” “valentinite”
NIH RePORTER
05/2019 | Text Search: “Antimony” OR “Antimonyl potassium tartrate” OR “Potassium antimonyl tartrate” OR “Sb2O3” OR “Senarmontite” OR “Potassium antimonyltartrate” OR; “Stibine” OR “Stibium” OR “Stibnite” OR “Tartar emetic” OR “Trichlorostibine” OR “Valentinite” OR “Antimonial saffron” OR “Antimonic oxide” OR “Antimonic sulfide” OR; “Antimonious oxide” OR “Antimonous chloride” OR “Antimonous sulfide” OR; “Diantimony pentaoxide” OR “Diantimony pentasulphide” OR “Diantimony pentoxide” OR “Diantimony trioxide” OR “Diantimony trisulfide” OR “Hydrogen antimonide” OR; “Potassium antimonyl D-tartrate” OR “Stibic anhydride" (Advanced), Search in: Projects AdminIC: All, Fiscal Year: Active Projects
Other | Identified throughout the assessment process

a Several versions of the TSCATS database were searched, as needed, by CASRN including TSCATS1 via Toxline (no date limit), TSCATS2 via https://yosemite.epa.gov/oppts/epatscat8.nsf/ReportSearch?OpenForm (date restricted by EPA receipt date), and TSCATS via CDAT (date restricted by ‘Mail Received Date Range’), as well as google for recent TSCA submissions.

The 2018 results were:

- Number of records identified from PubMed, TOXLINE, and TOXCENTER (after duplicate removal): 1,465
- Number of records identified from other strategies: 40
- Total number of records to undergo literature screening: 1,505

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on antimony:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 1,505
- Number of studies considered relevant and moved to the next step: 89

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 89
- Number of studies cited in the pre-public draft of the toxicological profile: 275
- Total number of studies cited in the profile: 332

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 January 2018 Literature Search Results and Screen for Antimony

Figure B-1. January 2018 Literature Search Results and Screen for Antimony