# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Human Health Sciences, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Division of Toxicology and Human Health Sciences, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

## Antimony Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL | 0.001 mg Sb/m^3^
Critical Effect: | Squamous metaplasia of the epiglottis
Reference: | NTP 2016
Point of Departure: | BMCL_10_ of 0.94 mg Sb/m^3^
Uncertainty Factor: | 30
LSE Graph Key: | 3
Species: | Mouse

MRL Summary: An acute-duration inhalation MRL of 0.001 mg Sb/m^3^ was derived for antimony based on an increased incidence of squamous metaplasia of the epiglottis observed in mice exposed to antimony trioxide for 17 days (NTP 2016). The MRL is based on a BMCL_10_ of 0.94 mg Sb/m^3^ (human equivalent BMCL_10_ of 0.035 mg Sb/m^3^) and an uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: No human studies have evaluated the acute inhalation toxicity of antimony. In laboratory animals, the acute toxicity has been evaluated for stibine, antimony trisulfide, and antimony trioxide. These studies clearly identify the respiratory tract as one of the most sensitive targets of antimony toxicity (Brieger et al. 1954; NIOSH 1979; NTP 2016). A 30-minute exposure to 1,395 mg Sb/m^3^ as stibine resulted in pulmonary edema and congestion and death in rats and guinea pigs (NIOSH 1979). Chronic lung inflammation was observed in rabbits exposed to 19.9 mg Sb/m^3^ as antimony trisulfide for 5 days (7 hours/day) and in rats exposed to 25 mg Sb/m^3^ as antimony trioxide for 12 exposures over a 16-day period (6 hours/day) (NTP 2016). NTP (2016) also found squamous metaplasia in the epiglottis of rats and mice exposed to 25 or 12 mg Sb/m^3^, respectively. The primary extrarespiratory effects also observed following acute exposure were degenerative changes in the heart and altered EKGs in rabbits exposed to 19.9 mg Sb/m^3^ as antimony trisulfide.

Selection of the Principal Study: The Brieger et al. (1954) and NTP (2016) studies were considered for derivation of an acute-duration inhalation MRL. Although the rats and mice in the NTP (2016) study were exposed to antimony trioxide over a 16- or 17-day period, the animals were only exposed for 12 or 13 times and the study was considered to be more reflective of effects associated with acute-duration exposure than intermediate-duration exposure. Potential points of departure (PODs) were calculated for both studies (see Selection of the POD section). The lowest POD was identified for the NTP (2016) mouse study, which was selected as the principal study.

Summary of the Principal Study:

NTP. 2016. Toxicology and carcinogenicity studies of antimony trioxide (CAS No. 1309-64-4) in Wistar HAN [Crl:WI (Han)] rats and B6C3F1/N mice (inhalation studies). National Toxicology Program, Research Triangle Park, NC. NTP TR 590. Draft for Peer Review.

Groups of five male and five female B6C3F1/N mice were exposed to 0, 3.75, 7.5, 15, 30, or 60 mg/m^3^ antimony trioxide (0, 3.1, 6.3, 12, 25, and 50 mg Sb/m^3^) 6 hours/day, 5 days/week for 13 exposures in a 17-day period. An additional group of five female mice was similarly exposed and held for a 28-day recovery period. The actual concentrations were 3.71, 7.43, 14.7, 30.2, and 59.4 mg Sb_2_O_3_/m^3^. The MMADs (geometric standard deviations) for the particles were 1.4 (1.9), 1.3 (1.9), 1.5 (1.9), 1.4 (1.9), and 1.4 (1.9) μm for the 3.1, 6.3, 12, 25, and 50 mg Sb/m^3^ concentrations, respectively. The following parameters were used to assess toxicity: twice daily observations; body weights on days 1, 6, and 13, and at termination; organ weights (kidney, liver, lung, testis, thymus); and histopathological examination in the control and 50 mg Sb/m^3^ group (histopathological examinations of the larynx, lung, lymph nodes, nose, pharynx, and trachea were conducted to a no-effect level). In the animals allowed to recover, antimony levels were measured in blood samples collected at the end of the exposure and recovery periods and in the lungs.

Although the mice were exposed to antimony trioxide over a 17-day period, the animals were only exposed for 13 times and the study was considered to be more reflective of effects associated with acute-duration exposure than intermediate-duration exposure.

No deaths, clinical findings, or alterations in body weight gain were observed. Significant increases in absolute lung weights were observed in males at ≥6.3 mg Sb/m^3^ and in females at ≥12 mg Sb/m^3^; increases in relative lung weights were observed in males at 50 mg Sb/m^3^ and in females at ≥3.1 mg Sb/m^3^. Minimal to mild squamous metaplasia was observed in the epiglottis epithelium at ≥25 mg Sb/m^3^; the incidences were 0/10 in controls and 2/10, 4/9, 10/10, and 10/10 in the 6.3, 12, 25, and 50 mg Sb/m^3^ groups, respectively. Increases in the presence of foreign body (presumably antimony trioxide) were observed in the lungs of mice exposed to ≥3.1 mg Sb/m^3^. No concentration-related alterations in lung clearance were observed. The clearance half-times ranged from 47 to 62 days.

Selection of the Point of Departure for the MRL: The MRL is based on a BMCL_10_ of 0.94 mg Sb/m^3^ for squamous metaplasia of the epiglottis in male and female mice.

Several endpoints were considered for derivation of an acute-duration inhalation MRL for antimony: altered EKGs and degenerative changes in the heart in rabbits exposed to 19.9 mg Sb/m^3^ as antimony trisulfide (Brieger et al. 1954), lung inflammation in rabbits exposed to 19.9 mg Sb/m^3^ as antimony trisulfide (Brieger et al. 1954), squamous metaplasia of the epiglottis in male and female rats exposed to ≥25 mg Sb/m^3^ as antimony trioxide (NTP 2016), chronic lung inflammation in rats exposed to ≥25 mg Sb/m^3^ as antimony trioxide (NTP 2016), and squamous metaplasia of the epiglottis in male and female mice exposed to ≥12 mg Sb/m^3^ as antimony trioxide (NTP 2016).

For the NTP (2016) study, the incidence data (Table A-1) for squamous metaplasia in rats and mice were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS; version 2.6.0) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR). Among all of the models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the benchmark concentration) was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. For all lesion types, a BMR of 10% was used. Since the response level for chronic inflammation was the same for all non-control concentrations (see Table A-1), BMD modeling was not conducted for this endpoint and the NOAEL was used as the POD. The model predictions for the epiglottal squamous metaplasia for rats and mice are presented in Tables A-2 and A-3 and the fits of the selected models are presented in Figures A-1 and A-2. The Brieger et al. (1954) study only tested one concentration of antimony trisulfide, and was not considered suitable for BMD modeling; the LOAEL of 19.9 mg Sb/m^3^ for lung and cardiovascular effects was considered the POD for this study.

Table A-1 Incidence of Respiratory Tract Effects in Male and Female Rats and Mice Exposed to Antimony Trioxide^a^

Effect | Concentrations (mg Sb/m^3^)
Effect | 0 | 3.1 | 6.3 | 12 | 25 | 50
Rats
Squamous metaplasia of epiglottis | 0/10 | –^b^ | –^b^ | 1/10 | 4/9^c^ | 5/10^c^
Chronic lung inflammation | 0/10 | 0/10 | 0/10 | 0/10 | 10/10^c^ | 10/10^b^
Mice
Squamous metaplasia of epiglottis (male and female) | 0/10 | –^d^ | 2/10 | 4/9^c^ | 10/10^c^ | 10/10^c^

a Male and female incidences were combined.

b Incidence in the female rats was 1/5; males were not examined at these concentrations.

c Significantly different from controls.

d Incidence in the female mice was 2/5; males were not examined at this concentration.

Source: NTP 2016

Table A-2 Model Predictions for the Incidence of Squamous Metaplasia of the Epiglottis in Male and Female Rats (Combined) Exposed to Antimony Trioxide (NTP 2016)

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Gamma^c^ | 2 | 1.04 | 0.60 | 0.00 | −0.49 | 0.83 | 37.76 | 7.77 | 4.18
Logistic | 2 | 3.09 | 0.21 | −0.28 | 1.41 | 1.41 | 40.25 | 16.36 | 10.83
LogLogistic ^d^ ^,^ ^e^ | 2 | 0.90 | 0.64 | 0.00 | −0.46 | 0.75 | 37.62 | 8.47 | 2.95
LogProbit^d^ | 3 | 0.99 | 0.80 | 0.00 | −0.16 | 0.78 | 35.68 | 10.99 | 7.27
Multistage (1-degree)^f^ | 3 | 1.03 | 0.79 | 0.00 | −0.59 | 0.79 | 35.78 | 6.79 | 4.17
Multistage (2-degree)^f^ | 3 | 1.03 | 0.79 | 0.00 | −0.59 | 0.79 | 35.78 | 6.79 | 4.17
Multistage (3-degree)^f^ | 3 | 1.03 | 0.79 | 0.00 | −0.59 | 0.79 | 35.78 | 6.79 | 4.17
Probit | 2 | 2.86 | 0.24 | −0.22 | 1.38 | 1.38 | 39.91 | 15.35 | 10.31
Weibull^c^ | 2 | 1.04 | 0.59 | 0.00 | −0.53 | 0.82 | 37.77 | 7.40 | 4.17

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Selected model. All models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMCL was selected (Log Logistic).

f Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10; ND (LS) = not determined; largest scaled residual >2

Figure A-1 Fit of LogLogistic Model to Data on Incidence of Epiglottal Squamous Metaplasia in Male and Female Rats Exposed to Antimony Trioxide (mg Sb/m^3^)

Table A-3 Model Predictions for the Incidence of Squamous Metaplasia of the Epiglottis in Male and Female Mice (Combined) Exposed to Antimony Trioxide (NTP 2016)

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Gamma^c^ | 3 | 1.04 | 0.79 | 0.00 | 0.48 | −0.71 | 27.68 | 5.49 | 2.39
Logistic | 3 | 0.85 | 0.84 | −0.43 | 0.62 | 0.62 | 27.48 | 5.83 | 3.53
LogLogistic^d^ | 3 | 1.77 | 0.62 | 0.00 | 0.66 | −0.86 | 28.64 | 5.79 | 3.17
LogProbit^d^ | 3 | 1.55 | 0.67 | 0.00 | 0.56 | −0.89 | 28.31 | 5.73 | 3.25
Multistage (1-degree)^e^,^f^ | 4 | 4.22 | 0.38 | 0.00 | −1.16 | −1.16 | 30.45 | 1.40 | 0.94
Multistage (2-degree)^e^ | 4 | 0.70 | 0.95 | 0.00 | 0.05 | 0.59 | 25.41 | 4.41 | 1.74
Multistage (3-degree)^e^ | 3 | 0.27 | 0.97 | 0.00 | 0.24 | −0.36 | 26.73 | 4.34 | 1.60
Multistage (4-degree)^e^ | 3 | 0.06 | 1.00 | 0.00 | 0.12 | 0.15 | 26.46 | 3.56 | 1.49
Probit | 3 | 0.59 | 0.90 | −0.34 | 0.51 | 0.51 | 27.12 | 5.48 | 3.28
Weibull^c^ | 3 | 0.61 | 0.89 | 0.00 | 0.48 | −0.51 | 27.08 | 5.33 | 2.40

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. All models provided adequate fit to the data. BMCLs for models providing adequate fit were not sufficiently close (differed by >3-fold). Therefore, the model with lowest BMCL was selected (Multistage 1 degree).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10; ND (LS) = not determined; largest scaled residual >2

Figure A-2 Fit of 1-Degree Multistage Model to Data on Incidence of Epiglottal Squamous Metaplasia in Male and Female Mice Exposed to Antimony Trioxide (mg Sb/m^3^)

A summary of the potential PODs (BMCLs for the selected models, LOAELs, or NOAELs for models without adequate fit) is presented in Table A-4.

Table A-4 Summary of Potential Points of Departures (PODs) and Human Equivalent Concentrations (HECs) for Acute-Duration Inhalation MRL for Antimony

Endpoint (reference) | PODs (mg Sb/m^3^) | RDDR values^a^ | HECs^b^ (mg Sb/m^3^)
Squamous metaplasia of the epiglottis in male and female rats (NTP 2016) | 2.95 (BMCL_10_) | 0.162^c^ | 0.085
Chronic lung inflammation (NTP 2016) | 12 (NOAEL) | 0.545^c^ | 1.1
Squamous metaplasia of the epiglottis in male and female mice (NTP 2016) | 0.94 (BMCL_10_) | 0.206^c^ | 0.035
Lung inflammation in rabbits (Brieger et al. 1954) | 19.9 (LOAEL) | 0.203^d^ | 1.2
Degenerative changes in heart and altered EKG readings in rabbits (Brieger et al. 1954) | 19.9 (LOAEL) | 1.060^d^ | 6.2

a RDDR values specific for each region of the respiratory tract (extrathoracic and pulmonary) were calculated using EPA’s RDDR calculator with the average of the male and female terminal body weights of 0.189 and 0.0281 kg for rats and mice, respectively, and 4.0 kg for rabbits.

b HEC calculated by multiplying the duration-adjusted POD (POD × 6 hours/24 hours × 5 days/7 days for the NTP [2016] study and POD × 7 hours/24 hours × 5 days/7 days for the Brieger et al. [1954] study) by the RDDR value.

c Calculated using a particle size of 1.4 μm (sigma g of 1.9).

d Calculated using a particle size of 2 μm (sigma g of 1.9); this is an assumed value; the investigators noted that most of the particles were <2 μm, but did not provide any additional information. EPA = Environmental Protection Agency; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed- adverse-effect level; NTP = National Toxicology Program; RDDR = regional deposited dose ratio

Calculations

Intermittent Exposure: Concentrations tested in the NTP (2016) and Brieger et al. (1954) studies were adjusted for intermittent exposure (6 hours/24 hours, 5 days/7 days for NTP [2016] and 7 hours/day for Brieger et al. [1954]).

Human Equivalent Concentration: HECs were calculated for each potential POD by multiplying the POD_ADJ_ by the regional deposited dose ratio (RDDR) for the appropriate region of the respiratory tract. The RDDRs were calculated using EPA’s RDDR calculator with the calculated average male and female terminal body weights of 0.189 and 0.0281 kg for rats and mice, respectively, for the NTP (2016) study and a reference body weight of 4.0 kg for the rabbits. The POD_HEC_ values are presented in Table A-4.

Uncertainty Factor:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

- MRL = BMCL_HEC_ ÷ uncertainty factors
- 0.001 mg Sb/m^3^ = 0.0.035 mg Sb/m^3^ ÷ 30

Other Additional Studies or Pertinent Information that Lend Support to this MRL: There are limited data for comparing the relative toxicity of antimony compounds following acute inhalation exposure. The respiratory tract was a sensitive target in animals exposed to stibine, antimony trioxide, or antimony trisulfide, but differences in the study designs do not allow for a direct comparison. Additionally, there are no data to allow for an assessment of the influence of valence state on the respiratory toxicity of antimony.

Agency Contacts (Chemical Managers): Melanie Buser

## Antimony Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The acute-duration inhalation MRL of 0.001 mg Sb/m^3^ was adopted as the intermediate-duration inhalation MRL. The intermediate-duration database was not considered suitable for derivation of an MRL. An MRL based on the lowest POD_HEC_ estimated from an intermediate-duration study is slightly higher than the acute-duration inhalation MRL.

Rationale for Not Deriving an MRL: Information on the toxicity of inhaled antimony following intermediate-duration exposure primarily comes from a 13-week study in rats exposed to antimony trioxide (Newton et al. 1994) that identified the respiratory tract as the most sensitive effect and 6–10-week studies in rats, rabbits, and dogs (Brieger et al. 1954) that examined a limited number of endpoints and identified the respiratory tract and myocardium as the most sensitive endpoints. The systematic review identified the respiratory effects as presumed health effects in humans and myocardial damage and alterations in EKGs as suspected health effect in humans. In the Newton et al. (1994) study, exposure to ≥4.11 mg Sb/m^3^ resulted in increases in alveolar/intra-alveolar macrophages, increases in relative lung weights, and increases in lung clearance half-times in rats killed at the end of the exposure period. In rats allowed to recover for 27 weeks, significant increases in the incidences of chronic interstitial inflammation and fibrosis were observed in rats exposed to 19.60 mg Sb/m^3^. Mild congestion and focal hemorrhages were also observed in the lungs of rats exposed to 2.20 mg Sb/m^3^ as antimony trisulfide for 6 weeks (Brieger et al. 1954); however, the investigators did not report the incidence of this effect, which precludes assessing the significance of the finding. Brieger et al. (1954) also found antimony trisulfide-induced alterations in EKGs and histological alterations in the myocardium of rats exposed to 2.20 mg Sb/m^3^ for 6 weeks, dogs exposed to 3.98 mg Sb/m^3^ for 10 weeks (no alterations were observed in dogs exposed to 3.81 mg Sb/m^3^ for 7 weeks), and rabbits exposed to 4.02 mg Sb/m^3^ for 6 weeks. A third intermediate-duration study reported unspecified lesions in the lungs, liver, kidneys, and pancreas (only qualitative data were provided), decreases in fertility, and decreases in litter size in rats exposed to 209 mg Sb/m^3^ as antimony trioxide for 1.5–2 months (Belyaeva 1967).

The lung effects (increases in lung clearance time, chronic interstitial inflammation, and interstitial fibrosis) and the myocardial effects (histological alterations and altered EKGs) observed in the rats and rabbits were considered as the basis for an intermediate-duration MRL for antimony; the effects observed in dogs were not considered because reference values are not available for estimating the RDDR. BMD modeling was utilized to estimate the potential PODs for the histological alterations in the lungs observed in the Newton et al. (1994) study, but could not be utilized for the cardiac effects from the Brieger et al. (1954) studies due to the lack of incidence data. These incidence data were fit to all available dichotomous models in EPA’s BMDS (version 2.6.0) using the extra risk option; see Appendix A for details on the BMD modeling results. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL (95% lower confidence limit on the benchmark concentration) was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. For all lesion types, a BMR of 10% was used. The results of the BMD modeling for the chronic interstitial inflammation and lung fibrosis are presented in Tables A-5 and A-6 and the fits of the selected models are presented in Figures A-3 and A-4.

Table A-5 Model Predictions for the Incidence of Chronic Lung Interstitial Inflammation in Rats Exposed to Antimony Trioxide for 13 Weeks Followed by a 27-Week Recovery Period (Newton et al. 1994)

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Gamma^c^ | 2 | 1.01 | 0.60 | 0.66 | −0.01 | −0.75 | 277.38 | 2.97 | 0.69
Logistic | 3 | 1.85 | 0.60 | 0.45 | 0.45 | −0.93 | 276.71 | 0.87 | 0.61
LogLogistic^d^ | 2 | 1.02 | 0.60 | 0.66 | 0.00 | −0.76 | 277.38 | 3.68 | 1.76
LogProbit^d^ | 2 | 1.02 | 0.60 | 0.66 | 0.00 | −0.76 | 277.38 | 3.44 | 1.68
Multistage (1-degree)^f^ | 3 | 3.05 | 0.38 | 0.49 | 0.30 | −1.30 | 278.32 | 0.64 | 0.43
Multistage (2-degree)^e^ | 2 | 0.79 | 0.67 | 0.56 | −0.21 | −0.59 | 277.19 | 1.81 | 0.59
Multistage (3-degree)^e^ | 2 | 0.53 | 0.77 | 0.43 | −0.14 | −0.52 | 276.90 | 1.33 | 0.57
Multistage (4-degree)^e^ | 2 | 0.47 | 0.79 | 0.39 | −0.13 | −0.50 | 276.83 | 1.19 | 0.55
Probit ^f^ | 3 | 1.23 | 0.75 | 0.46 | −0.73 | −0.73 | 275.81 | 0.95 | 0.66
Weibull^c^ | 2 | 0.90 | 0.64 | 0.62 | −0.08 | −0.70 | 277.27 | 2.30 | 0.67

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. All models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with lowest AIC was selected (Probit).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10; ND (LS) = not determined; largest scaled residual >2

Figure A-3 Fit of Probit Model to Data on Incidence of Chronic Lung Interstitial Inflammation in Rats Exposed to Antimony Trioxide (mg Sb/m^3^)

Table A-6 Model Predictions for the Incidence of Lung Fibrosis in Rats Exposed to Antimony Trioxide for 13 Weeks Followed by a 27-Week Recovery Period (Newton et al. 1994)

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Gamma^c^ | 2 | 2.97 | 0.23 | −1.42 | 0.32 | −1.42 | 298.77 | 3.40 | 1.31
Logistic ^f^ | 3 | 3.37 | 0.34 | 1.51 | 0.16 | −1.51 | 297.19 | 2.69 | 2.14
LogLogistic^d^ | 2 | 2.88 | 0.24 | −1.38 | 0.22 | −1.38 | 298.66 | 3.29 | 1.41
LogProbit^d^ | 2 | 2.69 | 0.26 | −1.32 | 0.13 | −1.32 | 298.45 | 3.25 | 2.08
Multistage (1-degree)^e^ | 3 | 4.56 | 0.21 | −1.60 | −0.52 | −1.60 | 298.39 | 1.61 | 1.17
Multistage (2-degree)^e^ | 2 | 3.26 | 0.20 | −1.51 | 0.41 | −1.51 | 299.09 | 3.40 | 1.27
Multistage (3-degree)^e^ | 2 | 3.26 | 0.20 | −1.51 | 0.41 | −1.51 | 299.09 | 3.40 | 1.27
Multistage (4-degree)^e^ | 2 | 3.26 | 0.20 | −1.51 | 0.41 | −1.51 | 299.09 | 3.40 | 1.27
Probit | 3 | 3.39 | 0.34 | −1.52 | 0.16 | −1.52 | 297.20 | 2.67 | 2.18
Weibull^c^ | 2 | 3.07 | 0.22 | −1.45 | 0.33 | −1.45 | 298.88 | 3.36 | 1.30

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Slope restricted to ≥1.

e Betas restricted to ≥0.

f Selected model. All models provided adequate fit to the data. BMCLs for models providing adequate fit were sufficiently close (differed by <3-fold). Therefore, the model with lowest AIC was selected (Logistic).

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10; ND (LS) = not determined; largest scaled residual >2

Figure A-4 Fit of Logistic Model to Data on Incidence of Lung Fibrosis in Rats Exposed to Antimony Trioxide (mg Sb/m^3^)

A summary of the PODs and HECs are presented in Table A-7. The POD_HEC_ values, which were based on BMCL_10_ or NOAEL values, ranged from 0.19 to 0.078 mg Sb/m^3^ and the POD_HEC_ values, based on LOAEL values, were 0.89 and 1.5 mg Sb/m^3^. To compare the two types of PODs, the POD_HEC_ values based on LOAELs were divided by an uncertainty factor of 10 resulting in values of 0.15 and 0.089 mg Sb/m^3^. The POD_HEC_ values for the increased lung clearance half-time, chronic lung interstitial inflammation, and degenerative heart effects and altered EKG readings in rabbits were similar, and the lowest value of 0.057 mg Sb/m^3^ for chronic lung inflammation was selected as the basis of the MRL. This human equivalent value of 0.057 mg Sb/m^3^ was divided by an uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability), resulting in an MRL of 0.002 mg Sb/m^3^. However, this MRL is slightly higher than the acute-duration inhalation MRL, and ATSDR adopted the acute-duration MRL of 0.001 mg Sb/m^3^ for intermediate-duration exposure.

Table A-7 Summary of Potential Points of Departures (PODs) and Human Equivalent Concentrations (HECs) for Intermediate-Duration Inhalation MRL for Antimony

Endpoint (reference) | PODs (mg Sb/m^3^) | RDDR values^a^ | HECs^b^ (mg Sb/m^3^)
Increased lung clearance half-times in rats (Newton et al. 1994) | 0.902 (NOAEL) | 0.487^c^ | 0.078
Chronic lung interstitial inflammation in rats (Newton et al. 1994) | 0.66 (BMCL10) | 0.487^c^ | 0.057
Chronic lung fibrosis in rats (Newton et al. 1994) | 2.14 (BMCL10) | 0.487^c^ | 0.19
Degenerative changes in heart and altered EKG readings in rats (Brieger et al. 1954) | 2.20 (LOAEL) | 3.185^d^ | 1.5
Degenerative changes in heart and altered EKG readings in dogs (Brieger et al. 1954) | 3.98 (LOAEL) | NA^e^ | NA
Degenerative changes in heart and altered EKG readings in rabbits (Brieger et al. 1954) | 4.02 (LOAEL) | 1.060^d^ | 0.89

a RDDR values specific for each region of the respiratory tract (extrathoracic and pulmonary) were calculated using EPA’s RDDR calculator, with estimated body weight of 0.230 kg for the Newton et al. (1994) study and reference body weights of 0.267 and 4.0 kg for rats and rabbits in the Brieger et al. (1954) study.

b HEC calculated by multiplying the duration-adjusted POD (POD x 6 hours/24 hours x 5 days/7 days for the Newton et al. [1994] study and 7 hours/day, 5 days/week for the Brieger et al. [1954] study) by the RDDR value.

c Calculated using a particle size of 3.05 μm (sigma g of 1.57).

d Calculated using a particle size of 2 μm (sigma g of 1.9), which is an assumed value; the investigators noted that most of the particles were <2 μm, but did not provide any additional information.

e RDDR calculator does not have default values for dogs and HECs could not be calculated.

BMCL = 95% lower confidence limit on the benchmark concentration; EKG = electrocardiogram; EPA = Environmental Protection Agency; LOAEL = lowest-observed-adverse-effect level; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; RDDR = regional deposited dose ratio

Agency Contacts (Chemical Managers): Melanie Buser

## Antimony Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic
MRL | 0.0003 mg Sb/m^3^
Critical Effect: | Lung inflammation in rats
Reference: | Newton et al. 1994
Point of Departure: | BMCL_10_ of 0.10 mg Sb/m^3^
Uncertainty Factor: | 30
LSE Graph Key: | 16
Species: | Rat

MRL Summary: A chronic-duration inhalation MRL of 0.0003 mg Sb/m^3^ was derived for antimony based on an increased incidence of lung inflammation in female rats exposed to antimony trioxide 6 hours/day, 5 days/week for 12 months (Newton et al. 1994). The MRL is based on a BMCL_10_ of 0.10 mg Sb.m^3^ (human equivalent BMCL of 0.008 mg Sb/m^3^) and an uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: The toxicity of airborne antimony has not been extensively studied in humans. Several occupational exposure studies have reported lung effects (pneumoconiosis, chronic bronchitis) in workers at antimony smelters (Cooper et al. 1968; Potkonjak and Pavlovich 1983; Schnorr et al. 1995). Signs of upper respiratory tract irritation including bleeding of the nose, rhinitis, upper airway inflammation, and laryngitis (Potkonjak and Pavlovich 1983; Renes 1953) have also been reported in workers. Other effects that have been observed in workers include altered EKGs (Brieger et al. 1954) and dermatitis, which is likely due to direct contact with skin (Potkonjak and Pavlovich 1983; Renes 1953). One study also reported reproductive disturbances and developmental effects (decreases in infant growth) in female workers exposed to metallic antimony, antimony trioxide, and antimony pentasulfide (Belyaeva 1967). Although some studies provided exposure levels, these studies were not considered suitable for derivation of a chronic MRL because many studies did not include control groups, wide ranges of antimony levels were reported, and many involved co-exposure to other compounds including arsenic.

A number of studies have evaluated the chronic toxicity of antimony compounds in rats and mice. These studies provide strong evidence that the respiratory tract is the primary target of antimony toxicity, which is supported by the systematic review of the toxicity data that concluded that respiratory tract toxicity is a presumed health effect in humans. The lowest LOAEL values were identified in three studies involving antimony trioxide exposure for 1–2 years (Newton et al. 1994; NTP 2016; Watt 1983). Higher LOAELs for lung effects were identified for other antimony compounds: 17.5 mg Sb/m^3^ as antimony ore for interstitial fibrosis (Groth et al. 1986) and 84 mg Sb/m^3^ as antimony trisulfide for lipoid pneumonia (Gross et al. 1952). Although these LOAELs are higher than those identified for antimony trioxide, the available data do not allow a comparison between compounds since adverse effects were often observed at the lowest concentration tested. A summary of the NOAEL and LOAEL values for the respiratory effects is presented in Table A-8. In addition to the pulmonary effects, effects have also been observed in the nasal cavity (respiratory epithelial hyperplasia), lymph nodes (lymphoid hyperplasia in bronchial and mediastinal lymph nodes), eyes (lenticular degeneration), and bone marrow (hyperplasia); the LOAELs for these effects (see Table A-8) are similar to those identified for respiratory effects.

Table A-8 Summary of NOAEL and LOAEL Values for Effects Observed in Target Tissues

NOAEL (mg Sb/m^3^) | LOAEL (mg Sb/m^3^) | Effect | Reference
Respiratory effects
0.05 | 0.43 | Chronic interstitial inflammation in female rats exposed to antimony trioxide for 1 year | Newton et al. 1994
| 1.6 | Focal fibrosis, pneumocyte hyperplasia in rats exposed to antimony trioxide for 55 weeks | Watt 1983
| 2.5 | Lung inflammation, proteinosis, alveolar epithelial hyperplasia, bronchiole epithelial hyperplasia, lung fibrosis in rats exposed to antimony trioxide for 2 years | NTP 2016
| 2.5 | Nasal respiratory epithelial hyperplasia in rats exposed to antimony trioxide for 2 years | NTP 2016
| 2.5 | Nasal respiratory epithelial inflammation in male mice exposed to antimony trioxide for 2 years | NTP 2016
| 2.5 | Lung inflammation, alveolar fibrosis, pleural fibrosis and inflammation, alveolar and bronchiolar epithelial hyperplasia in mice exposed to antimony trioxide for 2 years | NTP 2016
0.43 | 3.8 | Chronic interstitial inflammation in male rats exposed to antimony trioxide for 1 year | Newton et al. 1994
| 17.5 | Interstitial fibrosis and alveolar wall hypertrophy and hyperplasia in rats exposed to antimony ore for 1 year | Groth et al. 1986
| 36 | Interstitial fibrosis and alveolar wall hypertrophy and hyperplasia in rats exposed to antimony trioxide for 1 year | Groth et al. 1986
| 84 | Lipoid pneumonia in rats exposed to antimony trisulfide for 14.5 months | Gross et al. 1952
Bone marrow effects
| 2.5 | Bone marrow hyperplasia in mice exposed to antimony trioxide for 2 years | NTP 2016
Lymphoreticular effects
| 2.5 | Lymphoid hyperplasia in bronchial and mediastinal lymph nodes in rats exposed to antimony trioxide for 2 years | NTP 2016
| 2.5 | Lymphoid hyperplasia of bronchial lymph nodes in mice exposed to antimony trioxide for 2 years | NTP 2016
Ocular effects
0.05 | 0.43 | Lenticular degeneration in rats exposed to antimony trioxide for 1 year | Newton et al. 1994

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: Four studies identified LOAEL values of <5 mg Sb/m^3^ for lung effects in rats (Newton et al. 1994; NTP 2016; Watt 1983) and mice (NTP 2016). Watt (1983) found increases in the incidence of focal fibrosis, adenomatous hyperplasia, cholesterol clefts, and pneumocyte hyperplasia in rats exposed to 1.6 mg Sb/m^3^ for 55 weeks. In rats and mice exposed to 2.5 mg Sb/m^3^ as antimony trioxide for 2 years, inflammation, proteinosis, alveolar/bronchiolar hyperplasia, and fibrosis were observed in the lungs (NTP 2016). An increase in lung clearance times was observed in rats exposed to 3.8 mg Sb/m^3^ as antimony trioxide for 12 months and an increase in the severity and incidence of chronic lung inflammation was observed at 0.43 (females only) and 3.8 mg Sb/m^3^ was after a 1-year recovery period (Newton et al. 1994). Some non-respiratory effects have also been seen at similar concentrations, including lenticular degeneration in rats exposed to 0.43 mg Sb/m^3^ (Newton et al. 1994), bone marrow hyperplasia in mice exposed to 2.5 mg Sb/m^3^ (NTP 2016), and lymphoid hyperplasia in bronchial and/or mediastinal lymph nodes in rats and mice exposed to 2.5 mg Sb/m^3^ (NTP 2016). Newton et al. (1994) identified the lowest LOAEL value for chronic interstitial lung inflammation and lenticular degeneration in rats exposed to 0.43 mg Sb/m^3^ for 1 year with a 1-year recovery period; these effects were not observed at 0.05 mg Sb/m^3^. The other chronic-duration studies identified higher LOAEL values.

Summary of the Principal Study:

Newton PE, Bolte HF, Daly IW, et al. 1994. Subchronic and chronic inhalation toxicity of antimony trioxide in the rat. Fundam Appl Toxicol 22(4):561–576.

Groups of 65 male and 65 female Fischer 344 rats were exposed to 0, 0.06, 0.51, or 4.50 mg/m^3^ antimony trioxide dust (0, 0.05, 0.43, or 3.8 mg Sb/m^3^, respectively) 6 hours/day, 5 days/week for 12 months followed by a 12-month observation period. Groups of five rats/sex were terminated after 6 and 12 months of exposure and at 6 months postexposure; the remaining animals were terminated 12 months postexposure. The MMAD was 3.76±0.84 µm with a geometric standard deviation of 1.79±0.326. The following parameters were used to assess toxicity: weekly detailed observations, body weight measurements (weekly for the first 13 weeks and monthly thereafter), ophthalmoscopic examination, hematological (hemoglobin, hematocrit, erythrocyte count, mean corpuscular hemoglobin, hemoglobin concentration, and volume, and total leukocyte counts) and clinical chemistry (aspartate aminotransferase, alanine aminotransferase, alkaline phosphatase, blood urea nitrogen, fasting glucose, total protein, chloride, sodium, and potassium) indices assessed at 12, 18, and 24 months, and histopathological examination of the heart, nasal turbinates, larynx, trachea, lung, and peribronchial lymph nodes.

No increases in mortality were observed. Corneal effects were observed during the study; however, the investigators noted that the effects were equally distributed among exposed and control groups and were similar to spontaneous degenerative conditions observed in Fischer 344 rats. The investigators noted a concentration-related increase in the occurrence of chromodacryorrhea (incidence data not provided); they noted that microscopic periodontal disease was also observed in some rats and that the chromodacryorrhea may be secondary to this effect. At the end of the recovery period, an increase in the occurrence of cataracts (focal posterior cataract, posterior subcapsular cataract, complete cataract) was observed (incidences of 6/55, 12/49, 18/64, and 19/60 were reported in Bio/Dynamics 1990); the incidence was statistically significant at ≥0.43 mg Sb/m^3^ (Fisher Exact Test conducted by SRC). No treatment-related alterations in body weight gain, hematological indices, clinical chemistry indices, or lung weights were observed. At the end of the exposure period and at the end of the recovery period, statistically significant (Fisher Exact Test conducted by ATSDR) increases in the incidence of alveolar/intraalveolar macrophages were observed at ≥0.05 mg Sb/m^3^. Histological alterations were observed in the lungs of rats killed at the end of the recovery periods: chronic interstitial inflammation at 0.43 (females only) and 3.8 mg Sb/m^3^ and interstitial fibrosis at 3.8 mg Sb/m^3^. Although a high incidence of lung inflammation was also observed in controls, the investigators noted that the inflammation observed in the controls was considered a “spontaneous lesion” and that the incidence and severity of the inflammation was concentration-related (see Table A-9). Increases in antimony trioxide lung clearance half-times were observed; the half-times (data reported in Bio/Dynamics 1990) in the male and female rats were 3.0 and 4.2 months, respectively, at 0.43 mg Sb/m^3^ and 8.7 and 10.2 months, respectively, at 3.8 mg Sb/m^3^, as compared to 2.5 and 2.2 months, respectively, in the 0.05 mg Sb/m^3^ group. No significant increases in the incidence of neoplastic lesions were observed.

Table A-9 Incidence and Severity of Chronic Interstitial Lung Inflammation in Rats Exposed to Antimony Trioxide for 1 Year with a 1-Year Recovery

| Concentration (mg Sb/m^3^)
Severity | 0 | 0.05 | 0.43 | 3.8
Males
Minimal | 4/52 (12.5)^a^ | 7/52 (18.9) | 12/53 (33.3) | 0/52 (0)
Slight | 19/52 (59.4) | 27/52 (73) | 24/53 (66.7) | 14/52 (29.2)
Moderate | 8/52 (25) | 3/52 (8.1) | 0/53 (0) | 32/52 (66.7)
Moderately severe | 1/52 (3.1) | 0/52 (0) | 0/53 (0) | 2/52 (3.8)
Females
Minimal | 3/49 (9.1) | 12/52 (30) | 14/54 (29.1) | 1/50 (2.1)
Slight | 24/49 (72.7) | 23/52 (57.5) | 23/54 (47.9) | 29/50 (60.4)
Moderate | 6/49 (18.2) | 5/52 (12.5) | 11/54 (22.9) | 18/50 (37.5)
Moderately severe | 0/49 (0) | 0/52 (0) | 0/54 (0) | 0/50 (0)

a Percentage of total lesions with a specific severity score.

Source: Newton et al. 1994

Selection of the Point of Departure for the MRL: BMCL_10_ of 0.10 mg Sb/m^3^ (BMCL_HEC_ of 0.008 mg Sb/m^3^) for lung inflammation in female rats.

BMD modeling was utilized to estimate the potential PODs for the histological alterations observed in lungs and eyes. The incidence data from the Newton et al. (1994) (Table A-10) study were fit to all available dichotomous models in EPA’s BMDS (version 2.6.0) using the extra risk option. Adequate model fit was judged by three criteria: goodness-of-fit statistics (p-value >0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. The results of the BMD modeling for lung inflammation in female rats is presented in Table A-11 and the model fit is presented in Figure A-5. The incidence data for lung inflammation in males were not considered suitable for modeling since only the highest concentration group showed a response; thus, the data provide limited information on the shape of the concentration-response curve. For lenticular degeneration, none of the available models provided an adequate fit to the data.

Table A-10 Incidence of Nonneoplastic Lesions in Rats Exposed to Antimony Trioxide for 1 Year with a 1-Year Recovery

Effect | Concentration (mg Sb/m^3^)
Effect | 0 | 0.05 | 0.43 | 3.8
Chronic lung inflammation in males | 32/52 | 37/52 | 36/53 | 48/52^a^
Chronic lung inflammation in females | 33/49 | 40/52 | 48/54^a^ | 48/50^a^
Lenticular degeneration | 6/55 | 12/49 | 18/64^a^ | 19/60^a^

a Significantly different from controls.

Source: Newton et al. 1994

Table A-11 Model Predictions for Antimony Trioxide, Incidence of Chronic Lung Inflammation in Female Rats Exposed to Antimony Trioxide for 1 Year with a 1-Year Recovery Period (Newton et al. 1994)

Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Scaled residuals^b^ | | | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Model | DF | X^2^ | X^2^ Goodness-of-fit p-value^a^ | Dose below BMC | Dose above BMC | Overall largest | AIC | BMC_10_ (mg Sb/m^3^) | BMCL_10_ (mg Sb/m^3^)
Gamma ^c^ ^.^ ^d^ | 2 | 4.3 | 0.12 | 0.13 | 1.51 | 1.51 | 181.03 | 0.18 | 0.10
Logistic | 2 | 4.63 | 0.10 | 0.07 | 1.56 | 1.56 | 181.38 | 0.22 | 0.13
LogLogistic^e,f^ | 2 | 1.15 | 0.56 | −0.43 | 0.44 | −0.81 | 177.59 | 0.04 | 0.01
LogProbit^d^ | 2 | 5.21 | 0.07 | 0.26 | 1.47 | 1.47 | 181.64 | ND | ND
Multistage (1-degree)^g^ | 2 | 4.3 | 0.12 | 0.13 | 1.51 | 1.51 | 181.03 | 0.18 | 0.10
Multistage (2-degree)^g^ | 2 | 4.3 | 0.12 | 0.13 | 1.51 | 1.51 | 181.03 | 0.18 | 0.10
Multistage (3-degree)^g^ | 2 | 4.3 | 0.12 | 0.13 | 1.51 | 1.51 | 181.03 | 0.18 | 0.10
Probit | 2 | 4.9 | 0.09 | 0.03 | 1.62 | 1.62 | 181.68 | ND | ND
Weibull^c^ | 2 | 4.3 | 0.12 | 0.13 | 1.51 | 1.51 | 181.03 | 0.18 | 0.10

a Values <0.1 fail to meet conventional goodness-of-fit criteria.

b Scaled residuals at doses immediately below and above the BMC; also the largest residual at any dose.

c Power restricted to ≥1.

d Selected model. BMCLs for models providing adequate fit were sufficiently close; therefore the model with the lowest AIC was selected

e Slope restricted to ≥1.

f Model considered an outlier because the BMCL was 10 times lower than the other models.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); DF = degrees of freedom; ND = not determined, goodness-of-fit criteria, p<0.10; ND (LS) = not determined; largest scaled residual >2

Figure A-5 Fit of Gamma Model to Data on Incidence of Lung Interstitial Inflammation in Female Rats Exposed to Antimony Trioxide (mg Sb/m^3^)

The PODs for each endpoint are presented in Table A-12; for lung inflammation in males and lenticular degeneration, the NOAEL was used as the POD since the incidence data were not considered suitable for BMD modeling. The lowest POD_HEC_ was 0.008 mg Sb/m^3^ for lung inflammation in female rats.

Table A-12 Summary of Potential Points of Departure (PODs) for Derivation of Chronic-Duration Inhalation MRL for Antimony

Endpoint (reference) | POD (mg Sb/m^3^) | RDDR^a^ | HECb (mg Sb/m^3^)
Chronic interstitial inflammation in male rats (Newton et al. 1994) | 0.43 (NOAEL) | 0.330 | 0.025
Chronic interstitial inflammation in female rats (Newton et al. 1994) | 0.10 (BMCL10) | 0.436 | 0.008
Lenticular degeneration in rats (Newton et al. 1994) | 0.05 (NOAEL) | 2.797 | 0.025

a RDDR values specific for each region of the respiratory tract (pulmonary and extrarespiratory) were calculated using EPA’s RDDR calculator with reference body weights of 0.380 and 0.229 kg for male and female rats in the Newton et al. (1994) study and particle size of 3.76 μm (sigma g of 1.79).

b HEC calculated by multiplying the duration-adjusted POD (POD × 6 hours/24 hours × 5 days/7 days) by the RDDR value.

BMCL = 95% lower confidence limit on the benchmark concentration; HEC = human equivalent concentration; MRL = Minimal Risk Level; NOAEL = no-observed-adverse-effect level; POD = point of departure; RDDR = regional deposited dose ratio

Calculations

Intermittent Exposure: Each potential POD was adjusted for intermittent exposure (6 hours/24 hours, 5 days/7 days).

Human Equivalent Concentration: HECs were calculated by multiplying the POD_ADJ_ by the RDDR for the appropriate region of the respiratory tract. The RDDRs were calculated using EPA’s RDDR calculator with reference body weights of 0.380 and 0.229 kg for male and female rats and particle size of 3.76 μm (sigma g of 1.79). The POD_HEC_ values are presented in Table A-12.

Uncertainty Factor:

- 3 for extrapolation from animals to humans with dosimetric adjustments
- 10 for human variability

- MRL = POD_HEC_ ÷ uncertainty factors
- 0.0003 mg Sb/m^3^ = 0.008 mg Sb/m^3^ ÷ 30

Other Additional Studies or Pertinent Information that Lend Support to this MRL: There are limited data to compare the relative toxicity of antimony compounds. Chronic studies have tested antimony trioxide, antimony trisulfide, and antimony ore; the respiratory tract was the most sensitive target in all of these studies. It is difficult to compare the potency of the different compounds because in most cases, the lowest concentration tested was a LOAEL. No data were available to compare the toxicity of trivalent and pentavalent antimony compounds.

Agency Contacts (Chemical Managers): Melanie Buser

## Antimony Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL | 1 mg Sb/kg/day
Critical Effect: | Hepatocellular cytoplasmic vacuolization and forestomach focal ulceration
Reference: | NTP 1992
Point of Departure: | NOAEL of 99 mg Sb/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 2
Species: | Mouse

MRL Summary: An acute-duration oral MRL of 1 mg Sb/kg/day was derived for antimony based on an increased incidence of cytoplasmic vacuolization in the liver and focal ulceration in the forestomach of mice exposed to antimony potassium tartrate in drinking water for 14 days (NTP 1992). The MRL is based on a NOAEL of 99 mg Sb/kg/day and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Studies conducted in the 1920s and 1940s demonstrate that antimony potassium tartrate is a gastrointestinal irritant in humans (Dunn 1928) and animals (as reviewed by Elinder and Friberg 1986) resulting in vomiting and diarrhea shortly after exposure. Houpt et al. (1984) demonstrated that the mean latency to vomit was 30 minutes after dogs drank 4.8 mg Sb/kg as antimony potassium tartrate. These gastrointestinal effects are likely due to the antimony concentration rather than the dose. NTP (1992) evaluated the acute toxicity of antimony potassium tartrate in 14-day drinking water studies in rats and mice. In rats, the highest concentration (61 mg Sb/kg/day) did not result in significant alterations in body weight or histopathological alterations in major tissues and organs. In mice, exposure to 150 mg Sb/kg/day resulted in focal ulceration in the forestomach and minimal to moderate hepatocellular cytoplasmic vacuolization. Exposure to 99 and 150 mg Sb/kg/day resulted in a transient decrease in body weight gain; at termination, body weights were within 93% of controls. The decreases in body weight may have been secondary to the dramatic decrease in water intake, which was also observed in the exposed mice.

Selection of the Principal Study: Although the Houpt et al. (1984) study identified the lowest LOAEL for acute exposure, this study was not selected as the basis of the MRL because the study only evaluated overt signs of gastrointestinal irritation and was a single exposure study. The mouse NTP (1992) study was selected as the principal study for derivation of the MRL.

Summary of the Principal Study:

NTP. 1992. Toxicology studies of antimony potassium tartrate in F344/N rats and B6C3F1/N mice (drinking water and intraperitoneal injection studies). National Toxicology Program, Research Triangle Park, NC. NTP TOX 11.

This study is also reported in: Dieter MP, Jameson CW, Elwell MR. 1991. Comparative toxicity and tissue distribution of antimony potassium tartrate in rats and mice dosed by drinking water or intraperitoneal injection. J Toxicol Environ Health 34:51–82.

Groups of 10 male and 10 female B6C3F1 mice were exposed to 0, 0.30, 0.65, 1.25, 2.5, or 5.0 mg/mL antimony potassium tartrate (99–100% purity) in drinking water for 14 days. The investigators used water consumption data and body weight averages to calculate doses of 0, 59, 98, 174, 273, and 407 mg/kg/day antimony potassium tartrate (0, 21, 36, 63, 99, and 150 mg Sb/kg/day). The following parameters were evaluated to assess toxicity: twice daily observations, body weight measurements (days 1 and 8 and at termination), water consumption (days 7 or 8 and day 15), organ weights, histopathology of major tissues and organs in control and high-dose groups (five mice/sex/group) and all early deaths, and histopathological examination of the liver and forestomach of mice in all groups (five mice/sex/group).

One female mouse in the 150 mg Sb/kg/day group died prior to the end of the study. On day 8, decreases in body weight gain were observed in males exposed to 99 mg Sb/kg/day and in males and females exposed to 150 mg Sb/kg/day. However, by the end of the study, the final weights of all antimony groups were within 93% of the controls. Decreases in water consumption were observed at all antimony levels. The investigators noted that overt signs of toxicity (rough haircoat, emaciation, abnormal posture, hypoactivity, and decreased fecal material, consistent with avoidance of the antimony potassium tartrate containing water) were observed, but did not specify if this was observed in all groups. Histological alterations were observed in the forestomach and liver of mice in the 150 mg/kg/day group. In the forestomach, focal areas of ulceration with necrosis and inflammation of the squamous mucosa were observed; the incidence was not reported, although the investigators noted that gross forestomach lesions were observed in one male and three females. In the liver, minimal to moderate cytoplasmic vacuolization was observed in all mice in the 150 mg Sb/kg/day group; the vacuolization had a centrilobular distribution with some extension into portal areas.

Selection of the Point of Departure for the MRL: The NOAEL of 99 mg Sb/kg/day for liver lesions was selected as the POD for the MRL.

BMD modeling was not conducted since lesions were only observed in the high-dose group. The transient decrease in body weight observed at 99 and 150 mg Sb/kg/day was not selected as the POD because this decrease may have been the result of decreased water consumption likely due to taste aversion.

Uncertainty Factor:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = NOAEL ÷ uncertainty factors
- 1 mg Sb/kg/day = 99 mg Sb/kg/day ÷ 100

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Support for identifying the liver as the critical effect for antimony is supported by intermediate-duration studies in which histological alterations were observed in rats exposed to antimony metal or antimony trioxide (Sunagawa 1981) and increases in alanine aminotransferase and aspartate aminotransferase in humans receiving injections of pentavalent antimony (Andersen et al. 2005). Insufficient evidence is available to allow for a comparison of the hepatotoxicity of different antimony compounds or valence states. The absorption rate of antimony potassium tartrate is greater than that of other antimony compounds (ICRP [1981] recommends rates of 10 and 1%, respectively), which likely results in a higher toxicity. More side effects (all effects) were observed in patients treated with antimony potassium tartrate than with pentavalent antimony compounds, although studies directly comparing the valency states on antimony hepatotoxicity were not identified. Alverez et al. (2005) reported greater cardiotoxicity and lethality in guinea pigs receiving intramuscular injections of 10 mg Sb/kg/day as antimony potassium tartrate, as compared to guinea pigs administered 16 mg Sb/kg/day as meglumine antimoniate.

Agency Contacts (Chemical Managers): Melanie Buser

## Antimony Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL | 0.0006 mg Sb/kg/day
Critical Effect: | Decreased serum glucose in female rats
Reference: | Poon et al. 1998
Point of Departure: | NOAEL of 0.06 mg Sb/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 12
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.0006 mg Sb/kg/day was derived for antimony based on decreases in serum glucose levels in female rats exposed to antimony potassium tartrate in drinking water for 13 weeks (Poon et al. 1987). The MRL is based on a NOAEL of 0.06 mg Sb/kg/day and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Several studies have evaluated the intermediate-duration toxicity of antimony compounds. Observed effects include reductions in body weight gain, decreases in serum glucose levels, and developmental effects (decreased pup body weight and altered vasomotor response in pups). The NOAEL and LOAEL values for these effects are presented in Table A-13. The results of several 12–24-week studies provide evidence for compound-specific differences in toxicity that are likely reflective of differences in the relative absorption of the compounds. More soluble compounds such as antimony potassium tartrate and antimony trichloride appear to be more toxic than antimony trioxide.

Table A-13 List of NOAEL and LOAEL Values in Rats Exposed to Antimony or Antimony Compounds for Intermediate Durations

Exposure duration, compound | NOAEL (mg Sb/kg/day) | LOAEL (mg Sb/kg/day) | Effect | Reference
Body weight effects
GDs 1–22; Antimony trichloride (W) | 0.07 | 0.7 | Decreased maternal body weight gain (11%) | Marmo et al. 1987; Rossi et al. 1987
12 weeks; Antimony metal (F) | | 85 | Decreased body weight gain (10%) | Hiraoka 1986
13 weeks; Antimony potassium tartrate (W) | 42.17 | | No alterations in body weight gain | Poon et al. 1998
13 weeks; Antimony trioxide (F) | 1,408 | | No alterations in body weight gain | Hext et al. 1999
Serum glucose levels
13 weeks; Antimony potassium tartrate (W) | 0.06 | 0.64 | Decreases in serum glucose in female rats | Poon et al. 1998
Developmental effects
LDs 0–22; PNDs 22–60; Antimony trichloride (W) | | 0.1 (post-weaning dose) | Altered vasomotor response in pups | Angrisani et al. 1988; Marmo et al. 1987
GDs 0–22; pups exposed on PNDs 22–60; Antimony trichloride (W) | | 0.1 (post-weaning dose) | Altered vasomotor response in pups | Rossi et al. 1987; Marmo et al. 1987
GDs 0–22; pups exposed on PNDs 22–60; Antimony trichloride (W) | 0.07 | 0.7 | Decreased pup growth on PNDs 10–60 | Rossi et al. 1987

(F) = dietary exposure; GD = gestation day; LD = lactation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PND = postnatal day; (W) = drinking water exposure

Based on the limited available data, the toxicity of antimony potassium tartrate appears to be higher than antimony metal and antimony trioxide, which is likely due to the differences in absorption. ICRP (1981) recommends an absorption rate of 10% for antimony potassium tartrate and 1% for all other antimony compounds. A study (Alkhawajah et al. 1996) comparing the developmental toxicity of antimony trichloride (trivalent), sodium stibogluconate (pentavalent), and meglumine antimonate (pentavalent) in rats following intramuscular injections reported similar effects for the three compounds; although no direct comparisons were made, the magnitude of the alterations (decreases in fetal viability and body weight) appears to be similar for the three compounds.

Selection of the Principal Study: Three studies identified LOAEL values of 0.1–0.64 mg Sb/kg/day in rats exposed to antimony trichloride or antimony potassium tartrate. The effects observed at these concentrations included altered vasomotor response in rat pups exposed to antimony trichloride during gestation and/or lactation and on PNDs 22–60 (Angrisani et al. 1988; Rossi et al. 1987), decreases in pup growth on PNDs 10–60 (Rossi et al. 1987), and decreases in serum glucose levels in rats exposed to antimony potassium tartrate for 13 weeks (Poon et al. 1998). These three endpoints were considered for the basis of the intermediate-duration MRL. Developmental toxicity and decreases in serum glucose levels were both considered suspected health effects in humans based on the systematic review of the available data on antimony; of the two developmental effects, only the decrease in growth was considered due to the uncertainty associated with estimating the dose for the vasopressor studies. In these studies, rats were exposed during gestation and/or lactation and then exposed on PNDs 22–60; the 0.1 mg Sb/kg/day dose is an estimate of the postnatal exposure, but does not include an estimate of prenatal exposure or exposure via breast milk.

Selection of the Point of Departure for the MRL: NOAEL of 0.06 mg Sb/kg/day for decreased serum glucose in female rats.

BMD modeling was considered for the decreases in serum glucose levels and decreases in pup body weight on PNDs 10 and 22. The serum glucose levels (Table A-14) and pup body weights (Table A-15) were fit to all available continuous models in EPA’s BMDS (version 2.6.0). The following procedure for fitting continuous data was used. The simplest model (linear) was first applied to the data while assuming constant variance. If the data were consistent with the assumption of constant variance (p≥0.1), then the fit of the linear model to the means was evaluated and the polynomial, power, and Hill models were fit to the data while assuming constant variance. Adequate model fit was judged by three criteria: goodness-of-fit p-value (p>0.1), visual inspection of the dose-response curve, and scaled residual at the data point (except the control) closest to the predefined BMR. Among all of the models providing adequate fit to the data, the lowest BMCL was selected as the POD when the difference between the BMCLs estimated from these models was >3-fold; otherwise, the BMCL from the model with the lowest AIC was chosen. If the test for constant variance was negative, the linear model was run again while applying the power model integrated into the BMDS to account for nonhomogenous variance. If the nonhomogenous variance model provided an adequate fit (p≥0.1) to the variance data, then the fit of the linear model to the means was evaluated and the polynomial, power, and Hill models were fit to the data and evaluated while the variance model was applied. Model fit and POD selection proceeded as described earlier. If the test for constant variance was negative and the nonhomogenous variance model did not provide an adequate fit to the variance data, then the data set was considered unsuitable for modeling. For all models, a BMR of 1 standard deviation change from the control was used.

Table A-14 Serum Glucose Concentrations in Female Rats Exposed to Antimony Potassium Tartrate for 13 Weeks

Dose (mg Sb/kg/day) | Serum glucose concentration (mean±standard deviation, mg/dL)
0 | 242±55
0.06 | 217±22
0.64 | 200±25^a^
6.13 | 207±27^a^
45.69 | 198±25^a^

a Significantly different from controls.

Source: Poon et al. 1988

Table A-15 Alterations in Pup Body Weight on Postnatal Days (PNDs) 10 and 22 in Pups Exposed to Antimony Trichloride During Gestation and Lactation

Dose (mg Sb/kg/day) | Pup body weight (mean±standard error)
Dose (mg Sb/kg/day) | PND 10 | PND 22
0 | 23±1.8 (73)^a^ | 58±5.1 (66)
0.07 | 20±2.6 (80) | 52±4.0 (72)
0.7 | 17±0.4^b^ (63) | 31±2.8^b^ (56)

a Number in parentheses is the number of pups examined; data were not presented in a way that would allow analysis on a per-litter basis.

b Significantly different from controls.

Source: Rossi et al. 1987

None of the models provided adequate fit to the serum glucose data or the PND 10 body weight data. Although adequate statistical fit was found for the PND 22 body weight data (model results are presented in Table A-16), the BMDL for the model with the lowest AIC (Exponential, model 3) was 0.72 mg Sb/kg/day, which is the same value as the empirical LOAEL identified in the study and was not considered a suitable basis for an MRL. Thus, a NOAEL/LOAEL approach was utilized to identify the POD for the intermediate-duration oral MRL. The NOAEL and LOAEL values for the decreased serum glucose level and the decreased pup body weight were similar and the endpoint with the lowest LOAEL (decreased serum glucose level) was selected as the basis of the MRL.

Table A-16 Model Predictions for Alterations in Pup Body Weight on Postnatal Day (PND) 22 in Pups Exposed to Antimony Trichloride During Gestation and Lactation (Rossi et al. 1987)

Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Scaled residuals^c^ | | | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Model | Test for significant difference p-value^a^ | Variance p-value^b^ | Means p-value^b^ | Dose below BMD | Dose above BMD | Overall largest | AIC | BMD_1SD_ (mg/kg/day) | BMDL_1SD_ (mg/kg/day)
Constant variance
Linear^e^ | <0.0001 | <0.0001 | 0.54 | 0.05 | NA | −0.44 | 1,562.44 | NA | NA
Nonconstant variance
Exponential (model 2)^d^ | <0.0001 | 0.61 | 0.27 | 0.03 | NA | −0.31 | 1,540.28 | 1.32 | 0.86
Exponential (model 3)^d,e^ | <0.0001 | 0.61 | 0.27 | 0.03 | NA | −0.31 | 1,540.28 | 1.32 | 0.72
Exponential (model 4)^d^ | | | | | | | | | ND
Exponential (model 5)^d^ | | | | | | | | | ND
Hill^d^ | | | | | | | | | ND
Linear^f^ | <0.0001 | 0.61 | 0.20 | 0.00 | NA | 0.39 | 1,540.70 | 1.07 | 0.81
Polynomial (2-degree)^f^ | <0.0001 | 0.61 | 0.20 | 0.00 | NA | 0.39 | 1,540.70 | 1.07 | 0.80
Power^d^ | <0.0001 | 0.61 | 0.20 | 0.00 | NA | 0.39 | 1,540.70 | 1.07 | 0.71

a Values >0.05 fail to meet conventional goodness-of-fit criteria.

b Values <0.10 fail to meet conventional goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the benchmark dose; also the largest residual at any dose.

d Power restricted to ≥1.

e Selected model. Constant variance model did not provide adequate fit to the variance data. With nonconstant variance model applied, all models (except for the Exponential 4, and 5, and Hill models) provided adequate fit to the means. BMDLs for models providing adequate fit were sufficiently close (differed by <2–3-fold), so the model with the lowest AIC was selected (Exponential 3; the Exponential 2 and 3 had the same AIC, so the model with the more conservative BMDL was selected out of these two).

f Coefficients restricted to be negative.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 10 = exposure concentration associated with 10% extra risk); NA = not applicable; ND = not determined (BMDL computation failed); SD = standard deviation

Summary of the Principal Study:

Poon R, Chu I, Lecavalier P, 1998. Effects of antimony on rats following 90-day exposure via drinking water. Food Chem Toxicol 36:21–35.9487361

Groups of 15 male and 15 female Sprague-Dawley rats were exposed to 0, 0.5, 5, 50, or 500 ppm antimony as potassium antimony tartrate (99.95% pure) in drinking water for 13 weeks. Based on average water consumption and body weight data, the investigators calculated antimony doses of 0, 0.06, 0.56, 5.58, and 42.17 mg Sb/kg/day in males and 0, 0.06, 0.64, 6.13, and 45.69 mg Sb/kg/day in females. An additional group of 10 male and 10 female rats was exposed to 0 or 500 ppm for 13 weeks followed by a 4-week recovery period. The following parameters were used to assess toxicity: weekly body weight, food consumption, and water intake measurements; hematological indices (erythrocyte counts hemoglobin, hematocrit, mean corpuscular volume, and total and differential leukocyte counts); clinical chemistry indices (albumin, alkaline phosphatase, aspartate aminotransferase, creatine kinase, sorbitol dehydrogenase, bilirubin, calcium, cholesterol, creatinine, glucose, inorganic phosphate, lactic dehydrogenase, total protein, urea nitrogen, and uric acid); serum thyroxin and thyroid hormone binding ratio; organ weights (brain, thymus, heart, kidney, spleen, liver); and histopathological examination (brain, pituitary, thyroid and trachea, salivary glands, thymus, lung, heart, liver, kidneys, adrenals, spleen, pancreas, esophagus, stomach, small and large intestine, urinary bladder, skin, bone marrow, and gonadal tissues).

No alterations in survival or overt signs of toxicity were observed. Decreases in water consumption (35% lower than controls) and food consumption (12%) were observed in the 42.17/45.69 mg Sb/kg/day group during the exposure period but not during the recovery period.

- Body weight: A decrease in body weight gain, significant in males starting at week 6 and females at week 12, was observed at 42.17/45.69 mg Sb/kg/day; the body weights appeared to be within 10% of the controls. A significant increase in relative kidney weights was observed in the 42.17/45.69 mg Sb/kg/day group.
- Metabolic: A dose-related decrease (15–17%) in serum glucose levels was observed in females exposed to ≥0.64 mg Sb/kg/day; lower values were also observed in the males, but were not statistically different from controls. No differences in serum glucose levels were observed at the end of the recovery period. ATSDR notes that serum glucose levels in all groups (including controls) were higher than the range of normal values reported by the animal supplier (Charles River Laboratories 2006).
- Clinical chemistry: Decreases in serum creatinine levels and alkaline phosphatase levels were observed in males and females exposed to 42.17/45.69 mg Sb/kg/day at the end of the exposure period, but not at the end of the observation period. A decrease (24%) in serum cholesterol level was observed in females exposed to 45.69 mg Sb/kg/day; the toxicological significance of this alteration is not known.
- Hematological: Decreases in red blood cells and platelet counts and increases in mean corpuscular volume were observed in males exposed to 42.17 mg Sb/kg/day; in females, the only hematological alteration was an increase in monocytes at 45.69 mg Sb/kg/day. Significant increases in hepatic ethoxyresorufin-O-deethylase and glutathione-S-transferase activities were observed in males at 42.17 mg Sb/kg/day; glutathione-S-transferase activity was also increased in females at 45.69 mg Sb/kg/day.
- Hepatic: Histological alterations included anisokaryosis in the liver in all antimony exposed groups; dose-related increases in the severity were also observed. Anisokaryosis was also observed at the end of the recovery period. Other hepatic effects included an increase in hepatocellular portal density in all antimony groups and minimal nuclear hyperchromicity at ≥0.56/0.64 mg Sb/kg/day, but there was not consistent dose-response relationship for this endpoint. The severity scores for the anisokaryosis were 0.1, 0.6, 1.0, 1.9, and 2.8 in the 0, 0.06, 0.56, 5.58, and 42.17 mg Sb/kg/day males; a severity score of 1 is considered minimal, 2 is mild, and 3 is moderate. In the females, the respective severity scores were 0.9, 1.5, 2.3, 2.3, and 2.6. Similarly, the increase in portal density in the hepatocellular cytoplasm was graded as minimal at the two lowest doses in the males and females and mild at the two highest doses. The anisokaryosis, hepatocellular density, and hyperchromicity are considered adaptive changes and were not considered adverse.
- Skeletal: In the bone marrow, an increase in myeloid hyperplasia was observed at ≥5.58 mg Sb/kg/day in males and ≥0.64 mg Sb/kg/day in females.
- Spleen: The following alterations were observed in the spleen: sinus congestion at ≥0.56 mg Sb/kg/day in males, sinus hyperplasia at 42.17 mg Sb/kg/day in males and ≥0.64 mg Sb/kg/day in females, and arterial cuff atrophy at 42.17 mg Sb/kg/day in males. In the recovery period, increases in incidence of sinus congestion (males only), arterial cuff atrophy, periarteriolar lymphocyte sheath cell density, and sinus hematopoiesis were observed.
- Endocrine: Statistically significant increases in thyroid hormone binding ratio were observed in females at 6.13 and 45.69 mg Sb/kg/day. Thyroid histological alterations included an increase in epithelial height, reduced follicle size, and nuclear vesiculation in antimony rats; an increased occurrence of collapsed follicles was observed in the antimony recovery group. These thyroid effects did not show a strong dose-response relationship and did not appear to affect thyroid function; the investigators did not consider them adverse.

Uncertainty Factor:

- 10 for extrapolation from animals to humans
- 10 for human variability

- MRL = NOAEL ÷ uncertainty factors
- 0.006 mg Sb/kg/day = 0.06 mg Sb/kg/day ÷ 100

Other Additional Studies or Pertinent Information that Lend Support to this MRL: The MRL is based on health effects observed in animals exposed to soluble antimony compounds; it is likely that oral exposure to insoluble antimony compounds would result in adverse effects occurring at higher dose levels.

Agency Contacts (Chemical Managers): Melanie Buser

## Antimony Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Antimony
CAS Numbers: | 7440-36-0
Date: | October 2019
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: The chronic-duration oral database was considered inadequate for derivation of an MRL. The two available studies examined a limited number of endpoints and decreases in survival were observed in the only doses tested.

Rationale for Not Deriving an MRL: Two studies have evaluated the chronic toxicity of antimony (Kanisawa and Schroeder 1969; Schroeder et al. 1970) in rats and mice exposed to antimony potassium tartrate in drinking water for a lifetime. Decreases in survival were observed in rats exposed to 0.63 mg Sb/kg/day (Schroeder et al. 1970) and in mice exposed to 0.35 mg Sb/kg/day (Kanisawa and Schroeder 1969). Both studies examined a limited number of endpoints. In rats, no cardiovascular or body weight alterations were observed; however, a decrease in nonfasting glucose levels was found at 0.63 mg Sb/kg/day. No hepatic or body weight alterations were observed in mice. Given the limited number of endpoints examined and decreases in survival at the only dose tested, neither study was considered suitable for derivation of a chronic-duration oral MRL.

Agency Contacts (Chemical Managers): Melanie Buser