# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Data pertaining to the chemical identity of ammonia are presented in Table 4-1. These data are for ammonia in its pure gaseous state (i.e., anhydrous ammonia). Ammonia is also commercially and commonly available as an aqueous solution; the most common commercial formulation is 28–30% NH_3_ (Weast et al. 1988). At this concentration, ammonia forms a nearly saturated solution in water. Data on ammonia in aqueous solution, ammonium hydroxide, and ammonium ion are also included in Table 4-1 where appropriate.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Ammonium hydroxide is a weak base that is partially ionized in water according to the equilibrium:

N H_3_ + H_2_ 0 ≡ [ N H_4_ O H ] ≡ N H_4_^+^ + O H^−^

The dissociation constant, K_b_, is 1.774x10^5^ at 25 °C (pK_b_ is 4.751) and increases slightly with increasing temperature (Weast et al. 1988). At pH 9.25 half of the ammonia will be un-ionized (NH_3_) and half will be ionized (NH_4_^+^). At pH 8.25 and 7.25, 90, and 99% of the ammonia will be ionized, respectively. Therefore, at most environmentally significant pHs, ammonia will be largely ionized; the fraction of un-ionized ammonia will become increasingly more important at pHs above 7. As a result, many physical and chemical properties will be a function of pH. For example, the solubility of ammonia in water will increase with decreasing pH. The volatility of ammonia increases with increasing pH; therefore, it volatilizes freely from solution at high pH values. Ammonium salts such as chloride, nitrate, and sulfate are strongly dissociated and very soluble in water (Weast et al. 1988); therefore, changes in pH will not normally result in the formation of ammonium precipitates.

The physical and chemical properties of ammonia are presented in Table 4-2. Also included are some chemical and physical properties of ammonia in solution. Ammonia in solution is widely available, and it is often referred to as ammonium hydroxide and has been also historically referred to as “spirit of hartshorn” (Windholz 1983).

Table 4-1 Chemical Identity of Ammonia

Characteristic | Information | Reference
Chemical name | Ammonia
Synonym(s) | Anhydrous ammonia, AM-FOL, Ammonia gas, Liquid ammonia, Nitro-sil, R 717, Spirit of hartshorn | EPA 1987a; Windholz 1983
Registered trade name(s) | No data
Chemical formula | NH_3_
Chemical structure | [image]
Identification numbers:
CAS Registry | 7664-41-7 | HSDB 2003
NIOSH RTECS | B00875000 | NIOSH 2002a
anhydrous ammonia | B00875000
aqueous solution | B00875000
aqua ammonia | B00875000
EPA Hazardous Waste | No data
OHM/TADS | 7216584 | OHM-TADS 1988
DOT/UN/NA/IMCO shipping
anhydrous | UN 1005 | NIOSH 2002a
solution (10–35%) | UN 2672
solution (35–50%) | UN 2073
solution (>50%) | UN 1005
HSDB | 162 | HSDB 2003
NCI | No data

CAS = Chemical Abstracts Services; DOT/UN/NA/IMCO = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Ammonia

Property | Value | Reference
Molecular weight | 17.03 | LeBlanc et al. 1978
Color | Colorless | LeBlanc et al. 1978
Physical state | Gas at room temperature | LeBlanc et al. 1978
Melting point | −77.7 °C | LeBlanc et al. 1978
Boiling point | −33.35 °C | LeBlanc et al. 1978
Density:
Gas | 0.7710 g/L | Weast et al. 1988
Aqueous solution (28%) | 0.89801 (20 °C) g/L | Windholz 1983
Liquid | 0.6818 g/L (−33.35 °C, 1 atm) | Windholz 1983
Vapor density | 0.5967 (air=1) | Windholz 1983
Specific gravity (25 °C) | 0.747 g/L | Lide 1998
Odor | Sharp, intensely irritating | Sax and Lewis 1987
Odor threshold:
Air | 25 ppm (18 mg/m^3^) | Amoore and Hautala 1983
| 48 ppm (34 mg/m^3^) | Leonardos et al. 1969
| 53 ppm (38 mg/m^3^) | Budavari et al. 1996
Water | 1.5 ppm | Amoore and Hautala 1983
pKa | 9.25 (25°C) | Lide 1998
Solubility:
Water
at 0 °C | 42.8% (w/w) | LeBlanc et al. 1978
| 47% (w/w) | Budavari et al. 1996
at 15 °C | 38% (w/w) | Budavari et al. 1996
at 20 °C | 33.1% (w/w) | LeBlanc et al. 1978
| 34% (w/w) | Budavari et al. 1996
at 25 °C | 34% (w/w) | LeBlanc et al. 1978
| 31% (w/w) | Budavari et al. 1996
at 30 °C | 28% (w/w) | Budavari et al. 1996
at 50 °C | 18% (w/w) | Budavari et al. 1996
Organic solvent(s)
at 0 °C | 20% (w/w) in absolute ethanol | Budavari et al. 1996
at 25 °C | 10% (w/w) in absolute ethanol | Budavari et al. 1996
| 16% (w/w) in methanol | Budavari et al. 1996
| Soluble in chloroform and ether | Budavari et al. 1996
Partition coefficients:
Log K_ow_ | 0.23 (estimated) | EPIWIN 2000
Log K_oc_ | 1.155 (estimated) | EPIWIN 2000
Vapor pressure:
Anhydrous NH_3_ | 8.5 atm (20 °C) | Sax and Lewis 1987
| 10.2 atm (25 °C) | Daubert and Danner 1989
Aqueous NH_3_ (28%) | 2.9 atm (25 °C) | Daubert and Danner 1989
Henry’s law constant | 1.6×10^−5^ atm-m^3^/mol (25 °C) | Betterton 1992
| 7.3×10^−6^ atm-m^3^/mol (pH 7, 23.4 °C)^a^ | Ayers et al. 1985
| 1.60×10^−5^ atm-m^3^/mol (25 °C)^b^ | Yoo et al. 1986
| 5.01×10^−6^ atm-m^3^/mol (5 °C) | Brimblecombe and Dawson 1984
Autoignition temperature | 650 °C | LeBlanc et al. 1978
Flashpoint | Not available
Flammability limits in air | 16–25% | LeBlanc et al. 1978
Conversion factors
ppm (v/v) to mg/m^3^ in air (20 °C) | 1 ppm (v/v) = 0.707 mg/m^3^ | Verschueren 1983
mg/m^3^ to ppm (v/v) in air (20 °C) | 1 mg/m^3^ = 1.414 ppm (v/v)
pH in water | 11.6 (1 N) | Windholz 1983
| 11.1 (0.1 N)
| 10.6 (0.01 N)
Explosive limits | Not available

a Unitless constant extrapolated from cited data.

b Unconverted value of 0.0168 kg-atm/mol was calculated from equation in citation.

pKa = The dissociation constant of the conjugate acid