# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U.S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Ammonia Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ammonia
CAS Number: | 7664-41-7
Date: | July 2004
Profile Status: | Third Draft Post-Public
Route: | [ X ] Inhalation [ ] Oral
Duration: | [ X ] Acute [ ] Intermediate [ ] Chronic
Graph Key: | 14
Species: | Human

[underlined: Minimal Risk Level]: 1.7 [ ] mg/kg/day [ X ] ppm

[underlined: Reference]: Verberk MM. 1977. Effects of ammonia in volunteers. Int Arch Occup Environ Health 39:73–81.885623

[underlined: Experimental design]: The study examined the effects of exposure to ammonia in a group of 16 volunteers. Eight of them (experts) knew the effects of ammonia from the literature, but had had no personal contact, whereas the remaining eight subjects (non-experts) were students from a non-science faculty and were not familiar with ammonia or experiments in laboratory situations. All members of a group were exposed on the same day to one of the concentrations tested (50, 80, 110, or 140 ppm). The testing was repeated with a 1-week interval. Immediately before and after exposure, vital capacity, forced expiratory volume, and forced inspiratory volume were measured. During exposure, each subject recorded subjective feelings every 15 minutes as no sensation (0), just perceptible (1), distinctly perceptible (2), nuisance (3), offensive (4), or unbearable (5). No statistical analysis was performed and there was no group exposed to air only. A few weeks after the experiments, the subjects were tested to measure (pre-existing) non-specific reactivity of the airways to exogenous stimuli.

[underlined: Effects noted in study and corresponding doses]: None of the participants was hypersusceptible to non-specific irritants. Results of the pulmonary function tests after exposure were not statistically significantly different from pre-exposure values. For the non-experts, there was a clear increase in the number of reported symptoms for smell, eye irritation, throat irritation, cough, and general discomfort as the exposure concentration increased. The latter was not as clear for the experts. The number of symptoms recorded with a score >3 (nuisance) for smell, eye irritation, nose, throat, and urge to cough for the 50, 80, 110, and 140 ppm exposure groups was 2, 2, 7, and 11, respectively, for the experts and 6, 12, 18, and 29, respectively, for the non-experts. It should also be mentioned that the subjective responses appeared more pronounced in the non-expert group than in the expert group.

[underlined: Dose and end point used for MRL derivation]: 50 ppm for mild irritation to the eyes, nose, and throat in humans exposed to ammonia gas for 2 hours.

Because the effects observed were local irritation effects, they were not time-dependent (but rather concentration-dependent), an adjustment to 24-hour exposure was not necessary.

[ ] NOAEL [ X ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ X ] 3 for use of a minimal LOAEL
- [ ] 10 for extrapolation from animals to humans
- [ X ] 10 for human variability

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]?

N/A

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]:

N/A

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Although the Verberk et al. (1977) study has limitations (no statistical analysis, subjective end points, no control group), it demonstrates that concentrations of 50 ppm ammonia can produce minimal discomfort in healthy members of the general population and therefore, should be avoided. Additional relevant information is provided by a study by Ferguson et al. (1977). In that study, a group of six healthy volunteers, not previously accustomed to working in an ammonia environment, were exposed 5 days/week to 25 ppm (2 hours/day), 50 ppm (4 hours/day), or 100 ppm (6 hours/day) of ammonia, or to 50 ppm of ammonia 6 hours/day for 6 weeks. End points monitored included subjective and objective measures of eye and throat irritation as well as pulse rate, respiration rate, pulmonary function (FVC, FEV), assessment of neurological function (reflex, balance, and coordination), and body weight. The exposure protocol consisted of a pre-exposure evaluation by a physician, 3 hours of exposure (this conflicts with exposure data on table 2 of the study and mentioned above), a mid-point physician’s observation, lunch break, 3 additional hours of exposure, and a third physician’s observation 30 minutes after exposure ceased. The conjunctiva and mucosa of the nose and throat were examined by a physician before and after each daily exposure and the degree of irritation noted was described as mild, moderate, or marked. Exposure to ammonia had no significant effect on the measures of respiratory function or in the neurological tests conducted. The results of the evaluations of irritation conducted by the physician showed no significant differences between the exposure groups, including the 0 ppm exposure group (pre-exposure). All subjects experienced some watering of the eyes and a sensation of dryness in the nose and throat and there was one observation of definite redness in the mucosa of the nose after a 6-hour exposure to 100 ppm during which time, there was an excursion to 200 ppm ammonia. No redness was observed in this subject the following morning. Throughout the study, the physician observed 6 cases of eye irritation, 20 of nose irritation, and 9 of throat irritation, and most cases appeared to have occurred the first week of the study during exposure to 50 ppm. It is difficult to determine in this study a NOAEL or LOAEL for irritation due to the different exposure durations experienced by the subjects, but it would appear that an exposure concentration of 100 ppm ammonia for 6 hours caused no significant changes in the vital functions measured and that 50 ppm can cause eye, nose, and throat irritation.

NIOSH (1974) reviewed 15 studies of case reports in which subjects were exposed to very high, but unquantified, concentrations of ammonia. The 15 reports provided a representative array of documented clinical findings including death, permanent eye lesions, and chronic respiratory symptoms, as well as acute lower and upper respiratory symptoms. The only quantitative information available was that a worker died 6 hours after estimated exposure to 10,000 ppm ammonia for an unspecified time (Mulder and Van der Zalm 1967). Studies with volunteers, also reviewed by NIOSH (1974), generally used concentrations of ammonia much higher than those in the studies by Verberk et al. (1977) or Ferguson et al. (1977) and/or exposure durations of only minutes. For example, exposure to a concentration of 500 ppm for 30 minutes caused respiratory irritation graded as severe by 2 out 7 subjects (Silverman et al. 1949). Four out of 6 volunteers exposed to 50 ppm ammonia for 10 minutes graded the irritation as “moderate” and none described it as “discomforting” or “painful” (MacEwen et al. 1970). All of the subjects rated the odor as “highly penetrating” at 50 ppm and 3 subjects gave the same rating to 30 ppm. IBT (1973) exposed 10 subjects to 32, 50, 72, and 134 ppm for 5 minutes and the frequency of positive findings was as follows: at 32 ppm, 1 subject complained of dryness of the nose; at 50 ppm, 2 subjects complained of dryness of the nose; at 72 ppm, 3 subjects experienced eye irritation, 2 had nasal irritation, and 3 had throat irritation; and at 134 ppm, 5 subjects had signs of lacrimation, 5 had eye irritation, 7 had nasal irritation, 8 had throat irritation, and 1 had chest irritation.

Collectively, the available information from studies in humans supports the 50 ppm exposure level from the Verberk et al. (1977) study as a minimal LOAEL for irritation in acute studies. In general, studies in animals have used higher exposure concentrations. For ammonia, a corrosive irritant gas that affects the portal of entry and produces irritation of the eyes and respiratory tract, use of human data should be preferred over animal studies.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney, MPH

## Ammonia and Ammonium Compounds Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Ammonia and Ammonium Compounds
CAS Number: | 7664-41-7
Date: | July 2004
Profile Status: | Third Draft Post Public
Route: | [ X ] Inhalation [ ] Oral
Duration: | [ ] Acute [ ] Intermediate [ X ] Chronic
Graph Key: | 47
Species: | Humans

[underlined: Minimal Risk Level]: 0.1 [ ] mg/kg/day [ X ] ppm

[underlined: Reference]: Holness DL, Purdham JT, Nethercott JR. 1989. Acute and chronic respiratory effects of occupational exposure to ammonia. Am Ind Hyg Assoc J 50:646–650.2596404

[underlined: Experimental design]: The study evaluated sense of smell, prevalence of respiratory symptoms (cough, bronchitis, wheeze, dyspnea, and others), eye and throat irritation, and lung function parameters (FVC, FEV_1_, FEV_1_/FVC, FEF_50_, and FEF_75_) in humans exposed for an average of 12.2 years in a soda ash plant (Holness et al. 1989). The cohort consisted of 52 workers and 35 controls. The subjects were assessed on two workdays: on the first workday of their workweek and on the last workday of their workweek. Spirometry was performed at the beginning and end of each work shift, so that each worker had four tests done. To determine the exposure levels, exposed and control workers were sampled over one work shift; the average sample collection period was 8.4 hours. All of the participants in the study were males.

[underlined: Effects noted in study and corresponding doses]: Analysis of the results showed no significant differences in the prevalence of reported symptoms, but the exposed workers reported that exposure in the plant aggravated some of their reported symptoms (cough, wheeze, nasal complaints, eye irritation, and throat discomfort). Odor threshold was not affected by exposure to ammonia and there were no significant differences in baseline lung functions between exposed and control subjects. Analysis of each worker separately showed no significant relationship between the level of ammonia exposure and changes in lung function. Also, when the workers were divided into groups of individuals that were exposed to low (<6.25 ppm), medium (6.25–12.5 ppm), and high (>12.5 ppm) ammonia levels, no significant association was found between reporting of symptoms, decline in baseline function, or increasing decline in function over the work shift and exposure to ammonia. Furthermore, no association was evident between increasing years of exposure and decreasing lung function. However, the power of the indices of both level and length of exposure is low because only eight workers were in areas with relatively high ammonia exposure.

The MRL was calculated by adjusting the NOAEL of 9.2 ppm (the mean TWA exposure concentration) for continuous exposure (9.2 x 8/24 hours x 5/7 days) and dividing by an uncertainty factor of 10 for the protection of sensitive individuals. A modifying factor of 3 was used for the lack of reproductive and developmental studies.

[underlined: Dose and end point used for MRL derivation]: 9.2 ppm for no significant alterations in lung function in chronically exposed workers.

[ X ] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [ ] 10 for extrapolation from animals to humans
- [X] 10 for human variability

[underlined: Modifying Factors used in MRL derivation]:

[X] 3 for lack of reproductive and developmental studies

[underlined: Was a conversion used from ppm in food or water to a mg/body weight dose]?

N/A.

[underlined: If an inhalation study in animals, list the conversion factors used in determining human equivalent dose]:

N/A.

[underlined: Other additional studies or pertinent information which lend support to this MRL]: Earlier studies summarized by NIOSH (1974) found that workers accustomed to 20 ppm ammonia did not complain of irritation symptoms, but showed slight redness in the conjunctiva. Those not accustomed had eye and respiratory discomfort and irritation. Another report stated that air levels below 5 ppm were associated with barely noticeable eye irritation. In yet an additional report, concentrations of 15–28 ppm in the work area produced slight eye irritation. More recent data reported respiratory effects associated with chronic-duration exposure to pollutants, including ammonia, in livestock confinement buildings and an increase in respiratory symptoms (such as bronchial reactivity/hyperresponsiveness, inflammation, cough, wheezing, or shortness of breath) and/or a decrease in lung function (such as forced expiratory volume in the first second [FEV_1.0_], maximum expiratory flow rates [MEF_50_ and MEF_75_], and maximal mid-expiratory flow rate [MMEF]) in farmers exposed to ammonia levels of 2.3–20.7 ppm (Choudat et al. 1994; Cormier et al. 2000; Donham et al. 1995, 2000; Heederik et al. 1990; Reynolds et al. 1996; Vogelzang et al. 1997, 2000). The farmers were also exposed to other possible respiratory toxins, such as dust and endotoxins. A cross-sectional study of male workers at two fertilizer factories in Saudi Arabia showed a significant association between exposure to ammonia gas and respiratory symptoms and bronchial asthma (Ballal et al. 1998). No continuous exposure levels could be calculated for these workers because the number of days worked per week was not provided. There were no chronic-duration inhalation studies in animals.

[underlined: Agency Contact (Chemical Manager)]: Nickolette Roney, MPH