# 9 REFERENCES

*Cited in text

*Aarkrog A. 1988. Studies of Chernobyl debris in Denmark. Environ Int 14:149–155.
ACGIH. 2000. Threshold limit values for chemical substances and physical agents and biological exposure indices. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
*Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect 103(Suppl. 7):103–112.
*Adraino DC. 1979. Factors affecting the availability of americium-241 to the rice plant. J Agric Food Chem 27(6):1369–1375.544669
Adriano DC, Delaney MS, Hoyt GD, . 1977. Availability to plants and soil extraction of americium-241 as influenced by chelating agent, lime, and soil type. Environ Exp Bot 17:69–77.
Agarande M, Benzoubir S, Bouisset P, . 2001. Determination of ^241^Am in sediments by isotope dilution high resolution inductively coupled plasma mass spectrometry (ID HR ICP- MS). Appl Radiat Isot 55:161–165.11393755
*Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Federal Register 54(174):37618–37634.
Ahier BA, Tracy BL. 1995. Radionuclides in the Great Lakes basin. Environ Health Perspect 103(Suppl. 9):89–101.
*Alberts JJ, Wahlgren MA, Orlandini KA, . 1989. The distributions of ^239,240^Pu, ^238^Pu, ^241^Am and ^137^Cs among chemically-defined components of sediments, settling particulates and net plankton of Lake Michigan. J Environ Radioact 9(2):89–104.
*Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2^nd^ ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
*Alvarez A, Navarro N. 1996. Methods for actinides and Sr-90 determination in urine samples. Appl Radiat Isot 47:869–873.8976042
*Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
*Andersen ME, Clewell HJ III, Gargas ML, . 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87:185–205.3824380
Anderson AL, Campbell GW, Griffith RV. 1979. In vivo measurement of actinides in the human lung. NTIS UCRL-83548.
*Anderson SS, Livens FR, Singleton DL. 1990. Radionuclides in grey seals. Mar Pollut Bull 21(7):343–345.
*ANL. 1999. Environmental monitoring at Argonne National Laboratory. Argonne National Laboratory. http://www.anl.gov/OPA/env/EMfacts.html. August 31, 1999.
Antwerp University. 1990. Study of murine stroma in fetal and postnatal haemopoietic organs and after radiocontamination with 241-americium utero and as adults. Wilrijk, Belgium: Department of Biology, Antwerp University. NTIS/DE92001322.
*Arthur WJ, Janke DH. 1986. Radionuclide concentrations in wildlife occurring at a solid radioactive waste disposal area. Northwest Sci 60(3):154–165.
*Arthur WJ, Markham OD, Groves CR, . 1987. Radionuclide export by deer mice at a solid radioactive waste disposal area in southeastern Idaho. Health Phys 52(1):45–53.3542904
*Artinger R, Kienzler B, Schüler W, . 1998. Effects of humic substances on the ^241^Am migration in a sandy aquifer: Column experiments with Gorleben groundwater/sediment systems. J Contam Hydrol 35:261–275.
*Askbrant S, Melin J, Sandalls J, . 1996. Mobility of radionuclides in undisturbed and cultivated soils in Ukraine, Belarus and Russia six years after the Chernobyl fallout. J Environ Radioact 31(3):287–312.
Assinder DJ, Yamamoto M, Kim CK, . 1993. Radioisotopes of thirteen elements in intertidal coastal and estuarine sediments in the Irish Sea. J Radioanal Nucl Chem 170(2):333–346.
*ASTM. 1997. American Society for Testing of Materials. Annual Book of ASTM Standards, Vol. 12.01. Philadelphia, PA: ASTM, 626–629.
Atherton DR, Lloyd RD. 1972. The distribution and retention of ^249^Cf in beagle soft tissue. Health Phys 22:675–677.5083998
Atomic Energy of Canada. 1992. Proceedings of the fetal dosimetry workshop held in Chalk River, ON (Canada), 25-26 June 1991. Chalk River, Ontario: Chalk River Nuclear Labs, Atomic Energy of Canada. NTIS/DE94-622280. AECL-10578.
Atomic Energy Control Board. 1989. Literature review of the studies on uptake, retention and distribution of radionuclides by the foetus. Ottawa, Ontario: Atomic Energy Control Board. NTIS/DE92620289.
*Badjin VI, Molokanov AA. 1998. Application of the recent ICRP models for estimating the intake of ^241^Pu from ^241^Am whole-body counter measurements. Radiat Prot Dosim 79(1–4):141–144.
*Baeza A, del Río M, Miró C, . 1999. Recent evolution of the multi-isotopic radioactive content in ice of Livingston Island, Antarctica. Bull Environ Contam Toxicol 63:139–149.10441629
Bates JK, Bradley JP, Teetsov A, . 1992. Colloid formation during waste form reaction: Implications for nuclear waste disposal. Science 256:649–651.17843487
Battelle Pacific Northwest Labs. 1975. Effect of physico-chemical properties on metabolism of transuranium oxide aerosols inhaled by beagle dogs. Richland, WA: Battelle Pacific Northwest Labs. BNWLSA5430.
*Bauchinger M, Schmid E, Braselmann H. 1997. Cytogenetic evaluation of occupational exposure to external gamma-rays and internal ^241^Am contamination. Mutat Res 395:173–178.9465928
*Baum EM, Knox HD, Miller TR. 2002. Nuclides and isotopes: Chart of the nuclides. Knolls Atomic Power Laboratory.
Becker JS, Dietze H-J. 1999. Application of double-focusing sector field ICP mass spectrometry with shielded torch using different rebulizers for ultratrace and precise isotope analysis of long-lived radionuclides. J Anal Atom Spectrom 14(9):1493–1500
*Belot Y, Caput C, Gauthier D. 1982. Transfer of americium from sea water to atmosphere by bubble bursting. Atmos Environ 16(6):1463–1466.
*Bennett BG. 1976. Transuranic element pathways to man. U.S. Energy Research and Development Administration. IAEA-SM-199/40.
*Bennett BG. 1979. Environmental aspects of americium. Doctor of Philosophy Thesis, New York University.
*Bennett K, Biggs J, Fresquez P. 1996. Radionuclide contaminant analysis of small mammals, plants and sediments within Mortandad Canyon, 1994. Los Alamos, NM: Los Alamos National Laboratory. LA-13104-MS UC-908 UC-902 contract no. W-7504-ENG-36 DE-96-007-463.
Bensted JPM, Chir B, Taylor DM, . 1965. The carcinogenic effects of americium 241 and plutonium 239 in the rat. Br J Radiol 38:920–925.5850452
*Berezhnoi VI, Valetova NK, Dunaev GE, . 1991. Some data on transuranium element distribution in particle size fractions of Chernobyl soils. J Radioanal Nucl Chem 150(2):445–454.
*Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag.
Berry JR, McMurray BJ, Jech JJ, . 1983. 1976 Hanford americium exposure incident: Decontamination and treatment facility. Health Phys 45(4):883–892.6629782
Bertelli L, Puerta A, Wrenn ME, . 1998. Specific absorption parameters for uranium octoxide and dioxide: Comparison of values derived from human data and those predicted from animal studies. Radiat Prot Dosim 79(1–4):87–90.
Bertsche U. 1978. The response of diploid yeast to radiations at different LET I. Potentially lethal and lethal damage to reproductive capacity. Radiat Res 76:349–367.377367
Bertsche U. 1985. Micronucleus induction in mammalian cell cultures treated with ionizing radiations. Radiat Environ Biophys 24:27–44.3975348
Bidoglio G. 1982. Characterization of Am/III/ complexes with bicarbonate ions at groundwater concentration levels. Radiochem Radioanal Lett 53(1):45–60.
Bierkens J, Vangenechten JHD, Van Puymbroeck S, . 1986. Effect of Al and humic acids on the ^241^Am adsorption on the exoskeleton of the crayfish Astacus leptodactylus eschscholtz. Health Phys 50(2):277–280.2936701
Bistline RW, Watters RL, Lebel JL. 1972. A study of translocation dynamics of plutonium and americium from simulated wounds in beagle dogs. Health Phys 22:829–831.5084017
*BNA. 2001. Environment and Safety Library on the Web States and Territories. Bureau of National Affairs, Inc. Washington, D.C.: http://www.esweb.bna.com/. May 08, 2001.
*Bomben AM, Equillor HE, Oliveira AA. 1994. Simultaneous biphasic liquid scintillation determination of americium and plutonium. J Radioanal Nucl Chem 177(1):27–37.
*Bomford JA, Harrison JD. 1986. The absorption of ingested Pu and Am in newborn guinea pigs. Health Phys 51(6):804–808.3781854
*Boocock G, Popplewell DS. 1966. In vitro distribution of americium in human blood serum proteins. Nature 210:1283–1284.5967816
*Bradford WR, Curtis EJC. 1984. Radioactivity in environmental samples taken in the Sellafield and Ravenglass areas of West Columbia, 1977-1982. Sci Total Environ 35:267–283.6729443
Bradley SB, Clapham P. 1998. Contemporary flux of radionuclides to contaminated saltmarshes in the Esk Estuary, Cumbria. Water Air Soil Pollut 107:175–184.
*Brauning S, Cornaby B, McGinnis J, . 1986. Radioactivity levels in municipal sludge. Biocycle 27(5):48–51.
*Breitenstein BD. 1983. 1976 Hanford americium exposure incident: Medical management and chelation therapy. Health Phys 45(4):855–866.6629779
*Breitenstein BD, Palmer HE. 1989. Life follow-up of the 1976 americium accident victim. Radiat Prot Dosim 26(1/4):317–322.
Breitenstein BD, Newton CE, Norris HT. 1985. Part I: Introduction and history of the case. Health Phys 49(4):565–567.3930423
Breuer F, Clemente GF, Strambi E, . 1980. A case of internal contamination with plutonium oxide. In: International Radiation Protection Society. Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York: Pergamon Press, 607–610.
Brown WR. 1983. 1976 Hanford americium exposure incident: Psychological aspects. Health Phys 45(4):867–871.6629780
*Bruenger FW, Grube BJ, Atherton DR, . 1973. Binding of ^241^Am by bone protein. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 151–167. Contract No. AT(11-1)-119.
Bruenger FW, Kuswik-Rabiega G, Miller SC. 1992. Decorporation of aged americium deposits by oral administration of lipophilic polyamino carboxylic acids. J Med Chem 35:112–118.1732517
*Bruenger FW, Stevens W, Stover BJ. 1969. Americium-241 in the blood: In vivo and in vitro observations. Radiat Res 37:349–360.5765545
Bruenger FW, Stover BJ, Stevens W, . 1967. Interactions between Am III and serum constituents. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy, University of Utah College of Medicine, 196. Contract No. AT(11-1)-119.
*Budavari S, ed. 1996. The Merck index- An encyclopedia of chemical, drugs, and biologicals. 12^th^ ed. Whitehouse Station, NJ: Merck and Co., Inc., 413.
*Buldakov LA, Kalmykova ZI, Nifatov AP, . 1972. Metabolism and biological effects of inhaled ^241^Am and ^239^Pu in dogs. Health Phys 22:873–874.5084022
*Bulman RA. 1978. The movement of plutonium, americium, and curium through the food chain. Naturwissenschaften 65:137–143.205806
*Bulman RA, Johnson TE, Ham GJ, . 1993. Speciation of plutonium in potato and the gastrointestinal transfer of plutonium and americium from potato. Sci Total Environ 129:267–289.8434256
*Bunzl K, Kracke W. 1987. Soil to plant transfer of ^239+240^Pu, ^238^Pu, ^241^Am, ^137^Cs and ^90^Sr from global fallout in flour and bran from wheat, rye, barley and oats, as obtained by field measurements. Sci Total Environ 63:111–124.3035714
*Bunzl K, Kracke W. 1990. Simultaneous determination of ^238^Pu, ^239+240^Pu, ^241^Pu, ^241^Am, ^242^Cm, ^244^Cm, ^89^Sr, and ^90^Sr in vegetation samples, and application to Chernobyl-fallout contaminated grass. J Radioanal Nucl Chem 138(1):83–91.
*Bunzl K, Flessa H, Kracke W, . 1995. Association of fallout ^239+240^Pu and ^241^Am with various soil components in successive layers of a grassland soil. Environ Sci Technol 29:2513–2518.22191949
*Bunzl K, Förster H, Kracke W, . 1994. Residence times of fallout ^239+240^Pu, ^238^Pu, ^241^Am and ^137^Cs in the upper horizons of an undisturbed grassland soil. J Environ Radioact 22:11–27.
Bunzl K, Henrichs K, Kracke W. 1987. Fallout ^241^Am in human livers from the federal republic of Germany. Health Phys 53(5):533–536.3667280
*Bunzl K, Kracke W, Agapkina GI, . 1998. Association of Chernobyl-derived ^239+240^Pu, ^241^Am, ^90^Sr and ^137^Cs with different molecular size fractions of organic matter in the soil solution of two grassland soils. Radiat Environ Biophys 37:195–200.9840489
Burns PA, Cooper MB, Lokan KH, . 1995. Characteristics of plutonium and americium contamination at the former U.K. atomic weapons test ranges at Maralinga and Emu. Appl Radiat Isot 46(11):1099–1107.
Burton PJ. 1986. Laboratory studies on the remobilisation of actinides from Ravenglass estuary sediment. Sci Total Environ 52:123–145.
*Byrne AR, Komosa A. 1993. Possibilities for determination of ^241^Am in environmental samples by gamma counting, with and without radiochemistry. Sci Total Environ 130/131:197–206.
*Byrom J, Robinson C, Simmonds JR, . 1995. Food consumption rates for use in generalized radiological dose assessments. J Radiol Prot 15:(4) 335–341.
Caper SG, Cunningham WC. 2000. Element and radionuclide concentration in food: FDA total diet study 1991-1996. J AOAC Int 83(1):157–177.10693017
*Carnes BA, Groer PG, Kotek TJ. 1997. Radium dial workers: Issues concerning dose response and modeling. Radiat Res 147:707–714.9189169
Carpenter R, Beasley TM, Zahnle D, . 1987. Cycling of fallout (Pu, ^241^Am, ^137^Cs) and natural (U, Th, ^210^Pb) radionuclides in Washington continental slope sediments. Geochim Cosmochim Acta 51:1897–1921.
*Carroll J, Harms IH. 1999. Uncertainty analysis of partition coefficients in a radionuclide transport model. Water Res 33(11):2617–2626.
*Carroll J, Boisson F, Teyssie J-L, . 1999. Distribution coefficients (K_d_’s) for use in risk assessment models of the Kara Sea. Appl Radiat Isot 51:121–129.10376324
*Carter RE, Busch E, Johnson O. 1951. The relative physiological and toxicological properties of americium and plutonium. GRAI 14(NTIS/DEC95013620).
*Carvalho FP, Fowler SW. 1985. Biokinetics of plutonium, americium and californium in the marine isopod Cirolana borealis, with observations on its feeding and molting behavior. Mar Biol 89:173–181.
Casas M, Garcias F, Serra L, . 1992. Analysis for metal elements and radioactive isotopes in fly ash produced in lignite combustion at a thermal power plant. J Environ Sci Health Part A 27(2):419–432.
*Cataldo DA, Garland TR, Wildung RE, . 1980. Foliar absorption of transuranic elements: Influence of physicochemical form and environmental factors. J Environ Qual 9(3):364–369.
Cataldo DA, Garland TR, Wildung RE. 1981. Foliar retention and leachability of submicron plutonium and americium particles. J Environ Qual 10(1):31–37.
*CEDR. 2000. Comprehensive epidemiological data resource. http://cedr.lbl.edu. December 12, 2000.
*Chan TL, Lippman M. 1980. Experimental measurements and empirical modeling of the regional deposition of inhaled particles in humans. Am Ind Hyg Assoc J 47:399–408.
*Chassard-Bouchaud C. 1996. Analytical microscopy and environment. Current developments using bioindicators of pollution by stable and radioactive elements. Cell Mol Biol 42(3):361–383.8793191
*Chemical Abstract Service. 2000. Chemical Abstract Service Registry File Data Bank. December, 2000.
Chipperfield AR, Taylor DM. 1968. Binding of plutonium and americium to bone glycoproteins. Nature 219:609–610.4174288
*Chipperfield AR, Taylor DM. 1972. The binding of thorium(IV), plutonium(IV), americium(III) and curium(III) to the constituents of bovine cortical bone in vitro. Radiat Res 51:15–30.5037616
*Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
*Clifton RJ, Stevens HE, Hamilton EI. 1983. Concentration and depuration of some radionuclides present in a chronically exposed population of mussels (mytilus edulis). Mar Ecol Prog Ser 11(3):245–256.
Clifton RJ, Stevens HE, Hamilton EI. 1989. Uptake and depuration of ^241^Am, ^239+240^Pu, ^238^Pu, ^137^Cs and ^106^Ru by Mytilus edulis under natural stress. Mar Ecol Prog Ser 54:91–98.
*CO Department of Public & Environmental Health. 1999. Colorado Department of Public Health & Environment. Regulations. http://www.cdphe.state.co.us/cdphehom.asp. June 1, 2000.
*Cohen N, Wrenn ME. 1973. Metabolic characteristics of ^241^Am in the adult baboon. Radiat Res 55:129–143.4197799
*Cohen N, Antonelli R, Lo Sasso T, . 1978. Effect of ethanol on the retention of americium-241 in the baboon liver. J Toxicol Environ Health 4:825–833.104045
Cohen N, Sasso TL, Wrenn ME. 1979. Metabolism of americium-241 in man: An unusual case of internal contamination of a child and his father. Science 206:64–66.482925
*Colborn T, Clement C. 1992. Chemically-induced alterations in sexual and functional development: The Wildlife/Human Connection. In: Advances in modern environmental toxicology. Volume XXI. Princeton, NJ: Princeton Scientific Publishing Co.
*Cooper EL, Milintawisamai M, Panyatipsakul Y. 1993. Implementation of a radiochemical procedure for the analysis of isotopes of Pu, Am and Cm in food and environmental samples. Sci Total Environ 130/131:177–186.8469950
*Cooper JR, Gowing HS. 1981. The binding of americium and curium to human serum proteins. Int J Radiat Biol 40(5):569–572.
*Cooper MB, Burns PA, Tracy BL, . 1994. Characterization of plutonium contamination at the former nuclear weapons testing range at Maralinga in South Australia. J Radioanal Nucl Chem 177(1):161–184.
*Copplestone D, Johnson MS, Jones SR, . 1999. Radionuclide behaviour and transport in a coniferous woodland ecosystem: vegetation, invertebrates and wood mice, Apodemus slyvaticus. Sci Total Environ 239:95–109.10570837
*Copplestone D, Johnson MS, Jones SR. 2001. Behaviour and transport of radionuclides in soil and vegetation of a sand dune ecosystem. J Environ Radioact 55:93–108.11381556
*Cotton FA, Wilkinson G. 1980. The actinide elements: General remarks. In: Advanced inorganic chemistry: A comprehensive text. New York, NY: John Wiley & Sons, 1005–1042.
*Craig DK, Park JF, Powers GJ, . 1979. The disposition of americium-241 oxide following inhalation by beagles. Radiat Res 78:455–473.451167
*Craig DK, Park JF, Ryan JL. 1975. Effects of physico-chemical properties on metabolism of transuranium oxide aerosols inhaled by beagle dogs. Battelle Pacific Northwest Laboratories. NTIS No. BNWLSA5430.
*Crawley FEH, Goddard EA. 1976. The translocation of 241-americium and 242-curium from the respiratory system of the rat. Health Phys 30:191–197.1245418
*Culot JP, Blommaert W, Hurtgen C, . 1997. Radioactivity of the teeth in the follow-up of old contamination cases. J Radioanal Nucl Chem 226(1–2):139–143.
*Cunningham WC, Anderson DL, Baratta EJ. 1994. Radionuclides in domestic and imported foods in the United States, 1987-1992. J Assoc Off Anal Chem Int 77(6):1422–1427.
*Cunningham WC, Stroube WB, Baratta EJ. 1989. Chemical contaminants monitoring: Radionuclides in domestic and imported foods in the United States, 1983-1986. J Assoc Off Anal Chem 72(1):15–18.2715131
*Cutshall NH, Larsen IL, Olsen CR. 1983. Direct analysis of ^210^Pb in sediment samples: Self absorption corrections. Nucl Instrum Methods 206:309.
*Dacheux N, Aupiais J. 1997. Determination of uranium, thorium, plutonium, americium, and curium ultratraces by photon electron rejection α liquid scintillation. Anal Chem 69:2275–2282.21639361
*Dacheux N, Aupiais J. 1998. Determination of low concentrations of americium and curium by photon/electron rejecting alpha liquid scintillation. Anal Chim Acta 363:279–294.
Dasher D, Hanson W, Read S, . 2002. An assessment of the reported leakage of anthropogenic radionuclides from the underground nuclear test sites at Amchitka Island, Alaska, USA to the surface environment. J Environ Radioact 60:165–187.11936606
Datta S. 1982. Organ dose from inhaled radionuclides taking lull period into account. Radiat Prot Dosim 2(1):47–51.
*David AJ, Harrison JD. 1984. The absorption of ingested neptunium, plutonium and americium in newborn hamsters. Int J Radiat Biol 46(3):279–286.
Davies CP, Hodgson A, Stradling GN, . 1992. Studies on the nasal clearance of ^238^Pu and ^241^Am nitrates. J Aerosol Sci 23(Suppl. 1):S511–S514.
*Davis A, DeCurnou P, Eary LE. 1997. Discriminating between sources of arsenic in the sediments of a tidal waterway, Tacoma, Washington. Environ Sci Technol 31:185–191.
Davis WS, Denbow TJ, Lathrop JE. 1987. Aquatic sediments. J Water Pollut Control Fed 59(6):586–597.
*Dazhu Y, Yongjun Z, Mobius S. 1991. Rapid method for alpha counting with extractive scintillator and pulse shape analysis. J Radioanal Nucl Chem 147(1):177–189.
*DeVathaire CC, Crescini D, Remenieras J, . 1998. Monitoring of workers occupationally exposed to radionuclides in France: Results from February to August 1997 in the non-nuclear energy field. Rad Prot Dos 79(1–4):145–148.
Diamond ML, Mackay D, Cornett RJ, . 1990. A model of the exchange of inorganic chemicals between water and sediments. Environ Sci Technol 24(5):713–722.
Directorate of Fisheries Research. 1990. Determination of alpha-emitting nuclides of plutonium, americium and curium in environmental materials: Pt. 1. Sea water. Lowestoft, England: Directorate of Fisheries Research. NTIS/DE92614732.
*DOE. 1978. Toxicity of inhaled americium-241 dioxide. In: Pacific Northwest Laboratory Annual Report to the DOE Assistant Secretary of the Environment, 1977. U.S. Department of Energy. PNL-2500-Pt.1 US DOE, 3.34-3.35.
DOE. 1979a. Biotransport of transuranium radionuclides in dairy animals: A data summary. Washington, DC: U.S. Department of Energy. NTIS/EMSL-LV-0539-35.
*DOE. 1979b. In vivo measurement of actinides in the human lung. Washington, DC: U.S. Department of Energy. NTIS/UCRL-83548.
*DOE. 1979c. Summary report of the grazing studies conducted on a plutonium-contaminated range in area 13 of the Nevada test site. Washington, DC: U.S. Department of Energy. NTIS/EMSL-LV-0539-24.
*DOE. 1980. Transuranic elements in the environment. Office of Health and Environmental Research. U.S. Department of Energy. QH545.T74T73. 574.5222. 80-607069. ISBN 0-87079-119-2.
DOE. 1981. Lung-clearance classification of exp ^241^Am and exp ^238-240^Pu in dust collected near the sites of Hanford incidents 2827 and 2828. Washington, DC: U.S. Department of Energy. NTIS/DE81028258.
*DOE. 1984. Pacific Northwest Laboratory annual report for 1983 to the DOE Office of Energy Research, Fetal and juvenile radiotoxicity. U.S. Department of Energy. PNL-5000 Part 1, Springfield, VA: NTIS, 45–51.
DOE. 1985a. Environmental impact of a teratogenic actinide: A case study of americium-241. Washington, DC: U.S. Department of Energy. NTIS/DE86001795.
DOE. 1985b. Factors affecting the assessment of lung depositions of transuranics. Washington, DC: U.S. Department of Energy. NTIS/DE86004866.
*DOE. 1986. Pacific Northwest Laboratory Annual Report for 1985 to the DOE Office of Energy Research, Part 1-Biomedical sciences: Fetal and juvenile radiotoxicity. Richland, WA: US Department of Energy. Contract DE-AC06-76RLO 1830.
DOE. 1988. Pacific Northwest Laboratory Annual Report for 1987 to the DOE Office of Energy Research, Part 1-Biomedical sciences: Fetal and Juvenile Radiotoxicity. Richland, WA: US Department of Energy. Contract DE-AC06-76RLO 1830.
DOE. 1990. Radiation induced mesotheliomas in rats. Washington, DC: U.S. Department of Energy. NTIS/DE91017485.
*DOE. 1991a. Radioactive releases at the Savannah River site, 1954-1989. An environmental protection department summary. Washington, DC: U.S. Department of Energy. NTIS/DE92009983.
*DOE. 1991b. Radionuclides in surface soil at the Nevada test site. Washington, DC: U.S. Department of Energy. NTIS/DE91018825.
DOE. 1995a. Assays and screening of alpha contaminated soils using low-resolution alpha spectroscopy of thick soil samples. Washington, DC: U.S. Department of Energy. NTIS/DE95008969.
DOE. 1995b. Separation and analysis of actinides by extraction chromatography coupled with alpha liquid scintillation spectrometry. Washington, DC: U.S. Department of Energy. NTIS/DE96060013.
DOE. 1995c. Solubility-limited concentrations and aqueous speciation of U, Pu, Np, Am and Tc: Comparison between results of Bruno and Sellin (1992) and calculations using GEMBOCHS (version R16). Washington, DC: U.S. Department of Energy. NTIS/DE95015124.
*DOE. 1996. Radiological bioconcentration factors for aquatic, terrestrial, and wetland ecosystems at the Savannah River Site (U). Savannah River Site. U.S. Department of Energy. WSRC-TR-96-0231. DE-AC09-89SR18035.
*DOE. 1997a. Evaluation of the anthropogenic radionuclide concentrations in sediments and fauna collected in the Beaufort Sea and Northern Alaska. Los Alamos National Laboratory. U.S. Department of Energy. LA-13302-MS. UC-721. Contract W-7405-ENG-36. DE-97007-298.
*DOE. 1997b. EML Procedures Manual, 28^th^ Edition, HASL-300, Environmental Measurements Laboratory. U.S. Department of Energy. Sections 4.52, 4.54 (Am-01-RC, Am-02-RC, Am-04-RC, Am-06-RC, Pu-12-RC) 4,56 (Se-03), pp. 5.2-9, 5.4-2.
DOE. 1998. Assessment of radionuclides in the Savannah River Site, Environmental Summary. Oak Ridge TN: U.S. Department of Energy, Office of Scientific and Technical Information. DE-AC09-96SR18500,
*DOE. 1999a. Inventory and characteristics of spent nuclear fuel high level radioactive waste and other materials. U.S. Department of Energy. 0.80 ICSNF.pdf http://www.ymp.gov/deisdoc/Volume%20II/Appendix_A.pdf. August, 1999.
*DOE. 1999b. Savannah River site environmental data for 1999. Oak Ridge, TN: U.S. Department of Energy, Office of Scientific and Technical Information. DE-AC09-96SR18500.
*DOE. 2000. Radiation standards-inhaled air DAC for lung retention. U.S. Department of Energy. 10CFR835. http://www.nrc.gov. March 14, 2001.
*DOE. 2002a. Appendix A Inventory and characteristics of spent nuclear fuel, high level radioactive waste, and other materials. U.S. Department of Energy. http://www.ymp.gov:80/documents/feis_a/web_pdf/vol_2/eis_a_bm.pdf. November 13, 2002.
*DOE. 2002b. Statement by the Press Secretary. U.S. Department of Energy. http://www.whitehouse.gov/news/releases/2002/07/20020723-2.html. March 27, 2003.
*DOE. 2002c. National Spent Nuclear Fuel Program. U.S. Department of Energy. http://nsnfp.inel.gov/snfdata.asp. March 28, 2003.
*DOE. 2003a. National Nuclear Data Center, Brookhaven National Laboratory, Upton, NY. U.S. Department of Energy. http://www.nndc.bnl.gov/. April 04, 2003.
*DOE. 2003b. INEEL Annual Site Environmental Report- Calendar Year 2002, ISSN 1089-5469, September 2003. U.S. Department of Energy. http://www.nndc.bnl.gov/. April 04, 2003.
*DOE. 2004. Office of Civilian Radioactive Waste Management. U.S. Department of Energy. http://www.ocrwm.doe.gov/. April 23, 2004.
*Doerfel H, Oliveira CAN. 1989. In vivo measurement of ^241^Am organ burdens: Techniques and results of measurements after an incident in an industrial research institute. Radiat Prot Dosim 26(1/4):189–193.
*DOT. 2001. U.S. Department of Transportation. 40CFR173.435. Activity values for radionuclides. http://www.dot.gov. March 14, 2001.
*Dougherty JH. 1970. Preliminary report on hematological effects of ^241^Am in the beagle. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy, University of Utah College of Medicine, 354–362. Contract No. At(11-1)-119.
Dougherty JH. 1972a. ^241^Am toxicity to leukocytes of beagles for the first year post-injection. Radiat Res 51(2):504–505.
Dougherty JH. 1972b. Toxicity to blood cells of ^241^Am compared to other transuranium nuclides. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 272–281.
Durakovic AB, Hollins JG, Storr MC. 1973. The influence of age and sex on the metabolism of americium by rats. Health Phys 24:541–546.4707669
Durand JP, Milcent MC, Goudard F, . 1994. Chemical behavior of three radionuclides (cesium, americium and technetium) and their uptake at the cystosolic level in aquatic organisms. Biochem Mol Biol Int 33(3):521–534.7951070
*Durbin PJ. 1973. Metabolism and biological effects of the transplutonium elements. In: Hodge HC, Stannard JN, Hursh JB, eds. Uranium, plutonium, transplutonic elements. New York: Springer-Verlag, 739–896.
*Durbin PW, Schmidt CT. 1985. Part V: Implications for metabolic modeling. Health Phys 49(4):623–661.4044262
*Durbin PW, Kullgren B, Xu J, . 1994. In vivo chelation of Am(III), Pu(IV), Np(V) and U(VI) in mice by tren-(Me-3,2-HOPO). Radiat Prot Dosim 53(1–4):305–309.
Durbin PW, Schmidt CT, McInroy JF, . 1985. Estimation of initial distribution of americium in adult male human skeleton. Health Phys 49(1):162.
*Edvardsson KA, Lindgren L. 1976. Elimination of americium-241 after a case of accidental inhalation. In: Diagnosis and treatment of incorporated radionuclides. Vienna: International Atomic Energy Agency 497–502.
EFDB. 2000. Americium. Environmental Fate Exposure Database. Syracuse Research Corporation.
Eisele GR, Erickson BH. 1985. Gonadal retention and localization of ^241^Am in orally exposed swine. Health Phys 49(6):1276–1279.4077532
*Eisele GR, Bernard SR, Nestor CW. 1987. Gastrointestinal absorption of americium-241 by orally exposed swine: Comparison of experimental results with predictions of metabolic models. Radiat Res 112:62–73.3659299
*Eisenbud M. 1987. Environmental Radioactivity. 3rd ed. New York: Academic Press, Inc.
*Eisenbud M, Gesell T. 1997. Radioactive waste management. In: Environmental Radioactivity. 4^th^ Ed. New York: Academic Press, Inc, 334–377.
Ellender M, Haines JW, Harrison JD. 1995. The distribution and retention of plutonium, americium and uranium in CBA/H mice. Hum Exp Toxicol 14:38–48.7748615
*Ellender M, Harrison JD, Pottinger H, . 2001. Induction of osteosarcoma and acute myeloid leukaemia in CBA/H mice by the alpha-emitting nuclides, uranium-233, plutonium-239 and americium-241. Int J Radiat Biol 77(1):41–52.11213349
*Ellenhorn MJ, Schonwald S, Ordog G, ., eds. 1997. Medical toxicology: Diagnosis and treatment of human poisoning. 2^nd^ edition. Baltimore: Williams & Wilkins 1682–1723.
*Emery RM, Klopfer DC, Baker DA, . 1981. Potential radiation dose from eating fish exposed to actinide contamination. Health Phys 40:493–510.7228701
EMMI. 2000. EPA Environmental Monitoring Methods Index, Detail Analyte. Regulatory Names, Synonyms & Comments.
*EPA. 1976. Americium - Its behavior in soil and plant systems. Las Vegas, NV: Office of Research and Development, U.S. Environmental Protection Agency. EPA600/3-76-005. PB250797.
*EPA. 1979. Plutonium-239 and americium-241 uptake by plants from soil. Las Vegas, NV: Environmental Monitoring and Support Laboratory, U.S. Environmental Protection Agency. EPA600/3-79-026. PB298-241.
*EPA. 1984. U.S. “Mussel watch” program: Transuranic element data from Woods Hole Oceanographic Institution 1976-1983. Narragansett, RI: Environmental Research Laboratory, U.S. Environmental Protection Agency. WHOI-84-28. CRC-84-5.
*EPA. 1988. Limiting values of radionuclide intake and air concentration and dose conversion factors for inhalation, submersion, and ingestion. Federal Guidance Report No. 11. Washington, DC: Office of Radiation Programs, U.S. Environmental Protection Agency. EPA-520/1-88-020.
*EPA. 1993. External exposure to radionuclides in air, water, and soil. Federal Guidance Report No. 12. Washington, DC: Office of Radiation Program, U.S. Environmental Protection Agency. EPA-402-R-93-081.
EPA. 1997a. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: Risk Assessment Forum, U.S. Environmental Protection Agency. EPA/630/R-96/012.
EPA. 1997b. Health effects assessment summary tables. Washington, DC: Office of Emergency and Remedial Response, Office of Research and Development, U.S. Environmental Protection Agency. EPA 540/R-97-036. PB97-921199.
*EPA. 1997c. Radiation data report 91, July to September 1997, National Environmental Radiation Ambient Monitoring System (ERAMS), National Air and Radiation Environmental Laboratory (NAREL), U.S. Environmental Protection Agency. http://www.epa.gov/narel/erd91.pdf. May, 2000.
EPA. 1999. Compliance procedures methods for determining compliance with subpart 1. U.S. Environmental Protection Agency. 40 CFR 61 Appendix E.
*EPA. 2000a. Cancer risk coefficients for environmental exposure to radionuclides. Federal Guidance Report No. 13. Washington, DC.: U.S. Environmental Protection Agency.
*EPA. 2000b. Environmental Radiation Ambient Monitoring System (ERAMS). Environmental Radiation Data (ERD). U.S. Environmental Protection Agency. http://www.epa.gov/narel/erams/erdonline.html.
*EPA. 2000c. National primary drinking water regulations; Radionuclides; Final rule. U.S. Environmental Protection Agency. 65FR76707-76753. http://www.epa.gov/safewater/rads/radfr.html. December 7, 2000.
*EPA. 2001a. Concentration levels for environmental compliance. U.S. Environmental Protection Agency. 40 CFR 61. http://www.epa.gov/epahome/lawreg.htm. March 13, 2001.
*EPA. 2001b. Radioactive waste-release limits for containment requirements. U.S. Environmental Protection Agency. 40 CFR 191. http://www.epa.gov/epahome/cfr40.htm. March 13, 2001.
*EPA. 2001c. Reportable quantities. U.S. Environmental Protection Agency. 40 CFR 302.4. http://www.epa.gov/epahome/lawreg.htm. March 13, 2001.
*EPA. 2001d. Radioactive waste disposal: An environmental perspective. Low-level radioactive waste. U.S. Environmental Protection Agency. http://www.epa.gov/radiation/radwaste/llw.htm. March 13, 2001.
*EPA. 2002. Radionuclide carcinogenicity slope factors. Washington DC: U.S. Environmental Protection Agency. http://www.epa.gov/radiation/heast/docs/heast2_table_4-d2_0401.pdf.
*EPA. 2004a. Disposal guide for miscellaneous products. U.S. Environmental Protection Agency. http://www.epa.gov/grtlakes/seahome/housewaste/src/dspmisc.htm. March 10, 2004.
*EPA. 2004b. Smoke detectors and radiation. U.S. Environmental Protection Agency. http://www.epa.gov/radiation/sources/smoke_alarm.htm. January 05, 2004.
*EPA. 2004c. Radiation information: Americium. U.S. Environmental Protection Agency. http://www.epa.gov/radiation/radionuclides/americium.htm. March 11, 2004.
*EPA. 2004d. Environmental radiation protection standards for management and disposal of spent nuclear fuel, high-level and transuranic radioactive wastes. 40CFR191. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=f0242edb1ed2350025a9f6ea903537a9&rgn=div5&view=text&node=40:22.0.1.1.2&idno=40. April 23, 2004.
*EPA. 2004e. Criteria for the certification and recertification of the Waste Isolation Pilot Plant’s compliance with the 40CFR191 disposal regulations. Environmental Protection Agency. 40CFR194. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=f0242edb1ed2350025a9f6ea903537a9&rgn=div5&view=text&node=40:22.0.1.1.4&idno=40. April 23, 2004.
*EPRI. 1981. Transuranium and other long-lived radionuclides in the terrestrial environs of nuclear power plants. Battelle Pacific Northwest Laboratories. EA-2045. Research Project 1059. Illinois State Library.
Espinosa A, Aragon A, Stradling N, . 1998. Assessment of doses to adult members of the public in Palomares from inhalation of plutonium and americium. Radiat Prot Dosim 79(1–4):161–164.
*Essien IO, Sandoval DN, Kuroda PK. 1985. Deposition of excess amount of natural uranium from the atmosphere. Health Phys 48(3):325–331.3980219
Essington EH, Fowler EB, Polzer WL. 1981. The interactions of low-level, liquid radioactive wastes with soils: 2. Differences in radionuclide distribution among four surface soils. Soil Sci 132(1):13–18.
Ethington EF, Niswonger KR. 2000. Alpha spectrometry measurement reproducibility study for uranium, plutonium, and americium in water at Rocky Flats Environmental Technology Site. Health Phys 79:S38–S40.10910402
*Fasiska BC, Bohning DE, Brodsky A, . 1971. Urinary excretion of ^241^Am under DTPA therapy. Health Phys 21:523–529.5115125
*FDA. 1998. Accidental radioactive contamination of human food and animal feed: Recommendations for state and local agencies. U.S. Food and Drug Administration.
*FDA. 2000. Sources of radiation used for inspection of food-sealed units producing radiation. Food and Drug Administration. http://www.access.gpo.gov/cgi-bin/cfrassemble.cgi. March 14, 2001.
*FEDRIP. 2004. Federal Research In Progress Database. National Technical Information Service, Springfield, VA.
*Ferenbaugh JK, Fresquez PR, Ebinger MH, . 2002. Radionuclides in soil and water near a low-level disposal site and potential ecological and human health impacts. Environ Monit Assess 74:243–254.11944797
Filipy RE, Kathren RL. 1994. Changes in soft tissue concentrations of plutonium and americium with time after human occupational exposure. Health Phys 66(6)(Suppl.):S73.
*Filipy RE, Kathren RL. 1996. Changes in soft tissue concentrations of plutonium and americium with time after human occupational exposure. Health Phys 70(2):153–159.8567281
Filipy RE, Hall CA, Kathren RL, . 1993. Relationships of soft tissue concentrations of plutonium and americium in occupationally-exposed humans. Health Phys 64(6)(Suppl.):S54.
*Filipy RE, Kathren RL, McInroy JF. 1992. Relative concentrations of plutonium and americium in the liver, testes, and thyroid gland. Health Phys 62(6)(Suppl.):S17.
*Filipy RE, Kathren RL, McInroy JF, . 1994. Soft tissue concentrations of plutonium and americium in occupationally-exposed humans. Health Phys 67(5):477–485.7928359
*Filipy RE, Khokhryakov VF, Suslova KG, . 1996. Comparisons of biokinetic models for actinide elements with observed tissue analysis data from occupationally-exposed humans of two countries. Health Phys 70(6)(Suppl.):S82.
Filipy RE, Khokhryakov VF, Suslova KG, . 1998. Analysis for actinides in tissue samples from plutonium workers of two countries. J Radioanal Nucl Chem 234(1–2):171–174.
*Filipy RE, Toohey RE, Kathren RL, . 1995. Deterministic effects of ^241^Am exposure in the Hanford americium accident case. Health Phys 69(3):338–345.7635730
*Fisher NS, Bjerregaard P, Fowler SW. 1983. Interactions of marine plankton with transuranic elements: 3. Biokinetics of americium in euphausiids. Mar Biol 75:261–268.
*Fisher NS, Fowler SW, Boisson F, . 1999. Radionuclide bioconcentration factors and sediment partition coefficients in arctic seas subject to contamination form dumped nuclear wastes. Environ Sci Technol 33(12):1979–1982.
*Fisher NS, Teyssié J-L, Fowler SW, . 1996. Accumulation and retention of metals in mussels from food and water: A comparison under field and laboratory conditions. Environ Sci Technol 30(11):3232–3242.
*Fomon SJ. 1966. Body composition of the infant: Part I: The male “reference infant”. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
*Fomon SJ, Haschke F, Ziegler EE, . 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
*Fong SH, Alvarez JL. 1997. Data quality objectives for surface-soil cleanup operation using in situ gamma spectrometry for concentration measurements. Health Phys 72:286–295.9003715
*Fowler EB, Essington EH, Polzer WL. 1981. The interactions of low-level, liquid wastes with soils: 1. Behavior of radionuclides in soil-waste systems. Soil Sci 132(1):2–12.
*Fowler SW, Carvalho FP. 1985. Americium biokinetics in benthic organisms as a function of feeding mode. Bull Environ Contam Toxicol 35:826–834.4074951
*Francis AJ, Gillow JB, Dodge CJ, . 1998. Role of bacteria as biocolloids in the transport of actinides from a deep underground radioactive waste repository. Radiochim Acta 82:347–354.
*Fresquez PR, Armstrong DR, Mullen MA. 1998a. Radionuclides in soils collected from within and around Los Alamos National Laboratory: 1974-1996. J Environ Sci Health Part A A33(2):263–278.
*Fresquez PR, Armstrong DR, Mullen MA, . 1998b. The uptake of radionuclides by beans, squash, and corn growing in contaminated alluvial soils at Los Alamos National Laboratory. J Environ Sci Health B 33(1):99–122.9491570
*Fresquez PR, Kraig DH, Mullen MA, . 1999. Radionuclides and trace elements in fish collected upstream and downstream of Los Alamos National Laboratory and the doses to humans from the consumption of muscle and bone. J Environ Sci Health B B34(5):885–899.
*Fresquez PR, Biggs JR, Bennett KD. 1999. Radionuclides in deer and elk from Los Alamos National Laboratory and the doses to humans from the ingestion of muscle and bone. J Environ Sci Health B B34(5):901–915.
*Fresquez PR, Huchton JD, Mullen MA, . 2000. Radionuclides in pinon pine (Pinus edulis) nuts from Los Alamos National Laboratory lands and the dose from consumption. J Environ Sci Health B B35(5):611–622.
*Friberg I, Vesanen R. 1999. Detection limits for ^90^Sr, Pu, Am and Cm in soil and pasture vegetation shortly after a nuclear accident. Appl Radiat Isot 51:229–237.10376329
*Fry FA. 1976. Long-term retention of americium-241 following accidental inhalation. Health Phys 31:13–20.955912
*Fulker MJ, Jackson D, Leonard DRP, . 1998. Dose due to man-made radionuclides in terrestrial wild foods near Sellafield. J Radiol Prot 18(1):3–13.9594111
*Gilbert RO, Engel DW, Anspaugh LR. 1989. Transfer of aged ^239+240^Pu, ^238^Pu, ^241^Am, and ^137^Cs to cattle grazing a contaminated arid environment. Sci Total Environ 85:53–62.2814465
*Gillett NA, Hahn FF, Mewhinney JA, . 1985. Osteosarcoma development following single inhalation exposure to americium-241 in beagle dogs. Radiat Res 104:83–93.3863193
*Giwercman A, Carlsen E, Keiding N, . 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.7902273
*Goldberg ED. 1986. The mussel watch concept. Environ Monit Assess 7:91–103.24254800
*Goldstein SJ, Hensley CA, Armenta CE, . 1997. Environmental and human monitoring of americium-241 utilizing extraction chromatography and α-spectroscopy. Anal Chem 69:809–812.9068269
*Graham SG, Kirkman SJ. 1983. Identification of ^241^Am in the axillary lymph nodes with an intrinsic germanium detector. Health Phys 44:343–352.6862911
*Green N, Wilkins BT. 1995. Transfer of radionuclides to vegetable and other crops grown on land reclaimed from the sea. Sci Total Environ 173/174:385–392.8560228
*Griffith WC, Mewhinney JA, Muggenburg BA, . 1983. Bioassay model for estimation body burdens of ^241^Am from excretion analyses. Health Phys 44(Suppl. 1):545–554.6862929
*Gruner R, Seidel A, Winter R. 1981. The initial early distribution of monomeric ^239^Pu and ^241^Am in rat liver as determined by triton WR 1339 injection. Radiat Res 85:367–379.6258190
Gualdrini G, Battisti P, Biagini R, . 2000. Development and characterization of a head calibration phantom for in vivo measurements of actinides. Appl Radiat Isot 53:387 10879891
*Guilmette RA. 1986. A low energy photon detector for the radio assay of Pu and Am in biological samples. Health Phys 51:797–803.3781853
*Guilmette RA, Bay AS. 1981. Radio assays of americium or curium in biological material by isoctyl acid phosphate solvent extraction and α liquid scintillation counting. Anal Chem 53:2351–2354.7316214
*Guilmette RA, Durbin PW. 2003. Scientific basis for development of biokinetic models for radiocontaminated wounds. Radiat Prot Dosim 105(1–4):213–218.
Guilmette RA, Eidson AF. 1992. Using animal dosimetry models to interpret human bioassay data for actinide exposures. J Radioanal Nucl Chem 156(2):425–449.
*Guilmette RA, Muggenburg BA. 1988. Reducing the radiation dose from inhaled americium-241 using continuously administered DTPA therapy. Int J Radiat Biol 53(2):261–271.
*Guilmette RA, Cohen N, Wrenn ME. 1980. Distribution and retention of ^241^Am in the baboon. Radiat Res 81:100–119.6766219
Guilmette RA, Lindhorst PS, Hanlon LL. 1992. Interaction of plutonium and americium with bone mineral in vitro. Health Phys 62(6)(Suppl.):S16–S17.
*Guilmette RA, Lindhorst PS, Hanlon LL. 1998. Interaction of Pu and Am with bone mineral in vitro. Radiat Prot Dosim 79(1–4):453–458.
*Guilmette RA, Hakim R, Durbin PW, . 2003. Competitive binding of Pu and Am with bone mineral and novel chelating agents. Radiat Prot Dosim 105(1–4):527–534.
*Guilmette RA, Muggenburg BA, Cuddihy RG. 1988. Systemic absorption of americium from the nasal airways of dogs exposed intranasally to americium-241 nitrate and oxide aerosols. Health Phys 54(Suppl. 1):S27.
Gulin SB, Polikarpov GG, Egorov VN, . 2002. Radioactive contamination of the North-western Black Sea sediments. Estuaries 54:541–549.
*Guogang J, Testa C, Desideri D, . 1998. Sequential separation and determination of plutonium, americium-241 and strontium-90 in soils and sediments. J Radioanal Nucl Chem 230(1–2):21–27.
*Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
*Haddad LM, Shannon MW, Winchester JF, eds. 1998. Clinical management of poisoning and drug overdose. 3^rd^ edition. Philadelphia: W.B. Saunders, 413–425.
*Hafez MB, Hafez N. 1992. Quantitative determination of americium in biological materials. J Radioanal Nucl Chem 164(2):81–89.
*Halverson J. 1984. A review of application of mass spectrometry to low-level radionuclide metrology. Nucl Instrum Methods Phys Res 223:349–355.
*Ham GJ, Harrison JD, Popplewell DS, . 1994. The gastrointestinal absorption of neptunium, plutonium and americium in a primate (C. jacchus). Sci Total Environ 145:1–6.8016624
*Ham GJ, Hodgson SA, Youngman MJ, . 2003. Review of autopsy, in vivo and bioassay measurements on members of the public in the UK. NRPB-W42. http://www.nrpb.org/publications/w_series_reports/2003/nrpb_w42.htm. January 07, 2004.
*Ham GJ, Stradling GN, Breadmore SE. 1977. Determination of americium and curium in biological samples of extraction and liquid scintillation. Anal Chem 49:1268–1270.883655
*Hamilton EI, Clifton RJ. 1980. Concentration and distribution of the transuranium radionuclides ^239+240^Pu, ^238^Pu and ^241^Am in Mytilus edulis, Fucus vesiculosus and surface sediment of Esk estuary. Mar Ecol Prog Ser 3:267–277.
*Hamilton TF, Fowler SW, LaRosa J, . 1991. Comparative study of plutonium and americium bioaccumulation from two marine sediments contaminated in the natural environment. J Environ Radioact 14:211–223.
Hammarström L, Nilsson A. 1970a. Radiopathology of americium 241: I. Distribution of americium in adult mice. Acta Radiol 9:433–442.
*Hammarström L, Nilsson A. 1970b. Radiopathology of americium 241: II. Uptake in the developing teeth of rats. Acta Radiol 9:609–617.
Hammond SE, Lagerquist CR, Mann JR. 1968. Americium and plutonium urine excretion following acute inhalation exposure to high-fired oxides. Am Ind Hyg Assoc J 29(2):169–172.5656038
Hampton JC. 1983. 1976 Hanford americium exposure incident: Histologic and autoradiographic observations on skin. Health Phys 45(4):933–935.6629786
*Hanford. 1999. Hanford site environmental report for calendar year 1998. Sec. 2.5 Waste management. PNNL-12088, Pacific Northwest National Laboratory, Richland, WA. http://www.hanford.gov/docs/annualrp98/sec2.5. December 12, 2000.
Harley NH, Pasternack BS. 1979. Potential carcinogenic effects of actinides in the environment. Health Phys 37:291–300.229088
Harrison JD. 1991. The gastrointestinal absorption of the actinide elements. Sci Total Environ 100:43–60.1648260
Harrison JD, David AJ, Stather JW. 1980. The wound clearance and distribution of plutonium, americium and curium in rodents. Int J Radiat Biol 37(5):505–512.
Harrison JD, Hodgson A, Haines JW, . 1993. The biokinetics of plutonium-239 and americium-241 in the rat after subcutaneous deposition of contaminated particles from the former nuclear weapons site at Maralinga: Implications for human exposure. Hum Exp Toxicol 12:313–321.8104010
*Harrison JD, Naylor GPL, Stather JW. 1994. The gastrointestinal absorption of plutonium and americium in rats and guinea pigs after ingestion of dusts from the former nuclear weapons site at Maralinga: Implications for human exposure. Sci Total Environ 143:211–220.8209224
*Harrison JD, Smith H, David AF. 1988. Plutonium and americium uptake in rats fed with Cumbrian shellfish - implications for estimates of dose to man. Sci Total Environ 68:187–196.3363317
Harrison JD, Smith H, Stather JW. 1987. Comments on the paper “Transfer of environmental plutonium and americium across the human gut”. Sci Total Environ 64(3):325–332.3602997
*Harvey BR, Lovett MB, Blowers P. 1993. Quantifying the alpha-spectrometric analysis of plutonium and americium nuclides down to the 10µ Bq level. Appl Radiat Isot 44(6):957–966.
*HazDat. 2004. HazDat database. Agency for Toxic Substances and Disease Registry (ATSDR), Atlanta, GA. http://www.atsdr.cdc.gov/hazdat.html. March 03, 2004.
*Hegde AG, Bhat IS. 1983. Occupational exposure to airborne alpha emitters in a BWR atomic power station. Bull Radiat Prot 6(2):25–28.
Heid KR, Robinson B. 1985. Part II: Estimate of the initial systemic burden. Health Phys 49(4):569–575.3930424
*Heldal HE, Varskog P, Foyn L. 2002. Distribution of selected anthropogenic radionuclides (^137^Cs, ^238^Pu, ^239,240^Pu and ^241^Am) in marine sediments with emphasis on the Spitsbergen-Bear Island area. Sci Total Environ 293:233–245.12109476
*Herring GM, Vaughn J, Williamson M. 1962. Preliminary report on the site of localization and possible binding agent for yttrium, americium and plutonium in cortical bone. Health Phys 8:717–724.13954076
*Hisamatsu S, Takizawa Y. 1983. Placental transfer and distribution of ^241^Am in the rat. Radiat Res 94:81–88.6856770
*Hisamatsu S, Takizawa Y. 1987. Effect of gavaged chemical form of ^241^Am on its retention in mice. Radiat Res 111:334–339.3628720
Hodgson A, Shutt Al, Etherington G, . 2003. Comparison of predicted with observed biokinetics of inhaled plutonium nitrate and gandolinium oxide in humans. Radiat Prot Dosim 105(1–4):91–94.
*Hoel DG, Davis DL, Miller AB, . 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
*Hollins JG, Durakovic AB. 1972. The metabolism of americium in lactating rats. Health Phys 22:627–631.5083993
*Hollins JG, Durakovic A, Storr MC. 1973. The retention of americium and calcium by the skeleton of growing and mature female rats. Calcif Tissue Res 12:239–246.4747566
Holm E, Persson RBR. 1975. Fall-out plutonium in Swedish reindeer lichens. Health Phys 29(2):43–51.1150462
*Horikoshi T, Nakajima A, Sakaguchi T. 1981. Studies on the accumulation of heavy metal elements in biological systems. XIX. Accumulation of uranium by microorganisms. Eur J Appl Microbiol Biotechnol 12:90–96.
Horwitz EP, Dietz ML, Fisher DE. 1991. Separation and preconcentration of strontium from biological, environmental, and nuclear waste samples by extraction chromatography using a crown ether. Anal Chem 63:522–525 1829590
*Hoyt GD, Adriano DC. 1979. Americium-241 uptake by bahiagrass as influenced by soil type, lime, and organic matter. J Environ Qual 8(3):392–396.
*HPS. 2004. Health Physics Society Laboratory Accreditation Program. Health Physics Society. http://hps.org/aboutthesociety/labaccreditation.html. April 20, 2004.
Hunt DC, Crites TR, Lagerquist CR. 1981. Radiation and rocky flats in perspective. Colo Med 78(4):111–114.7285512
*Hunt GJ. 1998. Transfer across the human gut of environmental plutonium, americium, cobalt, caesium and technetium: Studies with cockles (Cerastoderma edule) from the Irish Sea. J Radiol Prot 18(2):101–109.9656190
*Hunt GJ, Leonard DRP, Lovett MB. 1986a. Transfer of environmental plutonium and americium across the human gut. Lancet 1(8478):439–440.
*Hunt GJ, Leonard DRP, Lovett MB. 1986b. Transfer of environmental plutonium and americium across the human gut. Sci Total Environ 53:89–109.3749873
Hunt GJ, Leonard DRP, Lovett MB. 1987. Response to the letter by J.D. Harrison, H. Smith and J.W. Stather commenting on the “Transfer of environmental plutonium and americium across the human gut”. Sci Total Environ 64(3):330–339.
*Hunt GJ, Leonard DRP, Lovett MB. 1990. Transfer of environmental plutonium and americium across the human gut: A second study. Sci Total Environ 90:273–282.2305242
*Hutchins DA, Stupakoff I, Fisher NS. 1996a. Temperature effects on accumulation and retention of radionuclides in the sea star, Asterias forbesi: Implications for contaminated northern waters. Mar Biol 125:701–706.
*Hutchins DA, Teyssie J-L, Boisson F, . 1996b. Temperature effects on uptake and retention of contaminant radionuclides and trace metals by the brittle star Ophiothrix fragilis. Mar Environ Res 41(4):363–378.
*IARC. 1989. Tumour development following internal exposures to radionuclides during perinatal period. Richland, WA: International Agency for Research on Cancer.
IARC. 1990. Chromium and chromium compounds. International Agency for Research on Cancer. IARC Monogr Eval Carcinog Risks Hum 49:49–256.
*IARC. 2002. Lyon, France: International Agency for Research on Cancer, World Health Organization. http://193.51.164.11/cgi/iHound/Chem/Chem.cgi. December 4, 2002.
ICRP. 1960. International Commission of Radiological Protection. Report of Committee II on permissible dose for internal radiation. Health Phys 3:146.
*ICRP. 1979. Limits for Intakes of Radionuclides by Workers. International Commission of Radiological Protection. ICRP Publication 30. New York: Pergamon Press.
*ICRP. 1983. Radionuclide transformations: Energy and intensity of emissions. International Commission of Radiological Protection. ICRP Publication 38. New York: Pergamon Press.
*ICRP. 1986. The metabolism of plutonium and related elements. International Commission of Radiological Protection. ICRP Publication 48. New York: Pergamon Press.
*ICRP. 1989. Age-dependent doses to members of the public from intake of radionuclides: Part 1. International Commission on Radiological Protection. Oxford: Pergamon Press, 67–68, 75–89.
ICRP. 1990. Age-dependent doses to members of the public from intake of radionuclides: Part 1. The International Commission on Radiological Protection. ICRP publication 56. New York, NY: Pergamon Press. http://www.elsevier.com/inca/publications. December 12, 2000.
*ICRP. 1993. Age-dependent doses to members of the public from intake of radionuclides: Part 2, ingestion dose coefficients. The International Commission on Radiological Protection. ICRP publication 67. New York, NY: Pergamon Press.
ICRP. 1994a. Age-dependent doses to members of the public from intake of radionuclides: Part 2, ingestion dose coefficients. The International Commission on Radiological Protection. ICRP publication 67. New York, NY: Pergamon Press. http://www.elsevier.com/inca/publications/store/. March 12, 2001.
*ICRP. 1994b. Human respiratory tract model for radiological protection. International Commission of Radiological Protection. ICRP Publication 66. New York: Pergamon Press.
*ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4 ingestion dose coefficients. The International Commission on Radiological Protection. ICRP publication 71. New York, NY: Pergamon Press.
*ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides: Part 5. Compilation of ingestion and inhalation dose coefficients. The International Commission on Radiological Protection. ICRP Publication 72. New York, NY: Pergamon Press.
*Ide HM. 1986. Americium and plutonium in fecal samples a screening procedure. In: Health and environmental chemistry: Analytical techniques, data management, and quality assurance. Gautier MA, Gladney ES, eds. Los Alamos, NM: Los Alamos National Laboratory. Report LA-10300-M.
*Ide HM, Moss WD, Gautier MA. 1985. Rapid screening methods for the analysis of Pu or Am in urine. Health Phys 49:970–976.4066357
Iliakis G. 1984. The mutagenicity of alpha particles in ehrlich ascites tumor cells. Radiat Res 99:52–58.6539929
*INEEL. 2000. Isotope report. National Low-Level Waste Management Program. Manifest Information Management System. Idaho National Engineering and Environmental Laboratory. http://mims.inel.gov/. June 12, 2000.
*IRIS. 2002. Americium. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.htm. December 4, 2002.
*Jaakkola T, Hakanen M, Keinonen M, . 1977. Plutonium and americium in the food chain lichen-reindeer-man. Springfield, VA: U.S. Department of Commerce.
Jacob P, Paretzke HG, Rosenbaum H, . 1988. Organ doses from radionuclides on the ground: Part I. Simple time dependences. Health Phys 54(6):617–633.3378894
*James AC. 1978. Lung deposition of sub-micron aerosols calculated as a function of age and breathing rate. In: National Radiological Protection Board annual Research and Development Report. National Radiological Protection Board. Harwell, United Kingdom,71–75.
*James AC, Stahlhofen W, Rudolf G, . 1994. Deposition of inhaled particles. In: ICRP Publication 66. Oxford: Pergamon Press, 231–299.
*Janke DH, Arthur WJ. 1985. Radionuclide transport by cottontail rabbits at a radioactive waste disposal area. Northwest Sci 59(3):221–229.
Jeanmaire L, Ballada J. 1971. Etude de deux cas de contamination par Am-241. In: Proceedings, radiation protection problems relating to transuranium elements. EUR 4612. Luxembourg: Directorate General for Dissemination of Information, 531–546.
*Jech JJ, Berry JR, Breitenstein BD. 1983. 1976 Hanford americium exposure incident: External decontamination procedures. Health Phys 45(4):873–881.6629781
*Jee WSS, Dell RB, Parks NJ, . 1985. Toxicity of plutonium and americium: Relationship of bone composition to location of ^226^Ra, ^239^Pu and ^241^Am induced bone sarcomas. EUR 9250:155–174.
Jefferies SJ, Gunston KJ. 1986. Further work concerning a case of Am contamination in the lateral axillary lymph nodes. Health Phys 50(6):839–842.3710793
*Jia G, Desideri D, Guerra F, . 1997. Determination of plutonium and americium in moss and lichen samples. J Radioanal Nucl Chem 220(1):15–19.
*Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson LJ, Watters RL, Lagerquist CR, . 1970. Relative distribution of plutonium and americium following experimental PuO_2_ implants. Health Phys 19:743–749.5535159
Johnson MS, Copplestone D, Fox WM, . 2001. Annual cycle of radionuclide contamination on tide-washed pasture in the Mersey Estuary, NW England. Estuaries 24(2):198–203.
Jones CW, Lloyd RD, Mays CW. 1980. Salicylic acid failed to increase the efficacy of Ca-DTPA in the decorporation of plutonium and americium. Radiat Res 84:149–151.7454978
*Joshi SR. 1989. Determination of ^241^Am in sediments by direct counting of low-energy photons. Appl Radiat Isot 40(8):691–699.
Juel K. 1994. High mortality in the Thule cohort: An unhealthy worker effect. Int J Epidemiol 23(6):1174–1178.7721519
Kalkwarf DR, Thomas VW, Nielson KK, . 1983. 1976 Hanford americium exposure incident: Urinary excretion of trace metals during DTPA treatments. Health Phys 45(4):937–947.6629787
*Kanapilly GM, Stanley JA, Newton GJ, . 1983. Characterization of an aerosol sample from the auxiliary building of the Three Mile Island reactor. Health Phys 45(5):981–989.6643066
Kargacin B, Volf V. 1989. Influence of nutritional factors on ^239^Np and ^233^Pa retention in weanling rats. Hum Toxicol 8:425–429.2591983
*Kathren RL. 1994. Toward improved biokinetic models for actinides: The United States Transuranium and Uranium Registries, a twenty-five year report. Rad Prot Dos 53(1–4):219–227.
*Kathren RL. 1995. The United States Transuranium and Uranium Registries: 1968-1993. Rad Prot Dos 60(4):349–354.
*Kathren RL, Lynch TP, Traub RJ. 2003. Six-year follow-up of an acute ^241^Am inhalation intake. Health Phys 84(5):576–581.12747476
*Kathren RL, McInroy JF, Reichert MM, . 1988. Partitioning of ^238^Pu, ^239^Pu and ^241^Am in skeleton and liver of U.S. Transuranium Registry autopsy cases. Health Phys 54(2):181–188.3338916
*Kathren RL, McInroy JF, Swint MJ. 1987. Actinide distribution in the human skeleton. Health Phys 52(2):179–192.3818285
*Kathren RL, Strom DJ, McInroy JF, . 1990. Distribution of plutonium and americium in the lungs and lymph nodes of United States Transuranium Registry registrants and relationship to smoking status. Health Phys 58(Suppl. 1):S48.
Kathren RL, Strom DJ, Sanders CL, . 1993. Distribution of plutonium and americium in human lungs and lymph nodes and relationship to smoking status. Radiat Prot Dosim 48(4):307–315.
Keith-Roach MJ, Day JP, Fifield K, . 2000. Seasonal variations in interstitial water transuranium element concentrations. Environ Sci Technol 34:4273–4277
*Kelly S, Dagle A. 1974. Cytogenetic damage in americium poisoning. NY State J Med 74(9):1597–1598.
Kelman BJ, Sikov MR. 1984. Transplacental movements of americium-241 in the guinea pig and early distribution kinetics in the dam. Teratology 29(2):40A.
*Kennedy WE, Cadwell LL, McKenzie DH. 1985. Biotic transport of radionuclides from a low-level radioactive waste site. Health Phys 49(1):11–24.4008258
Khokhryakov VF, Suslova KG, Filipy RE, . 2000. Metabolism and dosimetry of actinide elements in occupationally-exposed personnel of Russia and the United States: A summary progress report. Health Phys 79:S38–S40.10910402
*Knab D. 1979. Determination of americium in small environmental samples. Anal Chem 51(7):1905–1907.
*Knatko VA, Mayall A, Drugachenok MA, . 1993. Radiation doses in southern Byelorussia from the inhalation of specific radionuclides following the Chernobyl accident. Radiat Prot Dosim 48(2):179–183.
Kocher DC, Eckerman KF. 1981. Electron dose-rate conversion factors for external exposure of the skin. Health Phys 40:467–475.7228698
*Komori M, Nishio K, Kitada M, . 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29:4430–4433.2350547
*Kramer GH, Diebert T, Leon JW. 1989. Calibration of a double phoswich detector assembly for estimation of homogeneously or in homogeneously distributed ^241^Am and/or ^239^Pu in untreated fecal samples. Health Phys 56(3):361–365.2917867
*Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
*Krishnan K, Andersen ME, Clewell HJ III, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
*Labéjof L, Berry J-P, Duchambon P, . 1998. Apoptosis of rat kidney cells after 241-Americium administration. Anticancer Res 18:2409–2414.9703887
LaFuma J, Nenot JC, Morin M, . 1974. Respiratory carcinogenesis in rats after inhalation of radioactive aerosols of actinides and lanthanides in various physicochemical forms. In: Karbe E, Park JF, eds. Experimental lung cancer: Carcinogenesis and bioassays, international symposium. New York: Springer, 443–453.
Lagerquist CR, Hammond SE, Bokowski DL, . 1972a. Distribution of plutonium and americium in occupationally exposed humans as found from autopsy samples. Health Phys 23(3):418.
Lagerquist CR, Hammond SE, Bokowski DL, . 1973. Distribution of plutonium and americium in occupationally exposed humans as found from autopsy samples. Health Phys 25:581–584.4784267
*Lagerquist CR, Hammond SE, Hylton DB. 1972b. Distribution of plutonium and americium in the body 5 years after an exposure via contaminated punctured wound. Health Phys 22:921–924.5084028
LANL. 1999. Common isotopes. Los Alamos National Laboratory. http://pearl1.lanl.gov/periodic/commonis.html. February 9, 2000.
*LBL. 2000. The Evaluated Nuclear Structure Data File (ENSDF), The National Nuclear Data Center (NNDC). Isotope Explorer version 3.0 b1. Lawrence Berkeley National Laboratory. http://ie.lbl.gov. December 13, 2000.
Lee SC, Orlandini KA, Webb J, . 1998. Measurement of baseline atmospheric plutonium-239, 240 and americium-241 in the vicinity of the waste isolation pilot plant. J Radioanal Nucl Chem 234(1–2):267–272.
Lee SY, Tamura T, Larsen IL, . 1987. Characteristics of radionuclide-contaminated soils from the Sedan crater area at the Nevada test site. Soil Sci 144(2):113–121.
*Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Lefuma J, Chameaud J, Perraud R, . 1976. [An experimental study on a comparison between the toxic effects of radon-222 and its daughters on the lungs, and those exerted by alpha-emitters of the actinium series.] Occup Saf Health Ser 32:43–53. (French).
*Leggett RW. 1985. A model of the retention, translocation and excretion of systemic Pu. Health Phys 49(6):1115–1137.4077514
*Leggett RW. 1992. A retention-excretion model for americium in humans. Health Phys 62(4):288–310.1597379
*Leggett RW, Eckerman KF, Dunning DE, . 1984. On estimating dose rates to organs as a function of age following internal exposure to radionuclides. Oak Ridge, TN: U.S. Department of Energy. ORNL/TM8265.
*Leggett RW, Eckerman KF, Williams LR. 1982. Strontium-90 in bone: A case study in age-dependent dosimetric modeling. Health Phys 43:307–322.7174326
Leggett RW, Eckerman KF, Williams LR. 1993. An elementary method for implementing complex biokinetic models. Health Phys 64(3):260–271.8432645
*Leung H-W. 1993. Physiologically-based pharmacokinetic modeling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
*Lide DR, ed. 1994. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 75th ed. Boca Raton, Florida: CRC Press.
*Lide DR, ed. 1998. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 79th ed. Boca Raton, Florida: CRC Press.
Lide DR, ed. 2000. CRC Handbook of chemistry and physics: A ready-reference book of chemical and physical data. 81^st^ ed. Boca Raton, Florida: CRC Press, 4–40.
*Lindenbaum A, Rosenthal MW. 1972. Deposition patterns and toxicity of plutonium and americium in liver. Health Phys 22:597–605.5083990
*Litaor MI. 1995. Spatial analysis of plutonium-239 + 240 and americium-241 in soils around Rocky Flats, Colorado. J Environ Qual 24:506–516.
*Litaor MI, Barth GR, Zika EM. 1996. Fate and transport of plutonium-239+240 and americium-241 in the soil of Rocky Flats, Colorado. J Environ Qual 25:671–683.
*Litaor MI, Thompson ML, Barth GR, . 1994. Heavy metals in the environment: Plutonium-239 + 240 and americium-241 in soils east of Rocky Flats, Colorado. J Environ Qual 23:1231–1239.
*Livens FR, Hursthouse AS. 1993. Soil and sediment chemistry of the transuranic elements. Anal Proc 30:196–198.
*Livens FR, Horrill AD, Singleton DL. 1994. The relationship between concentrations of plutonium and americium in soil interstitial waters and their uptake by plants. Sci Total Environ 155:151–159.
*Livingston, AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4:301–324.351201
*LLNL. 1999. Livermore Big Trees Park: 1998 summary results. Lawrence Livermore National Laboratory. University of California, Livermore, California 94551. UCRL-ID-134581.
Lloyd RD, Mays CW. 1975. Determining liver retention of transuranium elements in living beagles. Radiat Environ Biophys 12:139–145.809801
Lloyd RD, Taylor GN. 1982. Low placental transfer of ^241^Am in a beagle long after ^241^Am injection. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division Department of Pharmacology University of Utah College of Medicine, 116–120. Contract No. DE-AC02-76EV-00119.
Lloyd RD, Atherton DR, Mays CW, . 1974. The early excretion, retention and distribution of injected curium citrate in beagles. Health Phys 27:61–67.4430633
Lloyd RD, Bruenger FW, Mays CW, . 1984a. Removal of Pu and Am from beagles and mice by 3,4,3-LICAM(C) or 3,4,3-LICAM(S). Radiat Res 99:106–128.6547537
*Lloyd RD, Jee WSS, Atherton DR, . 1972. Americium in beagles: biological effects and skeletal distribution. In: Stover BJ, Jee WSS, eds. Radiobiology of Plutonium. Salt Lake City: J.W. Press, 141–148.
Lloyd RD, Jones CW, Mays CW, . 1985a. Effect of Zn-DTPA therapy on the maternal transfer of ^241^Am or ^237^Pu to young mice. Health Phys 49(3):405–410.4030332
Lloyd RD, Mays CW, Jones CW, . 1984b. Retention and dosimetry of injected ^241^Am in beagles. Radiat Res 100:564–575.6505144
*Lloyd RD, Mays CW, Jones CW, . 1985b. Effect of age on the efficacy of Zn-diethylenetriaminepentaacetic acid therapy for removal of Am and Pu from beagles. Radiat Res 101:451–459.3983361
*Lloyd RD, Mays CW, Taylor GN, . 1970. Americium-241 studies in beagles. Health Phys 18:149–156.5416368
*Lloyd RD, McFarland SS, Taylor GN, . 1975a. Decorporation of ^241^Am in beagles by DTPA. Radiat Res 62:97–106.235147
*Lloyd RD, Miller SC, Taylor GN, . 1994a. Relative effectiveness of ^239^Pu and some other internal emitters for bone cancer induction in beagles. Health Phys 67:346–353.8083047
Lloyd RD, Miller SC, Taylor GN, . 1997. Comparison of internal emitter radiobiology in animals and humans. Health Phys 72(1):100–110.8972834
*Lloyd RD, Miller SC, Taylor GN. 2001. Does longevity in beagles injected with bone-seeking radionuclides depend upon radiation dose in the absence of known radiation effects? Health Phys 81(4):456–459.11569641
*Lloyd RD, Taylor GN, Angus W, . 1994b. Skeletal malignancies among beagles injected with ^241^Am. Health Phys 66(2):172–177.8282558
*Lloyd RD, Taylor GN, Angus W, . 1995. Soft tissue tumors in beagles injected with ^241^Am citrate. Health Phys 68(2):225–233.7814256
*Lloyd RD, Taylor GN, Jee WSS, . 1999. Relative radiosensitivity of bone tumor induction among beagles as a function of age at injection of ^239^Pu or ^226^RA. Health Phys 76(1):50–56.9883947
*Lloyd RD, Taylor GN, Mays CW, . 1975b. DTPA therapy of ^241^Am from a simulated wound site. Health Phys 29:808–811.1193906
*Lloyd RD, Taylor GN, Mays CW. 1998. ^241^Am removal by DTPA vs. occurrence of skeletal malignancy. Health Phys 75(6):640–645.9827511
Lo Sasso TJ. 1974. Measurement of ^241^Am kinetics in man. Master of Science Thesis, New York University, New York, NY.
Lo Sasso T, Cohen N, Wrenn ME. 1981. Distribution and retention of ^243,244^Cm in the adult baboon. Radiat Res 85:173–183.7465773
*Lovett MB, Boggis SJ, Blowers P. 1990. Aquatic environment protection: Analytical methods. Lowestoft: Directorate of Fisheries Research.
Lücke-Huhle C, Pech M, Herrlich P. 1986. Selective gene amplification in mammalian cells after exposure to ^60^Co γ rays ^241^Am α particles, or UV light. Radiat Res 106:345–355.3714979
*Lujaniene G, Lujanas V, Jankunaite D, . 1999. Speciation of radionuclides of the Chernobyl origin in aerosol and soil samples. J Environ Radioact 49:107–114.
Lynch TP, Kathren RL, Dagle GE, . 1989. Comparative skeletal distribution of Am and Pu in man, monkey, and baboon. Health Phys 57(Suppl. 1):81–88.2606708
*Lynch TP, Kathren RL, Dagle GE, . 1989. Comparative skeletal distribution of Am and Pu in man, monkey, and baboon. Health Phys 57(1):81–88.2606708
Lynch TP, Kathren RL, McInroy JF. 1988. Macrodistribution of plutonium and americium in four human skeletons. J Radiol Prot 8(2):67–76.
Macdonald RW, Bewers JM. 1996. Contaminants in the arctic marine environment: Priorities for protection. ICES J Mar Sci 53:537–563.
*Mahon DC. 1982. Uptake and translocation of naturally-occurring radionuclides of the uranium series. Bull Environ Contam Toxicol 29(6):697–703.7159779
*Malcolm SJ, Kershaw PJ, Cromar NJ, . 1990a. Iron and manganese geochemistry and the distribution of ^239,240^Pu and ^241^Am in the sediments of the north east Irish Sea. Sci Total Environ 95:69–87.
*Malcolm SJ, Kershaw PJ, Lovett MB, . 1990b. The interstitial water chemistry of ^239,240^Pu and ^241^Am in the sediments of the north-east Irish Sea. Geochemica et Cosmochimica Acta 54:29–35.
*MARSSIM. 2000. Multi-Agency Radiation Survey and Site Investigation Manual. NUREG-1575, Rev 1, Nuclear Regulatory Commission; EPA 402-R-97-016, Rev 1, U.S. Environmental Protection Agency; DOE/EH-0624, Rev 1, Department of Energy.
*Markham OD, Puphal KW, Filer TD. 1978. Plutonium and americium contamination near a transuranic storage area in southeastern Idaho. J Environ Qual 7(3):422–428.
*Marzano FN, Fiori F, Jia G, . 2000. Anthropogenic radionuclides bioaccumulation in Antarctic marine fauna and its ecological relevance. Polar Biol 23:753–758
*Matsunaga T, Ueno T, Amano H, . 1998. Characteristics of Chernobyl-derived radionuclides in particulate form in surface waters in the exclusion zone around the Chernobyl nuclear power plant. J Contam Hydrol 35:101–113.
*Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74:135–149.1387742
Mays CW, Lloyd RD, Atherton DR. 1974. Transuranium elements in gonadal tissue. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 308–309. Contract No. AT(11-1)-119.
Mays CW, Lloyd RD, Taylor GN, . 1987. Cancer incidence and lifespan vs. α-particle dose in beagles. Health Phys 52(5):617–624.3570798
*McCarthy JF, Czerwinski KR, Sanford WE, . 1998a. Mobilization of transuranic radionuclides from disposal trenches by natural organic matter. J Contam Hydrol 30:49–77.
*McCarthy JF, Sanford WE, Stafford PL. 1998b. Lanthanide field tracers demonstrate enhanced transport of transuranic radionuclides by natural organic matter. Environ Sci Technol 32(24):3901–3906.
*McCartney M, Kershaw PJ, Woodhead DS, . 1994. Artificial radionuclides in the surface sediments of the Irish Sea, 1968-1988. Sci Total Environ 141:103–138.
*McClellan RO, Casey HW, Bustad LK. 1962. Transfer of some transuranic elements to milk. Health Phys 8:689–694.
McDonald P, Baxter MS, Fowler SW. 1993. Distribution of radionuclides in mussels, winkles and prawns. Part 2. Study of organisms under laboratory conditions using alpha-autoradiography. J Environ Radioact 18:203–228.
McDonald P, Cook GT, Baxter MS, . 1992. The terrestrial distribution of artificial radioactivity in south-west Scotland. Sci Total Environ 111:59–82.
McDonald P, Vives i Batlle J, Bousher A, . 2001. The availability of plutonium and americium in Irish Sea sediments for re-dissolution. Sci Total Environ 267:109–123.11286207
*McInroy JF, Boyd HA, Eutsler BC, Romero D. 1985. The US Transuranium Registry report on the ^241^Am content of a whole body. Part IV: Preparation and analysis of the tissue and bones. Health Phys 49:587–621.4044261
McInroy JF, Kathren RL, Swint MJ, . 1988. Tissue ^241^Am content in a U.S. Transuranium Registry autopsy case eleven years after exposure from a glove box explosion. Health Phys 54(Suppl. 1):S26.
*McInroy JF, Kathren RL, Swint MJ. 1989. Distribution of plutonium and americium in whole bodies donated to the United States Transuranium Registry. Radiat Prot Dosim 26(1/4):151–158.
*McInroy JF, Kathren RL, Toohey RE, . 1995. Postmortem tissue contents of ^241^Am in a person with a massive acute exposure. Health Phys 69(3):318–323.7635727
*McKay LR, Brooks AL, McClellan RO. 1972. The retention, distribution, dose and cytogenetic effects of ^241^Am citrate in the Chinese hamster. Health Phys 22:633–640.5083994
McKay WA, Pattenden NJ. 1989. Radionuclides in shoreline waters of the northeast Irish Sea. Sci Total Environ 84:159–167.2772617
*McKay WA, Garland JA, Livesley D, . 1994. The characteristics of the shore-line sea spray aerosol and the landward transfer of radionuclides discharged to coastal sea water. Atmos Environ 28(21):3299–3309.
*McKenna P, Longworth RD. 1995. Residual Chernobyl fallout and Sellafield pollutants found on the Isle of Man. Sci Total Environ 173/174:7–14.8560234
*McMurray BJ. 1983. 1976 Hanford americium exposure incident: Accident description. Health Phys 45(4):847–853.6629778
*Métivier H. 2003. A new model for the human alimentary tract: The work of a committee 2 task group. Radiat Prot Dosim 105(1–4):43–48.
Mellado J, Llaurado M, Rauret G. 2002. Determination of actinides and strontium in fish samples by extraction chromatography. Anal Chim Acta 458:367–374.
*Mercer TT. 1967. On the role of particle size in the dissolution of lung burdens. Health Phys 13:1211–1221.6050527
*Mewhinney JA, Griffith WC. 1982. Models of Am metabolism in beagles and humans. Health Phys 42(5):629–644.7085303
*Mewhinney JA, Griffith WC. 1983. A tissue distribution model for assessment of human inhalation exposures to ^241^AmO_2_. Health Phys 44(Suppl. 1):537–544.6862928
Mewhinney JA, Muggenburg BA. 1977. Patterns of dose after inhalation of monodisperse or polydisperse aerosols. In: Boecker BB, Hobbs CH, Martinez BS, eds. Inhalation Toxicology Research Institute annual report: Lovelace Biomedical and Environmental Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 44–47.
*Mewhinney JA, Muggenburg BA. 1985. Comparison of retention of ^241^Am in immature, young adult, and aged dogs and in monkeys after inhalation of ^241^AmO_2_. In: Medinsky MA, Muggenburg BA, eds. Inhalation Toxicology Research Institute annual report: Lovelace Biomedical and Environmental Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 348–353.
Mewhinney JA, Griffith WC, Muggenburg BA. 1979. Comparison of metabolic models used to describe the fate of inhaled ^241^AmO_2_ based on inhalation studies in the beagle dog. Health Phys 37(6):830.
Mewhinney JA, Griffith WC, Muggenburg BA. 1980. Proposed retention model for human inhalation exposure to ^241^AmO_2_. In: International Radiation Protection Society, ed. Radiation protection: A systemic approach to safety: Proceedings of the 5th Congress of the International Radiation Protection Society, Jerusalem, March 1980. New York: Pergamon Press, 615–618.
*Mewhinney JA, Griffith WC, Muggenburg BA. 1982. The influence of aerosol size on retention and translocation of ^241^Am following inhalation of ^241^AmO_2_ by beagles. Health Phys 42(5):611–627.7085302
Mewhinney JA, Hobbs CH, Mo T, . 1976a. Radiation dose pattern following inhalation of monodisperse and polydisperse aerosols of ^241^AmO_2_ in beagle dogs I. In: Boecker BB, Jones RK, Barnett NJ, eds. Inhalation toxicology research institute annual report: Lovelace Biomedical and Environmental Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 93–95.
Mewhinney JA, Hobbs CH, Mo T. 1976b. Toxicity of inhaled polydisperse or monodisperse aerosols of ^241^AmO_2_ in Syrian hamsters III. In: Boecker BB, Jones RK, Barnett NJ, eds. Inhalation Toxicology Research Institute annual report: Lovelace Biomedical and Environmental Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 251–258.
Michel H, Barci-Funel G, Dalmasso J, . 2002. Plutonium and americium inventories in atmospheric fallout and sediment cores from Blelham Tarn, Cumbria (UK) J Environ Radioact 59:127–137.11900201
Mietelski JW, Gaca P, Jasińska M. 2000. Plutonium and other alpha-emitters in bones of wild, herbivorous animals, from north-eastern Poland. Appl Radiat Isot 53:251–257.10879870
Miettinen JK, Mussalo H, Hakanen M, . 1980. Distribution of plutonium and americium in human and animal tissues after chronic exposures. In: International Radiation Protection Society, ed. Radiation protection: A systemic approach to safety: Proceedings of the 5th congress of the International Radiation Protection Society, Jerusalem, March 1980. New York: Pergamon Press, 1049–1052.
Miller SC, Bruenger FW, Kuswik-Rabiega G, . 1992. Decorporation of plutonium by oral administration of a partially lipophilic polyaminocarboxylic acid. Health Phys 63(2):83–85.
Miller SC, Bruenger FW, Kuswik-Rabiega G, . 1993. Duration and dose-related effects of an orally administered, partially lipophilic polyaminocarboxylic acid on the decorporation of plutonium and americium. J Pharmacol Exp Ther 267(1):548–554.8229785
Moody JC, Stradling GN, Britcher AR. 1994. Biokinetics of three industrial plutonium nitrate materials: Implications for human exposure. Radiat Prot Dosim 53(1–4):169–172.
*Moody JC, Stradling GN, Gray SA. 1991. The biokinetics of four ^239^Pu/^241^Am dioxide bearing dusts in the rat after inhalation: The implications for occupational exposure. J Aerosol Sci 22(Suppl. 1):S805–S808.
Moreno J, Vajda N, Danesi PR, . 1997. Combined procedure for the determination of ^90^Sr, ^241^Am, and Pu radionuclides in soil samples. J Radioanal Nucl Chem 226(1–2):279–284.
Morgan KZ. 1976. Release of radioactive materials from reactors. In: Nuclear Power Safety. New York, NY: Pergamon Press.
Morgan A, Holmes A, Pratley FW. 1990. Solubility in the rat lung of actinides associated with estuarine silt from West Cumbria. J Radiol Prot 10(2):135–142.
*Morris K, Butterworth JC, Livens FR. 2000. Evidence for the remobilization of Sellafield waste radionuclides in an intertidal salt marsh, West Cumbria, U.K. Estuarine Coastal Shelf Sci 51:613–625.
*Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokin 5:485–527.
*Moskalev JI, Buldakov LA, Lyaginskaya AM, . 1969. Experimental study of radionuclide transfer through the placenta and their biological action on the fetus. In: Radiation biology of the fetal and juvenile Mammal. Richland, WA: Hanford Biology Symposium, 153–160.
Moskalev YI, Levdik TI, Lyubchanskii ER, . 1975. Metabolism and biological effects in rodents of plutonium and other actinide elements. In: Nygaard OF ., ed. Radiation research: Biomedical, chemical, and physical perspectives. New York, NY: Academic Press, 1214–1232.
*Moskalev YI, Lyaginskaya AM, Zalikin GA, . 1989. Carcinogenic effects in rat progeny exposed perinatally to radionuclides. In: Napalkov NP, Rice JM, Tomatis L, ., ed. Perinatal and multigeneration carcinogenesis. IARC scientific publications 96. Lyon, France: International Agency for Research on Cancer, 421–427.
*Moushatova P, Shopova V, Kilyovska M, Salovski P. 1996. Morphometric investigations of a liver of experimental animals treated with Americium 241. Scientific Works of the Medical University of Pleven, 27–29.
*Müller HL, Taya A, Drosselmeyer E, . 1989. Cellular aspects of retention and transport of inhaled soluble and insoluble actinide compounds in the rat lung. Sci Total Environ 83:239–251.2551034
Muggenburg BA, Mewhinney JA, Hahn FF, . 1979. Toxicity of inhaled alpha-emitting radionuclides - status report. In: Henderson RF, Diel JH, Martinez BS, eds. Inhalation toxicology research institute annual report: Lovelace Biomedical and Environmental Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 117–121.
*Mulsow S, Coquery M, Dovlete C. 1999. Radionuclide concentrations in underground waters of Mururoa and Fangataufa Atolls. Sci Total Environ 237/238:287–300.10568283
*Murray CN, Avogadro A. 1979. Effect of a long-term release of plutonium and americium into an estuarine-coastal sea ecosystem. I. Development of an assessment methodology. Health Phys 36:573–585.489311
*Murray CN, Kautsky H, Eicke HF. 1979. Transfer of actinides from the English Channel into the southern North Sea. Nature 278:617–620.
*Murray CN, Kautsky H, Hoppenheit M, . 1978. Actinide activities in water entering the northern North Sea. Nature 276:225–230.
*Murray RL. 1994. Understanding Radioactive Waste. Fourth ed. Columbus-Richland: Battelle Press.
Nabors CJ, Berliner DL, Stevens W. 1967. Preliminary comparison of the effects of ^241^Am and ^239^Pu on serum enzymes. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy, University of Utah College of Medicine, 207–217. Contract No. AT(11-1)-119.
Nabors CJ, Hinkley JS, Fowkes KL. 1974. Steroid 11 β-hydroxydehydrogenase activity in beagles bearing ^241^Am. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 326. Contract No. AT(11-1)-119.
*NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press.
National Radiological Protection Board. 1982. Gut uptake factors for plutonium, americium and curium. Hartwell, England: National Radiological Protection Board. DE83702055.
Naylor GPL, Haines JW, Whysall K, . 1993. Measurements of the gastrointestinal absorption and tissue distribution of plutonium, americium and polonium in experimental animals. Sci Total Environ 130:429–435.8469956
*NCRP. 1987. Use of bioassay procedures for assessment of internal radionuclide deposition. Bethesda, MD: National Council on Radiation Protection and Measurements. Report No. 87.
*NCRP. 1997. Deposition, retention and dosimetry of inhaled radioactive substances. National Council on Radiation Protection and Measures. Bethesda, MD. Report No. 125. http://www.ncrp.com. December 13, 2000.
*NCRP. 1998. Radionuclide exposure of the embryo/fetus. Bethesda, MD: National Council on Radiation Protection and Measurements. NCRP REPORT No. 128.
*NEA. 1988. Gastrointestinal absorption of selected radionuclides. Paris: Nuclear Energy Agency.
Nechev H, Sulovski P, Shopova Y, . 1982. Particularities in the metabolism of americium-241 after intratracheal application and in combination with external irradiation. Sci Works Higher Med Inst-Pleven 4(1):37–43.
*Nenot JC, Stather JW. 1980. The toxicity of plutonium, americium, and curium: Plutonium recycling in light water reactors. Oxford: Pergamon Press.
*Nenot JC, Masse R, Morin M, . 1972. An experimental comparative study of the behavior of ^237^Np, ^238^Pu, ^239^Pu, ^241^Am and ^242^Cm in bone. Health Phys 22:657–665.5083996
Nénot JC, Morin M, Lafuma J. 1971. Étude expérimentale de la décontamination du squelette apres inhalation de nitrate d’américium. Health Phys 21:395–400.5095639
Nevissi AE. 1992. Measurement of actinides and long-lived radionuclides in large coral samples. J Radioanal Nucl Chem 156(2):243–251.
*Nevissi A, Schell WR, Nelson VA. 1976. Plutonium and americium in soils of bikini atoll. International Atomic Energy Agency, Vienna. STI/PUB/410 ISBN 92-0-020076-1.
*Newton D, Taylor BT, Eakins JD. 1983. Differential clearance of plutonium and americium oxides from the human lung. Health Phys 44(Suppl. 1):431–439.6862919
*Nielson SP, Iosjpe M, Strand P. 1997. Collective doses to man from dumping of radioactive waste in the Arctic Seas. Sci Total Environ 202:135–146.9241883
Nielsen SP, Bengtson P, Bojanowsky R, . 1999. The radiological exposure of man from radioactivity in the Baltic Sea. Sci Total Environ 237/238:133–141.10568271
Nies H, Harms IH, Karcher MJ, . 1999. Anthropogenic radioactivity in the Arctic Ocean - Sci Total Environ 237/238:181–191.10568275
Nifatov AP, Buldakov LA, Matveev VI. 1972. Some late effects after a single inhalation of ^239^Pu and ^241^Am in dogs. Health Phys 22:875.4507896
NIOSH. 2000. NIOSH pocket guide to chemical hazards (NPG). Washington, DC: National Institute for Occupational Safety and Health. http://www.cdc.gov/niosh/npg/npgd0000.html. September 15, 2000.
*Nisbet AF, Shaw S. 1994. Summary of a 5-year lysimeter study on the time-dependent transfer of ^137^Cs, ^90^Sr, ^239,240^Pu and ^241^Am to crops from three contrasting soil types: 1. Transfer to the edible portion. J Environ Radioact 23:1–17.
Northcutt AR, Binney SE. 1988. In vivo counting of ^241^Am in human lungs and tracheobronchial lymph nodes. Health Phys 54(1):73–81.3335444
Noáke D, Roedler HD, Doerfel H, . 1989. Interpreting measurements after ^241^Am incorporation in terms of standard and adapted metabolic data. Radiat Prot Dosim 26(1/4):279–282.
*NRC. 1981. Distribution coefficients for radionuclides in aquatic environments. National Research Council, Washington DC: National Academy Press.
*NRC. 1993. Pesticides in the diets of infants and children. National Research Council. Washington, DC: National Academy Press.
*NRPB. 2002. Industrial uranium compounds: exposure limits assessment of intake and toxicity after inhalation. Report NRPB-W22, Chilton. National Radiological Protection Board.
*Nyhan JW, Drennon BJ, Abeele WV, . 1985. Distribution of plutonium and americium beneath a 33-yr old liquid waste disposal site. J Environ Qual 14(4):501–509.
Okabayashi H. 1980. Differential movement of plutonium and americium in lungs of rats following the inhalation of submicron plutonium nitrate aerosol. J Radiat Res 21:111–117.7381808
*O’Neil MJ, ed. 2001. The Merck Index- An encyclopedia of chemicals, drugs, and biologicals. 13^th^ ed. Whitehouse Station, NJ: Merck and Co., Inc., 69.
*Orlandini KA, Penrose WR, Harvey BR, . 1990. Colloidal behavior of actinides in an oligotrophic lake. Environ Sci Technol 24(5):706–712.
Ovcharenko EP. 1972. An experimental evaluation of the effects of transuranic elements on reproductive ability. Health Phys 22:641.4673433
*Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
*Paatero J, Jaakkola T. 1998. Transfer of plutonium, americium and curium from fallout into reindeer after the Chernobyl accident. Boreal Environment Research 3:181–189.
*Palmer HE, Rhoads MC. 1989. Determining the ratio of ^239^Pu to ^241^Am in wounds by measuring the Lγ x-rays with a Si(Li) detector. Health Phys 56:249–252.2917854
Palmer HE, Rieksts GA, Icayan EE. 1979. In vivo measurement of americium-241 in the Hanford americium accident. Health Phys 37(6):809.
*Palmer HE, Rieksts GA, Icayan EE. 1983. 1976 Hanford americium exposure incident: In vivo measurements. Health Phys 45(4):893–910.6629783
*Palmer HE, Spitz HB, Rieksts GA. 1985. Part III: Gamma-ray measurements. Health Phys 49(4):577–586.3930425
Paquet F, Durand J-P, Goudard F, . 1993. Distribution of [^241^Am] in hepato-pancreatic nuclear proteins of the lobster (Homarus gammarus). Biochem Mol Biol Int 29(4):635–644.8490574
*Paquet F, Poncy J-L, Ham GJ, . 1998. Transfer of polonium, neptunium, plutonium and americium to the primate fetus. Radiat Prot Dosim 79(1–4):303–306.
*Parrington, JR, Knox, HD, Breneman SL, ., eds. 1996. Nuclides and isotopes. 15^th^ Edition. General Electric Company and KAPL, Inc, 3–15, 44–49.
Paschoa AS, Arruda Neto JDT. 1992. Electrofission and photofission as tools to measure actinides in environmental and biological samples. J Radioanal Nucl Chem 156(2):297–311.
*Pattenden NJ, McKay WA. 1994. Studies of artificial radioactivity in the coastal environment of northern Scotland: A review. J Environ Radioact 24:1–51.
Paull B, Foulkes M, Jones P. 1994. Determination of alkaline earth metals in offshore oil-well brines using high-performance chelation ion chromatography. Anal Proc 31:209–211.
*Penrose WR, Polzer WL, Essington EH, . 1990. Mobility of plutonium and americium through a shallow aquifer in a semiarid region. Environ Sci Technol 24(2):228–234.
Petersen GR, Gilbert ES, Buchanan JA, . 1990. A case-cohort study of lung cancer, ionizing radiation, and tobacco smoking among males at the Hanford site. Health Phys 58(1):3–11.2294071
*Phalen RF, Oldham HJ, Beaucage CB, . 1985. Postnatal enlargement of human tracheobronchial airways and implications for particle deposition. Anat Rec 212:368–380.4073554
Pilon F, Lorthioir S, Birolleau J-C, . 1996. Determination of trace elements in radioactive and toxic materials by inductively coupled plasma mass spectrometry. J Anal Atom Spectrom 11:759–763.
Piltingsrud HV, Farr RL. 1978. A beta-alpha-gamma x-radiation (bag-x) detection probe for use with a plutonium-americium survey instrument. Health Phys 34:177–184.632097
*Platford RF, Joshi SR. 1986. The chemistry of uranium and related radionuclides in Lake Ontario waters. J Radioanal Nucl Chem 106(6):333–343.
*PNL. 2000. Hanford site environmental report for calendar year 1994. Air surveillance, airborne radionuclide concentrations in the Hanford Environs, 1994 compared to values from the previous 5 years. Facility Effluent Monitoring. Pacific Northwest National Laboratory. http://www.pnl.gov/. December 12, 2000.
*PNL. 1995. Hanford site environmental report for calendar year 1994. Air surveillance, airborne radionuclide concentrations in the Hanford Environs, 1994 compared to values from the previous 5 years. Facility Effluent Monitoring. Pacific Northwest National Laboratory, June 1995. http://www.pnl.gov/env/env_home.html. January 22, 2004.
*PNNL. 2000. 1999 Hanford site environmental report September 1999 PNNL-13230. Pacific Northwest National Laboratory. http://hanford-site.pnl.gov/envreport/. January 22, 2004.
*PNNL. 2001. Hanford site environmental report for calendar year 2000 PNNL-13487, September 2001. Pacific Northwest National .Laboratory. http://hanford-site.pnl.gov/envreport/. January 22, 2004.
*PNNL. 2002. Hanford site environmental report for calendar year 2001 PNNL-13910, September, 2002. Pacific Northwest National Laboratory. http:/;/Hanford-site.pnl.gov/envreport/ (http://Hanford-site.pnl.gov/envreport/). January 22, 2004.
*PNNL. 2003. Methods and models of the Hanford Internal Dosimetry Program. PNNL-MA-860 Richland, Washington. Pacific Northwest National Laboratory. http://www.pnl.gov/eshs/pub/pnn1860.html. March 09, 2004.
*Polig E. 1976. Topographic analysis of the micro distribution of ^241^Am in the rat femur as influenced by DTPA treatment. Radiat Res 67:128–141.940926
*Popplewell DS, Boocock G. 1967. Distribution of some actinides in blood serum proteins. In: Kornberg HA, Norwood WD, eds. Diagnosis and treatment of deposited radionuclides. Amsterdam: Excerpta Medica Foundation, 45–55.
*Popplewell DS, Ham GJ. 1989. Distribution of plutonium and americium in tissues from a human autopsy case. J Radiol Prot 9(3):159–164.
*Popplewell DS, Ham GJ, Johnson TE, . 1984. The uptake of plutonium-238, 239, 240, americium-241, strontium-90 and caesium-137 into potatoes. Sci Total Environ 38:173–181.6523121
*Poupard D, Jouniaux B. 1990. Determination of picogram quantities of americium and curium by thermal ionization mass spectrometry (TIMS). Radiochim Acta 41(1):25–28.
Priest ND, Birchall A. 1984. The calculation of bone doses from alpha-emitting bone surface seeking radionuclides for radiological protection purposes. Radiat Environ Biophys 23:149–153.6739719
*Priest ND, Freemont A, Humphreys JAH, . 1995. Histopathology and ^241^Am micro distribution in skeletal USTUR case 246. Health Phys 69(3):330–337.7635729
*Priest ND, Howells G, Green D, . 1983. Pattern of uptake of americium-241 by the rat skeleton and its subsequent redistribution and retention: Implications for human dosimetry and toxicology. Hum Toxicol 2:101–120.6840786
*Qu H, Stuit D, Glover SE, . 1998. Preconcentration of plutonium and americium using the actinide-CU^tm^ resin for human tissue analysis. J Radioanal Nucl Chem 234(1–2):175–181.
Raabe OG. 1984. Comparison of the carcinogenicity of radium and bone-seeking actinides. Health Phys 46(6):1241–1258.6327574
Raabe OG. 1996. Relative biological effectiveness for induction of cancer by protracted alpha versus beta internal irradiation. Health Phys 70(6):S8.
*Ragan HA, Mahaffey JA, Breitenstein BD. 1983. 1976 Hanford americium exposure incident: Hematologic effects. Health Phys 45(4):923–932.6629785
Ramounet B. 1997. Biokinetics of Pu and Am after inhalation of industrial (U, Pu)O_2_ and PuO_2_ in the rat: Preliminary results. Radiat Prot Dosim 79(1–4):53–56.
Ramounet B, Matton S, Guezingar-Liebard F, . 2000. Comparative biokinetics of plutonium and americium after inhalation of PuO_2_ and mixed oxides (U, Pu) O_2_ in rat. Int J Radiat Biol 76(2):215–222.10716642
*Rapiejko A, Rosson R, Lahr J . 2001. Radionuclides in Peconic River fish, mussels, and sediments. Health Phys 81(6):698–703.11725889
Riches AC, Herceg Z, Bryant PE, . 1997. Radiation-induced transformation of SV40-immortalized human thyroid epithelial cells by single exposure to plutonium α-particles in vitro. Int J Radiat Biol 72(5):515–521.9374431
Ristic M, Degetto S, Ast T, . 2002. Sample preparation for the determination of ^241^Am in sediments utilizing-γ-spectrometry. J Environ Radioact 59:179–189 11900205
Robertson DE, Thomas CW, Perkins RW, . 1981. Transuranium and other long-lived radionuclides in the terrestrial environs of nuclear power plants. Electric Power Research Institute, Environmental Physics and Chemistry Program, Energy Analysis and Environment Division, Palo Alto, CA. EA-2045. NTIS/DE82003074.
*Robinson B, Heid KR, Aldridge TL, . 1983. 1976 Hanford americium exposure incident: Organ burden and radiation dose estimates. Health Phys 45(4):911–921.6629784
*Robison WL, Noshkin VE, Conrado CL, . 1997a. The northern Marshall Island radiological survey: Data and dose assessment. Health Phys 73(1):37–48.9199217
*Robison WL, Bogen KT, Conrado CL. 1997b. An updated dose assessment for resettlement options at Bikini Atoll-a U.S. nuclear test site. Health Phys 73(1):100–114.9199221
*Robison WL, Noshkin VE. 1999. Radionuclide characterization and associated dose from long-lived radionuclides in close-in fallout delivered to the marine environment at Bikini and Enewetak Atolls. Sci Total Environ 237/238:311–327.10568285
Robison WL, Noshkin VE, Hamilton TF, . 2001. An assessment of the current day impact of various materials associated with the U.S. Nuclear Test Program in the Marshall Islands. U.S. Department of Energy. Lawrence Livermore National Laboratory. UCRL-LR-143980.
Robredo LM, Navarro T, Sierra I. 2000. Indirect monitoring of internal exposure in the decommissioning of a nuclear power plant in Spain. Appl Radiat Isot 53:343–350.
*Rommereim DN, Sikov MR. 1986. Relative embryotoxicity of ^239^Pu and ^241^Am in rats. Teratology 33(3):93C–94C.3738814
*Rommereim DN, Buschbom RL, Sikov MR. 1985. Comparison of embryotoxic effects of intravenously administered ^239^Pu and ^241^Am in rats. Health Phys 49:122–123.
*Romney EM, Wallace A, Schulz RK, . 1981. Plant uptake of ^237^Np, ^239,240^Pu, ^241^Am, and ^244^Cm from soils representing major food production areas of the United States. Soil Sci 132(1):40–59.
Roos P, Holm E, Persson RBR, . 1994. Deposition of ^210^Pb, ^137^Cs, ^239+240^Pu, ^238^Pu, and ^241^Am in the Antarctic Peninsula area. J Environ Radioact 24:235–251.
*Rose CL, McKay WA, Leonard DRP, . 1996. Radioactivity in two tide-washed marsh areas in the eastern Irish Sea: A radiological assessment. Sci Total Environ 191:1–13.8885422
Rosen JC, Cohen N, Wrenn ME. 1972. Short term metabolism of ^241^Am in the adult baboon. Health Phys 22:621–626.4628452
*Rosner G, Hötzl H, Winkler R. 1978. Measurements of transuranium nuclides in the environment at the Institute for Radiation Protection of the Gesellschaft für Strahlen- und Umweltforschung mbH, Munich. Environ Int 1:85–88.
*Rundo J, Fairman WD, Essling M, . 1977. Ingestion of ^241^Am sources intended for domestic smoke detectors: Report of a case. Health Phys 33:561–566.604299
Russell JJ, Lindenbaum A, Grahn D. 1979. The micro distribution, retention, and autoradiography of ^241^Am-citrate in mouse testis. Health Phys 37(6):831–832.
*Ryan TP, Dowdall AM, Long S, . 1999. Plutonium and americium in fish, shellfish and seaweed in the Irish environment and their contribution to dose. J Environ Radioact 44:349–369.
Ryan TP. 2002. Transuranic biokinetic parameters for marine invertebrates - a review. Environ Int 28:83–96.12046958
Sanada Y, Matsunaga T, Yanase N, . 2002. Accumulation and potential dissolution of Chernobyl-derived radionuclides in river bottom sediment. Appl Radiat Isot 56:751–760 11993951
*Sanchez AL, Horrill AD, Howard BJ, . 1998. Anthropogenic radionuclides in tide-washed pastures bordering the Irish Sea coast of England and Wales. Water Air Soil Pollut 106:403–424.
*Sanchez AL, Horrill AD, Singleton DL, . 1996. Radionuclides around nuclear sites in England and Wales. Sci Total Environ 181:51–63.
*Sanchez-Cabeza JA, Molero J. 2000. Plutonium, americium and radiocaesium in the marine environment close to the Vandéllos I nuclear power plant before decommissioning. J Environ Radioact 51:211–228.
Sanders CL. 1972. Deposition patterns and the toxicity of transuranium elements in lung. Health Phys 22:607–615.5083991
Sanders CL, Mahaffey JA. 1978. Toxicology of inhaled transuranic oxides in rodents. Pharmacologist 20(3):175.
*Sanders CL, Mahaffey JA. 1983. Inhalation carcinogenesis of high-fired ^241^AmO_2_ in rats. Radiat Res 94:66–80.6856769
*Sanders SM. 1974. Excretion of ^241^Am and ^244^Cm following two cases of accidental inhalation. Health Phys 27:359–365.4443274
*Sasser LB, Mahlum DD, Rommereim RL. 1986. Influence of pregnancy and lactation on maternal deposition and perinatal uptake of ^241^Am in the rat. Health Phys 50(5):595–604.3700111
Schell WR, Berg MT, Myttenaere C, . 1994. A review of the deposition and uptake of stable and radioactive elements in forests and other natural ecosystems for use in predictive modeling. Sci Total Environ 157:153–161.
*Schlenker RA, Oltman BG, Kathren RL. 1989. Bone surface deposition of ^241^Am in a person with occupational exposure. Radiat Prot Dosim 26(1/4):195–199.
Schmidt CT, Durbin P. 1985. A five-compartment model for the kinetic distribution of americium in man. Health Phys 49(1):161.
Schoeters GER, Vanderborght OLJ. 1983. Relative effectiveness of ^241^Am vs ^226^Ra approached by haemopoietic stem cell studies in various bone marrow sites of contaminated mice. Health Phys 44(Suppl. 1):555–570.6862930
*Schoeters GER, Maisin JR, Vanderborght OLJ. 1991. Toxicity of ^241^Am in male C57BL mice: Relative risk versus ^226^Ra. Radiat Res 126:198–205.2023989
Schoeters G, Van Den Heuvel R, Hurtgen C, . 1987. ^241^Am distribution in foetal haemopoietic organs of balb/c mice. In: Age-related factors in radionuclide metabolism and dosimetry. Netherlands: Kluwer Academic Publishers, 193–200.
*Schoeters G, Van Den Heuvel R, Leppens H, . 1990. Distribution of ^241^Am in offspring from BALB/c mice injected with ^241^Am and 14 days of gestation: Relation to calcium and iron metabolism and comparison with distribution of ^241^Am after injection of adults. Int J Radiat Biol 58(2):371–382.1974583
*Schoeters G, Van Den Heuvel R, Vanderborght O. 1985. The study of damage to bone marrow cells as a biological dosimeter after contamination with osteotropic α emitters. EUR 9250:51–61.
Schoeters GER, Vanderborght O, Maisin JR. 1986. Relative sensitivity of ^241^Am verses ^226^Ra in life span shortening and cancer induction in C57BL mice, comparison with other larger scale mouse experiments with ^226^Ra and with ^241^Am. Cancer Lett 30:S21.
Schoeters GER, Vander Plaetse F, Van Den Heuvel RL. 1992. High radiosensitivity of the mineralization capacity of adult murine bone marrow in vitro to continuous α-irradiation compared to acute X-irradiation. Int J Radiat Biol 61(5):675–683.1349632
*Schreckhise RG, Cline JF. 1980. Comparative uptake and distribution of plutonium, americium, curium and neptunium in four plant species. Health Phys 38:817–824.7390845
*Schulz RK, Tompkins GA, Leventhal L, . 1976. Uptake of plutonium and americium by barley from two contaminated Nevada test site soils. J Environ Qual 5(4):406–410.
*Seaborg, GT. 1991. Actinides and transactinides. Fourth ed., Vol. 1. Encyclopedia of chemical technology, 412–445
*Seaborg GT, Loveland WD. 1990. The elements beyond uranium. New York: John Wiley & Sons, Inc.
Seidel A. 1973a. Distribution of ^241^Am in the rat as influenced by dose and the pH of the injected solution. Int J Appl Radiat Isot 24:362–363.4723521
Seidel A. 1973b. Retention of ^241^Am by some endocrine organs of the rat and its response to DPTA-treatment. Int J Radiat Biol 23(4):415–416.
Seidel A. 1977. The deposition of ^241^Am and ^252^Cf in the skeleton of Chinese hamster, Syrian hamster and the rat. Health Phys 33:83–86.893106
*Seidel A. 1984. Influence of the antimicrotubular agents, colchicine and vinblastin on the uptake of americium by rat liver, kidneys, and skeleton. Toxicol Appl Pharmacol 76:113–117.6148793
*Seidel A. 1985. Colchicine reduces uptake of ^239^Pu and ^241^Am by rat liver but not their elimination. Int J Nucl Med Biol 12(4):339–340.4086202
*Seidel A, Wiener M, Krüger E, . 1986. Studies on the lysosomal binding of ^141^Ce, ^239^Np, ^239^Pu and ^241^Am in rat and Syrian hamster liver using carrier-free electrophoresis. Int J Rad Appl Instrum B13(5):515–518.
Sekimoto H, Nakamura H, Takagi N. 1996. Toxicity of radioactive wastes discharged from nuclear energy center in the future equilibrium state. Ann Nucl Energy 23(8):663–668.
Sekine K, Imai T, Kasai A. 1987. Liquid-liquid extraction separation and sequential determination of plutonium and americium in environmental samples by alpha-spectrometry. Talanta 34(6):567–570.18964360
*Setchell BP, Waites GMH. 1975. The blood-testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society.
*SEPA. 2000. Radioactivity in food and the environment, 1999 (RIFE-5). Scottish Environment Protection Agency, 33
Shiraishi K, Yamamoto M. 1996. Internal dose from ingestion for Japanese adult males. Health Phys 71(5):700–704.8887514
*Sibley TH, Stohr JS. 1990. Accumulation of Am-241 and Cm-244 from water and sediments by Hyalella sp. and Tubifex sp. Bull Environ Contam Toxicol 44:165–172.2306534
*Sikov MR. 1987. Placental transfer of the actinides and related heavy elements. In: Age-related factors in radionuclide metabolism and dosimetry. Netherlands: Kluwer Academic Publishers, 303–314.
Sikov MR. 1992. Hazards and risks from prenatal irradiation: Emphasis on internal radionuclide exposures. Radiat Prot Dosim 41(2–4):265–272.
*Sikov MR, Kelman BJ. 1989. Factors affecting the placental transfer of actinides. Health Phys 57(Suppl. 1):109–114.2558093
*Sikov MR, Mahlum DD. 1968. Cross-placental transfer of selected actinides in the rat. Health Phys 14:205–208.5637394
Sikov MR, Rommereim DN. 1986. Evaluation of the embryotoxicity of uranium in rats. Teratology 33(3):41C.
Silk TJ, Phipps AW, Bailey MR. 1997. Effects on dose coefficients for workers of recent changes in internal dosimetry. Radiat Prot Dosim 71(1):7–21.
*Sill CW, Williams RL. 1969. Radiochemical determination of uranium and the transuranium elements in process solutions and environmental samples. Anal Chem 41:1624–1632.5811587
Sjoblom K-L, Salo A, Bewers JM, . 1999. International Arctic Seas assessment project. Sci Total Environ 237/238:153–166.10568273
*Smith LR, Sullivan PA, Laferriere J, . 1983. Intake and subsequent fate of a ceramic particle containing 2.85 µCi ^241^Am: A case study. Health Phys 44(4):329–334.6841089
Sokolik GA, Ivanova TG, Leinova SL, . 2001. Migration ability of radionuclides in soil-vegetation cover of Belarus after Chernobyl accident. Environ Int 26:183–187.11341704
*Sontag W. 1983. The early distribution of ^239^Pu, ^241^Am, and ^233^U in the soft tissues and skeletons of old rats. A comparative study. Hum Toxicol 2:91–100.6840797
Sontag W. 1984. Long-term behaviour of ^239^Pu, ^241^Am and ^233^U in different bones of one-year-old rats: Macrodistribution and macrodosimetry. Hum Toxicol 3:469–483.6526395
Sontag W. 1986. Multicompartment kinetic models for the metabolism of americium, plutonium and uranium in rats. Hum Toxicol 5:163–173.3710493
Stanley JA, Edison AF, Mewhinney JA, . 1978. Inhalation toxicology of industrial plutonium and uranium oxide aerosols: II. Deposition, retention and dosimetry. Health Phys 35(6):888.
*Stanley JA, Edison AF, Mewhinney JA. 1982. Distribution, retention and dosimetry of plutonium and americium in the rat, dog and monkey after inhalation of an industrial-mixed uranium and plutonium oxide aerosol. Health Phys 43(4):521–530.7152912
Stather JW, Adams N, Gray SA, . 1987. Comparative studies on the transfer of radionuclides to the fetus in the rat - implications for human dosimetry. In: Age-related factors in radionuclide metabolism and dosimetry. Netherlands: Kluwer Academic Publishers, 371–377.
Stather JW, Dionian J, Brown J, . 1988. The risk of leukemia in sea scale from radiation exposure. Health Phys 55(2):471–481.3410721
*Stather JW, Harrison JD, Kendall GM. 1992. Radiation doses to the embryo and fetus following intakes of radionuclides by the mother. Radiat Prot Dosim 41(2/4):111–118.
*Stather JW, Harrison JD, Rodwell P, . 1979a. The gastrointestinal absorption of plutonium and americium in the hamster. Phys Med Biol 24(2):396–407.450980
*Stather JW, James AC, Brightwell J, . 1979b. The clearance of Pu and Am from the respiratory system of rodents after the inhalation of oxide aerosols of these actinides either alone or in combination with other metals. In: Biological implications of radionuclides released from nuclear industries: Proceedings of an international symposium on biological implications of radionuclides released from nuclear industries. Proceedings series-International Atomic Energy Agency: Viena, 3–25.
*Stevens W, Atherton DR, Bruenger FW, . 1977. Deposition of ^239^Pu, ^233^U and ^241^Am in the gonads of beagles and rats. In: Research in radiobiology. Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 223–227. Contract No. EY-76-C-02-0119.
Stevens W, Bruenger FW, Atherton DR, . 1978. The retention and distribution of ^241^Am and ^65^Zn, given as DTPA chelates in rats and of [^14^C]DPTA in rats and beagles. Radiat Res 75:397–409.102009
Stevens W, Bruenger FW, Bates D, . 1976. Retention and distribution of ^241^Amlll in neonatal beagles. In: Research in radiobiology: Annual report of work in progress in the Internal Irradiation Program. Utah: Radiobiology Division of the Department of Anatomy University of Utah College of Medicine, 167–171. Contract No. E(11-1)-119.
Stevens W, Stover BJ, Bruenger FW, . 1969. Some observations on the deposition of americium-241 in the thyroid gland of the beagle. Radiat Res 39:201–206.5789044
*Stover BJ, Bruenger FW, Stevens W. 1970. Association of americium with ferritin in the canine liver. Radiat Res 43:173–186.5450341
Stradling GN, Moody JC. 1995. Use of animal studies for assessing intakes of inhaled actinide-bearing dusts. J Radioanal Nucl Chem 197(2):309–329.
*Stradling GN, Stather JW. 1989. The use of animal experiments for assessing annual limits on intake and interpreting chest-monitoring data for workers exposed to industrial actinide-bearing dusts. Health Phys 37(Suppl. 1):221–228.
Stradling GN, Gray SA, Ellender M, . 1992. The efficacies of 3,4,3-LIHOPO and DTPA for enhancing the excretion of plutonium and americium from the rat: Comparison with other siderophore analogues. Int J Radiat Biol 62(4):487–497.1357063
Stradling GN, Ham GJ, Smith H, . 1978. The mobility of americium dioxide in the rat. Radiat Res 76:549–560.734055
*Stradling GN, Hengé-Napoli M-H, Paquet F, . 2000. Optimum treatment regimens with animals. Radiat Prot Dosim 87(1):29–40.
Stradling GN, Hodgson SA, Hodgson A, . 1998. Dose coefficients and assessment of intake after inhalation of contaminated dusts from Palomares. Radiat Prot Dosim 79(1/4):179–182.
Stradling GN, Pellow PG, Hodgson A, . 1997. Assessment of intake of a complex radionuclide bearing dust formed at a nuclear power plant. J Radioanal Nucl Chem 226(1–2):7–14.
*Stradling GN, Popplewell DS, Ham GJ. 1976. The chemical form of americium and curium in urine. Health Phys 31:517–519.1021558
Stradling GN, Stather JW, Gray SA, . 1987. Studies on the metabolic behavior of industrial actinide-bearing aerosols after deposition in the rat lung: An experimental basis for interpreting chest monitoring data and assessing limits on intake for workers. Hum Toxicol 6:365–375.3679244
*Stradling GN, Stather JW, Gray SA, . 1989. Assessment of intake of an actinide-bearing dust formed from the pond storage of spent magnox fuel. Radiat Prot Dosim 26(1/4):201–206.
*Stradling GN, Stather JW, Gray SA, . 1992. Radiological implications of inhaled ^239^Pu and ^241^Am in dusts at the former nuclear test site in Maralinga. Health Phys 63(6):641–650.1428884
*Stradling GN, Stather JW, Gray SA, . 1994. Biokinetics of inhaled plutonium-239 and americium-241 present in contaminated dusts at Maralinga. Ann Occup Hyg 38(Suppl. 1):257–263.8048787
*Suchanek TH, Lagunas-Solar MC, Raabe OG, . 1996. Radionuclides in fishes and mussels from the Farallon Islands nuclear waste dump site, California. Health Phys 71(2):167–178.8690599
*Sullivan MF. 1980a. Absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys 38:173–185.6246039
*Sullivan MF. 1980b. Absorption of actinide elements from the gastrointestinal tract of rats, guinea pigs and dogs. Health Phys 38:159–171.6246038
*Sullivan MF, Gorham LS. 1982. Further studies on the absorption of actinide elements from the gastrointestinal tract of neonatal animals. Health Phys 43(4):509–519.6295981
Sullivan MF, Gorham LS. 1983. Can information on the gastrointestinal absorption of actinide elements by neonatal rats, guinea pigs, dogs and swine be extrapolated to man? Health Phys 44(Suppl. 1):411–417.
*Sullivan MF, Ruemmler PS. 1988. Absorption of ^233^U, ^237^Np, ^238^Pu, ^241^Am and ^244^Cm from the gastrointestinal tracts of rats fed an iron-deficient diet. Health Phys 54(3):311–316.3346162
*Sullivan MF, Miller BM, Ruemmler PS, . 1985. Further studies on the influence of chemical form and dose on absorptions of Np, Pu, Am and Cm from the gastrointestinal tracts of adult and neonatal rodents. Health Phys 48(1):61–73.2981787
*Sullivan MF, Ruemmler PS, Ryan JL, . 1986. Influence of oxidizing of reducing agents on gastrointestinal absorption of U, Pu, Am, Cm, and Pm by rats. Health Phys 50(2):223–232.3005196
*Sütterlin U, Thies W-G, Haffner H, . 1984. Comparative studies on the lysosomal association of monomeric ^239^Pu and ^241^Am in rat and Chinese hamster liver: Analysis with sucrose, metrizamide, and percoll density gradients of subcellular binding as dependent on time. Radiat Res 98:293–306.6729039
*Sutton WW, Patzer RG, Potter GD. 1979. Biotransport of transuranium radionuclides. Environmental Monitoring Systems Laboratory, U.S. Environmental Protection Agency, Las Vegas, NV. NTIS No. EMSLLVO53935.
Svoboda V, Kotasková Z. 1983. Radiosensitivity and proliferative activity of vertebral CFU-S surviving in mice injected with oncogenic activities of ^239^Pu or ^241^Am. J Hyg Epidemiol Microbiol Immunol 27(3):329–335.
*Swift DJ, Nicholson MD. 2001. Variability in the edible fraction content of ^60^Co, ^99^Tc, ^110^mAG, ^137^Cs and ^241^Am between individual crabs and lobsters from Sellafield (north eastern Irish Sea). J Environ Radioact 54:311–326.11381940
*Takada K, Fikada H, Hattori T, Akaishi J. 1984. Equation for the urinary excretion of americium following a single uptake. Proceedings of the 6th International Congress of the International. Fachverband für Strahlenschutz E.V., Julich. Radiation Protection Association, Berlin, 1:477–480..
*Talbot RJ, Nicholls L, Morgan A, . 1989. Effect of inhaled α-emitting nuclides on mouse alveolar macrophages. Radiat Res 119:271–285.2756118
Taya A, Mewhinney JA. 1987. Toxicity and dissolution of ^241^AmO_2_ particles in cultured canine alveolar macrophages. Health Phys 52(Suppl. 1):S27.
*Taya A, Mewhinney JA. 1992. Cytotoxicity, uptake and dissolution of ^241^AmO_2_ particles in dog alveolar macrophages in vitro. Int J Radiat Biol 62(1):81–88.1353779
*Taya A, Carmack DB, Muggenburg BA, . 1992. An interspecies comparison of the phagocytosis and dissolution of ^241^AmO_2_ particles by rat, dog and monkey alveolar macrophages in vitro. Int J Radiat Biol 62(1):89–95.1353780
*Taya A, Hotz G, Seidel A. 1986. Biochemical and electron microscopic studies on binding and transport of americium and plutonium hydroxide polymers in bovine alveolar macrophages and rat lungs. J Aerosol Sci 17(3):370–375.
Taylor DM. 1972. Interactions between transuranium elements and the components of cells and tissues. Health Phys 22:575–581.5083989
*Taylor DM. 1973. Chemical and physical properties of the transplutonium elements. In: Hodge HC, Stannard JN, Hursh JB, eds. Uranium, plutonium, transplutonic elements. New York: Springer-Verlag, 717–738.
Taylor DM. 1986. Gut transfer of environmental plutonium and americium. Lancet 1(8481):611.
Taylor DM. 1989. The biodistribution and toxicity of plutonium, americium and neptunium. Sci Total Environ 83:217–225.2781271
Taylor DM, Danpure CJ. 1969. Lysosomal uptake of actinide elements. Biochem J 115(5):53.
Taylor DM, Path MRC, Planas-Bohne F, . 1985. The retention of metallic radionuclides in experimental abscesses in rats. Br J Radiol 58:655–659.4016497
*Taylor DM, Sowby FD, Kember NF, . 1961. The metabolism of americium and plutonium in the rat. Phys Med Biol 6:73–86.13775574
Taylor GN, Jee WSS, Dockum N, . 1969. Microscopic distribution of americium-241 in the beagle thyroid gland. Health Phys 17:723–725.5350119
Taylor GN, Jones CW, Gardner PA, . 1981. Two new rodent models for actinide toxicity studies. Radiat Res 86:115–122.7220799
*Taylor GN, Lloyd RD, Bruenger FW, . 1993a. ^241^Am-induced thyroid lesions in the beagle. Health Phys 64(6):653–660.8491622
*Taylor GN, Lloyd RD, Mays CW, . 1991. Plutonium- or americium-induced liver tumors and lesions in beagles. Health Phys 61(3):337–347.1880023
*Taylor GN, Lloyd RD, Mays CW, . 1992. Promotion of radiation-induced liver neoplasia by ethanol. Health Phys 62(2):178–182.1730560
Taylor GN, Lloyd RD, Mays CW, . 1993b. Liver cancer induction by ^239^Pu, ^241^Am, and Thorotrast in the grasshopper mouse, Onychomys leukogaster. Health Phys 64(2):141–146.8449707
*Taylor GN, Mays CW, Lloyd RD, . 1983. Comparative toxicity of ^226^Ra ^239^Pu ^241^Am ^249^Cf and ^252^Cf in C57BL/Do black and albino mice. Radiat Res 95:584–601.6611863
Terzaghi-Howe M, Ford JR, Turner JE, . 1996. Influence of cell position relative to planar alpha-particle sources on survival and preneoplastic transformation of primary rat tracheal epithelial cells. Radiat Res 145:432–441.8600503
*Thiels GM, Murray CN, Vanderborght OLJ, . 1984. The effect of water acidity and seasonal variability on the distribution of ^241^Am in the freshwater snail Lymnaea stagnalis L. Health Phys 47(3):485–487.6500954
Thind KS. 2001. Monitoring methods and dose assessment for internal exposures involving mixed fission and activation products containing actinides. Health Phys 80(1):47–53.11204117
Thomas RG. 1970. Estimation of ^241^Am body burdens by analysis of whole-body scanning, excreta, and body weight data. Health Phys 19:751–755.4998370
*Thomas RG, McClellan RO, Thomas RL, . 1972. Metabolism, dosimetry and biological effects of inhaled ^241^Am in beagle dogs. Health Phys 22:863–871.5084021
*Thompson RC. 1983. 1976 Hanford americium exposure incident: Overview and perspective. Health Phys 45(4):837–845.
*Thouvenot P, Hubert S, Moulin C, . 1993. Americium trace determination in aqueous and solid matrices by time-resolved laser-induced fluorescence. Radiochim Acta 61:15–21.
Tompkins JA, Pearson MW. 2001. Transuranic sealed source recovery project. Health Phys 81:S59–S61.11669192
*Toohey RE, Essling MA. 1980. Measurements of ^241^Am in vivo at long times after inhalation. Health Phys 38:139–145.6768697
*Toohey RE, Kathren RL. 1995. Overview and dosimetry of the Hanford americium accident case. Health Phys 69(3):310–317.7635726
*Toran L. 1994. Radionuclide contamination in groundwater: Is there a problem? In: Environmental science pollution control series. New York, NY: M. Dekker, 437–455.
Truscott JB, Jones P, Fairman BE. 2001a. Determination of actinide elements at femtogram per gram levels in environmental samples by on-line solid phase extraction and sector-field-inductively coupled plasma-mass spectrometry. Anal Chim Acta 433:245–253
Truscott JB, Jones P, Fairman BE, . 2001b. Determination of actinides in environmental and biological samples using high-performance chelation ion chromatography coupled to sector-field inductively coupled plasma mass spectrometry. J Chromatogr A 928:91–98.11589474
*Turner GA, Taylor DM. 1968. The transport of plutonium, americium and curium in the blood of rats. Phys Med Biol 13(4):535–546.5683324
*UIC. 1997. Most smoke detectors contain an artificially produced radioisotope: americium-241. Americium-241 is made in nuclear reactors, and is a decay product of plutonium-241. Uranium Information Center. Nuclear Issues Briefing Paper 35. http://www.uic.com.au/nip35.htm. January 27, 2000.
*UNSCEAR. 2000. Sources and effects of ionizing radiation. UNSCEAR 200 report. Volume 1. United Nations Scientific Committee on the Effects of Atomic Radiation. http://www.unscear.org/reports/2000_1.html. February 17, 2004.
*U.S. Energy Research and Development Administration. 1977. Plutonium and americium concentration along fresh-water food chains of the Great Lakes, U.S.A. Woods Hole, MA: U.S. Energy Research and Development Administration. COO-3568-18.
*USNRC. 1979. Environmental assessment of ionization chamber smoke detectors containing Am-241. Washington, DC: U.S. Nuclear Regulatory Commission. NRC-02-78-045. NUREG/CR-1156. http://www.nrc.gov/. December 13, 2000.
*USNRC. 1984. Lower limit of detection definition and elaboration of a purposed position for radiological effluent and environmental measurements. U.S. Nuclear Regulatory Commission U.S. Report NUREG/CR-4007.
*USNRC. 1992. Residual radioactive contamination form decommissioning: Technical basis for translating contamination levels to annual total effective dose equivalent. Washington, DC: Office of Nuclear Regulatory Research, U.S. Nuclear Regulatory Commission. NUREG/CR-5512.
*USNRC. 1996. Contribution of maternal radionuclide burdens to prenatal radiation doses. Washington, DC: Office of Nuclear Regulatory Research, U.S. National Regulatory Commission. NUREG/CR-5631.
USNRC. 1998a. U.S. Nuclear Regulatory Commission. 10CFR20 Subpart O.
*USNRC. 1998b. Minimum detectable concentrations with typical radiation survey instruments for various contaminants and field conditions. Washington, DC: Office of Nuclear Regulatory Research, U.S. Nuclear Regulatory Commission. NUREG/CR-1507.
*USNRC. 2001a. Radiation standards for occupational values, effluent concentrations, and releases to sewers. U.S. Nuclear Regulatory Commission. 10CFR20. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001b. Activity values for radionuclides. U.S. Nuclear Regulatory Commission. 10CFR71. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001c. Byproduct material for in vitro clinical or laboratory testing. U.S.Nuclear Regulatory Commission. 10CFR 31.11. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001d. Calibration or reference sources-shall not possess at any one time, at any one location of storage or use of ^241^Am. U.S. Nuclear Regulatory Commission. 10CFR 31.8. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001e. Exemption for low-level materials- contains only Americium in special form. U.S. Nuclear Regulatory Commission. 10CFR71.10. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001f. Export of byproduct material. U.S. Nuclear Regulatory Commission. 10CFR110.23. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001g. General applicability to domestic licensing of byproduct material-quantity of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. 10CFR30. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001h. Quantity of radioactive material requiring need for an emergency plan for responding to a release. U.S. Nuclear Regulatory Commission. 10CFR30.72. http://www.nrc.gov. March 13, 2001.
*USNRC. 2001i. Standards for protection against radiation-quantity of licensed material requiring labeling. U.S. Nuclear Regulatory Commission. 10CFR20. http://www.nrc.gov. March 13, 2001.
*USNRC. 2002. NRC News. NRC announces meeting on memorandum of understanding with EPA on cleanup of radioactiviely contaminated sites. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/reading-rm/doc-collections/news/2002/02-124.pdf. March 27, 2002.
*USNRC. 2004a. Licensing requirements for land disposal of radioactive waste. Nuclear Regulatory Commission. U.S. Nuclear Regulatory Commission. 10CFR61. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=284debaea3834014f52af4f28a1a6fa9&rgn=div5&view=text&node=10:2.0.1.1.7&idno=10. April 23, 2004.
*USNRC. 2004b. Disposal of high-level radioactive wastes in a geological repository at Yucca Mountain, Nevada. U.S. Nuclear Regulatory Commission. 10CFR63. http://ecfr.gpoaccess.gov/cgi/t/text/text-idx?c=ecfr&sid=284debaea3834014f52af4f28a1a6fa9&rgn=div5&view=text&node=10:2.0.1.1.9&idno=10. April 23, 2004.
USNRC. 2004c. Agreement state program. U.S. Nuclear Regulatory Commission. http://www.nrc.gov/what-we-do/state-tribal/agreement-states.html. April 27, 2004.
*USTUR. 1997. Acute accidental inhalation exposure to ^241^Am: Preliminary evaluation. In: Kathren, RL, Erhart SM, eds. Annual report. October 1, 1995-September 30, 1996. Richland, WA: United States Transuranium and Uranium Registries. USTUR007297.
*USTUR. 1999. United States Transuranium and Uranium Registries. http://www.tricity.wsu.edu/ustur/database.html. October 12, 2000.
Van Den Heuvel RL. 1990. Bone marrow from Balb/c mice radio contaminated with ^241^Am in utero shows a deficient in vitro haemopoiesis. Int J Radiat Biol 57(1):103–115.1967282
*Van Den Heuvel R, Gerber GB, Leppens H, . 1995. Long-term effects on tumor incidence and survival from ^241^Am exposure of the BALB/c mouse in utero and during adulthood. Int J Radiat Biol 68(6):679–686.8551111
Van Den Heuvel RL, Schoeters GER, Vanderborght OLJ. 1984. Effect of 241-Am on bone fibroblasts. Radiat Environ Biophys 23:137–140.6739716
Van Den Heuvel R, Schoeters G, Vanderborght O. 1987. Radiosensitivity to ^241^Am of bone marrow stromal cells in offspring of contaminated mice. In: Age-related factors in radionuclide metabolism and dosimetry. Netherlands: Kluwer Academic Publishers, 201–208.
*Van Den Heuvel R, Vander Plaetse F, Schoeters G. 1992. 241-Am distribution and retention in pregnant mice, in their offspring and in non-pregnant mice: Comparison between continuous Am administration and single injection. Radiat Prot Dosim 41(2/4):137–142.
Vasilik DG, Aikin IC, Coop KL, . 1984. In vivo assessment of lung burdens at the Los Alamos National Laboratory. GRAI 18:26p.
*Vicceellio P, ed. 1998. Emergency toxicology. 2^nd^ edition. Philadelphia: Lippincott-Raven, 991–996.
*Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
*Virginia Department of Health. 2000. Environmental Radiation Ambient Monitoring System (ERAMS). http://www.vdh.state.va.us. December 13, 2000.
von Zallinger C, Tempel K. 1998. Transplacental transfer of radionuclides. A review. J Vet Med Sci A45:581–590.
*Vyas BN, Mistry KB. 1980. Studies on the mobility of plutonium-239 and americium-241 in three major Indian soils. J Nucl Agric Biol 9:85–88.
Walker MI, McKay WA. 1991. Radionuclide distributions in seawater around the Sellafield pipeline. Estuarine Coastal Shelf Sci 32(4):385–394.
*Walker MI, McKay WA, Pattenden NJ, . 1986. Actinide enrichment in marine aerosols. Nature 323:141–143.
Walker RB, Gessel SP, Held EE. 1997. The ecosystem study on Rongelap Atoll. Health Phys 73(1):223–233.9199232
*Ware AR, Odell KJ, Martin JP. 1998. Analysis of radioactive metal ions in environmental and liquid effluent samples. J Radioanal Nucl Chem 228(1–2):5–13.
Warren S. 1975. Skeletal and tissue lesions resulting from exposure to radium and fission products. Ann Clin Lab Sci 5(2):75–81.1124916
Warwick PE, Croudace IW, Oh J-S. 2001. Radiochemical determination of ^241^Am and PU(α) in environmental materials. Anal Chem 73:3410–3416.11476242
Watson WS, Sumner DJ. 1996. The measurement of radioactivity in people living near the Dounreay Nuclear Establishment, Caithness, Scotland. Int J Radiat Biol 70(2):117–130.8794841
*Webb LM, Taylor DM, Williams DR. 1998. Computer modeling of the chemical speciation of lanthanide and actinide elements in the human gastrointestinal tract: Mouth and stomach. Radiat Prot Dosim 79(1/4):219–222.
Weiner RE, McInroy JF, Wegst AV. 1985. Determination of environmental levels of Pu, Am, U and Th in human fetal tissue. Health Phys 49(1):141.
Weiss JF, Walburg HE, McDowell WJ. 1978. Cross placental transfer of americium and plutonium in mice. Health Phys 35:895–896.
*Weiss JF, Walburg HE, McDowell WJ. 1980. Placental transfer of americium and plutonium in mice. Health Phys 39:903–911.7204048
*West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
*Whicker FW, Hinton TG, Orlandini KA, . 1999. Uptake of natural and anthropogenic actinides in vegetable crops grown on a contaminated lake bed. J Environ Radioact 45:1–12.
*Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Volume II: The Elements Part A. New York: Academic Press.
Withers EH, Page DL, Hollifield J, . 1975. Carcinoma of the thyroid with description of a new scanning technic. Am J Surg 130(4):395–398.1166929
Wuu J-L, Yuan M-C, Su S-H, . 2002. The alpha and beta emitter measurement system in INER. Appl Radiat Isot 56:261–264.11839025
*Xu GB, Yu CP. 1986. Effects of age on deposition of inhaled particles in the human lung. Aerosol Sci Technol 5:349–357.
Yamamoto M, Komura K, Sakanoue M, . 1985. Pu isotopes, ^241^Am and ^137^Cs in soils from the atomic bombed areas in Nagasaki and Hiroshima. J Radiat Res 26:211–223.4057155
*Zach R. 1985. Contribution of inhalation by food animals to man’s ingestion dose. Health Phys 49(5):737–745.4066337
*Ziegler EE, Edwards BB, Jensen RL, . 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372