# 8 REGULATIONS AND ADVISORIES

The international, national, and state regulations and guidelines regarding americium in air, water, and other media are summarized in Table 8-1.

The USNRC maintains a database of information regarding licensees authorized to possess americium isotopes (^241^Am through ^244^Am) within the 18 non-Agreement States (states not committed to self-regulation). This database includes more than 2,000 records of licensees and site possession limits in the microcurie to curie range. The isotope, ^241^Am, accounts for most of the licenses. Such records for USNRC Agreement States are maintained by the individual state radioactive material regulatory organizations. The USNRC and EPA each have responsibilities for regulating the cleanup of radioactivity and decommissioning of USNRC licensed sites. USNRC and EPA reached an agreement in 2002, in response to Congressional mandate, to preclude double regulation of these efforts. The agreement provides that EPA will defer exercise of authority under CERCLA for the majority of facilities decommissioned under USNRC authority. It also contains provisions for joint consultation when certain EPA parameters are exceeded, including groundwater exceeding EPA-permitted levels, USNRC contemplation of restricted release or alternate release criteria, and residual soil radioactivity concentrations exceeding those in the agreement (USNRC 2002).

No inhalation or oral MRLs were derived for americium or americium compounds.

The EPA IRIS database has withdrawn its cancer classification for radionuclides, but the EPA Office of Air and Radiation believes that all radionuclides, including the americium isotopes, should be considered to be known carcinogens, and has assigned them to Group A. Carcinogenic toxicity values for ^241^Am are listed in EPA’s Federal Radiation Guidance Report No. 13 (EPA 2000a). Lifetime excess total cancer risk per unit intake are included for inhalation (Table 2.1), drinking water ingestion (Table 2.2), and submersion, ground plane exposure, and soil intake (Table 2.3) of EPA (2000a). Media-specific usage rates (Table 3.1) provide a means of adjusting the values to be compatible with specific population groups (e.g., tap water intakes range from a low of 0.188 L/day for a newborn female to a high of 1.643 L/day for a 50-year-old male, with a societal average of 1.11 L/day). The EPA has not derived reference concentrations (RfCs) or reference doses (RfDs) for americium (IRIS 2002), but has derived a maximum contaminant level (MCL) of 15 pCi/L for total alpha-emitters (including americium), less uranium and radon (EPA 2000c).

Table 8-1 Regulations and Guidelines Applicable to Americium

Agency | Description | Information | | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | | No data
[underlined: NATIONAL]
Guidelines:
a. Air
ACGIH | Effective dose | | | ACGIH 2002
ACGIH | Any single year | 50 mSv | | ACGIH 2002
ACGIH | Averaged over 5 years | 20 mSv | | ACGIH 2002
ACGIH | Annual equivalent dose to | | | ACGIH 2002
ACGIH | Lens of the eye | 150 mSv | | ACGIH 2002
ACGIH | Skin | 500 mSv | | ACGIH 2002
ACGIH | Hands and feet | 500 mSv | | ACGIH 2002
ACGIH | Embryo-fetus exposures once the pregnancy is known | | | ACGIH 2002
ACGIH | Monthly equivalent dose | 0.5 mSv | | ACGIH 2002
ACGIH | Dose to the surface of women’s abdomen (lower trunk) | 2 mSv for the remainder of the pregnancy | | ACGIH 2002
ACGIH | Intake of radionuclide | 1/20 ALI | | ACGIH 2002
NIOSH | REL (10-hour TWA) | No data
[underlined: NATIONAL]
Regulations:
EPA | Concentration levels for environmental compliance | | | EPA 2001a 40CFR61, Appendix E
EPA | ^241^Am | 1.9×10^−15^ Ci/m^3^ | | EPA 2001a 40CFR61, Appendix E
EPA | ^242^Am | 1.5×10^−11^ Ci/m^3^ | | EPA 2001a 40CFR61, Appendix E
EPA | ^243^Am | 1.8×10^−15^ Ci/m^3^ | | EPA 2001a 40CFR61, Appendix E
OSHA | PEL (8-hour TWA) | No data
USNRC | Occupational values—inhalation | [underlined: ALI(μCi)] | [underlined: DAC(μCi/mL)] | USNRC 2001a 10CFR20, Appendix B
USNRC | ^241^Am | 6×10^−3^ | 3×10^−12^ | USNRC 2001a 10CFR20, Appendix B
USNRC | ^242^Am | 8×10^1^ | 4×10^−8^ | USNRC 2001a 10CFR20, Appendix B
USNRC | ^243^Am | 6×10^−3^ | 3×10^−12^ | USNRC 2001a 10CFR20, Appendix B
USNRC | Effluent concentrations—air | | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^241^Am | 2×10^−14^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^242^Am | 1×10^−10^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^243^Am | 2×10^−14^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
b. Water
USNRC | Effluent concentrations—water | | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^241^Am | 2×10^−8^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^242^Am | 5×10^−5^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^243^Am | 2×10^−8^ μCi/mL | | USNRC 2001a 10CFR20, Appendix B
EPA | Drinking water | | | EPA 2000c
EPA | Gross alpha activity, less U, Rn | 15 pCi/L | | EPA 2000c
c. Food
FDA | Derived intervention level^a^ (DIL; Bq/kg food) for Am in accidentally-contaminated human food | 2.0 | | FDA 1998
FDA | Sources of radiation used for inspection of food; sealed units producing radiation—^241^Am | 10 Gy maximum allowed dose to food | | FDA 2000 21CFR179.21
DOT | Activity values for radionuclides in transport | | | DOT 2001 40CFR173.435
DOT | ^241^Am, ^242^Am, and ^243^Am | | | DOT 2001 40CFR173.435
DOT | A_1_ | 5.41×10^1^ Ci | | DOT 2001 40CFR173.435
DOT | A_2_ | 5.41×10^−3^ Ci | | DOT 2001 40CFR173.435
EPA | Annual possession quantities for environmental compliance | | | EPA 2001a 40CFR61, Appendix E
EPA | ^241^Am | | | EPA 2001a 40CFR61, Appendix E
EPA | Gaseous form | 2.3×10^−6^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Liquid/powder forms | 2.3×10^−3^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Solid form | 2.3×10^0^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | ^242^Am | | | EPA 2001a 40CFR61, Appendix E
EPA | Gaseous form | 1.8×10^−2^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Liquid/powder forms | 1.8×10^1^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Solid form | 1.8×10^4^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | ^243^Am | | | EPA 2001a 40CFR61, Appendix E
EPA | Gaseous form | 2.3×10^−6^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Liquid/powder forms | 2.3×10^−3^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Solid form | 2.3×10^0^ Ci/year | | EPA 2001a 40CFR61, Appendix E
EPA | Radioactive waste—release limits for containment requirements^b^ | | | EPA 2001b 40CFR191, Appendix A
EPA | ^241^Am or ^243^Am | 1×10^2^ Ci | | EPA 2001b 40CFR191, Appendix A
EPA | Reportable quantity | | | EPA 2001c 40CFR302.4, Appendix B
EPA | ^241^Am | 1×10^−2^ Ci | | EPA 2001c 40CFR302.4, Appendix B
EPA | ^242^Am | 1×10^2^ Ci | | EPA 2001c 40CFR302.4, Appendix B
EPA | ^243^Am | 1×10^−2^ Ci | | EPA 2001c 40CFR302.4, Appendix B
EPA | Carcinogenicity—slope factors^c^ | | | EPA 2002
EPA | Ingestion—lifetime excess total cancer risk/pCi
EPA | Water
EPA | ^241^Am | 1.04×10^−10^
EPA | ^243^Am | 1.03×10^−10^
EPA | Food
EPA | ^241^Am | 1.34×10^−10^
EPA | ^243^Am | 1.34×10^−10^
EPA | Soil
EPA | ^241^Am | 2.17×10^−10^
EPA | ^243^Am | 2.17×10^−10^
EPA | Carcinogenicity—slope factors^c^ | | | EPA 2002
EPA | Inhalation—lifetime excess total cancer risk/pCi
EPA | ^241^Am | 2.81×10^−8^
EPA | ^243^Am | 2.70×10^−8^
EPA | External exposure—risk/year per pCi/g in soil
EPA | ^241^Am | 2.76×10^−8^
EPA | ^243^Am | 9.47×10^−8^
USNRC | Activity values for radionuclides in transport | | | USNRC 2001b 10CFR71, Table A-1
USNRC | ^241^Am, ^242^Am, and ^243^Am | | | USNRC 2001b 10CFR71, Table A-1
USNRC | A_1_ | 5.41×10^1^ Ci | | USNRC 2001b 10CFR71, Table A-1
USNRC | A_2_ | 5.41×10^−3^ Ci | | USNRC 2001b 10CFR71, Table A-1
USNRC | Specific activity | | | USNRC 2001b 10CFR71, Table A-1
USNRC | ^241^Am | 3.4 Ci/g | | USNRC 2001b 10CFR71, Table A-1
USNRC | ^242^Am | 1.0×10^1^ Ci/g | | USNRC 2001b 10CFR71, Table A-1
USNRC | ^243^Am | 2.0×10^−1^ Ci/g | | USNRC 2001b 10CFR71, Table A-1
USNRC | Byproduct material for in vitro clinical or laboratory testing—^241^Am | ≤0.005 μCi | | USNRC 2001c 10CFR31.11
USNRC | Calibration or reference sources; shall not possess at any one time, at any one location of storage or use of ^241^Am | ≤5 μCi | | USNRC 2001d 10CFR31.8
USNRC | Exemption for low-level materials; contains only Americium in special form | Aggregate radioactivity ≤20Ci | | USNRC 2001e 10CFR71.10
USNRC | Export of byproduct material | ≤1 Ci/shipment or ≤100 Ci/year | | USNRC 2001f 10CFR110.23
USNRC | General applicability to domestic licensing of byproduct material; quantity of licensed material requiring labeling | | | USNRC 2001g 10CFR30, Appendix B
USNRC | ^241^Am | 1×10^−2^ μCi
USNRC | Ionizing radiation measuring instruments containing, for purposes of internal calibration or standardization, one or more sources of byproduct material; exempt quantities of ^241^Am | 0.05 μCi | | USNRC 2001g 10CFR30.15(a)(9)
USNRC | Occupational values—oral ingestion (ALI) | | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^241^Am | 8×10^−1^ μCi | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^242^Am | 4×10^3^ μCi | | USNRC 2001a 10CFR20, Appendix B
USNRC | ^243^Am | 8×10^−1^ μCi | | USNRC 2001a 10CFR20, Appendix B
USNRC | Quantity of radioactive material requiring need for an emergency plan for responding to a release—^241^Am, ^242^Am, and ^243^Am | | | USNRC 2001h 10CFR30.72, Schedule C
USNRC | Release fraction | 0.001%
USNRC | Quantity | 2 Ci
USNRC | Standards for protection against radiation—quantity of licensed material requiring labeling | | | USNRC 2001i 10CFR20, Appendix C
USNRC | ^241^Am | 1×10^−3^ μCi
USNRC | ^242^Am | 1×10^1^ μCi
USNRC | ^243^Am | 1×10^−3^ μCi
[underlined: STATE] ^d^
a. Air
Illinois | Concentrations in air above natural background | | | BNA 2001
Illinois | ^241^Am | S | 2×10^−13^ μCi/mL
Illinois | ^241^Am | I | 4×10^−12^ μCi/mL
Illinois | ^242m^Am | S | 2×10^−13^ μCi/mL
Illinois | ^242m^Am | I | 9×10^−12^ μCi/mL
Illinois | ^242^Am | S | 1×10^−9^ μCi/mL
Illinois | ^242^Am | I | 2×10^−9^ μCi/mL
Illinois | ^243^Am | S | 2×10^−13^ μCi/mL
Illinois | ^243^Am | I | 4×10^−12^ μCi/mL
Illinois | ^244^Am | S | 1×10^−7^ μCi/mL
Illinois | ^244^Am | I | 8×10^−7^ μCi/mL
New Jersey | Maximum permissible average concentrations in air | | | BNA 2001
New Jersey | Occupational (40-hour week)
New Jersey | ^241^Am | S | 6×10^−12^ μCi/mL
New Jersey | ^241^Am | I | 1×10^−10^ μCi/mL
New Jersey | ^242m^Am | S | 6×10^−12^ μCi/mL
New Jersey | ^242m^Am | I | 3×10^−10^ μCi/mL
New Jersey | ^242^Am | S | 4×10^−8^ μCi/mL
New Jersey | ^242^Am | I | 5×10^−8^ μCi/mL
New Jersey | ^243^Am | S | 6×10^−12^ μCi/mL
New Jersey | ^243^Am | I | 1×10^−10^ μCi/mL
New Jersey | ^244^Am | S | 4×10^−6^ μCi/mL
New Jersey | ^244^Am | I | 2×10^−5^ μCi/mL
New Jersey | Maximum permissible average concentrations in air | | | BNA 2001
New Jersey | Non-occupational
New Jersey | ^241^Am | S | 2×10^−13^ μCi/mL
New Jersey | ^241^Am | I | 4×10^−12^ μCi/mL
New Jersey | ^242m^Am | S | 2×10^−13^ μCi/mL
New Jersey | ^242m^Am | I | 9×10^−12^ μCi/mL
New Jersey | ^242^Am | S | 1×10^−9^ μCi/mL
New Jersey | ^242^Am | I | 2×10^−9^ μCi/mL
New Jersey | ^243^Am | S | 2×10^−13^ μCi/mL
New Jersey | ^243^Am | I | 4×10^−12^ μCi/mL
New Jersey | ^244^Am | S | 1×10^−7^ μCi/mL
New Jersey | ^244^Am | I | 8×10^−7^ μCi/mL
b. Water
Colorado | Standards applicable to surface waters—^241^Am | 15 pCi/L | | BNA 2001
Colorado | Groundwater levels of radioactive materials shall not exceed this amount—Am | 15 pCi/L | | CO Dept of Public Health and Environ 1999
New Jersey | Maximum permissible average concentrations in water | | | BNA 2001
New Jersey | Occupational (40-hour week)
New Jersey | ^241^Am | S | 1×10^−4^ μCi/mL
New Jersey | ^241^Am | I | 8×10^−4^ μCi/mL
New Jersey | ^242m^Am | S | 1×10^−4^ μCi/mL
New Jersey | ^242m^Am | I | 3×10^−3^ μCi/mL
New Jersey | ^242^Am | S | 4×10^−3^ μCi/mL
New Jersey | ^242^Am | I | 4×10^−3^ μCi/mL
New Jersey | ^243^Am | S | 1×10^−4^ μCi/mL
New Jersey | ^243^Am | I | 8×10^−4^ μCi/mL
New Jersey | ^244^Am | S | 1×10^−1^ μCi/mL
New Jersey | ^244^Am | I | 1×10^−1^ μCi/mL
New Jersey | Maximum permissible average concentrations in water | | | BNA 2001
New Jersey | Non-occupational
New Jersey | ^241^Am | S | 4×10^−6^ μCi/mL
New Jersey | ^241^Am | I | 2×10^−5^ μCi/mL
New Jersey | ^242m^Am | S | 4×10^−6^ μCi/mL
New Jersey | ^242m^Am | I | 9×10^−5^ μCi/mL
New Jersey | ^242^Am | S | 1×10^−4^ μCi/mL
New Jersey | ^242^Am | I | 1×10^−4^ μCi/mL
New Jersey | ^243^Am | S | 4×10^−6^ μCi/mL
New Jersey | ^243^Am | I | 3×10^−5^ μCi/mL
New Jersey | ^244^Am | S | 5×10^−3^ μCi/mL
New Jersey | ^244^Am | I | 5×10^−3^ μCi/mL
c. Food | | No data
d. Other
Arkansas | Determination of A_1_ and A_2_ quantities for transportation | | | BNA 2001
Arkansas | ^241^Am
Arkansas | A1 | 8 Ci
Arkansas | A2 | 0.008 Ci
Arkansas | Specific activity | 3.2 Ci/g
Arkansas | ^243^Am
Arkansas | A1 | 8 Ci
Arkansas | A2 | 0.008 Ci
Arkansas | Specific activity | 1.9×10^−1^ Ci/g
Arkansas | Standards for protection against radiation—^241^Am | 0.01 μCi | | BNA 2001
California | Ionizing radiation measuring instruments containing, for purposes of internal calibration or standardization, one or more source of radioactive material; ^241^Am is considered an exempt quantity | <0.05 μCi | | BNA 2001
Colorado | Determination of A_1_ and A_2_ for transportation | | | BNA 2001
Colorado | ^241^Am, ^242m^Am, and ^243^Am | 54.1 Ci
Colorado | A1 | 5.41×10^−3^ Ci
Colorado | A2
Florida | Quantity of radioactive material requiring need for an emergency plan for responding to a release | | | BNA 2001
Florida | ^241^Am, ^242^Am, and ^243^Am
Florida | Release fraction | 0.001%
Florida | Quantity | 2 Ci
Georgia | Packages transported between locations within the U.S. which contain only Am or Pu in special form with an aggregate radioactivity | Not to exceed 20 Ci | | BNA 2001
Mississippi | Packages transported between locations within the U.S. which contain only Am or Pu in special form with an aggregate radioactivity | Not to exceed 20 Ci | | BNA 2001

a The FDA-recommended Derived Intervention Level (DIL) for radionuclides of ^241^Am, is defined as the DIL for the most sensitive age group (3 months) that was calculated from the most limiting Protective Action Goal (PAG; 50 mSv committed dose equivalent to the bone).

b Release limit per 1,000 metric tons of heavy metal (MTHM) or other unit of waste.

c Radionuclide slope factors are calculated by EPA’s Office of Radiation and Indoor Air (ORIA) to assist HEAST users with risk-related evaluations and decision-making at various stages of the remediation process. Ingestion and inhalation slope factors are central estimates in a linear model of the age-averaged, lifetime attributable radiation cancer incidence (fatal and nonfatal cancer) risk per unit of activity inhaled or ingested, expressed as risk/picocurie (pCi). External exposure slope factors are central estimates of the lifetime attributable radiation cancer incidence risk for each year of exposure to external radiation from photon-emitting radionuclides distributed uniformly in a thick layer of soil, and are expressed as risk/year per pCi/gram of soil.

d The states included in this section are only those that were available from the BNA database.

ACGIH = American Conference of Governmental Industrial Hygienists; ALI = annual limits on intake; BNA = Bureau of National Affairs; CFR = Code of Federal Regulations; DAC = derived air concentration; DIL = Derived Intervention Level; DOE = Department of Energy; DOT = Department of Transportation; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; I = insoluble; IARC = International Agency for Research on Cancer; mSv = millisievert; NIOSH = National Institute for Occupational Safety and Health; OSHA = Occupational Safety and Health Administration; PAG = protective action goal; PEL = permissible exposure limit; S = soluble; REL = recommended exposure limit; TLV = threshold limit value; TWA = time-weighted average; USNRC = U.S. Nuclear Regulatory Commission