# 4 CHEMICAL, PHYSICAL, and RADIOLOGICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Americium is a human-made actinide element (atomic number 95) and has no stable isotopes. It was discovered by Glen Seaborg, Leon Morgan, Ralph James, and Albert Ghiorso in 1944 and isolated by B.B. Cunningham as the isotope ^241^Am in Am(OH)_3_ in the fall of 1945. It was named after the Americas (Seaborg 1991; Seaborg and Loveland 1990). Actinides are the 15 elements starting with actinium, atomic number 89, and extending to lawrencium, atomic number 103. All of the isotopes of these elements are radioactive. Of the 15 americium isotopes and isomers currently identified, the longest-lived is ^243^Am.

## 4.2 PHYSICAL, CHEMICAL, AND RADIOLOGICAL PROPERTIES

Americium is a silvery, ductile, very maleable, non-magnetic metal. Americium melts at 1,176 °C, boils at 2,011 °C, and has an electron configuration of 5f^7^7s^2^. The Chemical Abstract Service (CAS) registry numbers, decay modes, half-lives, and specific activities of the four principal americium isotopes and isomers, ^241^Am,^242m^Am, ^242^Am, and ^243^Am, are presented in Table 4-1. ^241^Am and ^243^Am decay by alpha emission forming neptunium (atomic number 93), ^237^Np (t_½_=2.14×10^6^ years) and ^239^Np (t_½_=2.355 days) as the respective products. ^239^Np subsequently decays to ^239^Pu (t_½_=2.411×10^4^ years), and then to ^235^U, which is also a naturally-occurring isotope of uranium. The decay of ^241^Am to ^237^Np is accompanied by a predominant gamma ray photon of 59.54 keV. ^242m^Am is an isomer (long-lived excited state of the nucleus) of ^242^Am and has a half-life of 141 years; 95.5% of ^242m^Am undergoes an isomeric transition to ^242^Am (t_½_=16.02 hours) with the emission of a 48.6 keV gamma ray, and 0.5% decays by alpha emission to ^238^Np. ^242^Am primarily (87%) undergoes beta decay to curium 242 (atomic number 96) (t_½_=162.8 days), which decays to ^238^Pu (t_½_=87.74 years) and then to ^234^U (t_½_=2.45×10^5^ years) (another naturally-occurring uranium isotope); 17% undergoes electron capture to ^242^Pu (t_½_=3.76×10^5^ years).

^241^Am has a high specific activity of 3.428 Ci/g (0.1268 TBq/g), emitting ~7×10^9^ alpha particles/mg/minute. ^243^Am has a specific alpha activity about 17 times lower than ^241^Am and is therefore more attractive for chemical investigations of the element (ICRP 1983; Lide 1998; O’Neil 2001; Seaborg 1991).

Table 4-1 Principal Amencium Isotopes

Isotope^a^ | CAS Registry No. | Decay mode/percent (product) | Decay mode energy (MeV) | Particle energy | | Half-life (years) | Specific activity^b^ (Ci/g) | Gamma energy (keV)
Isotope^a^ | CAS Registry No. | Decay mode/percent (product) | Decay mode energy (MeV) | Energy (MeV) | Intensity (percent) | Half-life (years) | Specific activity^b^ (Ci/g) | Gamma energy (keV)
^241^Am | 14596-10-2; 86954-36-1^c^ | ∀ (_93_^237^ Np ) | 5.637 | 5.4431; 5.4857; 5.3884; Others | 12.8; 85.2; 1.4; <1 | 432.2 | 3.43 | 26.34; 33.192; 59.536
^242m^Am | 13981-54-9 | I.T./95.5 (^242^Am) | 0.048 | | | 141 | 10.5 | 48.63
^242m^Am | | ∃-/0.5 (_93_^238^ Np ) | 5.62 | 5.141; 5.2070 | 0.026; 0.4 | | | 86.48; 109.44; 163.04
^242^Am | 13981-54-9 | ∃^-^/83 (_96_^242^ Cm ) | 0.665 | 0.63 | 46 | 16.02 hours | 808,000 | 42.2
^242^Am | | EC/17 (_94_^242^ Pu ) | 0.750 | 0.67 | 37 | | | 44.53
^243^Am | 14993-75-0 | ∀ (_93_^239^ Np ) | 5.438 | 5.1798; 5.2343; 5.2766 Others | 1.1; 11; 88; <1 | 7,370 | 0.199 | 43.54; 74.67; 86.57; 117.70; 141.97

a An m after the atomic mass indicates one of multiple isomers of a given atomic mass.

b LANL 1999 (1 Ci=0.037 TBq)

c CAS Registry Number for ^241^Am^3+^ ion

Source: Baum 2002: DOE 1997b: ICRP 1983: LBL 2000: Lide 1998

The known oxidation states of americium are +2, +3, +4, +5, and +6. However, the stable oxidation states are +3 and +4; the common oxidation state is +3, in which state, the behavior of americium and other actinides is similar to the lanthanides. The trivalent state is the only state of importance in biological systems. The +2 oxidation state is very unstable and has only been produced in solid compounds. The stability of the americium oxidation states higher than +3 is less than that of uranium, neptunium, and plutonium (Cotton and Wilkinson 1980; Nenot and Stather 1979; Seaborg 1991). Am^+3^ hydrolyzes and forms weak complexes with serum proteins and other ligands. The physical and chemical properties of americium and selected americium compounds are shown in Table 4-2. Properties of some americium ions are shown in Table 4-3. The decay schemes for ^241^Am and ^243^Am are shown in Tables 4-4 and 4-5.

Table 4-2 Physical and Chemical Properties of Amencium and Selected Americium Compounds

Property | Value
Property | Americium | Americium(II) oxide | Americium(III) oxide | Americium(III) chloride | Americium(III) fluoride | Americium nitrate | Americium citrate
Atomic/molecular weight^a^ | 243 | 275 | 534 | 349 | 300 | 429 | 432
Chemical formula | Am | AmO_2_ | Am_2_O_3_ | AmCl_3_ | AmF_3_ | Am(NO_3_)_3_ | AmC_6_H_5_O_7_
Synonyms | No data | No data | No data | No data | No data | Americium trinitrate | No data
Chemical Abstracts Service Registry No. | 7440-35-9^b^ | 12005-67-3 | 12254-64-7 | 13464-46-5 | 13708-80-0 | 25933-53-3 | 11078-88-9
Color | Silvery | Black | Tan | Pink | Pink | No data | No data
Physical form | Solid metal | Cubic crystals | Hexagonal crystals | Hexagonal crystals | Hexagonal crystals | No data | No data
Odor | No data | No data | No data | No data | No data | No data | No data
Melting point, °C | 1,176 | >1,000 (decomposes) | No data | 500 | 1,393 | No data | No data
Boiling point, °C | 2,011 | Not relevant | No data | No data | No data | No data | No data
Autoignition temperature | No data | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant | Not relevant
Solubility:
Water | Insoluble | No data | No data | Soluble | No data | No data | No data
Other solvents | Soluble in acid | Soluble in acid | Soluble in acid | No data | No data | No data | No data
Density, g/cm^3^ | 12 | 11.68 | 11.77 | 5.87 | 9.53 | No data | No data
Partition coefficients | No data | No data | No data | No data | No data | No data | No data
Vapor pressure | No data | No data | No data | No data | No data | No data | No data
Refractive index | No data | No data | No data | No data | No data | No data | No data

a Calculated for ^243^Am

b This is also a generic CAS Registry Number for americium (unspecified form).

Source: Chemical Abstract Service 2000; Lide 1994, 1998, 2000

Table 4-3 Properties of Some Americium Ions

Ion | Color | Stability
Am^3+^ | Pink or yellow | Stable; difficult to oxidize
Am^4+^ | Color unknown | Occurs in solution only as complex fluoride and carbonate ions
AmO_2_^+^ | Yellow | Disproportionates in strong acid; reduces fairly rapidly under action of own alpha emissions (^241^Am) at low acidification
AmO_2_^2+^ | Rum colored | Easily reduced; reduces fairly rapidly under the action of its own alpha radiation (^241^Am)

Source: Seaborg 1991

Table 4-4 ^241^Am Decay Scheme^a^

Nuclide | | Half-life | Energies and intensities of emitted radiation
Nuclide | | Half-life | Alpha (α) | | Beta (β) max | | Gamma (γ)
Nuclide | | Half-life | keV | % | MeV | % | keV | %
^241^Am; ↓ | | 432.2 years | 5,485; 5,443 | 84.5; 13.0 | | | 13.9; 59.5; 26.3 | 42; 35.9; 2.4
^237^Np; ↓ | | 2.144×10^6^ years | 4,788; 4,771; 4,766; 4,639; 4,664 | 47; 25; 8; 6.2; 3.3 | | | 13.3; 29.4; 86.5; 8.2; 95.9 | 58; 15; 12.4; 9; 2.7
^233^Pa; ↓ | | 26.97 days | | | 232; 156; 260; 174; 572 | 40; 27.7; 17; 16.4; 4 | 13.6; 312.2; 98.4; 94.7; 111.0 | 56; 38.6; 17.7; 10.9; 8.2
^233^U; ↓ | | 1.592×10^5^ years | 4,824; 4,784 | 84.4; 13.2 | | | 13.0 | 6.0
^229^Th; ↓ | | 7,340 years | 4,845; 4,901; 4,815; 5,053; 4,968 | 56.2; 10.2; 9.3; 6.6; 6.0 | | | 12.3; 88.5; 85.4; 100.0; 11.1 | 79; 24.7; 15.0; 11.3; 8
^225^Ra; ↓ | | 14.9 days | | | 331; 371 | 69.5; 30.5 | 40.0; 12.7 | 30.0; 15.2
^225^Ac; ↓ | | 10.0 days | 5,830; 5,792; 5,791; 5,732; 5,637 | 50.7; 18.1; 8.6; 8.0; 4.4 | | | 12.0; 10.6 | 20.9; 9.3
^221^Fr; ↓ | | 4.9 minutes | 6,341; 6,126 | 83.4; 15.1 | | | 218.2; 11.4 | 11.6; 2.2
^217^; At ↓ | | 0.323 seconds | 7,066 | 99.9 | | | 258.5 | 0.056
^213^Bi | | 45.59 minutes | 5,869 | 1.94 | 1422 | 65.9 | 440.5 | 26.1
97.84% ↓ 2.16% | | | | | 982 | 31.0 | 79.3 | 2.0
^213^Po; ↓ | | 3.65 micro-seconds | 8,376 | 100.0 | | | 778.8 | 0.005
| ^209^TI; ↓ | 2.2 minutes | | | 660 | 98.8 | 1567.1; 465.1; 117.2; 75.0; 10.6 | 99.8; 96.9; 84.3; 10.7; 9.4
^209^Pb ↓ | | 3.253 hours | | | 0.644 | 100
^209^Bi | | stable

a Minimum intensity 2%, up to five energies, with at least one entry per radiation type (DOE 2003)

Table 4-5 ^243^Am Decay Scheme^a^

Nuclide | | Half-life | Energies and intensities of emitted radiation
Nuclide | | Half-life | Alpha (α) | | Beta (β) max | | Gamma (γ)
Nuclide | | Half-life | keV | % | MeV | % | keV | %
^243^Am; ↓ | | 7,370 years | 5,275; 5,233; 5,181 | 87.4; 11.0; 1.1 | | | 74.7; 13.9; 43.5 | 68.2; 21.4; 5.9
^239^Np; ↓ | | 2.3565 days | | | 436.5; 330.4; 391.9; 714.1 | 45; 40.5; 11; 2.0 | 14.3; 106.1; 103.8; 277.6; 99.6 | 63; 27.2; 22.5; 14.4; 14.0
^239^Pu; ↓ | | 24,110 years | 5,157; 5,144; 5,106 | 73.3; 15.1; 11.5 | | | 13.6 | 4.9
^235^U; ↓ | | 703,800,000 years | 4,398; 4,366; 4,215; 4,596; 4,325 | 55; 17.0; 5.7; 5.0; 4.4 | | | 185.7; 13.0; 143.8; 93.4; 163.3 | 57.2; 36; 11.0; 5.8; 5.1
^231^Th; ↓ | | 25.52 hours | | | 288.1; 305.3; 206.0; 287.2; 142.2 | 40; 33; 12.8; 12; 2.8 | 13.3; 25.6; 84.2 | 72; 14.1; 6.6
^231^Pa; ↓ | | 32,760 years | 5,014; 4,951; 5,028; 5,059; 4,736 | 25.4; 22.8; 20.0; 11.0; 8.4 | | | 12.7; 27.4; 300.0; 302.6 | 36; 10.3; 2.5; 2.2
^227^Ac; ↓ | | 21.772 years | 4,953 | 0.658 | 44.8; 35.5 | 53; 35 | 12.0 | 0.088
98+% 1.4% | | | | | 20.3 | 10
^227^Th; ↓ | | 18.68 days | 6,038; 5,978; 5,757; 5,709; 5,713 | 24.2; 23.5; 20.4; 8.3; 4.9 | | | 12.3; 236.0; 50.1; 256.2; 329.8 | 40; 12.9; 8.4; 7.0; 2.9
| ^223^Fr; ↓ | 22.00 minutes | | | 1,099.,0; 1,069.4; 914.3 | 70; 15.0; 10.1 | 50.1; 12.3; 79.7; 234.8; 49.8 | 34; 30; 8.7; 3.0; 2.8
^223^Ra; ↓ | | 11.43 days | 5,716; 5,607; 5,747; 5,540; 5,434 | 51.6; 25.2; 9.0; 9.0; 2.2 | | | 83.8; 11.7; 81.1; 269.5; 94.9 | 25.4; 25; 15.3; 13.9; 11.5
^219^Rn; ↓ | | 3.96 seconds | 6,819; 6,553; 6,425 | 79.4; 12.9; 7.5 | | | 271.2; 401.8 | 10.8; 6.6
^215^Po ↓ | | 1.781 milli-seconds | 7,386 | 100.0
^211^Pb; ↓ | | 36.1 minutes | | | 1379; 547 | 91.3; 6.3 | 404.9; 832.0 | 3.8; 3.5
^211^Bi; ↓ | | 2.14 minutes | 6,623; 6,278 | 83.5; 16.2 | | | 351.1 | 12.9
^207^TI ↓ | | 4.77 minutes | | | 1427 | 99.7 | 897.8 | 0.26
^207^Pb | | stable

a Minimum intensity 2%, up to five energies, with at least one entry per radiation type (DOE 2003)