# 9 REFERENCES

* Not cited in text

Abbate C, Giorgianni C, Brecciaroli R, 2003. Spirometric function in non-smoking workers exposed to aluminum. Am J Ind Med 44(4):400–404.14502768
Abd-Elghaffar SK, El-Sokkary GH, Sharkawy AA. 2005. Aluminum-induced neurotoxicity and oxidative damage in rabbits: Protective effect of melatonin. Neuro Endocrinol Lett 26(5):609–616.16264393
Abd El-Rahman SS. 2003. Neuropathology of aluminum toxicity in rats (glutamate and GABA impairment). Pharmacol Res 47(3):189–194.12591013
Abercrombie DE, Fowler RC. 1997. Possible aluminum content of canned drinks. Toxicol Ind Health 13(5):649–654.9284535
Abraham JL, Burnett BR. 1983. Quantitative analysis of inorganic particulate burden in situ in tissue sections. Scan Electron Microsc 2:681–696.
Abramson MJ, Wlodarczyk JH, Saunders NA, 1989. Does aluminum smelting cause lung disease? Am Rev Respir Dis 139:1042–1057.2648910
ACGIH. 2005. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27:532–537.4029526
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Advenier E, Landry C, Colomb V, 2003. Aluminum contamination of parenteral nutrition and aluminum loading in children on long-term parenteral nutrition. J Pediatr Gastroenterol Nutr 36(4):448–453.12658033
AEC. 1971. Sources of trace elements in aerosols - approach to clean air. Argonne, IL: U.S. Atomic Energy Commission. ORA Project 089030. Contract No. AT1111705.
Agarwal SK, Ayyash L, Gourley CS, 1996. Evaluation of the developmental neuroendocrine and reproductive toxicology of aluminum. Food Chem Toxicol 34(1):49–53.8603797
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Division of Toxicology.
Agency for Toxic Substances and Disease Registry. 1990. Biomarkers of organ damage or dysfunction for the renal, hepatobiliary, and immune systems. Subcommittee on Biomarkers of Organ Damage and Dysfunction. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Ahn H-W, Fulton B, Moxon D, 1995. Interactive effects of fluoride and aluminum uptake and accumulation in bones of rabbits administered both agents in their drinking water. J Toxicol Environ Health 44(3):337–350.7897695
Akila R, Stollery BT, Riihimaki V. 1999. Decrements in cognitive performance in metal inert gas welders exposed to aluminum. Occup Environ Med 56(9):632–639.10615297
Akira M. 1995. Uncommon pneumoconioses: CT and pathologic findings. Radiology 197(2):403–409.7480684
Albers PH, Camardese MB. 1993. Effects of acidification on metal accumulation by aquatic plants and invertebrates. 1. Constructed wetlands. Environ Toxicol Chem 12:959–967.
Alder JF, Samuel AJ, West TS. 1976. The single element determination of trace metals in hair by carbon-furnace atomic absorption spectrometry. Anal Chim Acta 87(2):313–321.999015
Alder JF, Samuel AJ, West TS. 1977. The anatomical and longitudinal variation of trace element concentration in human hair. Anal Chim Acta 92:217–221.889106
Alderman FR, Gitelman HJ. 1980. Improved electrothermal determination of aluminum in serum by atomic absorption spectroscopy. Clin Chem 26:258–260.7353272
Alfrey AC. 1980. Aluminum metabolism in uremia. Neurotoxicology 1:43–53.
Alfrey AC. 1981. Aluminum and tin. In: Bronner F, Coburn JW, eds. Disorders of mineral metabolism. Vol. 1. Trace minerals. New York, NY: Academic Press, 353–368.
Alfrey AC. 1984. Aluminum intoxication. N Engl J Med 310(17):1113–1115.6708992
Alfrey AC. 1987. Aluminum metabolism and toxicity in uremia. J UOEH 9 Suppl:123–132.3602743
Alfrey AC. 1993. Aluminum toxicity in patients with chronic renal failure. Ther Drug Monit 15(6):593–597.8122300
Alfrey AC, Hegg A, Craswell P. 1980. Metabolism and toxicity of aluminum in renal failure. Am J Clin Nutr 33(7):1509–1516.7395774
Alfrey AC, LeGendre GR, Kaehny WD. 1976. The dialysis encephalopathy syndrome: Possible aluminum intoxication. N Engl J Med 294(4):184–188.1244532
Allain P, Mauras Y. 1979. Determination of aluminum in blood, urine, and water by inductively coupled plasma emission spectrometry. Anal Chem 51(13):2089–2091.532969
Allen DD, Orvig C, Yokel RA. 1995. Evidence for energy-dependent transport of aluminum out of brain extracellular fluid. Toxicology 98:31–39.7740551
Allen SK, Allen JM, Lucas S. 1996. Dissolved metal concentrations in surface waters from west-central Indiana contaminated with acidic mine drainage. Bull Environ Contam Toxicol 56:240–243.8720095
Al-Masalkhi A, Walton SP. 1994. Pulmonary fibrosis and occupational exposure to aluminum. J Ky Med Assoc 92:59–61.8163901
Al-Saleh I, Shinwari N. 1996. Aluminum in Saudi children. Biometals 9:385–392.8837460
Altman PK, Dittmer DS. 1974. Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies for Experimental Biology, 1987–2008, 2041.
Alvarez E, Perez A, Calvo R. 1993. Aluminum speciation in surface waters and soil solutions in areas of sulphide mineralization in Galicia (N.W. Spain). Sci Total Environ 133:17–37.
Amaducci LA, Fratiglioni L, Rocca WA, 1986. Risk factors for clinically diagnosed Alzheimer's disease: A case-control study of an Italian population. Neurology 36(7):922–931.3714054
Anane R, Bonini M, Creppy EE. 1997. Transplacental passage of aluminum from pregnant mice to fetus organs after maternal transcutaneous exposure. Hum Exp Toxicol 16(9):501–504.9306136
Anane R, Bonini M, Grafeille MJ, 1995. Bioaccumulation of water soluble aluminum chloride in the hippocampus after transdermal uptake in mice. Arch Toxicol 69(8):568–571.8534202
Andersen JR. 1987. Graphite furnace atomic absorption spectrometric screening methods for determination of aluminum in hemodialysis concentrates. J Anal Atom Spectrom 2:257–259.
Andersen JR. 1988. Aluminum in peritoneal dialysis fluids as determined by stabilized temperature platform furnace atomic absorption spectrometry. J Pharm Biomed Anal 6(1):29–33.16867437
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York: Marcel Dekker, Inc., 9–25.
Andersen ME, Clewell HJ 3rd, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Andreoli SP. 1990. Aluminum levels in children with chronic renal failure who consume low-phosphorus infant formula. J Pediatr 116(2):282–285.2299504
Andreoli SP, Bergstein JM, Sherrard DJ. 1984. Aluminum intoxication from aluminum-containing phosphate binders in children with azotemia not undergoing dialysis. N Engl J Med 310:1079–1084.6708989
*Anthony J, Fadl S, Mason C, 1986. Absorption, deposition and distribution of dietary aluminum in immature rats: Effects of dietary vitamin D3 and food-borne chelating agent. J Environ Sci Health B 21(2):191–205.3011882
AOAC. 1990. Method 990.08: Metals in solid wastes. Inductively coupled plasma atomic emission method. First action 1990. In: Helrich K, ed. Changes in official methods of analysis of the Association of Official Analytical Chemists. First Supplement. Arlington, VA: Association of Official Analytical Chemists, Inc., 14–17, 43.
APHA. 1998a. Method 3113 B: Metals by atomic absorption spectroscopy. In: Clesceri LS, Greenberg AE, Eaton AD, , eds. Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association/American Water Works Association/Water Environment Federation, 3–24 to 3–31.
APHA. 1998b. Method 3120 B: Metals by plasma emission spectroscopy. In: Clesceri LS, Greenberg AE, Eaton AD, , eds. Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association/American Water Works Association/Water Environment Federation, 3–37 to 3–43.
APHA. 1998c. Method 3125: Metals by inductively coupled plasma/mass spectroscopy. In: Clesceri LS, Greenberg AE, Eaton AD, , eds. Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association/American Water Works Association/Water Environment Federation, 3–44 to 3–52.
APHA. 1998d. Method 3500-Al: Aluminum. In: Clesceri LS, Greenberg AE, Eaton AD, , eds. Standard methods for the examination of water and wastewater. Washington, DC: American Public Health Association, American Water Works Association, Water Environment Federation, 3–56 to 3–59.
Arieff AI, Cooper JD, Armstrong D, 1979. Dementia, renal failure, and brain aluminum. Ann Intern Med 90(5):741–747.434672
Banasik A, Lankoff A, Piskulak A, 2005. Aluminum-induced micronuclei and apoptosis in human peripheral-blood lymphocytes treated during different phases of the cell cycle. Environ Toxicol 20(4):402–406.16007643
Banks WA, Kastin AJ, Fasold MB. 1988. Differential effect of aluminum on the blood-brain barrier transport of peptides, technetium and albumin. J Pharmacol Exp Ther 244:579–585.2894456
*Banks WA, Maness LM, Banks MF, 1996. Aluminum-sensitive degradation of amyloid beta-protein-40 by m urine and human intracellular enzymes. Neurotoxicol Teratol 81:671–677.
Barnes DG, Dourson M. 1988. Reference dose (RfD) description and use in health risk assessments. Regul Toxicol Pharmacol 8:471–486.3222488
Bast-Pettersen R, Drablos PA, Goffeng LO, 1994. Neuropsychological deficit among elderly workers in aluminum production. Am J Ind Med 25(5):649–662.8030636
Bast-Pettersen R, Skaug V, Ellingsen D, 2000. Neurobehavioral performance in aluminum welders. Am J Ind Med 37(2):184–192.10615099
Baxter MJ, Burrell JA, Crews HM, 1989. Aluminium in infant formulae and tea and leaching during cooking. In: Massey RC, Taylor D, eds. Aluminium in food and the environment: Proceedings of a symposium organised by the Environment and Food Chemistry groups of the Industrial Division of the Royal Society of Chemistry, London, 17th May 1988. Special publication No. 73. London, England: The Royal Society of Chemistry, Thomas Graham House, 77–87.
Baxter MJ, Burrell JA, Crews H, 1991. Aluminum levels in milk and infant formulae. Food Addit Contam 8(5):653–660.1818839
Baxter MJ, Burrell JA, Massey RC. 1990. The aluminium content of infant formula and tea. Food Addit Contam 7(1):101–107.2307259
Baxter DC, Frech W, Lundberg E. 1985. Determination of aluminum in biological materials by constant-temperature graphite furnace atomic-emission spectrometry. Analyst 110:475–482.4025836
Baydar T, Nagymajtenyi L, Isimer A, 2005. Effect of folic acid supplementation on aluminum accumulation in rats. Nutrition 21(3):406–410.15797685
Baylor NW, Egan W, Richman P. 2002. Aluminum salts in vaccines–US perspective. Vaccine 20(Suppl 3):S18–S23.12184360
Bellia JP, Birchall JD, Roberts NB. 1996. The role of silicic acid in the renal excretion of aluminum. Ann Clin Lab Sci 26:227–233.8726215
*Benett RW, Persaud TVN, Moore KL. 1975. Experimental studies on the effects of aluminum on pregnancy and fetal development. Anat Anz 138:365–378.1217743
Benson RL, Worsfold PJ, Sweeting FW. 1990. On-line determination of residual aluminum in potable and treated waters by flow-injection analysis. Anal Chim Acta 238:177–182.
Berger GS. 1994. Epidemiology of endometriosis. In: Berger GS, ed. Endometriosis: Advanced management and surgical techniques. New York, NY: Springer-Verlag, 3–7.
Bergfors E, Bjorkelund C, Trollfors B. 2005. Nineteen cases of persistent pruritic nodules and contact allergy to aluminum after injection of commonly used aluminum-absorbed vaccines. Eur J Pediatr 164(11):691–697.16044278
Berlyne GM, Ben-Ari J, Pest D, 1970. Hyperaluminaemia from aluminum resins in renal failure. Lancet 2(7671):494–496.4194940
Bernuzzi V, Desor D, Lehr PR. 1986. Effects of prenatal aluminum exposure on neuromotor maturation in the rat. Neurobehav Toxicol Teratol 8:115–119.3713960
Bernuzzi V, Desor D, Lehr PR. 1989a. Effects of postnatal aluminum lactate exposure on neuromotor maturation in the rat. Bull Environ Contam Toxicol 42(3):451–455.2706356
Bernuzzi V, Desor D, Lehr PR. 1989b. Developmental alterations in offspring of female rats intoxicated by aluminum chloride or lactate during gestation. Teratology 40(1):21–27.2763207
Bettinelli M, Baroni U, Fontana F, 1985. Evaluation of the L'vov platform and matrix modification for the determination of aluminum in serum. Analyst 110:19–22.3985343
Biego GH, Joyeux M, Hartemann P, 1998. Daily intake of essential minerals and metallic micropollutants form foods in France. Sci Total Environ 217(1–2):27–36.9695171
Bilkei-Gorzo A. 1993. Neurotoxic effect of enteral aluminum. Food Chem Toxicol 31(5):357–361.8505021
Birchall JD, Chappell JS. 1988. The chemistry of aluminum and silicon in relation to Alzheimer's disease. Clin Chem 34:265–267.2830051
Bishop NJ. 1992. Aluminium in infants feeding: Is it a problem? Eur J Clin Nutr 46(Suppl 4):S37–S39.1286647
Bishop NJ, Morley R, Day J P, 1997. Aluminum neurotoxicity in preterm infants receiving intravenous-feeding solutions. N Engl J Med 336:1557–1561.9164811
*Bjertness E, Alexander J, Taylor G, 1992. Aluminum and the causation of Alzheimer's disease: A combined clinical, neuropathological, and trace element study. J Trace Elem Exp Med 5:73.
Bloodworth BC, Hock CT, Boon TO. 1991. Aluminium content in milk powders by inductively-coupled argon plasma-optical emission spectrometry. Food Addit Contam 8(6):749–754.1812022
Blotcky AJ, Hobson D, Leffler JA, 1976. Determination of trace aluminum in urine by neutron activation analysis. Anal Chem 48:1084–1088.1267172
Bodek I, Lyman WJ, Reehl WF, , eds. 1988. Aluminum (Al). Environmental inorganic chemistry: Properties, processes, and estimation methods. New York, NY: Pergamon Press, 6.7–1 to 6.7–9.
Böhler-Sommeregger K, Lindemayr H. 1986. Contact sensitivity to aluminum. Contact Dermatitis 15(5):278–281.3816191
*Bolla KI, Briefel G, Spector D, 1992. Neurocognitive effects of aluminum. Arch Neurol 49(10):1021–1026.1417509
Bost TW, Newman LS. 1993. Metal-induced interstitial lung diseases: A clinicopathologic approach. Semin Resp Med 14(3):197–211.
Bougle D, Bureau F, Voirin J, 1991. Aluminum levels in term and premature infants on enteral nutrition. Trace Elem Med 8:172–174.
Bouman AA, Platenkamp AJ, Posma FD. 1986. Determination of aluminum in human tissues by flameless atomic absorption spectroscopy and comparison of references values. Ann Clin Biochem 23(Part 1):97–101.3767258
Bozynski ME, Sedman AB, Naglie RA, 1989. Serial plasma and urinary aluminum levels and tissue loading in preterm twins. JPEN J Parenter Enteral Nutr 13(4):428–431.2506381
Broe GA, Henderson AS, Creasey H, 1990. A case-control study of Alzheimer's disease in Australia. Neurology 40(11):1698–1707.2146525
Brooks AW, White KN, Bailey SE. 1992. Accumulation and excretion of aluminium and iron by the terrestrial snail Helix aspersa. Comp Biochem Physiol 103C:577–583.
Browning E. 1969. Aluminum. In: Browning E, ed. Toxicity of industrial metals. New York, NY: Appleton-Century-Crofts, 3–22.
Brumbaugh WG, Kane DA. 1985. Variability of aluminum in organs and whole bodies of smallmouth bass (Micropterus dolomieui). Environ Sci Technol 19:828–831.22196607
Brusewitz S. 1984. Aluminum. Vol. 203. Stockholm, Sweden: University of Stockholm, Institute of Theoretical Physics.
Buchta M, Kiesswetter E, Otto A, 2003. Longitudinal study examining the neurotoxicity of occupational exposure to aluminum-containing welding fumes. Int Arch Occup Environ Health 76(7):539–548.12838425
Buchta M, Kiesswetter E, Schaper M, 2005. Neurotoxicity of exposures to aluminium welding fumes in the truck trailer construction industry. Environ Toxicol Pharmacol 19(3):677–685.21783542
Buckler DR, Cleveland L, Little EE, 1995. Survival, sublethal responses, and tissue residues of Atlantic salmon exposed to acidic pH and aluminum. Aquat Toxicol 31:203–216.
Buergel PM, Soltero RA. 1983. The distribution and accumulation of aluminum in rainbow trout following a whole-lake alum treatment. J Freshwater Ecol 2(1):37–44.
Burge PS, Scott JA, McCoach J. 2000. Occupational asthma caused by aluminum. Allergy 55(8):779–780.10955707
*Burgess E. 1991. Aluminum toxicity from oral sucralfate therapy. Nephron 59(3):523–524.1758558
*Burnatowska-Hledin MA, Doyle TM, Eadie MJ, 1986. 1, 25-Dihydroxy-vitamin D3 increase serum and tissue accumulation of aluminum in rats. J Lab Clin Med 108(2):96–102.3755457
Burt R, Wilson MA, Mays MD, 2003. Major and trace elements of selected pedons in the USA. J Environ Qual 32(6):2109–2121.14674533
Butte W, Heinzow B. 2002. Pollutants in house dust as indicators of indoor contamination. Rev Environ Contam Toxicol 175:1–46.12206053
Cai HR, Cao M, Meng FQ, 2007. Pulmonary sarcooid-like granulomatosis induced by aluminum dust: Report of a case and literature review. Chin Med J 120(17):1556–1560.17908469
Campbell PGC, Hansen HJ, Dubreuil B, 1992. Geochemistry of Quebec north shore salmon rivers during snowmelt: Organic acid pulse and aluminum mobilization. Can J Fish Aquat Sci 49:1938–1952.
*Candy JM, Mountfort SA, McArthur FK, 1991. Aluminum accumulation and senile plaque formation in the brains. Neurotoxicology 12:123.
Cann CE, Prussin SG, Gordan GS. 1979. Aluminum uptake by the parathyroid glands. J Clin Endocrinol Metab 49(4):543–545.479346
Capar SG, Yess NJ. 1996. U.S. Food and Drug Administration survey of cadmium, lead and other elements in clams and oysters. Food Addit Contam 13:553–560.8799717
Carmichael KA, Fallon MD, Dalinka M, 1984. Osteomalacia and osteitis fibrosa in a man ingesting aluminum hydroxide antacid. Am J Med 76(6):1137–1143.6328994
Caroli S, Alimonti A, Coni E, 1994. The assessment of reference values for elements in human biological tissues and fluids: A systematic review. Crit Rev Anal Chem 24:363–398.
Carrillo F, Perez C, Camara C. 1992. Sensitive flow-injection-spectrofluorimetric method to determine aluminium III in water. Anal Chim Acta 262:91–96.
Castelain PY, Castelain M, Vervloet D, 1988. Sensitization to aluminium by aluminium-precipitated dust and pollen extracts. Contact Dermatitis 19(1):58–60.3180769
CEC. 1984. Aluminum. In: Alessio L, Berlin A, Boni M, , eds. Biological indicators for the assessment of human exposure to industrial chemicals. Brussels, Luxembourg: Commission of the European Communities, 21–29. PB86229242.
Cech I, Montera J. 2000. Spatial variations in total aluminum concentrations in drinking water supplies studied by geographic information system (GIS) methods. Water Res 34(10):2703–2712.
*Chan JCM, Jacob M, Brown S, 1988. Aluminum metabolism in rats: Effects of vitamin-D, dihydrotachysterol, 1,25-dihydroxyvitamin-D and phosphate binders. Nephron 48(1):61–64.3340256
Chan-Yeung M, Wong R, MacLean L, 1983. Epidemiologic health study of workers in an aluminum smelter in British Columbia, Canada: Effects on respiratory system. Am Rev Respir Dis 127:465–469.6838051
Chappuis P, de Vernejoul MC, Paolaggi F, 1989. Relationship between hair, serum and bone aluminium in hemodialyzed patients. Clin Chim Acta 179(3):271–278.2714000
Chappuis P, Duhaux L, Paolaggl F, 1988. Analytical problems encountered in determining aluminum status from hair in controls and hemodialyzed patients. Clin Chem 34(11):2253–2255.3180419
Chedid F, Fudge A, Teubner J, 1991. Aluminium absorption in infancy. J Paediatr Child Health 27(3):164–166.1888563
ChemFinder. 2008. Aluminum and compounds. ChemFinder.com database and internet searching. http://chemfinder.camsoft.com/. January 9, 2008.
ChemIDplus. 2008. Aluminum and compounds. ChemIDplus. Bethesda, MD: U.S. National Library of Medicine. http://sis.nlm.nih.gov/chemical.html. January 9, 2008.
Chen W-J, Monnat RJ J, Chen M, 1978. Aluminum induced pulmonary granulomatosis. Hum Pathol 9(6):705–711.730152
Chiba M, Sera K, Hashizume M, 2004. Element concentrations in hair of children living in environmentally degraded districts of the East Aral Sea region. J Radioanal Nucl Chem 259(1):149–152.
Chines A, Pacifici R. 1990. Antacid and sucralfate-induced hypophosphatemic osteomalacia: A case report and review of the literature. Calcif Tissue Int 47(5):291–295.2257522
Chinoy NJ, Sharma AK, Patel TN, 2004. Recovery from fluoride and aluminum induced free radical liver toxicity in mice. Fluoride 37(4):257–263.
Chopra JS, Kalra OP, Malik VS, 1986. Aluminum phosphide poisoning: A prospective study of 16 cases in one year. Postgrad Med J 62:1113–1116.3658848
Christie H, MacKay RJ, Fisher AM. 1963. Pulmonary effects of inhalation of aluminum by rats and hamsters. Am Ind Hyg Assoc J 24:47–56.14021151
Chung FHY. 1992. Bakery processes (chemical leavening). In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 3. Antibiotics (b-lactams) to batteries. New York, NY: John Wiley & Sons, Inc., 892–902.
*Clayton RM, Sedowofia SKA, Rankin JM, 1992. Long-term effects of aluminum on the fetal mouse brain. Life Sci 51(25):1921–1928.1453876
Cleveland L, Buckler DR, Brumbaugh WG. 1991. Residue dynamics and effects of aluminum on growth and mortality in brook trout. Environ Toxicol Chem 10:243–248.
Cleveland L, Little EE, Wiedmeyer RH, 1989. Chronic no-observed-effect concentrations of aluminum for brook trout exposed in low-calcium, dilute acidic water. In: Lewis TE, ed. Environmental chemistry and toxicology of aluminum. Chelsea, MI: Lewis Publishers, Inc., 229–246.
Clewell HJ III, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1:111–113.3843496
Colin-Jones D, Langman MJ, Lawson DH, 1989. Alzheimer's disease in antacid users. Lancet 1(8652):1453.
Colomina MT, Esparza JL, Corbella J 1998. The effect of maternal restraint on developmental toxicity of aluminum in mice. Neurotoxicol Teratol 20(6):651–656.9831127
Colomina MT, Gomez M, Domingo JL, 1992. Concurrent ingestion of lactate and aluminum can result in developmental toxicity in mice. Res Commun Chem Pathol Pharmacol 77(1):95–106.1439184
Colomina MT, Gomez M, Domingo JL, 1994. Lack of maternal and developmental toxicity in mice given high doses of aluminum hydroxide and ascorbic acid during gestation. Pharmacol Toxicol 74(4–5):236–239.8090692
Colomina MT, Roig JL, Sanchez DJ, 2002. Influence of age on aluminum-induced neurobehavioral effects and morphological changes in rat brain. Neurotoxicology 23(6):775–781.12520767
Colomina MT, Roig JL, Torrente M, 2005. Concurrent exposure to aluminum and stress during pregnancy in rats: Effects on postnatal development and behavior of the offspring. Neurotoxicol Teratol 27(4):565–574.16024221
Colomina MT, Sanchez DJ, Domingo JL, 1999. Exposure of pregnant mice to aluminum and restraint stress: Effects on postnatal development and behavior of the offspring. Psychobiology 27(4):521–529.
Commissaris RL, Cordon JJ, Sprague S, 1982. Behavioral changes in rats after chronic aluminum and parathyroid hormone administration. Neurobehav Toxicol Teratol 4(3):403–410.7099360
Connor DJ, Harrell LE, Jope RS. 1989. Reversal of an aluminum-induced behavioral deficit by administration of deferoxamine. Behav Neurosci 103(4):779–783.2765182
*Connor DJ, Jope RS, Harrell LE. 1988. Chronic, oral aluminum administration to rats: Cognition and cholinergic parameters. Pharmacol Biochem Behav 31:467–474.2854266
Connor JJ, Shacklette HT. 1975. Background geochemistry of some rocks, soils, plants, and vegetables in the conterminous United States. United States Geological Survey. Professional Paper 574-F.
Cooke K, Gould MH. 1991. The health effects of aluminium-a review. J R Soc Health 111:163–168.1795349
Cooper JA, Watson JG, Huntzicker JJ. 1979. Summary of the Portland Aerosol Characterization Study (PACS). Presented at the 72nd Annual Meeting of the Air Pollution Control Association, Cincinnati, Ohio, June 24–29, 1979. Cincinnati, OH: Air Pollution Control Association, 1–16.
Cotton FA, Wilkinson G, Murillo CA, , eds. 1999. The group 13 elements: Al, Ga, In, Tl. Advanced inorganic chemistry. 6th ed. New York, NY: John Wiley & Sons, Inc., 175–207.
Couri D, Liss L, Ebner K. 1980. Determination of aluminum in biological samples. Neurotoxicology 1:17–24.
Cournot-Witmer G, Zingraff J, Plachot JJ, 1981. Aluminum localization in bone from hemodialyzed patients: Relationship to matrix mineralization. Kidney Int 20(3):375–385.7300127
Cranmer JM, Wilkins JD, Cannon DJ, 1986. Fetal-placental-maternal uptake of aluminum in mice following gestational exposure: Effect of dose and route of administration. Neurotoxicology 7(2):601–608.3785766
Crapper DR, DeBoni U. 1978. Brain aging and Alzheimer's disease. Can Psychiatr Assoc J 23:229–233.667780
Crapper McLachlan DR. 1989. Aluminum neurotoxicity: Criteria for assigning a role in Alzheimer's disease. In: Lewis TE, ed. Environmental chemistry and toxicology of aluminum. Chelsea, MI: Lewis Publishers, Inc., 299–315.
Crombie DW, Blaisdell JL, MacPherson G. 1944. The treatment of silicosis by aluminum powder. Can Med Assoc J 50:318–328.20323057
Cucarella C, Montoliu C, Hermenegildo C, 1998. Chronic exposure to aluminum impairs neuronal glutamate-nitric oxide-cyclic GMP pathway. J Neurochem 70:1609–1614.9580158
Dabeka RW, McKenzie AD. 1990. Aluminum levels in Canadian infant formulae and estimation of aluminum intakes from formulae by infants 0–3 months old. Food Addit Contam 7(2):275–282.2354745
Dabeka RW, Conacher HB S, Salminen J, 1992. Survey of bottled drinking water sold in Canada. Part 1. Lead, cadmium, arsenic, aluminum, and fluoride. J AOAC Int 75(6):949–953.
Dahlgren RA, Ugolini FC. 1989. Aluminum fractionation of soil solutions from unperturbed and tephra-treated spodosols, Cascade range, Washington, USA. Soil Sci Soc Am J 53:559–566.
Dantzman CL, Breland HL. 1970. Chemical status of some water sources in south central Florida. Soil Sci Soc Am Proc 29:18–28.
Dawson EB, Evans DR, Harris WA, 2000. Seminal plasma trace metal levels in industrial workers. Biol Trace Elem Res 74(2):97–105.11051584
Dawson EB, Ritter S, Harris WA, 1998. Comparison of sperm viability with seminal plasma metal levels. Biol Trace Elem Res 64:215–219.9845475
Day JP, Barker J, Evans LJ A, 1991. Aluminum absorption studied by 26Al tracer. Lancet 337(8753):1345.
Dean JR. 1989. Ion chromatographic determination of aluminum with ultraviolet spectrophotometric detection. Analyst 114:165–168.
*Dedman DJ, Treffry A, Candy JM, 1992. Iron and aluminum in relation to brain ferritin in normal individuals and Alzheimer's-disease and chronic renal-dialysis patients. Biochem J 287(Part 2):509–514.1445209
de Kom JFM, Dissels H MH, van der Voet GB, 1997. Serum aluminum levels of workers in the bauxite mines. Clin Toxicol 35(6):645–651.
de la Flor St. Remy RR, Sanchez MLF, Sastre JBL, 2004. Determination of essential and toxic total elements in premature human milk by inductively coupled plasma mass spectrometry (ICP-ORC-MS), using an octopole reaction cell. J Anal Atom Spectrom 19(5):616–622.
Deloncle R, Huguet F, Babin P, 1999. Chronic administration of aluminium L-glutamate in young mature rats: Effects on iron levels and lipid peroxidation in selected brain areas. Toxicol Lett 104(1–2):65–73.10048751
Deng Z, Coudray C, Gouzoux L, 2000. Effects of acute and chronic coingestion of AlCl3 with citrate or polyphenolic acids on tissue retention and distribution of aluminum in rats. Biol Trace Elem Res 76(3):245–256.11049223
DeVoto E, Yokel RA. 1994. The biological speciation and toxicokinetics of aluminum. Environ Health Perspect 102(11):940–951.9738208
De Vuyst P, Dumortier P, Rickaert F, 1986. Occupational lung fibrosis in an aluminum polisher. Eur J Respir Dis 68(2):131–140.3699115
De Vuyst P, Dumortier P, Schandenè L, 1987. Sarcoidlike lung granulomatosis induced by aluminum dusts. Am Rev Respir Dis 135(2):493–497.3813209
D'Haese PCD, Couttenye MM, Goodman WG, 1995. Use of the low-dose desferrioxamine test to diagnose and differentiate between patients with aluminum-related bone disease, increased risk for aluminum toxicity, or aluminum overload. Nephrol Dial Transplant 10:1874–1884.8592597
Dick RB, Krieg EF J, Sim MA, 1997. Evaluation of tremor in aluminum production workers. Neurotoxicol Teratol 19(6):447–453.9392780
Dinman BD. 1983. Aluminum, alloys, and compounds. In: Encyclopaedia of occupational health and safety. Vol. 1. Geneva: International Labour Office, 131–135.
Dinman BD. 1987. Aluminum in the lung: The pyropowder conundrum. J Occup Med 29(11):869–876.3316541
DiPaolo JA, Casto BC. 1979. Quantitative studies of in vitro morphological transformation of Syrian hamster cells by inorganic metal salts. Cancer Res 39(3):1008–1013.427740
Dixon RL, Sherins RJ, Lee IP. 1979. Assessment of environmental factors affecting male fertility. Environ Health Perspect 30:53–68.446458
Dlugaszek M, Fiejka MA, Graczyk A, 2000. Effects of various aluminum compounds given orally to mice on Al tissue distribution and tissue concentrations of essential elements. Pharmacol Toxicol 86(3):135–139.10752672
DOE. 1984. A review and analysis of parameters for assessing transport of environmentally released radionuclides through agriculture. U.S. Department of Energy. ORNL-5786.
DOI. 1970. Trace metals in waters of the United States. A five year summary of trace metals in rivers and lakes of the United States (Oct. 1, 1962- Sept. 30, 1967). Cincinnati, OH: U.S. Department of the Interior, Federal Water Pollution Control Administration, Division of Pollution Surveillance.
DOI. 1971. Geochemical cycles involving flora, lake water, and bottom sediments. Washington, DC: U.S. Department of the Interior, Office of Water Resources Research. PB206197.
DOI. 1983. Removal of leachable metals and recovery of alumina from utility coal ash. Washington, DC: U.S. Department of the Interior, Bureau of Mines. PB83191650.
DOI. 1984. Study of availability and composition of metal bearing wastes (generated in titanium extraction and fabrication, aluminum smelters, chromite bearing refractory and foundry sands and mercury battery industries). Washington, DC: U.S. Department of the Interior, Bureau of Mines. PB84207091.
Domingo JL, Gomez M, Bosque MA, 1989. Lack of teratogenicity of aluminum hydroxide in mice. Life Sci 45(3):243–247.2761341
Domingo JL, Gomez M, Llobet JM, 1991. Influence of some dietary constituents on aluminum absorption and retention in rats. Kidney Int 39(4):598–601.2051716
Domingo JL, Gomez M, Sanchez DJ, 1993. Effect of various dietary constituents on gastrointestinal absorption of aluminum from drinking water and diet. Res Commun Chem Pathol Pharmacol 79(3):377–380.8480083
Domingo JL, Llobet JM, Gomez M, 1987b. Nutritional and toxicological effects of short-term ingestion of aluminum by the rat. Res Commun Chem Pathol Pharmacol 56(3):409–419.3628968
Domingo JL, Llorens J, Sanchez DJ, 1996. Age-related effects of aluminum ingestion on brain aluminum accumulation and behavior in rats. Life Sci 58(17):1387–1395.8622564
Domingo JL, Paternain JL, Llobet JM, 1987c. The effects of aluminum ingestion of reproduction and postnatal survival in rats. Life Sci 41(9):1127–1131.3613867
Domingo JL, Paternain JL, Llobet JM, 1987a. Effects of oral aluminum administration on perinatal and postnatal development in rats. Res Commun Chem Pathol Pharmacol 57(1):129–132.3671875
Donald JM, Golub MS, Gershwin ME, 1989. Neurobehavioral effects in offspring of mice given excess aluminum in diet during gestation and lactation. Neurotoxicol Teratol 11(4):345–351.2796889
Dong D, Xie Z, Du Y, 1999. Influence of soil pH on aluminum availability in the soil and aluminum in tea leaves. Commun Soil Sci Plant Anal 30(5/6):873–883.
Drablos PA, Hetland S, Schmidt F 1992. Uptake and excretion of aluminum in workers exposed to aluminum fluoride and aluminum oxide. Proceedings of the second international conference on aluminum and health, Tampa, Fl, February 2–6, 1992. New York, NY: Aluminum Association, 157–160.
Dreetz CD, Lund W. 1992. Air-intake filters used for multi-element analysis of airborne particulate matter by inductively coupled plasma atomic emission spectrometry. Anal Chim Acta 262:299–305.
Drew RT, Gupta BN, Bend JR, 1974. Inhalation studies with a glycol complex of aluminum-chloride-hydroxide. Arch Environ Health 28(6):321–326.4829086
Driscoll CT, Letterman RD. 1988. Chemistry and fate of aluminum (III) in treated drinking water. J Environ Eng 114:21–37.
Drueke TB, Jouhanneau P, Banide H, 1997. Effects of silicon, citrate and the fasting state on the intestinal absorption of aluminum in rats. Clin Sci 92(1):63–67.
Du Val G, Grubb BR, Bently PJ. 1986. Tissue distribution of subcutaneously administered aluminum chloride in weanling rabbits. J Toxicol Environ Health 19:97–104.3746943
Duggan JM, Dickeson JE, Tynan PF, 1992. Aluminium beverage cans as a dietary source of aluminium. Med J Aust 156(9):604–605.1625612
*Dwyer CM, Kerr RE. 1993. Contact allergy to aluminum in 2 brothers. Contact Dermatitis 29:36–38.8365151
Dyrssen D, Haraldsson C, Nyberg E, 1987. Complexation of aluminum with DNA. J Inorg Biochem 29(1):67–75.3559548
Dzubay TG. 1980. Chemical element balance method applied to dichotomous sampler data. Ann NY Acad Sci 338:126–144.
*Ecelbarger CA, MacNeil GG, Greger JL. 1994. Aluminum retention by aged rats fed aluminum and treated with desferrioxamine. Toxicol Lett 73(3):249–257.8091432
Edling NPG. 1961. Aluminum pneumoconiosis: A roentgendiagnostic study of five cases. Acta Radiol 56:170–178.13889219
Edwardson JA, Moore PB, Ferrier IN, 1993. Effect of silicon on gastrointestinal absorption of aluminum. Lancet 342(8865):211–212.8100932
Eisenreich SJ. 1980. Atmospheric input of trace metals to Lake Michigan (USA). Water Air Soil Pollut 13(3):287–301.
El-Demerdash FM. 2004. Antioxidant effect of vitamin E and selenium on lipid peroxidation, enzyme activities and biochemical parameters in rats exposed to aluminum. J Trace Elem Med Biol 18(1):113–121.15487771
*Elinder CG, Ahrengart L, Lidums V, 1991. Evidence of aluminum accumulation in aluminum welders. Br J Ind Med 48(11):735–738.1954151
Elliott JE. 2005. Trace metals, stable isotope ratios, and trophic relations in seabirds from the North Pacific Ocean. Environ Toxicol Chem 24(12):3099–3105.16445091
Ellis H, Scurr JH. 1979. Axillary hyperhidrosis - topical treatment with aluminium chloride hexahydrate. Postgrad Med J 55:868–869.548949
Elmore D, Phillips FM. 1987. Accelerator mass spectrometry for measurement of long-lived radioisotopes. Science 236:543–550.17740475
*Engelbrecht FM, Byers PD, Stacy BD, 1959. Tissue reactions to injected aluminum and alumina in the lungs and livers of mice, rats, guinea-pigs and rabbits. J Pathol Bacteriol 77:407–416.13642188
EPA. 1983a. Method 202.1: Aluminum (atomic absorption, direct aspiration). Methods for the chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600479020. http://web1.er.usgs.gov/nemi/method_pdf/5267.pdf. March 21, 2006.
EPA. 1983b. Method 202.2: Aluminum (AA, furnace technique). Methods for chemical analysis of water and wastes. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600479020. http://web1.er.usgs.gov/nemi/method_pdf/5268.pdf. March 21, 2006.
EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office. EPA600687008.
EPA. 1990. Interim methods for development of inhalation reference doses. Washington, DC: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment. EPA600888066F.
EPA. 1994a. Method 200.7: Inductively coupled plasma-atomic emission spectrometric method for trace element analysis of water and wastes. In: Methods for the determination of metals in environmental samples. Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R94111. http://web1.er.usgs.gov/nemi/method_pdf/4690.pdf. March 21, 2006.
EPA. 1994b. Method 200.8: Determination of trace elements in waters and wastes by inductively coupled plasma - mass spectrometry. In: Methods for the determination of metals in environmental samples. Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R94111. http://web1.er.usgs.gov/nemi/method_pdf/4665.pdf. March 21, 2006.
EPA. 1994c. Method 200.9: Trace elements in water, solids, and biosolids by stabilized temperature graphite furnace atomic absorption spectrometry. In: Methods for the determination of metals in environmental samples. Supplement 1. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600R94111. http://web1.er.usgs.gov/nemi/method_pdf/4797.pdf. March 21, 2006.
EPA. 1995. Toxic Chemical Release Inventory Reporting Form R and Instructions- Revised 1994 version. Washington, DC: Office of Pollution Prevention, U.S. Environmental Protection Agency. EPA745K95051.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. EPA630R96012.
EPA. 1998. Reregistration eligibility decision (RED): Al and Mg phosphide. Washington, DC: U.S. Environmental Protection Agency. EPA738R98017.
EPA. 2000. Method 6010C: Inductively coupled plasma-atomic emission spectrometry. In: Test methods for evaluating solid waste, physical/chemical methods. Washington, DC: U.S. Environmental Protection Agency. SW846. http://www.epa.gov/sw-846/pdfs/6010c.pdf. March 21, 2006.
EPA. 2003. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. EPA816F03016. http://www.epa.gov/safewater/mcl.html. March 07, 2006.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. Office of Environmental Information. EPA260B05001.
EPA. 2006a. Acute Exposure Guideline Levels (AEGLs) Washington, DC: U.S. Environmental Protection Agency, Office of Pollution Prevention and Toxics. http://www.epa.gov/oppt/aegl/chemlist.htm. March 07, 2006.
EPA. 2006b. Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 116.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr116.4.pdf. January 8, 2008.
EPA. 2006c. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.epa.gov/ttn/atw/orig189.html. March 07, 2006.
EPA. 2006d. Identification and listing of hazardous waste. Washington, DC: U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261, Appendix VIII. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006e. National recommended water quality criteria. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Office of Science and Technology. http://www.epa.gov/waterscience/criteria/nrwqc-2006.pdf. January 8, 2008.
EPA. 2006f. 2006 Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. EPA822R06013. http://www.epa.gov/waterscience/criteria/drinking/dwstandards.pdf. April 11, 2007.
EPA. 2006g. Pesticides classified for restricted use. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 152.175. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 07, 2006.
EPA. 2006h. Table 117.3. Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 117.3. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr117.3.pdf. January 8, 2008.
EPA. 2006i. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr302.4.pdf. January 08, 2008.
EPA. 2006j. Superfund, emergency planning, and community right-to-know programs. Extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006k. Toxic chemical release reporting: Community right-to-know. Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://a27.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf (http://a257.g.akamaitech.net/7/257/2422/22jul20061500/edocket.access.gpo.gov/cfr_2006/julqtr/pdf/40cfr372.65.pdf). January 08, 2008.
EPA. 2006l. Tolerances and exemptions from tolerances for pesticide chemicals in food. Aluminum hydroxide. Aluminum oxide. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.910. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2006m. Tolerances and exemptions from tolerances for pesticide chemicals in food. Aluminum sulfate. Phenol. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 180.920. http://www.epa.gov/epacfr40/chapt-I.info/chi-toc.htm. March 08, 2006.
EPA. 2008. National secondary drinking water regulations. Secondary maximum contaminant levels. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 143.3.http://www.epa.gov/lawsregs/search/40cfr.html. July 30, 2008.
Erasmus RT, Savory J, Wills MR, 1993. Aluminum neurotoxicity in experimental animals. Ther Drug Monit 15:588–592.8122299
Ermolenko LV, Dedkov YM. 1988. Photometric determination of aluminum in water with the sulfonitrazo DAF reagent. J Anal Chem USSR 43:815–820.
Exley C, Burgess E, Day JP, 1996. Aluminum toxicokinetics. J Toxicol Environ Health 48:569–584.8772799
Fairweather-Tait SJ, Faulks RM, Fatemi SJ A, 1987. Aluminium in the diet. Hum Nutr Food Sci Nutr 41F:183–192.
Farina M, Rotta LN, Soares FA, 2005. Hematological changes in rats chronically exposed to oral aluminum. Toxicology 209(1):29–37.15725511
FDA. 2002. Antacid products for over-the-counter (OTC) human use. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR Part 331, 222–226.
FDA. 2005. Beverages. Bottled water. U.S. Food and Drug Administration. Code of Federal Regulations. 21 CFR 165.110. http://a257.g.akamaitech.net/7/257/2422/01apr20051500/edocket.access.gpo.gov/cfr_2005/aprqtr/pdf/21cfr165.110.pdf. January 08, 2008.
FEDRIP. 2006. Aluminum. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Feinroth M, Feinroth MV, Berlyne GM. 1982. Aluminum absorption in the rat everted gut sac. Miner Electrolyte Metab 8(1):29–35.7167130
Fernandez de la Campa MR, Garcia MED, Sanz-Medel A. 1988. Room-temperature liquid phosphorimetry of the aluminum-ferron chelate in micellar media. Determination of aluminum. Anal Chim Acta 212:235–243.
Fernandez-Lorenzo JR, Cocho JA, Rey-Goldar ML, 1999. Aluminum contents of human milk, cow's milk, and infant formulas. J Pediatr Gastroenterol Nutr 28(3):270–275.10067727
Fernández-Martin JL, Canteros A, Serrano M, 1998. Prevention of aluminium exposure through dialysis fluids. Analysis of changes in the last 8 years. Nephrol Dial Transplant 13(Suppl 3):78–81.
Filipek LH, Nordstrom DK, Ficklin WH. 1987. Interaction of acid mine drainage with waters and sediments of West Squaw Creek in the West Shasta mining district, California. Environ Sci Technol 21:388–396.22280180
Fimreite N, Hansen OO, Pettersen HC. 1997. Aluminum concentrations in selected foods prepared in aluminum cookware, and its implications for human health. Bull Environ Contam Toxicol 58(1):1–7.8952918
Finberg L, Dweck HS, Holmes F, 1986. Aluminum toxicity in infants and children. Pediatrics 78:1150–1154.3786043
Finelli VN, Que Hee SS, Niemeier RW. 1981. Influence of exposure to aluminum chloride and fluoride dusts on some biochemical and physiological parameters in rats. In: Brown SS, Davies DS, eds. Organ-directed toxicity: Chemical indices and mechanisms. New York, NY: Pergamon Press, 291–295.
Fisher DW, Gambell AW, Likens GE, 1968. Atmospheric contributions to water quality of streams in the Hubbard Brook Experimental Forest, New Hampshire. Water Resour Res 4:1115–1126.
Flarend RE, Elmore D. 1997. Aluminium-26 as a biological tracer using accelerator mass spectrometry. In: Zatta PF, Alfrey AC, eds. Aluminum toxicity in infants health and disease. Singapore: World Scientific, 16–39.
Flarend R, Bin T, Elmore D, 2001. A preliminary study of the dermal absorption of aluminum from antiperspirants using aluminum-26. Food Chem Toxicol 39(2):163–168.11267710
Flarend RE, Hem SL, White JL, 1997. In vivo absorption of aluminum-containing vaccine adjuvants using 26Al. Vaccine 15(12–13)1314–1317.9302736
Flaten TP. 1990. Geographical associations between aluminum in drinking water and death rates with dementia (including Alzheimer's disease), Parkinson's disease and amyotrophic lateral sclerosis in Norway. Environ Geochem Health 12(1–2):152–167.24202581
Flaten TP. 2001. Aluminium as a risk factor in Alzheimer's disease, with emphasis on drinking water. Brain Res Bull 55(2):187–196.11470314
Flaten TP, Odegard M. 1988. Tea, aluminium and Alzheimer's disease. Food Chem Toxicol 26(11–12):959–960.3209136
Fleming J, Joshi JG. 1987. Ferritin: Isolation of aluminum-ferritin complex from brain. Proc Natl Acad Sci USA 84(22):7866–7870.3479769
Fleming RF, Lindstrom RM. 1987. Precise determination of aluminum by instrumental neutron activation. J Radioanal Nucl Chem 113:35–42.
Flendrig JA, Kruis H, Das HA. 1976. Aluminum intoxication: The cause of dialysis dementia? Proc Eur Dial Transplant Assoc 13:355–363.
Florence AL, Gauthier A, Ponsar C, 1994. An experimental animal model of aluminum overload. Neurodegeneration 3(4):315–323.7842302
Fomon SJ. 1966. Body composition of the infant. Part I: The male reference infant. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35:1169–1175.7081099
Forbes WF, Hayward LM, Agwani N. 1992. Geochemical risk factors for mental functioning, based on the Ontario Longitudinal Study of Aging (LSA). I. Results from a preliminary investigation. Can J Aging 13(2):269–281.
Forbes WF, McAiney CA, Hayward LM, 1994. Geochemical risk factors for mental functioning, based on the Ontario Longitudinal Study of Aging (LSA). II. The role of pH. Can J Aging 13(2):249–266.
Forster DP, Newens AJ, Kay DW K, 1995. Risk factors in clinically diagnosed presenile dementia of the Alzheimer type: A case-control study in northern England. J Epidemiol Commun Health 49(3):253–258.
Fraga CG, Oteiza PI, Golub MS, 1990. Effects of aluminum on brain lipid peroxidation. Toxicol Lett 51(2):213–219.2330606
Freda J, McDonald DG. 1990. Effects of aluminum on the leopard frog, rana pipiens: Life stage comparisons and aluminum uptake. Can J Fish Aquat Sci 47:210–216.
Frick KG, Herrmann J. 1990. Aluminum accumulation in a lotic mayfly at low pH-a laboratory study. Ecotoxicol Environ Saf 19:81–88.2311564
Froment DH, Buddington B, Miller NL, 1989a. Effect of solubility on the gastrointestinal absorption of aluminum from various aluminum compounds in the rat. J Lab Clin Med 114(3):237–242.2769017
Froment DPH, Molitoris BA, Buddington B, 1989b. Site and mechanism of enhanced gastrointestinal absorption of aluminum by citrate. Kidney Int 36(6):978–984.2601265
Fu HJ, Hu QS, Lin ZN, 2003. Aluminum-induced apoptosis in cultured cortical neurons and its effect on SAPK/JNK signal transduction pathway. Brain Res 980(1):11–23.12865155
Fuchs C, Brasche M, Paschen K, 1974. [Aluminum determination in serum by flameless atomic absorption.] Clin Chim Acta 52:71–80. (German)4827460
Gaffuri E, Donna A, Pietra R, 1985. Pulmonary changes and aluminum levels following inhalation of alumina dust: A study on four exposed workers. Med Lav 76(3):222–227.4046960
Gallego H, Lewis EJ, Crutchfield CE. 1999. Crystal deodorant dermatitis: Irritant dermatitis to alum-containing deodorant. Cutis 64(1):65–66.10431678
Gandolfi L, Stella MP, Zambenedetti P, 1998. Aluminum alters intracellular calcium homeostasis in vitro. Biochim Biophys Acta 1406(3):315–320.9630699
Ganrot PO. 1986. Metabolism and possible health effects of aluminum. Environ Health Perspect 65:363–441.2940082
Garbossa G, Galvez G, Castro ME, 1998. Oral aluminum administration to rats with normal renal function. 1. Impairment of erythropoiesis. Hum Exp Toxicol 17(6):312–317.9688354
Garbossa G, Gutnisky A, Nesse A. 1996. Depressed erythroid progenitor cell activity in aluminum-overloaded mice. Miner Electrolyte Metab 22(4):214–218.8807624
Gardiner PE, Stoeppler M. 1987. Optimisation of the analytical conditions for the determination of aluminum in human blood plasma and serum by graphite furnace atomic absorption spectrometry. Part 2. Assessment of the analytical method. J Anal Atom Spectrom 2:401–404.
Gardiner PE, Ottaway JM, Fell GS, 1981. Determination of aluminum in blood plasma or serum by electrothermal atomic absorption spectrometry. Anal Chim Acta 128:57–66.
Gardiner PE, Schierl R, Kreutzer K. 1987. Aluminum speciation in soil solutions as studied by size exclusion chromatography. Plant Soil 103(1):151–154.
Garruto RM, Shankar SK, Yanagihara R, 1989. Low-calcium, high-aluminum diet-induced motor neuron pathology in cynomolgus monkeys. Acta Neuropathol 78(2):210–219.2750490
Gauthier E, Fortier I, Courchesne F, 2000. Aluminum forms in drinking water and risk of Alzheimer's disease. Environ Res 84(3):234–246.11097797
Ghribi O, Dewitt DA, Forbes MS, 2001. Co-involvement of mitochondria and endoplasmic reticulum in regulation of apoptosis: Changes in cytochrome c, Bcl-2 and Bax in the hippocampus of aluminum-treated rabbits. Brain Res 903(1–2):66–73.11382389
*Gibbs GW. 1985. Mortality of aluminum reduction plant workers, 1950 through 1977. J Occup Med 27(10):761–770.4067680
Gibbs GW, Horowitz I. 1979. Lung cancer mortality in aluminum reduction plant workers. J Occup Med 21:347–353.469596
Gilks B, Churg A. 1987. Aluminum-induced pulmonary fibrosis: Do fibers play a role? Am Rev Respir Dis 136(1):176–179.3605831
Giordano R, Lombardi G, Ciaralli L, 1999. Major and trace and elements in sediments from Terra Nova Bay, Antartica. Sci Total Environ 227(1):29–40.
Gitelman HJ, Alderman FR, Kurs-Lasky M, 1995. Serum and urinary aluminum levels of workers in the aluminum industry. Ann Occup Hyg 39(2):181–191.7741415
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environ Health Perspect Suppl 101(2):65–71.
Goenaga X, Williams DJ A. 1988. Aluminum speciation in surface waters from a Welsh upland area. Environ Pollut 52:131–149.15092612
Goh CL. 1990. Aluminum chloride hexahydrate versus palmar hyperhidrosis. Evaporimeter assessment. Int J Dermatol 29(5):368–370.2361796
Golden NH, Rattner BA, McGowan PC, 2003. Concentrations of metals in feathers and blood of nestling Black-Crowned Night-Herons (Nycticorax mycticorax) in Chesapeake and Delaware Bays. Bull Environ Contam Toxicol 70(2):385–393.12545375
Golomb D, Ryan D, Eby N, 1997. Atmospheric deposition of toxics onto Massachusetts Bay-I. Metals. Atmos Environ 31:1349–1359.
Golub MS, Domingo JL. 1996. What we know and what we need to know about developmental aluminum toxicity. J Toxicol Environ Health 48(6):585–597.8772800
Golub MS, Germann SL. 1998. Aluminum effects on operant performance and food motivation of mice. Neurotoxicol Teratol 20(4):421–427.9697968
Golub MS, Germann SL. 2001. Long-term consequences of developmental exposure to aluminum in a suboptimal diet for growth and behavior of Swiss Webster mice. Neurotoxicol Teratol 23(4):365–372.11485839
Golub MS, Tarara RP. 1999. Morphometric studies of myelination in the spinal cord of mice exposed developmentally to aluminum. Neurotoxicology 20(3):953–959.10693976
Golub MS, Donald JM, Gershwin ME, 1989. Effects of aluminum ingestion on spontaneous motor activity of mice. Neurotoxicol Teratol 11(3):231–235.2755419
Golub MS, Germann SL, Han B, 2000. Lifelong feeding of a high aluminum diet to mice. Toxicology 150(1–3):107–117.10996667
Golub MS, Gershwin ME, Donald JM, 1987. Maternal and developmental toxicity of chronic aluminum exposure in mice. Fundam Appl Toxicol 8(3):346–357.3569705
Golub MS, Han B, Keen CL, 1992b. Effects of dietary aluminum excess and manganese deficiency on neurobehavioral endpoints in adult mice. Toxicol Appl Pharmacol 112(1):154–160.1733044
Golub MS, Han B, Keen CL, 1994. Auditory startle in Swiss Webster mice fed excess aluminum in diet. Neurotoxicol Teratol 16(4):423–425.7968944
Golub MS, Han B, Keen CL, 1995. Behavioral performance of Swiss Webster mice exposed to excess dietary aluminum during development or during development and as adults. Toxicol Appl Pharmacol 133(1):64–72.7597711
Golub MS, Han B, Keen CL. 1996. Iron and manganese uptake by offspring of lactating mice fed a high aluminum diet. Toxicology 109(2–3):111–118.8658542
Golub MS, Keen CL, Gershwin ME. 1992a. Neurodevelopmental effect of aluminum in mice: Fostering studies. Neurotoxicol Teratol 14(3):177–182.1635538
Golub MS, Takeuchi PT, Gershwin ME, 1993. Influence of dietary aluminum cytokine production by mitogen-stimulated spleen cells from Swiss Webster mice. Immunopharmacol Immunotoxicol 15(5):605–619.8301020
Gomez M, Domingo JL, Llobet JM, 1986. Short-term oral toxicity study of aluminum in rats. Arch Farmacol Toxicol 12(2–3):145–151.3619503
Gomez M, Domingo JL, Llobet JM. 1991. Developmental toxicity evaluation of oral aluminum in rats: Influence of citrate. Neurotoxicol Teratol 13(3):323–328.1886542
Gomez M, Esparza JL, Domingo JL, 1999. Chelation therapy in aluminum-loaded rats: Influence of age. Toxicology 137(3):161–168.10522496
Gomez M, Sanchez DJ, Llobet JM, 1997a. The effect of age on aluminum retention in rats. Toxicology 116(1–3):1–8.9020501
Gomez M, Sanchez DJ, Llobet JM, 1997b. Concentrations of some essential elements in the brain of aluminum-exposed rats in relation to the age of exposure. Arch Gerontol Geriatr 24:287–294.15374116
Gonzalez-Munoz MJ, Mesenguer I, Sanchez-Reus MI, 2007. Beer consumption reduces cerebral oxidation caused by aluminum toxicity by normalizing gene expression of tumor necrotic factor alpha and several antioxidant enzymes. Food Chem Toxicol 46(3):1111–1118.18096288
Goralewski G. 1947. [The aluminium lung: A new industrial disease.] Z Gesamte Inn Med 2:665–673. (German)
Gorsky JE, Dietz AA. 1978. Determination of aluminum in biological samples by atomic absorption spectrophotometry with a graphite furnace. Clin Chem 24:1485–1490.688606
Gorsky JE, Dietz AA, Spencer H, 1979. Metabolic balance of aluminum studied in six men. Clin Chem 25(10):1739–1743.476923
Gosink TA. 1975. Rapid simultaneous determination of picogram quantities of aluminum and chromium from water by gas phase chromatography. Anal Chem 47:165–168.
Goyens P, Brasseur D. 1990. Aluminum and infants. (Comment on: Pediatrics 84(6):1105–1107). Pediatrics 86(4):650–652.2216642
Grams GW. 1992. Aluminum compounds: Aluminum halides and aluminum nitrate. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 2: Alkanolamines to antibiotics (glycopeptides). New York, NY: John Wiley & Sons, Inc., 281–290.
Gräske A, Thuvander A, Johannisson A, 2000. Influence of aluminum on the immune system – an experimental study on volunteers. Biometals 13(2):123–133.11016399
Graves AB, Rosner D, Echeverria D, 1998. Occupational exposures to solvents and aluminum and estimated risk of Alzheimer's disease. Occup Environ Med 55:627–633.9861186
Graves AB, White E, Koepsell TD, 1990. The association between aluminum-containing products and Alzheimer's disease. J Clin Epidemiol 43:35–44.2319278
Greger JL. 1992. Dietary and other sources of aluminum intake. Aluminum in biology and medicine. Ciba Found Symp 169:26–49.1490425
Greger JL, Baier MJ. 1983. Excretion and retention of low or moderate levels of aluminum by human subjects. Food Chem Toxicol 21(4):473–477.6684629
Greger JL, Donnaubauer SE. 1986. Retention of aluminum in the tissues of rats after the discontinuation of oral exposure to aluminum. Food Chem Toxicol 24(12):1331–1334.3804136
Greger JL, Sutherland JE. 1997. Aluminum exposure and metabolism. Crit Rev Clin Lab Sci 34(5):439–474.9405895
Greger JL, Goetz W, Sullivan D. 1985. Aluminum levels in foods cooked and stored in aluminum pans, trays and foil. J Food Prot 48(9):772–777.30939687
Griswold WR, Reznik V, Mendoza SA 1983. Accumulation of aluminum in a nondialyzed uremic child receiving aluminum hydroxide. Pediatr 71(1):56–58.
Gross P, Harley RA Jr, deTreville RT P. 1973. Pulmonary reaction to metallic aluminum powders. Arch Environ Health 26:227–236.4696378
Guerold F, Giamberini L, Tourmann JL, 1995. Occurrence of aluminum in chloride cells of Perla marginata (plecoptera) after exposure to low pH and elevated aluminum concentration. Bull Environ Contam Toxicol 54:620–625.7767040
Guillard O, Fauconneau B, Olichon D, 2004. Hyperaluminemia in a woman using an aluminum-containing antiperspirant for 4 years. Am J Med 117(12):956–959.15629736
Guillard O, Tiphaneau K, Reiss D, 1984. Improved determination of aluminum in serum by electrothermal atomic absorption spectrometry and zeeman background correction. Anal Lett 17:1593–1605.
*Gupta SK, Waters DH, Gwilt PR. 1986. Absorption and disposition of aluminum in the rat. J Pharm Sci 75(6):586–589.3735104
Guzelian PS, Henry CJ, Olin SS, eds. 1992. Similarities and differences between children and adults: Implications for risk assessment. Washington, DC: International Life Sciences Institute Press.
Hackenberg U. 1972. Chronic ingestion by rats of standard diet treated with aluminum phosphide. Toxicol Appl Pharmacol 23:147–158.5071038
Haddad CM, Shannon MW, Winchester JF. 1998. Clinical management of poisoning and drug overdose. 3rd ed. Philadelphia, PA: WB Saunders, 186.
Halatek T, Sinczuk-Walczak H, Rydzynski K. 2005. Prognostic significance of low serum levels of Clara cell phospholipid-binding protein in occupational aluminium neurotoxicity. J Inorg Biochem 99(9):1904–1911.16099050
Halatek T, Trzcinka-Ochocka M, Matczak W, 2006. Serum Clara cell protein as an indicator of pulmonary impairment in occupational exposure at aluminum foundry. Int J Occup Med Environ Health 19(4):211–223.17402216
Hamdy RD. 1993. The accumulation of dietary aluminum by rainbow trout, Oncorhynchus mykiss, at high exposure concentrations. J Fish Biol 42:603–606.
Hamilton EI, Minski MJ, Cleary JJ. 1973. The concentration and distribution of some stable elements in healthy human tissues from the United Kingdom - an environmental study. Sci Total Environ 1(4):341–374.
Hänninen H, Matikainen E, Kovala T, 1994. Internal load of aluminum and the central nervous system function of aluminum welders. Scand J Work Environ Health 20(4):279–285.7801073
Harris WR, Messori L. 2002. A comparative study of aluminum(III), gallium(III), indium(III), and thallium(III) binding to human serum transferrin. Coord Chem Rev 228:237–262.
Hawkins NM, Coffey S, Lawson MS, 1994. Potential aluminum toxicity in infants fed special infant formula. J Pediatr Gastroenterol Nutr 19(4)377–381.7876989
HazDat. 2008. Aluminum. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/hazdat.html. June 19, 2008.
He SC, Qiao N, Sheng W. 2003. Neurobehavioral, autonomic nervous function and lymphocyte subsets among aluminum electrolytic workers. Int J Immunopathol Pharmacol 16(2):139–144.12797904
Hellou J, Fancey LL, Payne JF. 1992a. Concentrations of twenty-four elements in bluefin tuna, Thunnus thynnus from the Northwest Atlantic. Chemosphere 24(2):211–218.
Hellou J, Warren WG, Payne JF, 1992b. Heavy metals and other elements in three tissues of cod, Gadus morhua from the Northwest Atlantic. Mar Pollut Bull 24(9):452–458.
Henshaw PF, Bewtra JK, Biswas N. 1993. Occurrence of aluminum, lead, and trihalomethanes in drinking water from the Great Lakes. J Great Lakes Res 19:521–532.
Herbert A, Sterling G, Abraham J, 1982. Desquamative interstitial pneumonia in an aluminum welder. Hum Pathol 13(8):694–699.7106732
Hermenegildo C, Saez R, Minoia C, 1999. Chronic exposure to aluminum impairs the glutamate-nitric oxide-cyclic GMP pathway in the rat in vivo. Neurochem Int 34(3):245–253.10355491
*Hewitt CD, Innes DJ, Herman MM, 1992. Hematological changes after long-term aluminum administration to normal adult rabbits. Ann Clin Lab Sci 22(2):85–94.1562169
Heyman A, Wilkinson WE, Stafford JA, 1984. Alzheimer's disease: A study of epidemiological aspects. Ann Neurol 15(4):335–341.6742780
His E, Beiras R, Seaman MN, 1996. Sublethal and lethal toxicity of aluminum industry effluents to early developmental stages of the Crassostrea gigas oyster. Arch Environ Contam Toxicol 30:335–339.
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969–1986. J Natl Cancer Inst 84(5):313–320.1738181
Hoffman GL, Duce RA, Zoller WH. 1969. Vanadium, copper, and aluminum in the lower atmosphere between California and Hawaii. Environ Sci Technol 3:1207–1210.
Hohl C, Gerisch P, Korschinek G, 1994. Medical application of 26Al. Nucl Instr Meth Phys Res B 92:478–482.
Hosovski E, Mastelica Z, Sunderic D, 1990. Mental abilities of workers exposed to aluminum. Med Lav 81(2):119–123.2250607
Hostynek JJ, Hinz RS, Lorence CR, 1993. Metals and the skin. Crit Rev Toxicol 23:171–235.8329115
House RA. 1992. Factors affecting plasma aluminum concentrations in nonexposed workers. J Occup Med 34:1013–1017.1403189
Hovatta O, Venalainen E-R, Kuusimaki L, 1998. Aluminum, lead and cadmium concentrations in seminal plasma and spermatozoa, and semen quality in Finnish men. Hum Reprod 13(1):115–119.9512240
HSDB. 2008. Aluminum and compounds. Hazardous Substances Data Bank. Bethesda, MD: National Library of Medicine. http://toxnet.nlm.nih.gov/cgi-bin/sis/htmlgen?HSDB. January 9, 2008.
Huang JY, Wu MS, Wu CH. 2001. The effect of an iron supplement on serum aluminum level and desferrioxamine mobilization test in hemodialysis patients. Ren Fail 23(6):789–95.11777318
Hull MJ, Abraham JL. 2002. Aluminum welding fume-induced pneumoconiosis. Hum Pathol 33(8):819–825.12203215
IARC. 1984. Polynuclear aromatic compounds. Part 3: Industrial exposures in aluminum production, coal gasification, coke production, and iron and steel founding. Vol. 34. Lyon, France: World Health Organization, International Agency for Research on Cancer, 37–64.
IARC. 1987. Aluminum production. Overall evaluation of carcinogenicity: An updating of IARC monographs (Volumes 1 to 42). Supplement 7. Lyon, France: World Health Organization, International Agency for Research on Cancer, 89–91.
ICRP. 1994. Human respiratory tract model for radiological protection. ICRP publication 66. Oxford: Pergamon Press, 1–120.
*Ijomah G, Corrigan FM, Holliday J, 1993. Aluminum, cadmium, lipids and prevalence of dementia in people living near an aluminum smelter. Trace Elem Med 10:6–12.
Ikem A, Nwankwoala A, Odueyungbo S, 2002. Levels of 26 elements in infant formula from USA, UK, and Nigeria by microwave digestion and ICP-OES. Food Chem 77(4):439–447.
Imahori A, Fukushima I, Shiobara S, 1979. Multielement neutron activation analysis of human scalp hair. A local population survey in the Tokyo metropolitan area. J Radioanal Chem 52(1):167–180.
Iregren A, Sjogren B, Gustafsson K, 2001. Effect on the nervous system in different groups of workers exposed to aluminium. Occup Environ Med 58(7):453–460.11404450
IRIS. 2008. Aluminum phosphide. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. March 08, 2006.
Ittel TH, Buddington B, Miller NL, 1987. Enhanced gastrointestinal absorption of aluminum in uremic rats. Kidney Int 32(6):821–826.3430966
Jacqmin H, Commenges D, Letenneur L, 1994. Components of drinking water and risk of cognitive impairment in the elderly. Am J Epidemiol 139(1):48–57.8296774
Jacqmin-Gadda H, Commenges D, Letenneur L, 1996. Silica and aluminum in drinking water and cognitive impairment in the elderly. Epidemiology 7:281–285.8728442
James BR, Riha SJ. 1989. Aluminum leaching by mineral acids in forest soils: I. Nitric-sulfuric acid differences. Soil Sci Soc Am J 53:259–264.
Jansen S, Broadley MR, Robbrecht E, 2002. Aluminum hyperaccumulation in angiosperms: A review of its phylogenetic significance. Bot Rev 68(2):235–269.
Jederlinic PJ, Abraham JL, Churg A, 1990. Pulmonary fibrosis in aluminum oxide workers. Investigation of nine workers with pathologic examination and microanalysis in three of them. Am Rev Respir Dis 142:1179–1184.2240841
Jeffery EH, Abreo K, Burgess E, 1996. Systemic aluminum toxicity: Effects on bone, hematopoietic tissue, and kidney. J Toxicol Environ Health 48(6):649–665.8772804
Jephcott CM. 1948. Fume exposure in the manufacture of alumina abrasives. Occup Med 5:701–709.18124573
Jernelov A. 1971. Phosphate reduction in lakes by precipitation with aluminum sulphate. In: Jenkins SH, ed. Advances in water pollution research: Proceedings of the Fifth International Conference held in San Francisco and Hawaii, 1970. New York, NY: Pergamon Press, I-15/1 to I-15/6.
Jing Y, Wang Z, Song Y. 2004. Quantitative study of aluminum-induced changes in synaptic ultrastructure in rats. Synapse 52(4):292–298.15103695
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs cerebral cortex. Brain Res 190:3–16.6769537
Johnson VJ, Kim SH, Sharma RP. 2005. Aluminum-maltolate induces apoptosis and necrosis in Neuro-2a cells: Potential role for p53 signaling. Toxicol Sci 83(2):329–339.15537749
Jones KC, Bennett BG. 1986. Exposure of man to environmental aluminum-An exposure commitment assessment. Sci Total Environ 52(1–2):65–82.3726522
Jope RS, Johnson GVW. 1992. Neurotoxic effects of dietary aluminum. Aluminum in biology and medicine. Ciba Found Symp 169:254–267.1337035
*Jordan JW. 1961. Pulmonary fibrosis in a worker using an aluminum powder. Br J Ind Med 18:21–23.
Joshi SP, Toma RB, Medora N, 2003. Detection of aluminum residue in sauces packaged in aluminum pouches. Food Chem 83(3):383–386.
Jouhanneau P, Lacour B, Raisbeck G, 1993. Gastrointestinal absorption of aluminum in rats using 26Al and accelerator mass spectrometry. Clin Nephrol 40(4):244–248.8261684
Jouhanneau P, Raisbeck GM, Yiou F, 1997. Gastrointestinal absorption, tissue retention, and urinary excretion of dietary aluminum in rats determined by using 26 Al. Clin Chem 43(6 Part 1):1023–1028.
Jugdaohsingh R, Reffitt DM, Oldham C, 2000. Oligomeric but not monomeric silica prevents aluminum absorption in humans. Am J Clin Nutr 71(4):944–949.10731501
Julka D, Gill KD. 1995. Development of a possible peripheral marker for aluminum neurotoxicity. Med Sci Res 23:311–314.
Julka D, Vasishta RK, Gill KD. 1996. Distribution of aluminum in different brain regions and body organs of rat. Biol Trace Elem Res 52(2):181–192.8773759
Jyoti A, Sharma D. 2006. Neuroprotective role of Bacopa monniera extract against aluminium-induced oxidative stress in the hippocampus of the brain. Neurotoxicology 27(4):451–457.16500707
Kabata-Pendias A, Pendias H, eds. 1984. Trace elements in soils and plants. Boca Raton, FL: CRC Press, Inc., 134–136.
Kada T, Hirano K, Shirasu Y. 1980. Screening of environmental chemical mutagens by the rec-assay system with Bacillus subtilis. Chem Mutagen 6:149–173.
Kaehny WD, Hegg AP, Alfrey AC. 1977. Gastrointestinal absorption of aluminum from aluminum-containing antacids. N Engl J Med 296(24):1389–1390.859546
Kaizer RR, Correa MC, Spanevello RM, 2005. Acetylcholinesterase activation and enhanced lipid peroxidation after long-term exposure to low levels of aluminum on different mouse brain regions. J Inorg Biochem 99(9):1865–1870.16055195
*Kandiah J, Kies C. 1994. Aluminum concentrations in tissues of rats: Effect of soft drink packaging. BioMetals 7(1):57–60.8118174
Kanematsu N, Hara M, Kada T. 1980. Rec assay and mutagenicity studies on metal compounds. Mutat Res 77:109–116.6769036
Karlik SJ, Eichhorn GL, Crapper-McLachlan DR. 1980. Molecular interactions of aluminum with DNA. Neurotoxicology 1:83–88.
Katz AC, Frank DW, Sauerhoff MW, 1984. A 6-month dietary toxicity study of acidic sodium aluminum phosphate in beagle dogs. Food Chem Toxicol 22(1):7–9.6537941
Keeler R. 1991. ICP mass spectrometry shows its mettle. Res Dev 33:44–48.
Keirsse H, Smeyers-Verbeke J, Verbeelen D, 1987. Critical study of the speciation of aluminum in biological fluids by size-exclusion chromatography and electrothermal atomic absorption spectrometry. Anal Chim Acta 196:103–114.
Khanna P, Nehru B. 2007. Antioxidant enzymatic system in neuronal and glial cells enriched fractions of rat brain after aluminum exposure. Cell Mol Neurobiol 27(7):959–969.18041579
Khosla SN, Nand N, Khosla P. 1988. Aluminum phosphide poisoning. J Trop Med Hyg 91:196–198.3404567
Kiesswetter E, Schoeper M, Buchta M, 2007. Longitudinal study on potential neurotoxic effects of aluminium: I. Assessment of exposure and neurobehavioural performance of Al welders in the train and truck construction industry over 4 years. Int Arch Occup Environ Health 81(1):41–67.17522885
Kilburn KH. 1998. Pulmonary and neurological effects of aluminum. In: Rom WN, ed. Environmental and occupational medicine. Philadelphia, PA: Lippincott-Raven, 1065–1073.
King SW, Savory J, Wills MR. 1981. The clinical biochemistry of aluminum. CRC Crit Rev Clin Lab Sci 14:1–20.
Kinney PL, Chillrud SN, Ramstrom S, 2002. Exposures to multiple air toxics in New York City. Environ Health Perspect 110(Suppl 4):539–546.12194883
*Kirsner JB. 1942. The effect of calcium carbonate, aluminum phosphate, and aluminum hydroxide on mineral excretion in man. J Clin Invest 22:47–52.
Kislinger G, Steinhausen C, Alvarez-Bruckmann M, 1997. Investigations of the human aluminium biokinetics with 26Al and AMS. Nucl Instrum Methods Phys Res B 123:259–265.
Klein GL, Snodgrass WR, Griffin MP, 1989. Hypocalcemia complicating deferoxamine therapy in an infant with parenteral nutrition-associated aluminum overload: Evidence for a role of aluminum in the bone disease of infants. J Pediatr Gastroenterol Nutr 9:400–403.2515268
Klosterkotter W. 1960. Effects of ultramicroscopic gamma-aluminum oxide on rats and mice. AMA Arch Ind Health 21:458–472.14409972
*Kobayashi N, Ide G, Katsuki H, 1968. Effects of aluminum compound on the development of experimental lung tumor in mice. Jpn J Cancer Res 59:433–436.
Kobayashi S, Fujiwara S, Arimoto S, 1989. Hair aluminium in normal aged and senile dementia of Alzheimer type. Prog Clin Biol Res 317:1095–1109.2602406
Koch KR, Pougnet MA B, De Villiers S. 1989. Determination of aluminium levels in tea and coffee by inductively coupled plasma optical emission spectrometry and graphite furnace atomic absorption spectrometry. Analyst 114:911.
Kohila T, Parkkonen E, Tahti H. 2004. Evaluation of the effects of aluminum, ethanol and their combination on rat brain synaptosomal integral proteins in vitro and after 90-day oral exposure. Arch Toxicol 78(5):276–282.15254985
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human liver. Biochemistry 29:4430–4433.2350547
Konishi Y, Yagyu K, Kinebuchi H, 1996. Chronic effect of aluminum ingestion on bone in calcium-deficient rats. Pharmacol Toxicol 78:429–434.8829206
Koo WWK, Kaplan LA, Bendon R, 1986. Response to aluminum in parenteral nutrition during infancy. J Pediatr 109(5):877–883.3095522
Koo WWK, Kaplan LA, Krug-Wispe SK. 1988. Aluminum contamination of infant formulas. J Parenter Enteral Nutr 12(2):170–173.
Koo WWK, Krug-Wispe SK, Succop P, 1992. Sequential serum aluminum and urine aluminum: Creatinine ratio and tissue aluminum loading in infants with fractures/rickets. Pediatrics 89(5 Part 1):877–881.1579398
Korogiannos C, Babatsikou F, Tzimas S, 1998. Aluminum compounds and occupational lung disease. Eur Respir J 12(Suppl 28):139S.
*Kovalchik MT, Kaehny WD, Hegg AP, 1978. Aluminum kinetics during hemodialysis. J Lab Clin Med 92:712–720.712205
Kowalczyk GS, Gordon GE, Rheingrover SW. 1982. Identification of atmospheric particulate sources in Washington, DC, using chemical element balances. Environ Sci Technol 16:79–90.
Krantzberg G, Stokes PM. 1990. Metal concentrations and tissues distribution in larvae of Chironomus with reference to x-ray m icroprobe analysis. Arch Environ Contam Toxicol 19:84–93.
Krasovskii GN, Vasukovich LY, Chariev OG. 1979. Experimental study of biological effects of lead and aluminum following oral administration. Environ Health Perspect 30:47–51.446457
Kraus T, Schaller KH, Angerer J, 2000. Aluminum dust-induced lung disease in the pyro-powder-producing industry: Detection by high-resolution computed tomography. Int Arch Occup Environ Health 73(1):61–64.10672493
Krishnan K, Andersen ME. 1994. Physiologically-based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Andersen ME, Clewell H, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang R, ed. Toxicology of chemical mixtures. New York: Academic Press, 399–437.
Lal B, Gupta A, Gupta A, 1993. Aluminum ingestion alters behaviour and some neurochemicals in rats. Indian J Exp Biol 31(1):30–35.8500814
Lansdown AB. 1973. Production of epidermal damage in mammalian skins by some simple aluminum compounds. Br J Dermatol 89:67–76.4788320
Lantzy RJ, MacKenzie FT. 1979. Atmospheric trace metals: Global cycles and assessment of man's impact. Geochim Cosmochim Acta 43(4):511–525.
Lauricella AM, Garbossa G, Nesse A. 2001. Dissimilar behavior of lymph cells in response to the action of aluminum. In vitro and in vivo studies. Int Immunopharmacol 1(9–10):1725–1732.11562064
Leblondel G, Allain P. 1980. Blood and brain aluminum concentrations in mice after intraperitoneal injection of different aluminum compounds. Res Commun Chem Pathol Pharmacol 27(3):579–586.7384646
Lee RE Jr, Von Lehmden DJ. 1973. Trace metal pollution in the environment. J Air Pollut Control Assoc 23(1):853–857.4746266
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44:55–77.9057784
LeGendre GR, Alfrey AC. 1976. Measuring picogram amounts of aluminum in biological tissue by flameless atomic absorption analysis of a chelate. Clin Chem 22:53–56.812616
Leikin JB, Paloucek FP. 2002. Leikin and Paloucek’s poisoning and toxicology handbook. 3rd ed. Hudson, OH: Lexi-Comp, Inc., 214–217.
Letterman RD, Driscoll CT. 1988. Survey of residual aluminum in filtered water. J Am Water Works Assoc 80(4):154–158.
Letzel S, Schaller KH, Angerer J, 1996. Biological monitoring of occupational aluminium powder exposure. Occup Hyg 3:271–280.
Leung H-W. 1993. Physiologically-based pharmacokinetic modelling. In: Ballentine B, Marro T, Turner P, eds. General and applied toxicology. New York: Stockton Press, 153–164.
Lewis C, Macias ES. 1980. Composition of size-fractionated aerosol in Charleston, West Virginia. Atmos Environ 14:185–194.
Lewis RJ, ed. 2001. Hawley's condensed chemical dictionary. New York, NY: John Wiley & Sons, Inc., 39–46, 118, 555.
Liao YH, Yu HS, Ho CK, 2004. Biological monitoring of exposures to aluminium, gallium, indium, arsenic, and antimony in optoelectronic industry workers. J Occup Environ Med 46(9):931–936.15354058
Lichte FE, Hopper S, Osborn TW. 1980. Determination of silicon and aluminum in biological matrices by inductively coupled plasma emission spectrometry. Anal Chem 52(1):120–124.7356170
Lide DR, ed. 2005. CRC handbook of chemistry and physics. New York, NY: CRC Press, 4–3 to 4–4, 4–44 to 4–46, 4–79.
Lim B, Jickells TD. 1990. Dissolved, particulate and acid-leachable trace metal concentrations in North Atlantic precipitation collected on the Global Change expedition. Global Biogeochem Cycles 4:445–458.
Lin JL, Yang YJ, Yang SS, 1997. Aluminum utensils contribute to aluminum accumulation in patients with renal disease. Am J Kidney Dis 30:653–665.9370180
Lione A. 1983. The prophylactic reduction of aluminum intake. Food Chem Toxicol 21(1)103–109.6337934
Lione A. 1985a. Aluminum intake from non-prescription drugs and sucralfate. Gen Pharmacol 16(3):223–228.3839482
Lione A. 1985b. Aluminum toxicology and the aluminum-containing medications. Pharmacol Ther 29(2):255–285.3915094
Lione A, Allen PV, Smith JC. 1984. Aluminum coffee percolators as a source of dietary aluminum. Food Chem Toxicol 22(4):265–268.6539273
Liss L, Thornton DJ. 1986. The rationale for aluminum absorption control in early stages of Alzheimer's disease. Neurobiol Aging 7(6):552–554.
Litaor MI. 1987. Aluminum chemistry: Fractionation, speciation, and mineral equilibria of soil interstitial waters of an alpine watershed, Front Range, Colorado. Geochim Cosmochim Acta 51:1285–1295.
Litov RE, Sickles VS, Chan GM, 1989. Plasma aluminum measurements in term infants fed human milk or a soy-based infant formula. (Comment in: Pediatrics 86(4):650–652). Pediatrics 84(6):1105–1107.2587141
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2–3):301–324.351201
Ljunggren KG, Lidums V, Sjogren B. 1991. Blood and urine concentrations of aluminum among workers exposed to aluminum flake powders. Br J Ind Med 48:106–109.1998604
Llansola M, Minana MD, Montoliu C, 1999. Prenatal exposure to aluminum reduces expression of neuronal nitric oxide synthase and of soluble guanylate cyclase and impairs glutamatergic neurotransmission in rat cerebellum. J Neurochem 73(2):712–718.10428068
Llobet JM, Domingo JL, Gomez M, 1987. Acute toxicity studies of aluminum compounds: Antidotal efficacy of several chelating agents. Pharmacol Toxicol 60:280–283.3588526
Lopez FF, Cabrera C, Lorenzo ML, 1998. Aluminium levels in wine, beer and other alcoholic beverages consumed in Spain. Sci Total Environ 220(1):1–9.9800382
López FF, Cabrera C, Lorenzo ML, 2000. Aluminium levels in spices and aromatic herbs. Sci Total Environ 257(2–3):191–197.10989928
Lovell MA, Ehmann WD, Markesbery WR. 1993. Laser microprobe analysis of brain aluminum in Alzheimer's disease. Ann Neurol 33(1):36–42.8257483
Lowe TP, Day DD. 2002. Metal concentrations in zebra mussels and sediments from embayments and riverine environments of eastern Lake Erie, southern Lake Ontario, and the Niagara River. Arch Environ Contam Toxicol 43(3):301–308.12202926
Ma LQ, Tan F, Harris WG. 1997. Concentrations and distributions of eleven metals in Florida soils. J Environ Qual 26:769–775.
Macdonald TL, Martin RB. 1988. Aluminum ion in biological systems. Trends Biochem Sci 13(1):15–19.3072691
Madigosky SR, Alvarez-Hernandez X, Glass J. 1991. Lead, cadmium, and aluminum accumulation in the Red Swamp crayfish (Procambarus clarkii g.) collected from roadside drainage ditches in Louisiana. Arch Environ Contam Toxicol 20:253–258.2015001
MAFF. 1999. MAFF UK - 1997 Total diet study: Aluminium, arsenic, cadmium, chromium, copper, lead, mercury, nickel, selenium, tin and zinc. Ministry of Agriculture, Fisheries and Food. Joint Food Safety and Standards Group. Food Surveillance Information Sheet Number 191. http://archive.food.gov.uk/maff/archive/food/infsheet/1999/no191/191tds.htm. June 06, 2006.
Mahieu S, Calvo ML, Millen N, 1998. Crecimiento y metabolismo del calcio en ratas sometidas a intoxicacion cronica con hidroxido de aluminio. Acta Physiol Pharmacol Ther Latinoam 48:32–40.9504191
Mahieu S, Millen N, Contini Mdel C, 2006. Urinary concentrating mechanism and Aquaporin-2 abundance in rats chronically treated with aluminum lactate. Toxicology 223(3):209–218.16675087
Mahieu S, Millen N, Gonzalez M, 2005. Alterations of the renal function and oxidative stress in renal tissue from rats chronically treated with aluminum during the initial phase of hepatic regeneration. J Inorg Biochem 99:1858–1864.16129492
Mahieu ST, Gionotti M, Millen N, 2003. Effect of chronic accumulation of aluminum on renal function, cortical renal oxidative stress and cortical renal organic anion transport in rats. Arch Toxicol 77(11):605–612.12928767
Main J, Ward MK. 1992. Potentiation of aluminum absorption by effervescent analgesic tablets in a haemodialysis patient. Br Med J 304(6843):1686.1633526
Maitani T, Kubota H, Hori N, 1994. Distribution and urinary excretion of aluminum injected with several organic acids into mice: Relationship with chemical state in serum studied by the HPLC-ICP method. J Appl Toxicol 14(4):257–261.7963237
Makjanic J, McDonald B, Chen CPLH, 1998. Absence of aluminum in neurofibrillary tangles in Alzheimer's disease. Neurosci Lett 240(3):123–126.9502219
Malakoff D. 2000. Public health. Aluminum is put on trial as a vaccine booster. Science 288(5470):1323–1234.10847840
Mameli O, Caria MA, Melis P, 2006. Effect of aluminum consumption on the vestibulo-ocular reflex. Metab Brain Dis 21(2–3):89–107.16855873
Mandić ML, Grgic J, Grgic Z, 1995. Aluminum levels in human milk. Sci Total Environ 170:165–170.7481740
Manna GK, Das RK. 1972. Chromosome aberrations in mice induced by aluminum chloride. Nucleus 15:180–186.
Markesbery WR, Ehmann WD, Alauddin M, 1984. Brain trace element concentrations in aging. Neurobiol Aging 5:19–28.6738782
Markesbery WR, Ehmann WD, Hossain TI M, 1981. Instrumental neutron activation analysis of brain aluminum in Alzheimer disease and aging. Ann Neurol 10:511–516.7325600
Martell AE, Motekaitis RJ. 1989. Coordination chemistry and speciation of Al (III) in aqueous solution. In: Lewis TE, ed. Environmental chemistry and toxicology of aluminum. Chelsea, MI: Lewis Publishers, Inc., 3–17.
Martin RB. 1986. The chemistry of aluminum as related to biology and medicine. Clin Chem 32(10):1797–1806.3019589
Martino FAR, Fernandez-Sanchez ML, Sanz-Medel A. 2000. Total determination of essential and toxic elements in milk whey by double focusing ICP-MS. J Anal Atom Spectrom 15(2):163–168.
Martyn CN, Coggon DN, Inskip H, 1997. Aluminum concentrations in drinking water and risk of Alzheimer’s disease. Epidemiol 8:281–286.
Martyn CN, Osmond C, Edwardson JA, 1989. Geographical relation between Alzheimer's disease and aluminum in drinking water. Lancet 1(8629):59–62.2562879
Marumo F, Tsukamoto Y, Iwanami S, 1984. Trace element concentrations in hair, fingernails and plasma of patients with chronic renal failure on hemodialysis and hemofiltration. Nephron 38:267–272.6514076
Marzin DR, Phi HV. 1985. Study of the mutagenicity of metal derivatives with Salmonella-typhimurium TA102m. Mutat Res 155(1–2):49–51.3881664
*Mayor GH, Burnatowska-Hledin MA. 1983. Impaired renal function and aluminum metabolism. Fed Proc 42:2979–2983.6617895
Mayor GH, Lohr TO, Sanchez TV, 1985. Aluminum metabolism and toxicity in renal failure: A review. J Environ Pathol Toxicol Oncol 6(1):43–50.3906081
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2–3):135–149.1387742
McCormack KM, Ottosen LD, Sanger VL, 1979. Effect of prenatal administration of aluminum and parathyroid hormone on fetal development in the rat (40493). Proc Soc Exp Biol Med 161:74–77.441074
McDermott JR, Smith AI, Iqbal K, 1979. Brain aluminum in aging and Alzheimer disease. Neurology 29(6):809–814.572003
McDermott JR, Smith AI, Ward MK, 1978. Brain-aluminum concentration in dialysis encephalopathy. Lancet 1(8070):901–904.76845
McDonald DG, Wood CM, Rhem RG, 1991. Nature and time course of acclimation to aluminum in juvenile brook trout (Salvelinus fontinalis). 1. Physiology. Can J Fish Aquat Sci 48:2006–2015.
McDowell I, Hill G, Lindsay J, 1994. The Canadian study of health and aging: Risk factors for Alzheimer's disease in Canada. Neurology 44:2073–2080.7969962
McKeever SWS, Moscovitch M, Townsend PD, eds. 1995. Aluminum oxide. Thermoluminescence dosimetry materials: Properties and uses. Kent, England: Nuclear Technology Publishing, 117–132.
McLachlan DRC, Bergeron C, Smith JE, 1996. Risk for neuropathologically confirmed Alzheimer's disease and residual aluminum in municipal drinking water employing weighted residential histories. Neurology 46(2):401–405.8614502
McLaughlin AIG, Kazantzis G, King E, 1962. Pulmonary fibrosis and encephalopathy associated with the inhalation of aluminum dust. Br J Ind Med 19:253–263.13932137
Meiklejohn A, Posner E. 1957. The effect of the use of calcined alumina in china biscuit placing on the health of the workman. Br J Ind Med 14:229–231.13471866
Menounou N, Presley BJ. 2003. Mercury and other trace elements in sediment cores from central Texas lakes. Arch Environ Contam Toxicol 45(1):11–29.12948169
Meyer-Baron M, Schaper M, Knapp G, 2007. Occupational aluminum exposure: Evidence in support of its neurobehavioral impact. Neurotoxicology 28(6):1068–1078.17692380
Michel P, Commenges D, Dartigues JF, 1990. Study of the relationship between Alzheimer's disease and aluminum in drinking water. Neurobiol Aging 11:264.
Migliore L, Cocchi L, Nesti C, 1999. Micronuclei assay and FISH analysis in human lymphocytes treated with six metal salts. Environ Mol Mutagen 34(4):279–284.10618176
Milham S Jr. 1979. Mortality in aluminum reduction plant workers. J Occup Med 21(7):475–480.469612
Miller RG, Kopfler FC, Kelty KC, 1984a. The occurrence of aluminum in drinking water. J Am Water Works Assoc 76:84–91.
Miller RR, Churg AM, Hutcheon M, 1984b. Pulmonary alveolar proteinosis and aluminum dust exposure. Am Rev Respir Dis 130(2):312–315.6465685
Milliner DS, Malekzadeh M, Lieberman E, 1987. Plasma aluminum levels in pediatric dialysis patients: Comparison of hemodialysis and continuous ambulatory peritoneal dialysis. Mayo Clin Proc 62(4):269–274.3561041
Misawa T, Shigeta S. 1992. Behavioral effects of repeated aluminum administration in the rat. Tokai J Exp Clin Med 17:155–159.1343422
Missel JR, Schetinger MR, Gioda CR, 2005. Chelating effect of novel pyrimidines in a model of aluminum intoxication. J Inorg Biochem 99(9):1853–1857.16098596
Mitchell J, Manning GB, Molyneux M, 1961. Pulmonary fibrosis in workers exposed to finely powdered aluminum. Br J Ind Med 18:10–20.13771334
Molitoris BA, Froment DH, Mackenzie TA, 1989. Citrate: A major factor in the toxicity of orally administered aluminum compounds. Kidney Int 36:949–953.2689754
Molloy DW, Standish TI, Nieboer E, 2007. Effects of acute exposure to aluminum on cognition in humans. J Toxicol Environ Health A 70(23):2011–2019.17966072
*Monteagudo FSE, Isaacson LC, Wilson G, 1988. Aluminum excretion by the distal tubule of the pig kidney. Nephron 49(3):245–250.3398986
Montoliu C, Felipo V. 2001. Aluminum interferes with NMDA receptor-associated signal transduction and with the process of glutamate neurotoxicity in cerebellar neurons in culture. Neurotoxicology 22(4):535.
Moomaw JC, Nakamura MT, Sherman GD. 1959. Aluminum in some Hawaiian plants. Pac Sci 13:335–341.
Moreno A, Dominguez C, Ballabriga A. 1994. Aluminum in the neonate related to parenteral nutrition. Acta Paediatr 83(1):25–29.8193468
Morris CM, Candy JM, Oakley AE, 1989. Comparison of the regional distribution of transferrin receptors and aluminium in the forebrain of chronic renal dialysis patients. J Neurol Sci 94:295–306.2614472
Morrow PE. 1988. Possible mechanisms to explain dust overloading of the lungs. Fundam Appl Toxicol 10:369–384.3286345
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants. Clin Pharmacokin 5:485–527.
Moshtaghie AA, Skillen AW. 1986. Binding of aluminum to transferrin and lactoferrin. Biochem Soc Trans 14:916–917.
Moyers JL, Ranweiler LE, Hopf SB, 1977. Evaluation of particulate trace species in Southwest desert atmosphere. Environ Sci Technol 11(8):789–795.
Mulder J, Vanbreemen N, Eijck HC. 1989. Depletion of soil aluminum by acid deposition and implications for acid neutralization. Nature 337:247–249.
Muller G, Bernuzzi V, Desor D, 1990. Developmental alterations in offspring of female rats orally intoxicated by aluminum lactate at different gestation periods. Teratology 42(3):253–261.2274891
*Muller G, Burnel D, Gery A, 1993a. Element variations in pregnant and nonpregnant female rats orally intoxicated by aluminum lactate. Biol Trace Elem Res 39:211–219.7509178
Muller G, Hutin M-F, Burnel D, 1992. Aluminum transfer through milk in female rats intoxicated by aluminum chloride. Biol Trace Elem Res 34(1):79–87.1382524
Muller JP, Steinegger A, Schlatter C. 1993b. Contribution of aluminum from packaging m aterials and cooking utensils to the daily aluminum intake. Z Lebensm Unters Forsch 197(4):332–341.8249476
Müller M, Anke M, Illing-Gunther. 1998. Aluminium in foodstuffs. Food Chem 64(4):419–428.
Mundy WR, Freudenrich T, Shafer TJ, 1995. In vitro aluminum inhibition of brain phosphoinositide metabolism: Comparison of neonatal and adult rats. Neurotoxicology 16:35–44.7603643
Munoz DG. 1998. Is exposure to aluminum a risk factor for the development of Alzheimer disease?— No. Arch Neurol 55(5):737–739.9605734
Mur JM, Moulin JJ, Meyer-Bisch C, 1987. Mortality of aluminum reduction plant workers in France. Int J Epidemiol 16:257–264.3610453
Musk AW, deKlerk NH, Beach JR, 2000. Respiratory symptoms and lung function in alumina refinery employees. Occup Environ Med 57(4):279–283.10810116
Musk AW, Greeville HW, Tribe AE. 1980. Pulmonary disease from occupational exposure to an artificial aluminum silicate used for cat litter. Br J Ind Med 37(4):367–372.7448131
Mussi I, Calzaferri G, Buratti M, 1984. Behaviour of plasma and urinary aluminum levels in occupationally exposed subjects. Int Arch Occup Environ Health 54(2):155–161.6480123
Nagy S, Nikdel S. 1986. Tin, iron and aluminum contents of commercially canned single-strength grapefruit juice stored at varying temperatures. J Agric Food Chem 34:588–593.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Navarro-Blasco I, Alvarez-Galindo JI. 2003. Aluminum content of Spanish infant formula. Food Addit Contam 20(5):470–481.12775466
Nayak P. 2002. Aluminum: Impacts and disease. Environ Res 89(2):101–115.12123643
Naylor KE, Eastell R, Shattuck KE, 1999. Bone turnover in preterm infants. Pediatr Res 45(3):363–363.10088655
Nedzvetsky VS, Tuzcu M, Yasar A, 2006. Effects of vitamin E against aluminum neurotoxicity in rats. Biochemistry 71(3):239–244.16545059
Nehru B, Anand P. 2005. Oxidative damage following chronic aluminium exposure in adult and pup rat brains. J Trace Elem Med Biol 19(2–3):203–208.16325537
Nehru B, Bhalla P. 2006. Reversal of an aluminium induced alteration in redox status in different regions of rat brain by administration of centrophenoxine. Mol Cell Biochem 290(1–2):185–191.16969688
Nehru B, Bhalla P, Garg A, 2007. Further evidence of centrophenoxine mediated protection in aluminum exposed rats by biochemical and light microscopy analysis. Food Chem Toxicol 45(12):2499–2505.17688990
Nelson WO, Campbell PGC. 1991. The effects of acidification on the geochemistry of Al, Cd, Pb, and Hg in freshwater environments: A literature review. Environ Pollut 71:91–130.15092117
Neri LC, Hewitt D. 1991. Aluminum, Alzheimer's disease, and drinking water. Lancet 338(8763):390.
Nieboer E, Gibson BL, Oxman AD, 1995. Health effects of aluminum: A critical review with emphasis on aluminum in drinking water. Environ Rev 3(1):29–81.
*Nielsen FH, Shuler TR, Zimmerman TJ, 1988. Dietary magnesium, manganese and boron affect the response of rats to high dietary aluminum. Magnesium 7(3):133–147.3185013
NIH. 2004. Aluminum compounds: Household products database. National Institutes of Health. U.S. National Library of Medicine. http://hpd.nlm.nih.gov/cgi-bin/household/search. March 15, 2006.
NIOSH. 1991. National occupational exposure survey m atrix. Cincinnati, OH: Department of Health and Human Services, National Institute for Occupational Safety and Health. December 11, 1996.
NIOSH. 1994. Method 7013: Aluminum and compounds, as Al. NIOSH manual of analytical methods (NMAM). Washington, DC: National Institute for Occupational Safety and Hazards. http://www.cdc.gov/niosh/nmam/pdfs/7013.pdf. March 21, 2006.
NIOSH. 1997. Aluminum phosphide. International chemical safety cards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/ipcsneng/neng0472.html. March 22, 2006.
NIOSH. 2003a. Method 7300: Elements by ICP (nitric/perchloric acid ashing). NIOSH manual of analytical methods (NMAM). Cincinnati, OH: National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication 94–113. http://www.cdc.gov/niosh/nmam/pdfs/7300.pdf. March 21, 2006.
NIOSH. 2003b. Method 7303: Elements by ICP (hot block/HCl/HNO3 digestion). NIOSH manual of analytical methods (NMAM). Washington, DC: National Institute for Occupational Safety and Hazards. http://www.cdc.gov/niosh/nmam/pdfs/7303.pdf. March 21, 2006.
NIOSH. 2003c. Method 7301: Elements by ICP (aqua regia ashing). NIOSH manual of analytical methods (NMAM). Washington, DC: National Institute for Occupational Safety and Hazards. http://www.cdc.gov/niosh/nmam/pdfs/7301.pdf. March 21, 2006.
NIOSH. 2005. Aluminum and aluminum oxide. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention. http://www.cdc.gov/niosh/npg/. January 14, 2008.
Nishioka H. 1975. Mutagenic activities of metal compounds in bacteria. Mutat Res 31:185–189.805366
Nolte E, Beck E, Winklhofer C, 2001. Compartmental model for aluminum biokinetics. Hum Exp Toxicol 20(2):111–117.11327511
Nostrandt AC, Shafer TJ, Mundy WR, 1996. Inhibition of rat brain phosphatidylinositol-specific phospholipase C by aluminum: Regional differences, interactions with aluminum salts, and mechanisms. Toxicol Appl Pharmacol 136(1):118–125.8560464
NPIRS. 2008. Aluminum phosphide. Chemical ingredients database. National Pesticide Information Retrieval System. U.S. Environmental Protection Agency, U.S. Department of Agriculture. http://ppis.ceris.purdue.edu/htbin/cnamlist.com. January 7, 2008.
NRC. 1982. Aluminum (Al). Drinking water and health. Vol. 4. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 155–167.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council, National Academy Press.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, Department of Health and Human Services. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. January 11, 2008.
Nyholm NE. 1981. Evidence of involvement of aluminum in causation of defective formation of eggshells and of impaired breeding in wild passerine birds. Environ Res 26(2):363–71.7318791
Oberly TJ, Piper CE, McDonald DS. 1982. Mutagenicity of metal salts in the L5178Y mouse lymphoma assay. J Toxicol Environ Health 9:367–376.7097791
Offit PA, Jew RK. 2003. Addressing parents' concerns: Do vaccines contain harmful preservatives, adjuvants, additives, or residuals? Pediatrics 112(6 Part 1):1394–1397.14654615
Ogasawara Y, Sakamoto T, Ishii K, 2002. Effects of the administration routes and chemical forms of aluminum on aluminum accumulation in rat brain. Biol Trace Elem Res 86(3):269–278.12019523
Olivier P, Marzin D. 1987. Study of the genotoxic potential of 48 inorganic derivatives with the SOS chromotest. Mutat Res 189:263–269.3118206
Omokhodion FO, Howard JM. 1994. Trace elements in the sweat of acclimatized persons. Clin Chim Acta 231(1):23–28.7704945
Ondov JM, Zoller WH, Gordon GE. 1982. Trace element emissions of aerosols from motor vehicles. Environ Sci Technol 16(6):318–328.
Ondreicka R, Ginter E, Kortus J. 1966. Chronic toxicity of aluminum in rats and mice and its effects on phosphorus metabolism. Br J Ind Med 23(4):305–312.5926895
Oneda S, Takasaki T, Kurowaki K, 1994. Chronic toxicity and tumorigenicity study of aluminum potassium sulfate in B6C3F1 mice. In Vivo 8(3):271–278.7803703
O'Neil MJ, Smith A, Heckelman PE, 2001. Aluminum and aluminum compounds. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. Whitehouse Station, NJ: Merck & Co., Inc., 59–65.
OSHA. 2001. Method ID-109-SG: Aluminum oxide in workplace atmospheres. Sampling and analytical methods. Occupational Safety and Health Administration. U.S. Department of Labor. http://www.osha.gov/dts/sltc/methods/inorganic/t-id109sg-pv-02-0110-m/t-id109sg-pv-02-0110-m.html. March 07, 2006.
OSHA. 2002. Method ID-121: Metal and metalloid particulates in workplace atmospheres (atomic absorption). Sampling and analytical methods. Occupational Safety and Health Administration. U.S. Department of Labor. http://www.osha.gov/dts/sltc/methods/inorganic/id121/id121.html. March 21, 2006.
OSHA. 2007a. Air contaminants. Occupational safety and health standards for shipyard employment. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. http://edocket.access.gpo.gov/cfr_2007/julqtr/pdf/29cfr1915.1000.pdf. July 30, 2008.
OSHA. 2007b. Limits for air contaminants. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. http://edocket.access.gpo.gov/cfr_2007/julqtr/pdf/29cfr1910.1000.pdf. July 30, 2008.
OTA. 1990. Neurotoxicology: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Oteiza PI, Golub MS, Gershwin ME, 1989. The influence of high dietary aluminum on brain microtubule polymerization in mice. Toxicol Lett 47:279–285.2749772
Oteiza PI, Keen CL, Han B, 1993. Aluminum accumulation and neurotoxicity in Swiss-Webster mice after long-term dietary exposure to aluminum and citrate. Metabolism 42(10):1296–1300.8412742
Owen GM, Brozek J. 1966. Influence of age, sex, and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Owen LMW, Crews HM, Bishop NJ, 1994. Aluminum uptake from some foods by guinea pigs and the characterization of aluminum in in vivo intestinal digesta by sec-ip-ms. Food Chem Toxicol 32(8):697–705.8070734
Partridge NA, Regnier FE, White JL, 1989. Influence of dietary constituents on intestinal absorption of aluminum. Kidney Int 35(6):1413–1417.2770121
Paternain JL, Domingo JL, Llobet JM, 1988. Embryotoxic and teratogenic effects of aluminum nitrate in rats upon oral administration. Teratology 38:253–257.3227492
*Peng J-HF, Xu Z-C, Xu Z-X, 1992. Aluminum-induced acute cholinergic neurotoxicity in rat. Mol Chem Neuropathol 17(1):79–89.1388451
Pennington JA T. 1987. Aluminum content of foods and diets. Food Addit Contam 5(2):161–232.
Pennington JA T, Jones JW. 1989. Dietary intake of aluminum. In: Gitelman HJ, ed. Aluminum and health: A critical review. New York, NY: Marcel Dekker Inc., 67–100.
Pennington JA T, Schoen SA. 1995. Estimates of dietary exposure to aluminum. Food Addit Contam 12(1):119–128.7758626
Perl DP, Brody AR. 1980. Alzheimer's disease: X-ray spectrometric evidence of aluminum accumulation in neurofibrillary tangle-bearing neurons. Science 208:297–299.7367858
Perl DP, Good PF. 1987. Uptake of aluminum into central nervous system along nasal-olfactory pathways. Lancet 1(8540):1028.
*Perl DP, Good PF. 1988. Aluminum, environment and central nervous-system disease. Environ Technol Lett 9:901–906.
Perl DP, Gajdusek DC, Garruto RM, 1982. Intraneuronal aluminum accumulation in amytotrophic lateral sclerosis and Parkinsonism-dementia of Guam. Science 217:1053–1055.7112111
Pettersen JC, Hackett DS, Zwicker GM, 1990. Twenty-six week toxicity study with KASAL (basic sodium aluminum phosphate) in beagle dogs. Environ Geochem Health 12(1–2):121–123.24202578
Pierre F, Baruthio F, Diebold F, 1995. Effect of different exposure compounds on urinary kinetics of aluminum and fluoride in industrially exposed workers. Occup Environ Med 52(6):396–403.7627317
Pigott GH, Gaskell BA, Ishmael J. 1981. Effects of long term inhalation of alumina fibres in rats. Br J Exp Pathol 62(3):323–331.7248173
Pillay KK S, Thomas CC Jr. 1971. Determination of the trace element levels in atmospheric pollutants by neutron activation analysis. J Radioanal Chem 7:107–118.
*Pineau A, Durand C, Guillard O, 1992. Role of aluminum in skin reactions after diphtheria-tetanus-pertussis-poliomyelitis vaccination: An experimental study in rabbits. Toxicology 73(1):117–125.1589878
Pivnick EK, Kerr NC, Kaufman RA, 1995. Rickets secondary to phosphate depletion: A sequela of antacid use in infancy. Clin Pediatr 34(2):73–78.
Plankey BJ, Patterson HH. 1987. Kinetics of aluminum-fulvic acid complexation in acidic waters. Environ Sci Technol 21:595–601.19994981
Pötzl K. 1970. Inorganic chemical analyses of nonpolluted aerosols sample at 1800 meters altitude. J Geophys Res 75:2347–2352.
Polizzi S, Pira E, Ferrara M, 2001. Neurotoxic effects of aluminum among foundry workers. Neurotoxicology 22(4):540.
Polizzi S, Pira E, Ferrara M, 2002. Neurotoxic effects of aluminum among foundry workers and Alzheimer's disease. Neurotoxicology 23(6):761–774.12520766
Posner E, Kennedy MCS. 1967. A further study of china biscuit placers in Stoke-on-Trent. Br J Ind Med 24:133–142.6023078
Powell JJ, Thompson RPH. 1993. The chemistry of aluminum in the gastrointestinal lumen and its uptake and absorption. Proc Nutr Soc 52:241–253.8493270
Priest ND. 1993. Satellite symposium on ‘Alzheimer's disease and dietary aluminum’: The bioavailability and metabolism of aluminum compounds in man. Proc Nutr Soc 52:231–240.8493269
Priest ND. 2004. The biological behaviour and bioavailability of aluminum in man, with special reference to studies employing aluminum-26 as a tracer: Review and study update. J Environ Monit 6(5):375–403.15152306
Priest ND, Newton D, Day JP, 1995. Human metabolism of aluminum-26 and gallium-67 injected as citrates. Hum Exp Toxicol 14(3):287–293.7779460
Priest ND, Talbot RJ, Austin JG, 1996. The bioavailability of 26Al-labelled aluminum citrate and aluminum hydroxide in volunteers. BioMetals 9(3):221–228.8696074
Priest ND, Talbot RJ, Newton D, 1998. Uptake by man of aluminum in a public water supply. Hum Exp Toxicol 17(6):296–301.9688351
Progar JJ, May JC, Rains TC, 1996. Preparation of an intra-laboratory reference material-determination of the aluminum content of a pooled 5% albumin (human) solution by ETAAS, MFS and ICP-AES. Biologicals 24:87–93.8889054
Provan SD, Yokel RA. 1988. Influence of calcium on aluminum accumulation by the rat jejunal slice. Res Commun Chem Pathol Pharmacol 59(1):79–92.3353581
Provan SD, Yokel RA. 1990. Reduced intestinal calcium and dietary calcium intake, increased aluminum absorption, and tissue concentration in the rat. Biol Trace Elem Res 23:119–132.
Que Hee SS, Boyle JR. 1988. Simultaneous multielemental analysis of some environmental and biological samples by inductively coupled plasma atomic emission spectrometry. Anal Chem 60:1033–1042.3407946
Que Hee SS, Finelli VN, Fricke FL, 1982. Metal content of stack emissions, coal and fly ash from some eastern and western power plants in the U.S.A. as obtained by ICP-AES. Int J Environ Anal Chem 13:1–18.
Que Hee SS, Igwe OJ, Boyle JR. 1988. Elemental alterations during the exposure of 1,2-dichloroethane (EDC), disulfiram (DSF), and EDC-DSF to male Sprague-Dawley rats. Biol Trace Elem Res 18:61–80.
Qureshi N, Malmberg RH. 1985. Reducing aluminum residuals in finished water. J Am Water Works Assoc 77(10):101–108.
Quiterio SL, Escaleira V, Sousa CR S, 2004. Metals in airborne particulate matter in downtown Rio de Janeiro, Brazil. Bull Environ Contam Toxicol 72(5):916–922.15266686
Radiation Safety Guide. 1999. Occupational radiation exposure monitoring - External monitoring. http://www.nih.gov/od/ors/ds/rsb/rsguide/orem.htm. June 15, 1999.
Radiation Safety Newsletter. 1998. Aluminum. Office of Radiological Safety, Georgia Tech. http://www.ors.gatech.edu/News9804.htm. June 15, 1999.
Radon K, Nowak D, Szadkowski D. 1999. Lack of combined effects of exposure and smoking on respiratory health in aluminium potroom workers. Occup Environ Med 56(7):468–472.10472318
Rahman H, Skillen AW, Channon SM, 1985. Methods for studying the binding of aluminum by serum protein. Clin Chem 31(12):1969–1973.4064285
Rajasekaran K. 2000. Effects of combined exposure to aluminum and ethanol on food intake, motor behavior and a few biochemical parameters in pubertal rats. Environ Toxicol Pharmacol 9(1–2):25–30.11137465
Ranau R, Oehlenschlager J, Steinhart H. 2001. Aluminium levels of fish fillets baked and grilled in aluminium foil. Food Chem 73(1):1–6.
Randall ME. 1983. Aluminium toxicity in an infant not on dialysis. Lancet 1(8337):1327–1328.
Razniewska G, Trzcinka-Ochocka M. 2003. ET-AAS as a method for determination of aluminum in blood serum and urine. Chem Analityczna 48:107–113.
Recker RR, Blotcky AJ, Leffler JA, 1977. Evidence for aluminum absorption from the gastrointestinal tract and bone deposition by aluminum carbonate ingestion with normal renal function. J Lab Clin Med 90:810–815.908869
Reiber S, Kukull W, Standish-Lee P. 1995. Drinking water aluminum and bioavailability. J Am Water Works Assoc 87(5):86–100.
Rice KC. 1999. Trace-element concentrations in streambed sediment across the conterminous United States. Environ Sci Technol 33(15):2499–2504.
Riddell AR. 1948. Pulmonary changes encountered in employees engaged in the manufacture of alumina abrasives. Occup Med 5:710–717.18113772
Rifat SL, Eastwood MR, Crapper-McLachlan DR, 1990. Effect of exposure of miners to aluminum powder. Lancet 336(8724):1162–1165.1978033
Riihimäki V, Hanninen H, Akila R. 2000. Body burden of aluminum in relation to central nervous system function among metal inert-gas welders. Scand J Wo rk Environ Health 26(2):118–130.
Robinson MJ, Ryan SW, Newton CJ, 1987. Blood aluminium levels in preterm infants fed parenterally or with cows' milk formulae. Lancet 2(8569):1206.
Rockette HE, Arena VC. 1983. Mortality studies of aluminum reduction plant workers: Potroom and carbon department. J Occup Med 25:549–557.6886861
Rodella L, Ricci F, Borsani E, 2004. Exposure to aluminium decreases nitric oxide synthetase expression in the rat cerebral cortex in time dependent manner. J Histochem Cytochem 52(Suppl 1):S25.
Rogers MA, Simon DG. 1999. A preliminary study of dietary aluminium intake risk of Alzheimer's disease. Age Ageing 28(2):205–209.10350420
Roider G, Drasch G. 1999. Concentrations of aluminum in human tissues - investigations on an occupationally non-exposed population in Southern Bavaria (Germany). Trace Elem Electrolytes 16(2):77–86.
Roig JL, Fuentes S, Teresa CM, 2006. Aluminum, restraint stress and aging: Behavioral effects in rats after 1 and 2 years of aluminum exposure. Toxicology 218(2–3):112–124.16289752
*Roloff VLE, Platt B, Riedel G. 2002. Long-term study of chronic oral aluminum exposure and spatial working m emory in rats. Behav Neurosci 116(2):351–356.11996320
Rondeau V, Commenges D, Jacqmin-Gadda H, 2000. Relation between aluminum concentrations in drinking water and Alzheimer's disease: An 8-year follow-up study. Am J Epidemiol 152(1):59–66.10901330
Rondeau V, Jacamin-Gadda H, Commenges D, 2001. Aluminum in drinking water and cognitive decline in elderly subjects: The Paquid cohort. (Comment on: Am J Epidemiol 153(7):695–703). Am J Epidemiol 154(3):288–290.
Roodhooft AM, van de Vyver FL, D'Haese PC, 1987. Aluminum accumulation in children on chronic dialysis: Predictive value of serum aluminum levels and desferrioxamine infusion test. Clin Nephrol 28(3):125–129.3665205
Rossbach B, Buchta M, Csanady GA, 2006. Biological monitoring of welders exposed to aluminium. Toxicol Lett 162(2–3):239–245.16280209
Rosseland BO, Eidhuset TD, Staurnes M. 1990. Environmental effects of aluminum. Environ Geochem Health 12:17–27.24202562
Roy AK, Talukder G, Sharma A. 1990. Effects of aluminium sulphate on human leukocyte chromosomes in vitro. Mutat Res 244:179–183.2355939
Saba-El-Rigal N. 2004. Effect of ascorbic acid on enzymatic and non-enzymatic antioxidants in mice liver after aluminum sulphate intoxication. Bull Natl Res Cent 29(4):483–496.
*Sahin G, Varol I, Temizer A, 1994. Determination of aluminum levels in the kidney, liver, and brain of mice treated with aluminum hydroxide. Biol Trace Elem Res 41(1–2):129–135.7946900
Saiyed SM, Yokel RA. 2005. Aluminum content of some foods and food products in the USA, with aluminum food additives. Food Addit Contam 22(3):234–244.16019791
Salib E, Hillier V. 1996. A case-control study of Alzheimer's disease and aluminum occupation. Br J Psychiatry 168(2):244–249.8837919
Salusky IB, Coburn JW, Foley J, 1986. Effects of oral calcium carbonate on control of serum phosphorus and changes in plasma aluminum levels after discontinuation of aluminum-containing gels in children receiving dialysis. J Pediatr 108(5 Part 1):767–770.3701525
Salusky IB, Coburn JW, Nelson P, 1990. Prospective evaluation of aluminum loading from formula in infants with uremia. J Pediatr 116:726–729.2329421
Sanchez DJ, Gomez M, Llobet JM, 1997. Effects of aluminum on the mineral metabolism of rats in relation to age. Pharmacol Toxicol 80(1):11–17.9148276
Santos F, Chan JC M, Yang MS, 1987. Aluminum deposition in the central nervous system. Preferential accumulation in the hippocampus in weanling rats. Med Biol 65(1):53–55.3613692
*Santucci D, Rankin J, Laviola G, 1994. Early exposure to aluminum affects eight-arm maze performance and hippocampal nerve growth factor in adult mice. Neurosci Lett 166:89–92.8190365
Sanz-Medel A, Roza RR, Alonso RG, 1987. Atomic spectrometric methods (atomic absorption and inductively coupled plasma atomic emission) for the determination of aluminum at the parts per billion level in biological fluids. J Anal Atom Spectrom 2(2):177–184.
Sarin S, Julka D, Gill KD. 1997. Regional alterations in calcium homeostasis in the primate brain following chronic aluminum exposure. Mol Cell Biochem 168:95–100.9062898
Saunders FM. 1988. Heavy metal impact on disposal and reclamation of aluminum-anodizing residues. Environ Technol Lett 9:945–956.
Savory J, Wills MR. 1986. Analytical methods for aluminum measurement. Kidney Int 29(Suppl 18):S24–S27.
Schaller KH, Csanady G, Filser J, 2007. Elimination kinetics of metals after an accidental exposure to welding fumes. Int Arch Occup Environ Health 80(7):635–641.17323068
Schenk RU, Bjorksten J, Yeager L. 1989. Composition and consequences of aluminum in water, beverages and other ingestibles. In: Lewis TE, ed. Environmental chemistry and toxicology of aluminum. Chelsea, MI: Lewis Publishers, Inc., 247–269.
Schmid K, Angerer J, Letzel S, 1995. Use of bone mineral content determination by x-ray absorptiometry in the evaluation of osteodystrophy among workers exposed to aluminum powders. Sci Total Environ 163(1–3):147–151.7716492
Schönholzer KW, Sutton RA L, Walker VR, 1997. Intestinal absorption of trace amounts of aluminum in rats studied with 26aluminum and accelerator mass spectrometry. Clin Sci 92(4):379–383.
Schonwald S. 2004. Aluminum. In: Dart RC, ed. Medical toxicology. 3rd ed. New York, NY: Lippincott, Williams, and Wilkins, 1387–1390.
Schroeder HA, Mitchener M. 1975a. Life-term studies in rats: Effects of aluminum, barium beryllium and tungsten. J Nutr 105(4):421–427.1113208
Schroeder HA, Mitchener M. 1975b. Life-term effects of mercury, methyl, mercury, and nine other trace metals on mice. J Nutr 105:452–458.1113210
Schupf N, Silverman W, Zigman WB, 1989. Aluminum and Alzheimer's disease [Letter]. Lancet 1(8632):267–269.2563424
*Sedman AB, Alfrey AC, Miller NL, 1987. Tissue and cellular basis for impaired bone formation in aluminum-related osteomalacia in the pig. J Clin Invest 79(1):86–92.3793934
Setchell BP, Waites GMH. 1975. The blood testis barrier. In: Creep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shafer TJ, Mundy WR. 1995. Effects of aluminum on neuronal signal transduction: Mechanisms underlying disruption of phosphoinositide hydrolysis. Gen Pharmacol 26(5):889–895.7557263
Sharma P, Mishra KP. 2006. Aluminum-induced maternal and developmental toxicity and oxidative stress in rat brain: Response to combined administration of Tiron and glutathione. Reprod Toxicol 21(3):313–321.16040227
Shaver CG. 1948. Pulmonary changes encountered in employees engaged in the manufacture of alumina abrasives. Occup Med 5:718–728.18113773
Shaver CG, Riddell AR. 1947. Lung changes associated with the manufacture of alumina abrasives. J Ind Hyg Toxicol 29:145–157.20296238
Sheldon L, Umana M, Bursey J, 1986. Biological monitoring techniques for human exposure to industrial chemicals: Analysis of human fat, skin, nails, hair, blood, urine, and breath. Park Ridge, NJ: Noyes Publications, 86–122.
Shore D, Wyatt RJ. 1983. Aluminum and Alzheimer's disease. J Nerv Ment Dis 171(9):553–558.6350535
Sighinolfi GP, Gorgoni C, Bonori O, 1989. Comprehensive determination of trace elements in human saliva by ETA-AAS. Mikrochim Acta 97(3–4):171–179.
Sim M, Dick R, Russo J, 1997. Are aluminum potroom workers at increased risk of neurological disorders? Occup Environ Med 54(4):229–235.9166127
Simmer K, Fudge A, Teubner J, 1990. Aluminum concentrations in infant formulae. J Paediatr Child Health 26(1):9–11.2331424
Simonsson BG, Sjoberg A, Rolf C, 1985. Acute and long-term airway hyperreactivity in aluminum-salt exposed workers with nocturnal asthma. Eur J Respir Dis 66:105–118.3882443
Sinczuk-Walczak H, Szymczak M, Razniewska G, 2003. Effects of occupational exposure to aluminum on nervous system: Clinical and electroencephalographic findings. Int J Occup Environ Health 16(4):301–310.
Sjögren B, Elinder C-G, Lidums V, 1988. Uptake and urinary excretion of aluminum among welders. Int Arch Occup Environ Health 60(2):77–79.3346084
Sjögren B, Gustavsson P, Hogstedt C. 1990. Neuropsychiatric symptoms among welders exposed to neurotoxic metals. Br J Ind Med 47(10):704–707.2223663
Sjögren B, Lidums V, H akansson M, 1985. Exposure and urinary excretion of aluminum during welding. Scand J Work Environ Health 11(1):39–43.3992220
Sjögren B, Ljunggren KG, Almkvist O, 1996. A follow-up study of five cases of aluminosis. Int Arch Occup Environ Health 68(3):161–164.8919843
Slanina P, Falkeborn Y, Frech W, 1984. Aluminum concentrations in the brain and bone of rats fed citric acid, aluminum citrate or aluminum hydroxide. Food Chem Toxicol 22(5):391–397.6539288
Slanina P, Frech W, Bernhardson A, 1985. Influence of dietary factors on aluminum absorption and retention in the brain and bone of rats. Acta Pharmacol Toxicol 56(4):331–336.
Slanina P, Frech W, Ekstrom L-G, 1986. Dietary citric acid enhances absorption of aluminum in antacids. Clin Chem 32(3):539–541.3948402
Snoeyink VL, Jenkins D, eds. 1980. Water chemistry. New York: John Wiley and Sons, 146, 209–210.
Sohn S-J, Shin J-H, Park Y-S, 1996. Components of drinking water and risk of cognitive impairment in the rural elderly. Chonnam J Med Sci 9(2):189–193.
Soni MG, White SM, Flamm WG, 2001. Safety evaluation of dietary aluminum. Regul Toxicol Pharmacol 33(1):66–79.11259180
Sorenson JRJ, Campbell IR, Tepper LB, 1974. Aluminum in the environment and human health. Environ Health Perspect 8:3–95.4470920
Sparling DW, Lowe TP. 1996. Environmental hazards of aluminum to plants, invertebrates, fish, and wildlife. Rev Environ Contam Toxicol 145:1–127.7494908
SRI. 2007. 2007 Directory of chemical producers: United States. Menlo Park, CA: SRI Consulting, 451–454, 840, 873.
Staley JT, Haupin W. 1992. Aluminum and aluminum alloys. In: Kroschwitz JI, Howe-Grant M, eds. Kirk-Othmer encyclopedia of chemical technology. Vol. 2: Alkanolamines to antibiotics (glycopeptides). New York: John Wiley & Sons, Inc., 248–249.
Stauber JL, Florence TM, Davies CM, 1999. Bioavailability of Al in alum-treated drinking water. J Am Water Works Assoc 91(11):84–93.
Steinhagen WH, Cavender FL, Cockrell BY. 1978. Six month inhalation exposures of rats and guinea pigs to aluminum chlorhydrate. J Environ Pathol Toxicol 1:267–277.722194
Steinhausen C, Kislinger G, Winklhofer C, 2004. Investigation of the aluminum biokinetics in humans: A 26Al tracer study. Food Chem Toxicol 42(3):363–371.14871578
Stevens RK, Dzubay TG, Russwurm G, 1978. Sampling and analysis of atmospheric sulfates and related species. Atmos Environ 12:55–68.
Stitch SR. 1957. Trace elements in human tissue. I. A semi-quantitative spectrographic survey. Biochem J 67:97–109.13471517
Stokinger HE. 1981. The metals. In: Clayton GD, Clayton FE, eds. Patty's industrial hygiene and toxicology. New York, NY: John Wiley Sons, 1493–1505.
Stone CJ, McLaurin DA, Steinhagen WH, 1979. Tissue deposition patterns after chronic inhalation exposures of rats and guinea pigs to aluminum chlorhydrate. Toxicol Appl Pharmacol 49:71–76.473204
Strong MJ, Garruto RM, Joshi JG, 1996. Can the mechanisms of aluminum neurotoxicity be integrated into a unified scheme? J Toxicol Environ Health 48:599–613.8772801
Suarez-Fernandez MB, Soldado AB, Sanz-Medel A, 1999. Aluminum-induced degeneration of astrocytes occurs via apoptosis and results in neuronal death. Brain Res 835(2):125–136.10415367
Subcommittee on Flame-Retardant Chemicals. 2000. Toxicological risks of selected flame-retardant chemicals. Subcommittee on Flame-Retardant Chemicals, Committee on Toxicology, Board on Environmental Studies and Toxicology. Commission on Life Sciences, National Research Council. Washington, DC: National Academy Press, 99–100.
Sutherland JE, Greger JL. 1998. Effect of the size of an oral dose of aluminum on the relative importance of biliary v. urinary aluminium excretion in conscious rats. Food Chem Toxicol 36(6):505–512.9674958
Sweet CW, Vermette SJ, Landsberger S. 1993. Sources of toxic trace elements in urban air in Illinois. Environ Sci Technol 27:2502–2510.
Talbot RJ, Newton D, Priest ND, 1995. Inter-subject variability in the metabolism of aluminum following intravenous injection as citrate. Hum Exp Toxicol 14:595–599.7576820
Taylor FB, Symons GE. 1984. Effects of acid rain on water supplies in the Northeast. J Am Water Works Assoc 76:34–42.
Taylor GA, Moore PB, Ferrier IN, 1998. Gastrointestinal absorption of aluminum and citrate in man. J Inorg Biochem 69(3):165–169.9629675
Teraoka H. 1981. Distribution of 24 elements in the internal organs of normal males and the metallic workers in Japan. Arch Environ Health 36(4):155–165.7271320
Testolin G, Erba D, Ciappellano S, 1996. Influence of organic acids on aluminum absorption and storage in rat tissues. Food Addit Contam 13(1):21–27.8647304
*Theriault G, Cordier S, Harvey R. 1984b. Skin telangiectases in workers at an aluminum plant. N Engl J Med 303(22):1278–1281.
Theriault G, Cordier S, Tremblay C, 1984a. Bladder cancer in the aluminum industry. Lancet 1(8383):947–950.6143877
Thomson SM, Burnett DC, Bergmann JD, 1986. Comparative inhalation hazards of aluminum and brass powders using bronchopulmonary lavage as an indicator of lung damage. J Appl Toxicol 6(3):197–209.3722713
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Thorne BM, Cook A, Donohoe T, 1987. Aluminum toxicity and behavior in the weanling Long-Evans rat. Bull Pyschon Soc 25:129–132.
Thorne BM, Donohoe T, Lin K-N, 1986. Aluminum ingestion and behavior in the Long-Evans rat. Physiol Behav 36(1):63–67.3952185
Tipton IH, Cook MJ. 1963. Trace elements in human tissue. Part II. Adult subjects from the United States. Health Phys 9:103–145.13985137
Tipton IH, Shafer JJ. 1964. Statistical analysis of lung trace element levels. Arch Environ Health 8:58–67.14067552
TRI05. 2007. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Office of Information Analysis and Access. Office of Environmental Information. U.S. Environmental Protection Agency. Toxics Release Inventory. http://www.epa.gov/triexplorer/. December 27, 2007.
Trieff NM, Romana LA, Esposito A, 1995. Effluent from bauxite factory induces developmental and reproductive damage in sea urchins. Arch Environ Contam Toxicol 28:173–177.
Tsou VM, Young RM, Hart MH. 1991. Elevated plasma aluminum levels in normal infants receiving antacids containing aluminum. Pediatrics 87(2):148–151.1987526
Ueda M, Mizoi Y, Maki Z, 1958. A case of aluminum dust lung: A necropsy report. Kobe J Med Sci 4:91–99.
USGS. 1964. Chemical composition of snow in the Northern Sierra Nevada and other areas. Geochemistry of water. U.S. Geological Survey, U.S. Department of Interior. U.S. Geol Surv Water Supply Paper 1535-J.
USGS. 1984a. Characterization of aluminum chemistry for acid precipitation. Reston, VA: U.S. Geological Survey, Water Resources Division. PB85214542.
USGS. 1984b. Residual aluminum in potable water. Technical completion report. Reston, VA: U.S. Geological Survey, Water Resources Division. PB85214963.
USGS. 1984c. Element concentrations in soils and other surficial materials of the conterminous United States. Alexandria, VA: U.S. Geological Survey. Geological Survey Professional Paper 1270.
USGS. 1996. Method I-1472–95: Methods of analysis by the U.S. Geological Survey National Water Quality Laboratory. Determination of dissolved aluminum and boron in water by inductively coupled plasma-atomic emission spectrometry. Denver, CO: U.S. Geological Survey. Open-File Report 96–149. http://web1.er.usgs.gov/nemi/method_pdf/8915.pdf. March 21, 2006.
USGS. 2007a. Bauxite and alumina. Minerals yearbook: Vol. I. Metals and minerals. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/bauxite/myb1-2006-bauxi.pdf. January 14, 2008.
USGS. 2007b. Aluminum. Minerals yearbook: Vol. I. Metals and minerals. U.S. Geological Survey. http://minerals.usgs.gov/minerals/pubs/commodity/aluminum/myb1-2006-alumi.pdf. January 14, 2008.
USGS. 2007c. Aluminum. Mineral commodity summaries 2007. U.S. Geological Survey, 18–19. http://minerals.usgs.gov/minerals/pubs/mcs/2007/mcs2007.pdf. January 14, 2008.
USGS. 2007d. Bauxite and alumina. Mineral commodity summaries, January 2006. U.S. Geological Survey, 28–29. http://minerals.usgs.gov/minerals/pubs/mcs/2007/mcs2007.pdf. January 14, 2008.
Valkonen S, Aitio A. 1997. Analysis of aluminum in serum and urine for the biomonitoring of occupational exposure. Sci Total Environ 199:103–110.9200852
Vallyathan V, Berferon WN, Robichaux PA, 1982. Pulmonary fibrosis in an aluminum arc welder. Chest 81(3):372–374.7056115
Vandenplas O, Delwiche JP, Vanbilsen ML, 1998. Occupational asthma caused by aluminum welding. Eur Resp J 11(5):1182–1184.
van der Voet G. 1992. Intestinal absorption of aluminum. Aluminum in biology and medicine. Ciba Found Symp 169:109–117.1490418
*van der Voet GB, de Wolff FA. 1987. The effect of di-and trivalent iron on the intestinal absorption of aluminum in rats. Toxicol Appl Pharmacol 90(2):190–197.3629595
van der Voet GB, de Haas EJ M, de Wolff FA. 1985. Monitoring of aluminum in whole blood, plasma, serum, and water by a single procedure using flameless atomic absorption spectrophotometry. J Anal Toxicol 9:97–100.4010240
Van Landeghem GF, D'Haese PC, Lamberts LV, 1994. Quantitative HPLC/ETAAS hybrid method with an on-line metal scavenger for studying the protein binding and speciation of aluminum and iron. Anal Chem 66(2):216–222.8116878
Varner JA, Horvath WJ, Huie CW, 1994. Chronic aluminum fluoride administration. 1. Behavioral observations. Behav Neural Biol 61(3):233–241.8067979
Varner JA, Huie C, Horvath W, 1993. Chronic AlF3 administration: II. Selected histological observations. Neurosci Res Commun 13(2):99–104.
Varner JA, Jensen KF, Horvath W, 1998. Chronic administration of aluminum-fluoride or sodium-fluoride to rats in drinking water: Alterations in neuronal and cerebrovascular integrity. Brain Res 784(1–2):284–298.9518651
Varrica D, Aiuppa A, Dongarra G. 2000. Volcanic and anthropogenic contribution to heavy metal content in lichens from Mt. Etna and Vulcano Island (Sicily). Environ Pollut 108(2):153–162.15092945
Veien NK, Hattel T, Justesen O, 1986. Aluminum allergy. Contact Dermatitis 15:295–297.3816193
Vela MM, Toma RB, Reiboldt W, 1998. Detection of aluminum residue in fresh and stored canned beer. Food Chem 63(2):235–239.
Venugopal B, Luckey TD, eds. 1978. Metal toxicity in mammals. Vol 2. New York, NY: Plenum Press, 104–112.
Versieck J, Cornelis R. 1980. Measuring aluminum levels. N Engl J Med 302(8):468–469.7351960
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238:476–483.8681961
Vittori D, Nesse A, Perez G, 1999. Morphologic and functional alterations of erythroid cells induced by long-term ingestion of aluminum. J Inorg Biochem 76(2):113–120.10612063
Vogt KA, Dahlgren R, Ugolini F, 1987. Aluminum, Fe, Ca, Mg, K, Mn, Cu, Zn and P in above-and belowground biomass. II. Pools and circulation in a subalpine Abies amabilis stand. Biogeochem 4:295–311.
von Stockhausen HB, Schrod L, Bratter P, 1990. Aluminum loading in premature infants during intensive care as related to clinical aspects. J Trace Elem Electrolytes Health Dis 4:209–213.2136283
Vuori K-M, Witick A, Jokela S. 1990. Accumulation of aluminum in Fontinalis dalecarlica br. eur. in a brownwater river in western Europe. Aqua Fenn 20:203–204.
Waldron-Edward D, Chan P, Skoryna SC. 1971. Increased prothrombin time and metabolic changes with high serum aluminum levels following long-term exposure to Bayer-process alumina. Can Med Assoc J 105(12):1297–1299.4338426
Walker WJ, Cronan CS, Patterson HH. 1988. A kinetic-study of aluminum adsorption by aluminosilicate clay-minerals. Geochim Cosmochim Acta 52:55–62.
Walton J, Tuniz C, Fink D, 1995. Uptake of trace amounts of aluminum into the brain from drinking water. Neurotoxicology 16(1):187–190.7603640
Wangen LE, Jones MM. 1984. The attenuation of chemical elements in acidic leachates from coal mineral wastes by soils. Environ Geol Water Sci 6:161–170.
Warady BA, Ford DM, Gaston CE, 1986. Aluminum intoxication in a child: Treatment with intraperitoneal desferrioxamine. Pediatrics 78(4):651–655.3763276
Ward NI. 1989. Environmental contamination of aluminum and other elements in North Cornwall as a result of the Lowermoor water treatment works incident. In: Vernet J-P, ed. Heavy metals in the environment. Edinburgh: CEP Consultants, 118–121.
Wawschinek O, Petek W, Lang J, 1982. The determination of aluminum in human plasma. Mikrochim Acta 1:335–339.
Weberg R, Berstad A. 1986. Gastrointestinal absorption of aluminum from single doses of aluminum containing antacids in man. Eur J Clin Invest 16(5):428–432.3100311
Wedrychowski A, Schmidt WN, Hnilica LS. 1986. The in-vivo cross-linking of proteins and DNA by heavy metals. J Biol Chem 261(7):3370–3376.3512554
Weintraub R, Hams G, Meerkin M, 1986. High aluminum content of infant milk formulas. Arch Dis Child 61(9):914–916.3767424
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
Wettstein A, Aeppli J, Gautschi K, 1991. Failure to find a relationship between mnestic skills of octogenarians and aluminum in drinking water. Int Arch Occup Environ Health 63(2):97–103.1889888
White DM, Longstreth WT J, Rosenstock L, 1992. Neurologic syndrome in 25 workers from an aluminum smelting plant. Arch Intern Med 152:1443–1448.1627023
WHO. 2000. Air quality guidelines. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/Document/AIQ/AirQualRepMtg.pdf. March 08, 2006.
WHO. 2004. Guidelines for drinking-water quality. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. March 08, 2006.
Widdowson EM, Dickerson JW T. 1964. Chapter 17: Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advanced treatise. Vol. II: The elements Part A. New York, NY: Academic Press.
*Wide M. 1984. Effect of short-term exposure to five industrial metals on the embryonic and fetal development of the mouse. Environ Res 33(1):47–53.6692813
Wigle DT. 1977. Bladder cancer: Possible new high-risk occupation. Lancet 2(8082):83–84.
Wilhelm M, Jager DE, Ohnesorge FK. 1990. Aluminum toxicokinetics. Pharmacol Toxicol 66:4–9.2408032
Wilhelm M, Ohnesorge FK, Lombeck I, 1989. Uptake of aluminum, cadmium, copper, lead, and zinc by human scalp hair and elution of the adsorbed metals. J Anal Toxicol 13:17–21.2496275
Wilkinson KJ, Campbell PG C. 1993. Aluminum bioconcentration at the gills surface of juvenile Atlantic salmon in acidic media. Environ Toxicol Chem 12:2083–2095.
Wills MR, Savory J. 1989. Aluminum and chronic renal failure: Sources, absorption, transport, and toxicity. CRC Crit Rev Clin Lab Sci 27(1):59–107.
*Wills MR, Hewitt CD, Sturgill BC, 1993. Long-term oral or intravenous aluminum administration in rabbits. I. Renal and hepatic changes. Ann Clin Lab Sci 23(1):1–16.7679266
Wilson CL, Arfsten DP, Carpenter RL, 2002. Effect of Navy chaff release on aluminum levels in an area of the Chesapeake Bay. Ecotoxicol Environ Saf 52(2):137–142.12061831
Winterberg B, Bertram H-P, Korte R, 1987. Hair analysis for aluminum monitoring in patients on long-term hemodialysis. Trace Elem Med 4(2):72–74.
Wood CM, McDonald DG, Ingersoll CG, 1990. Effects of water acidity, calcium, and aluminum on whole body ions of brook trout (Salvelinus fontinalis) continuously exposed from fertilization to swim-up: A study by instrumental neutron activation analysis. Can J Fish Aquat Sci 47(8):1593–1603.
Wood DJ, Cooper C, Stevens J, 1988. Bone mass and dementia in hip fracture patients from areas with different aluminum concentrations in water supplies. Age Ageing 17(6):415–419.3239502
Woodson GC. 1998. An interesting case of osteomalacia due to antacid use associated with stainable bone aluminum in a patient with normal renal function. Bone 22(6):695–698.9626411
Woolfson AD, Gracey GM. 1988. Methods for the determination of trace aluminum contamination in dialysis fluids. J Clin Pharm Ther 13:243–248.3069848
Wrobel K, Gonzalez EB, Wrobel K, 1995. Aluminum and silicon speciation in human serum by ion-exchange high-performance liquid chromatography-electrothermal atomic absorption spectrometry and gel electrophoresis. Analyst 120(3):809–815.7741232
Xu N, Majidi V, Markesbery WR, 1992a. Brain aluminum in Alzheimer's disease using an improved GFAAS method. Neurotoxicology 13(4):735–743.1302300
*Xu ZC, Tang J, Xu ZX, 1992b. Kinetics of aluminum in rats. IV. Blood and cerebrospinal fluid kinetics. Toxicol Lett 63(1):7–12.1412525
Yeardley RB, Lazorchak JM, Paulsen SG. 1998. Elemental fish tissue contamination in northeastern U.S. Lakes: Evaluation of an approach to regional assessment. Environ Toxicol Chem 17(9):1875–1884.
Yokel RA. 1985. Toxicity of gestational aluminum exposure to the maternal rabbit and offspring. Toxicol Appl Pharmacol 79(1):121–133.4049399
Yokel RA. 1987. Toxicity of aluminum exposure to the neonatal and immature rabbit. Fundam Appl Toxicol 9(4):795–806.3692032
Yokel RA, McNamara PJ. 1985. Aluminum bioavailability and disposition in adult and immature rabbits. Toxicol Appl Pharmacol 77(2):344–352.3975904
Yokel RA, McNamara PJ. 1988. Influence of renal impairment, chemical form, and serum protein binding on intravenous and oral aluminum kinetics in the rabbit. Toxicol Appl Pharmacol 95(1):32–43.3413794
Yokel RA, McNamara PJ. 1989. Elevated aluminum persists in serum and tissues of rabbits after a 6-hour infusion. Toxicol Appl Pharmacol 99(1):133–138.2727994
Yokel RA, McNamara PJ. 2001. Aluminium toxicokinetics: An updated minireview. Pharmacol Toxicol 88(4):159–167.11322172
Yokel RA, Allen DD, Ackley DC. 1999. The distribution of aluminum into and out of the brain. J Inorg Biochem 76(2):127–132.10612065
Yokel RA, Meurer KA, Hong CB, 1997. Short-term oral 3-hydroxypyridin-4-one dosing increases aluminum excretion and partially reverses aluminum-induced toxicity in the rabbit independent of chelator lipophilicity. Drug Metab Dispos 25(2):182–190.9029049
Yokel RA, Rhineheimer SS, Brauer RD, 2001a. Aluminum bioavailability from drinking water is very low and is not appreciably influenced by stomach contents or water hardness. Toxicology 161(1–2):93–101.11295258
Yokel RA, Rhineheimer SS, Sharma P, 2001b. Entry, half-life, and desferrioxamine-accelerated clearance of brain aluminum after a single 26Al exposure. Toxicol Sci 64(1):77–82.11606803
Yokel RA, Wilson M, Harris WR, 2002. Aluminum citrate uptake by immortalized brain endothelial cells: Implications for its blood-brain barrier transport. Brain Res 930(1–2):101–110.11879800
Yoshida S, Gershwin ME, Keen CL, 1989. The influence of aluminum on resistance to Listeria monocytogenes in Swiss-Webster mice. Int Arch Allergy Appl Immunol 89:404–409.2793227
Yukawa M, Suzuki-Yasumoto M, Amano K, 1980. Distribution of trace elements in the human body determined by neutron activation analysis. Arch Environ Health 35:36–44.7362268
Yumoto S, Nagai H, Kobayashi K, 2003. 26Al incorporation into the brain of suckling rats through maternal milk. J Inorg Biochem 97:155–160.14507472
Yumoto S, Nagai H, Matsuzaki H, 2000. Transplacental passage of 26Al from pregnant rats to fetuses and 26Al transfer through maternal milk to suckling rats. Nucl Instrum Methods Phys Res B 172:925–929.
Zafar TA, Weaver CM, Martin BR, 1997. Aluminum (Al26) metabolism in rats. Proc Soc Exp Biol Med 216(1):81–85.9316614
Zapatero MD, Garcia de Jalon A, Pascual F, 1995. Serum aluminum levels in Alzheimer's disease and other senile dementias. Biol Trace Elem Res 47:235–240.7779552
Zatta P, Favarato M, Nicolini M. 1993. Deposition of aluminum in brain tissues of rats exposed to inhalation of aluminum acetylacetonate. NeuroReport 4(9):1119–1122.8219037
Zatta P, Ibn-Lkhayat-Idrissi M, Zambenedetti P, 2002. In vivo and in vitro effects of aluminum on the activity of mouse brain acetylcholinesterase. Brain Res Bull 59(1):41–45.12372547
Zhang ZJ, Qian YH, Hu HT, 2003. The herbal medicine Dipsacus asper wall extract reduces the cognitive deficits and overexpression of β-amyloid protein induced by aluminum exposure. Life Sci 73(19):2443–2454.12954453
Zheng W. 2001. Neurotoxicology of the brain barrier system: New implications. J Toxicol Clin Toxicol 39(7):711–719.11778669
Zhou Y, Yokel RA. 2005. The chemical species of aluminum influence its paracellular flux across and uptake into Caco-2 cells, a model of gastrointestinal absorption. Toxicol Sci 87(1):15–26.15933224
Ziegler EE, Edwards BB, Jensen RL 1978. Absorption and retention of lead by infants. Pediatr Res 12:29–34.643372