# 8 REGULATIONS AND ADVISORIES

The international and national regulations and guidelines regarding aluminum and aluminum compounds in air, water, and other media are summarized in Table 8-1.

ATSDR has derived an intermediate-duration oral minimal risk level (MRL) of 1 mg Al/kg/day for aluminum. This MRL is based on a NOAEL of 26 mg Al/kg/day and a LOAEL of 130 mg Al/kg/day for neurodevelopmental effects in the offspring of mice exposed to aluminum lactate in the diet on gestation day 1 through lactation day 21 followed by pup exposure until postnatal day 35 (Golub and Germann 2001). The MRL was derived by dividing the NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) and a modifying factor of 0.3 to account for the higher bioavailability of the aluminum lactate used in the principal study, as compared to the bioavailability of aluminum in the human diet and drinking water.

ATSDR has derived a chronic-duration oral MRL of 1 mg Al/kg/day for aluminum. This MRL is based on a LOAEL of 100 mg Al/kg/day for neurological effects in mice exposed to aluminum lactate in the diet during gestation, lactation, and postnatally until 2 years of age (Golub et al. 2000). The MRL was derived by dividing the LOAEL by an uncertainty factor of 300 (3 for the use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability) and a modifying factor of 0.3 to account for the higher bioavailability of the aluminum lactate used in the principal study, as compared to the bioavailability of aluminum in the human diet and drinking water.

EPA has not derived a reference dose (RfD) or reference concentration (RfC) for aluminum, but has derived an RfD for aluminum phosphide of 4x10^−4^ mg/kg/day based on a NOAEL of 0.51 mg/kg of food or 0.025 mg/kg/day (phosphine) converted to 0.043 mg/kg/day of aluminum phosphide for body weight and clinical parameters observed in a rats during a chronic oral study (IRIS 2008).

Table 8-1 Regulations and Guidelines Applicable to Aluminum and Compounds

Agency | Description | Information | Reference
[underlined: INTERNATIONAL]
Guidelines:
IARC | Carcinogenicity classification for aluminum production | Group 1^a^ | IARC 1987
WHO | Air quality guidelines | No data | WHO 2000
| Drinking water quality guidelines for aluminum^b^ | ≤0.1 mg/L in large water treatment facilities | WHO 2004
| | ≤0.2 mg/L in small water treatment facilities
[underlined: NATIONAL]
Regulations and Guidelines:
a. Air
ACGIH | TLV (8-hour TWA) for aluminum and compounds (as Al) | | ACGIH 2005
| Metal dust | 10 mg/m^3^
| Pyro powders | 5 mg/m^3^
| Soluble salts | 2 mg/m^3^
| Alkyls (NOS) | 2 mg/m^3^
| TLV (8-hour TWA) for aluminum oxide^c^ | 10 mg/m^3^
EPA | AEGL-1 for aluminum phosphide^d^ | Not recommended due to insufficient data | EPA 2006a
| AEGL-2 for aluminum phosphide^d^
| 10 minutes | 4.0 ppm
| 30 minutes | 4.0 ppm
| 60 minutes | 2.0 ppm
| 4 hours | 0.50 ppm
| 8 hours | 0.25 ppm
| AEGL-3 for aluminum phosphide^d^
| 10 minutes | 7.2 ppm
| 30 minutes | 7.2 ppm
| 60 minutes | 3.6 ppm
| 4 hours | 0.90 ppm
| 8 hours | 0.45 ppm
| Hazardous air pollutant | No data | EPA 2006c; 42 USC 7412
NIOSH | REL (10-hour TWA) | | NIOSH 2005
| Aluminum | 10 mg/m^3^ (total dust); 5 mg/m^3^ (respirable fraction)
| Aluminum oxide | 15 mg/m^3^ (total dust); 5 mg/m^3^ (respirable fraction)
OSHA | PEL (8-hour TWA) for general industry for aluminum metal (as Al) and aluminum oxide | 15 mg/m^3^ (total dust); 5 mg/m^3^ (respirable fraction) | OSHA 2007b; 29 CFR 1910.1000
| PEL (8-hour TWA) for shipyard industry for aluminum metal (as Al) and aluminum oxide | 15 mg/m^3^ (total dust); 5 mg/m^3^ (respirable fraction) | OSHA 2007a; 29 CFR 1915.1000
b. Water
EPA | Designated as hazardous substances in accordance with Section 311(b)(2)(A) of the Clean Water Act for aluminum sulfate | Yes | EPA 2006b; 40 CFR 116.4
| Drinking water standards and health advisories | 0.05–0.2 mg/L | EPA 2006f
| National primary drinking water standards | No data | EPA 2003
| National secondary drinking water standards for aluminum | 0.05–0.2 mg/L | EPA 2008; 40 CFR 143.3
| Reportable quantities of hazardous substances designated pursuant to Section 311 of the Clean Water Act for aluminum sulfate | 5,000 pounds | EPA 2006h; 40 CFR 117.3
| Water quality criteria for human health for aluminum | | EPA 2006e
| Freshwater CMC | 750 μg/L
| Freshwater CCC | 87 μg/L
c. Food
FDA | Bottled drinking water for aluminum | 0.2 mg/L | FDA 2005; 21 CFR 165.110
d. Other
ACGIH | Carcinogenicity classification for aluminum oxide | A4^e^ | ACGIH 2005
EPA | Carcinogenicity classification for aluminum phosphide | No data | IRIS 2008
| RfC for aluminum phosphide | No data
| RfD for aluminum phosphide | 4×10^−4^ mg/kg/day
EPA | Identification and listing of hazardous substances; hazardous waste number for aluminum phosphide | P006 | EPA 2006d; 40 CFR 261, Appendix VIII
| Pesticide classified as restricted use for aluminum phophide | Yes^f^ | EPA 2006g; 40 CFR 152.175
| Pesticide exemptions from the requirement of a tolerance | | EPA 2006l; 40 CFR 180.910
| Aluminum hydroxide (for use as a diluent and carrier) | Yes^g^
| Aluminum oxide (for use as a diluent) | Yes^g^
| Aluminum sulfate (for use as a safener adjuvant) | Yes^g^ | EPA 2006m; 40 CFR 180.920
| Superfund, emergency planning, and community right-to-know | | EPA 2006i; 40 CFR 302.4
| Designated CERCLA hazardous substance | Yes
| Reportable quantity
| Aluminum phosphide | 100 pounds
| Aluminum sulfate | 5,000 pounds
| Effective date of toxic chemical release reporting | | EPA 2006k; 40 CFR 372.65
| Aluminum (fume or dust) | 01/01/87
| Aluminum oxide (fibrous forms) | 01/01/87
| Aluminum phosphide | 01/01/95
| Extremely hazardous substances and their threshold planning quantities for aluminum phosphide | 500 pounds | EPA 2006j; 40 CFR 355, Appendix A
NTP | Carcinogenicity classification | No data | NTP 2004

a Group 1: carcinogenic to humans

b Reason for not establishing a guideline value: owing to limitations in the animal data as a model for humans and the uncertainty surrounding the human data, a health-based guideline value cannot be derived; however, practicable levels based on optimization of the coagulation process in drinking-water plants using aluminium-based coagulants are derived: ≤0.1 mg/L in large water treatment facilities, and ≤0.2 mg/L in small facilities.

c TWA: the value is for particulate matter containing no asbestos and <1% crystalline silica.

d AEGL-1 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience notable discomfort, irritation, or certain asymptomatic nonsensory effects. AEGL-2 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience irreversible or other serious, long-lasting adverse health effects or an impaired ability to escape. AEGL-3 is the airborne concentration of a substance above which it is predicted that the general population, including susceptible individuals, could experience life-threatening health effects or death.

e A4: not classifiable as a human carcinogen.

f Pesticide classified as restricted use: limited to use by or under the direct supervision of a certified applicator for agricultural crop uses. Criteria influencing restriction includes inhalation hazard to humans.

g Pesticide exemptions from the requirement of a tolerance: residues of the following materials are exempted from the requirement of a tolerance when used in accordance with good agricultural practice as inert (or occasionally active) ingredients in pesticide formulations applied to growing crops or to raw agricultural commodities after harvest.

ACGIH = American Conference of Governmental Industrial Hygienists; AEGL = Acute Exposure Guideline Level; Al = aluminum; CERCLA = Comprehensive Environmetnal Response, Compensation, and Liability Act; CFR = Code of Federal Regulations; CCC = Criterion Continuous Concentration; CMC = Criteria Maximum Concentration; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; IARC = International Agency for Research on Cancer; IRIS = Integrated Risk Information System; NIOSH = National Institute for Occupational Safety and Health; NOS = not otherwise specified; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit values; TWA = time-weighted average; USC = United States Code; WHO = World Health Organization