# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Aluminum is a naturally occurring element that appears in the second row of Group 13 (IIIA) of the periodic table (O’Neil et al. 2001). Table 4-1 lists common synonyms and other pertinent identification information for aluminum and selected aluminum compounds.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Aluminum is a silvery-white, malleable, and ductile metal. In moist air, a protective oxide coating of aluminum oxide is formed on its surface. In compounds, aluminum typically occurs in its +3 oxidation state (Lide 2005; O’Neil et al. 2001). Table 4-2 lists important physical and chemical properties of aluminum and selected aluminum compounds.

Table 4-1 Chemical Identity of Aluminum and Compounds^a^

Characteristic | Information
Chemical name | Aluminum | Aluminum chloride | Aluminum chlorohydrate (anhydrous) | Aluminum hydroxide | Aluminum lactate | Aluminum nitrate | Aluminum oxide | Aluminum phosphate | Aluminum phosphide | Aluminum fluoride | Aluminum sulfate anhydrous | Aluminum carbonate | Aluminum potassium sulfate | Alchlor
Synonym(s) | Aluminium^b^; alumina fibre; metana; aluminium bronze; aluminum dehydrated; aluminium flake; aluminum powder; aluminum-27; Noral aluminum; PAP-1 | Aluminum trichloride; aluminum chloride (1:3); Pearsall | Aluminol ACH; aluminum chloride hydroxide oxide, basic; aluminum chloride oxide; aluminum oxychloride; PAC 250A; Astringen; Chlorhydrol; Locron | alpha-Alumina trihydrate; alumina hydrate; alumina hydrated; aluminum oxide trihydrate; aluminum oxide hydrate; aluminum (III) hydroxide; hydrated alumina; hydrated aluminum oxide; aluminum hydrate; aluminum trihydrate; hydrated alumina; Alcoa 331/C 30BF/C 330/C 333; Alugel; Alumigel; BACO AF260; British Aluminum AF260; Calmogastrin; Higilite H 31S/ H 32/ H 42; Hychol 705; Hydrafil; Hydral 705/710; Martinal A/A-S/F-A; Reheis F 1000 | Aluminum, tris (2-hydroxypropanoato-O^1^,O^2^); propanoic acid, 2-hydroxy-, aluminum complex; aluminum tris (α-hydroxypropionate) | Aluminum trinitrate; aluminum (III) nitrate (1:3); nitric acid, aluminum salt; nitric acid, aluminum (3+) salt | Activated aluminum oxide; α-alumina; aluminum sesquioxide; aluminum trioxide; β-aluminum oxide; γ-alumina; Almite; Alon; Aloxite; Alumite; Alundum; Campalox; Dispal Alumina; Exolon XW 60; Faserton; Hypalox II; Ludox CL; Martoxin; Microgrit WCA; Poraminar | Aluminum orthophosphate; phosphoric acid; aluminum salt (1:1); Aluphos; Phosphaljel; Phosphalugel; aluminum monophosphate | Aluminum monophosphide; AL-Phos; AlP; Celphos; Delicia; Delicia Gastoxin; Detia; Phostoxin; Quickphos | Aluminum trifluoride | Alum; aluminum sulfate (2:3); cake alum; filter alum; papermaker’s alum; pearl alum; pickle alum; aluminum trisulfate; sulfuric acid, aluminum salt (3:2) | Carbonic acid, aluminium salt | Alum potassium; burnt alum; sulfuric acid, aluminum potassium salt (2:1:1); Tai-Ace K 150; Tai-Ace K 20 | Aluminum chloride hydroxide propylene glycol complex
Chemical formula | Al | AlCl_3_ | Unspecified^d^ | Al(OH)_3_ | C_9_H_15_AlO_9_ | Al(NO_3_)_3_ | Al_2_O_3_ | AlPO_4_ | AlP | AlF_3_ | Al_2_(SO_4_)_3_ | Al_2_O_3_·CO_2_; normal aluminum carbonate Al_2_(CO_3_)_3_ is not known as an individual compound^e^ | AlKO_8_S_2_ | Unspecified
Chemical structure | Al | Al^3+^ (Cl^−^)_3_ | Unspecified | Al^3+^ (OH^−^)_3_ | [image] | Al^3+^ (NO_3_^−^)_3_ | (Al^3+^)_2_ (O^2−^)_3_ | Al^3+^ PO_4_^3−^ | [image] | Al^3+^ (F^−^)_3_ | (Al^3+^)_2_ (SO_4_^2−^)_3_ | No data | K^+^ Al^3+^ (SO_4_^2−^)_2_ | Unspecified
Identification numbers:
CAS registry | 7429-90-5 | 7446-70-0 | 1327-41-9 | 21645-51-2 | 18917-91-4 | 13473-90-0^f^ | 1344-28-1 | 7784-30-7 | 20859-73-8 | 7784-18-1 | 10043-01-3 | 53547-27-6 | 10043-67-1 | 52231-93-3
EINECS | 231-072-3 | 231-208-1 | 215-477-2 | 244-492-7 | 242-670-9 | 236-751-8 | 215-691-6 | 232-056-9 | 244-088-0 | 232-051-1 | 233-135-0 | 238-440-2 | 233-141-3 | No data
NIOSH RTECS | BD330000 | BD0525000 | No data | BD0940000 | No data | No data | BD1200000 | TB6450000 | BD1400000^c^ | BD0725000 | BD1700000 | No data | No data | No data
EPA hazardous waste code | No data | D003 | No data | No data | No data | No data | No data | No data | P006 | No data | No data | No data | No data | No data
EPA Pesticide Chemical Code | 000111 | 013901 | No data | No data | No data | No data | No data | No data | 066501 | No data | 013906 | No data | No data | No data
DOT/UN/NA/IMCO shipping | UN 1309; UN 1396; IMO 4.1; IMO 4.3; NA 9260 | UN 1726; UN 2581; IMO 8.0 | No data | No data | No data | UN 1438; IMO 5.1 | No data | No data | UN 1397; UN 3048; IMO 4.3; IMO 6.1 | No data | NA 9078; NA 1760 | No data | No data | No data
HSDB | 507 | 607 | No data | 575 | No data | 574 | 506 | No data | 6035 | 600 | 5067 | No data | No data | No data

a All information obtained from ChemIDplus 2006, ChemFinder 2008, and HSDB 2008, except where noted.

b British spelling (Lewis 2001)

c NIOSH 1997

d Aluminum chlorohydrate: CAS No. 12042-91-0; Chemical formula: Al_2_ClH_5_O_5·_xH_2_O (ChemIDplus 2006)

e Lewis 2001

f Aluminum nitrate nonahydrate (CAS No. 7784-27-2)

CAS = Chemical Abstracts Service; DOT/UN/NA/IMO = Department of Transportation/United Nations/North America/Intergovernmental Maritime Dangerous Goods Code; EINECS = European Inventory of Existing Commercial Chemical Substances; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NIOSH = National Institute for Occupational Safety and Health; RTECS = Registry of Toxic Effects of Chemical Substances

Table 4-2 Physical and Chemical Properties of Aluminum and Compounds^a^

Property | Information
Chemical name | Aluminum | Aluminum chloride | Aluminum chlorohydrate | Aluminum hydroxide | Aluminum lactate | Aluminum nitrate | Aluminum oxide | Aluminum phosphate | Aluminum phosphide | Aluminum fluoride | Aluminum sulfate | Aluminum carbonate | Aluminum potassium sulfate | Alchlor
Molecular weight | 26.98 | 133.34 | No data | 78.01 | 294.19^b^ | 213.00 | 101.94 | 121.95^b^ | 57.95 | 83.98 | 342.14 | No data | 258.20 | No data
Color | Silver white | White when pure, ordinarily gray or yellow to greenish | Glassy^b^ | White | Colorless^c^ | Colorless^d^ | White | White^b^ | Dark gray or dark yellow | White | White, lustrous | White^c^ | White | No data
Physical state | Malleable, ductile metal; cubic crystal | White hexagonal deliquescent or moisture sensitive plates | Solid^b^ | Bulky, amorphous powder | Powder^c^ | Rhombic crystals^d^ | Crystalline powder | Infusible powder^b^ | Cubic crystals | Hexagonal crystals | Crystals, pieces, granules or powder | Lumps or powder^c^ | Powder | No data
Melting point | 660 °C | 192.6 °C | No data | 300 °C | No data | 73 °C^d^ | approximately 2,000 °C | >1,460 °C^b^ | 2,550 °C | 1,291 °C | Decomposes at 770 °C | No data | 92 °C^e^ | No data
Boiling point | 2,327 °C | 182.7 °C at 752 mm Hg (sublimation temperature) | No data | No data | No data | Decomposes at 135 °C^d^ | 2,980 °C | No data | No data | Sublimes at 1,272 °C and 760 mm Hg | No data | No data | Loses 18 H_2_O at 64.5 °C; anhydrous at 200 °C^e^ | No data
Density (g/cm^3^) | 2.70 | 2.48 | No data | 2.42 | No data | No data | 4.0 at 20 °C | 2.56^b^ | 2.85 at 15 °C | 3.10 | 1.61 | No data | 1.75^e^ | No data
Odor | Odorless | Strong odor of hydrogen chloride | No data | No data | No data | No data | Odorless | No data | Garlic odor | No data | Odorless | No data | Odorless^e^ | No data
Odor threshold: | | | | | | | | | | | | No data
Water | No data | 0.5 mg/L (calculating on the aluminum ion) | No data | No data | No data | No data | No data | No data | No data | No data | No data | | No data | No data
Air | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | | No data | No data
Solubility:
Water | Insoluble in water | Reacts violently with water producing hydrochloric acid and heat | Dissolves in H_2_O, forming slightly turbid colloidal solutions (up to 55% w/w)^b^ | Insoluble in water | Freely soluble in water^b^ | Very soluble in water^d^ | Soluble in cold water, 0.000098 g/100 cc; insoluble in hot water | Practically insoluble in water^b^ | Decomposes^b^ | 0.559 g/100 mL at 25 °C | Soluble in 1 part H_2_O | Insoluble^c^ | 1 gram dissolves in about 20 mL of cold water, about 1 mL of boiling water | No data
Other solvents | Soluble in HCl, H_2_SO_4_, hot water, and alkalies | Soluble in benzene, carbon tetrachloride, chloroform | No data | Soluble in alkaline or acid solutions | No data | Very soluble in alcohol; very slightly soluble in acetone; almost insoluble in ethyl acetate, pyridine^d^ | Very slightly soluble in acid, alkali | Practically insoluble in acetic acid; very slightly soluble in concentrated HCl and HNO_3_ acids^b^ | No data | Sparingly soluble in acids and alkalies; insoluble in alcohol and acetone | Insoluble in ethanol | Dissolves in hot HCl or H_2_SO_4_ acid^c^ | Practically insoluble in alcohol | No data
Partition coefficients:
Log K_ow_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Log K_oc_ | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
pH | No data | No data | ~4.3 (15% aqueous solution)^b^ | No data | No data | Aqueous solution is acidic^d^ | No data | No data | No data | No data | Aqueous solution (1 g/mL) not less than 2.9 | No data | Aqueous solutions are acidic | No data
Vapor pressure | 1 mm Hg at 1,284 °C | 1 mm Hg at 100 °C | No data | No data | No data | No data | 1 mm Hg at 2,158 °C | No data | No data | 1 mm Hg at 1,238 °C | Essentially zero | No data | No data | No data
Henry’s law constant | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Autoignition temperature | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flashpoint | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data
Flammability | Finely divided aluminum dust is easily ignited | Not combustible, but heating may produce irritants and toxic gases | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | Noncombustible^e^ | No data
Explosive limits | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data | No data

a All information obtained from HSDB 2008, except where noted.

b O’Neil et al. 2001

c Lewis 2001

d Aluminum nitrate nonahydrate (CAS No. 7784-27-2)

e Al_2_(SO_4_)_3_·K_2_SO_4_·24H_2_O (Lewis 2001)