# APPENDIX A ATSDR MINIMAL RISK LEVELS AND WORKSHEETS

The Comprehensive Environmental Response, Compensation, and Liability Act (CERCLA) [42 U .S.C. 9601 et seq.], as amended by the Superfund Amendments and Reauthorization Act (SARA) [Pub. L. 99–499], requires that the Agency for Toxic Substances and Disease Registry (ATSDR) develop jointly with the U.S. Environmental Protection Agency (EPA), in order of priority, a list of hazardous substances most commonly found at facilities on the CERCLA National Priorities List (NPL); prepare toxicological profiles for each substance included on the priority list of hazardous substances; and assure the initiation of a research program to fill identified data needs associated with the substances.

The toxicological profiles include an examination, summary, and interpretation of available toxicological information and epidemiologic evaluations of a hazardous substance. During the development of toxicological profiles, Minimal Risk Levels (MRLs) are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified duration of exposure. MRLs are based on noncancer health effects only and are not based on a consideration of cancer effects. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the no-observed-adverse-effect level/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (365 days and longer) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive chemical-induced end point considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Division of Toxicology and Environmental Medicine, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published levels. For additional information regarding MRLs, please contact the Division of Toxicology and Environmental Medicine, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop F-32, Atlanta, Georgia 30333.

## Aluminum Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aluminum
CAS Numbers: | 7429–90-5
Date: | June 2008
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [X] Intermediate [] Chronic
Graph Key: | 46
Species: | Mouse

[underlined: Minimal Risk Level]: 1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Golub MS, Germann SL. 2001. Long-term consequences of developmental exposure to aluminum in a suboptimal diet for growth and behavior in Swiss Webster mice. Neurotoxicol Teratol 23:365–372.11485839

[underlined: Experimental design]: Groups of pregnant Swiss Webster mice were exposed to 0, 100, 500, or 1,000 mg Al/kg diet on gestational days 0–21 and during lactation until day 21. On PND 21, one male and one female pup from each litter were placed on the same diet as the dam. The offspring were exposed until PND 35. The composition of the diet was modified from the National Research Council's recommendations; the investigators noted that the nutrients were reduced to correspond to the usual intake of these nutrients by young women. The average daily intakes of phosphorus, calcium, magnesium, iron, and zinc in women aged 18–24 years are 83, 56, 71, 69, and 67% of the RDA; these percents were used to modify the recommended dietary intake for the mice used in this study. Doses of 26, 130, and 260 mg Al/kg/day are calculated by averaging reported estimated doses of 10, 50, and 100 mg Al/kg/day for adults (i.e., at beginning of pregnancy) and 42, 210, and 420 mg Al/kg/day maximal intake during lactation. The doses at lactation were calculated using doses estimated in previous studies with similar exposure protocols performed by the same group of investigators (Golub et al. 1995). At 3 months of age, the females were tested for neurotoxicity using the Morris water maze. At 5 months of age, males were tested for motor activity and function using rotarod, grip strength, wire suspension, mesh pole descent, and beam traversal tests.

[underlined: Effect noted in study and corresponding doses]: No alterations in pregnancy weight gain or pup birth weights were observed. At PND 21, significant decreases in pup body weights were observed at 130 and 260 mg/kg/day. No information on maternal weight gain during lactation was reported; however, the investigators noted that the decrease in pup weight was not associated with reduced maternal food intake. At PND 35, the decrease in body weight was only significant at 260 mg/kg/day. On PND 90, female mice in the 260 mg/kg/day group weighed 15% less than controls. Decreases in heart and kidney weights were observed at 260 mg/kg/day in the females. Also, decreases in absolute brain weight were observed in females at 260 mg/kg/day and relative brain weights were observed at 26 or 260 mg/kg/day. In the males, significant decreases in body weight were observed at 130 (10%) and 260 (18%) mg/kg/day at 5 months; an increase in food intake was also observed these doses. In the Morris maze (tested at 3 months in females), fewer animals in the 260 mg/kg/day group had escape latencies of <60 seconds during sessions 1–3 (learning phase) and a relocation of the visible cues resulted in increased latencies at 130 and 260 mg/kg/day. Body weight did not correlate with latency to find the platform or with the distribution of quadrant times. The investigators concluded that controls used salient and/or nonsalient cues, 26 and 130 mg/kg/day animals used both cues, but had difficulty using only one cue, and 260 mg/kg/day animals only used the salient cues. In the males tested at 5 months, a significant decrease in hindlimb grip strength was observed at 260 mg/kg/day, an increase in the number of rotations on the rotorod as observed at 260 mg/kg/day, and a shorter latency to fall in the wire suspension test as was observed at 130 and 260 mg/kg/day. The investigators noted that there were significant correlations between body weight and grip strength and number of rotations. When hindlimb grip strength was statistically adjusted for body weight, the aluminum-exposed mice were no longer significantly different from controls.

[underlined: Reference]: Colomina MT, Roig JL, Torrente M, 2005. Concurrent exposure to aluminum and stress during pregnancy in rats: effects on postnatal development and behavior of the offspring. Neurotoxicol Teratol 27:565–574.16024221

[underlined: Experimental design]: Groups of female Sprague-Dawley rats were exposed to 0, 50, or 100 mg Al/kg/day aluminum nitrate nonahydrate in drinking water; citric acid (710, 355, and 710 mg/kg/day in the control, 50, and 100 ppm groups, respectively) was added to the drinking water to increase aluminum absorption. The adult rats were exposed to aluminum for 15 days prior to mating and the during gestation and lactation periods; after weaning, the pups were exposed to the same aluminum concentration as the mothers from postnatal day 21 through 68. The basal diet (Panlab rodent chow) contained 41.85 μg Al/g diet. Aluminum doses were calculated by adding the basal dietary aluminum doses (calculated using reference values for mature Sprague-Dawley rats) to reported aluminum doses from water; the total aluminum doses were 3, 53, and 103 mg Al/kg/day. In addition to aluminum exposure, some animals in each group underwent restraint stress for 2 hours/day on gestation days 6–20; the restraint consisted of placing the rats in cylindrical holders. The following neurobehavioral tests were performed on the offspring: righting reflex (PNDs 4, 5, 6), negative geotaxis (PNDs 7, 8, 9), forelimb grip strength (PNDs 10–13), open field activity (PND 30), passive avoidance (PND 35), and water maze (only tested at 53 mg/kg/day on PND 60). On PND 68, rats were killed and aluminum levels were measured in the cortex, hippocampus, striatum, cerebellum, and brainstem.

Effect noted in study and corresponding doses: No significant alterations in body weight, food consumption, or water consumption were observed during gestation in the dams exposed to aluminum. The investigators noted that decreases in water and food consumption were observed during the lactation period in the rats exposed to 103 mg Al/kg/day, but the data were not shown, and maternal body weight during lactation was not mentioned. No significant alterations in the number of litters, number of fetuses per litter, viability index, or lactation index were observed. Additionally, no differences in days at pinna detachment or eye opening were observed. Age at incisor eruption was significantly higher in males exposed to 53 mg/kg/day, but not in males exposed to 103 mg/kg/day or in females. A significant delay in age at testes descent was observed at 103 mg/kg/day and vagina opening was delayed at 53 and 103 mg/kg/day. A decrease in forelimb grip strength was observed at 103 mg/kg/day; no alterations in other neuromotor tests were observed. Additionally, no alterations in open field behavior or passive avoidance test were observed. In the water maze test, latency to find the hidden platform was decreased in the 53 mg/kg/day group on test day 2, but not on days 1 or 3; no significant alteration in time in the target quadrant was found.

[underlined: Dose and end point used for MRL derivation]: The Golub and Germann (2001) and Colomina et al. (2005) studies identify four end points that could be used as the point of departure for derivation of the intermediate-duration oral MRL:

(1) latency to fall off wire in wire suspension test; adverse effect level of 130 mg Al/kg/day, no effect level of 26 mg Al/kg/day (Golub and Germann 2001);
(2) latency to locate the platform following cue relocation in the water maze test; adverse effect level of 130 mg Al/kg/day, no effect level of 26 mg Al/kg/day (Golub and Germann 2001);
(3) decreased forelimb grip strength; adverse effect level of 103 mg Al/kg/day, no effect level of 53 mg Al/kg/day (Colomina et al. 2005); and
(5) delay in vagina opening; adverse effect level of 53 mg Al/kg/day, no effect level not identified (Colomina et al. 2005).

Benchmark dose modeling was considered for each of these end points. Continuous variable models in the EPA Benchmark Dose Software (BMDS version 1.3.2) were fit to the data. A change of 1 standard deviation from control was selected as the BMR. Benchmark dose modeling was not conducted for latency to fall from the wire and forelimb grip strength because it is unclear whether the data reported in Table 5 (Golub and Germann 2001) and Figure 2 (Colomina et al. 2005), respectively, was for the mean ±SEM or the mean ± standard deviation. For delay in maturation, none of the available models provided an adequate fit (as assessed by the p-values for variance); therefore, the data set is unsuitable for BMD modeling. For the change in the latency to find the platform, the constant variance linear model provided an adequate fit. However, the BMD (419 mg Al/kg/day) and BMDL (186 mg A l/kg/day) were higher than the dose at which the change in latency was statistically significant (130 mg Al/kg/day), suggesting that using the change of 1 standard deviation from controls may not be an appropriate BMR for these data.

Using a NOAEL/LOAEL approach, the NOAEL of 26 mg Al/kg/day identified in the Golub and Germann (2001) study was selected as the point of departure for the MRL.

[X] NOAEL [ ] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [ ] 10 for use of a LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

Modifying Factors used in MRL derivation:

- [X] 0.3 to account for possible differences in the bioavailability of the aluminum lactate used in the Golub and Germann (2001) study and the bioavailability of aluminum from drinking water and a typical U.S. diet.

No studies were identified that estimated the bioavailability of aluminum lactate following long-term dietary exposure; however, a bioavailability of 0.63% was estimated in rabbits receiving a single dose of aluminum lactate (Yokel and McNamara 1988). Yokel and McNamara (2001) and Powell and Thompson (1993) suggested that the bioavailability of aluminum from the typical U.S. diet was 0.1%; the bioavailability of aluminum from drinking water ranges from 0.07 to 0.39% (Hohl et al. 1994; Priest et al. 1998; Stauber et al. 1999; Steinhausen et al. 2004). These data suggest that aluminum lactate has a higher bioavailability than aluminum compounds typically found in drinking water or the diet.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? Golub and Germann (2001): Doses of 26, 130, and 260 mg Al/kg/day are calculated by averaging reported estimated doses of 10, 50 and 100 mg Al/kg/day for adults (i.e., at beginning of pregnancy), and 42, 210, and 420 mg Al/kg/day maximal intake during lactation. The doses at lactation were calculated using doses were estimated in previous studies with similar exposure protocols performed by the same group of investigators (e.g., Golub et al. 1995).

Colomina et al. (2005): Doses of 3, 53, and 103 mg Al/kg/day were calculated by adding the basal dietary aluminum doses (calculated using reference values for mature Sprague-Dawley rats) to reported aluminum doses from water.

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: The neurotoxicity and neurodevelopmental toxicity of aluminum are well-documented effects of aluminum in orally-exposed in mice and rats. A wide variety of behavioral tests were conducted in rats and mice; alterations in motor function were the most consistently observed effects. Decreases in forelimb and/or hindlimb grip strength have been observed in adult mice exposed to 195 mg Al/kg/day as aluminum lactate in the diet for 90 days (Golub et al. 1992b), mice (6 weeks of age at study beginning) exposed to 195 mg Al/kg/day as aluminum lactate in the diet for 5–7 weeks (Oteiza et al. 1993), the offspring of mice exposed on gestation day 1 through lactation day 21 to 155 mg Al/kg/day (Donald et al. 1989; Golub et al. 1995) or 250 mg Al/kg/day (Golub et al. 1995) as aluminum lactate, and the offspring of rats exposed to 103 mg Al/kg/day as aluminum nitrate in drinking water (with added citric acid) for 15 days prior to mating and on gestation day 1 through lactation day 21 (Colomina et al. 2005). Decreases in spontaneous motor activity were observed in mice exposed to 130 mg Al/kg/day for 6 weeks (Golub et al. 1989) or 195 mg Al/kg/day for 90 days (Golub et al. 1992b). Motor impairments have also been detected in mice in the wire suspension test in which offspring exposed to 130 mg Al/kg/day had a shorter latency to fall from the wire and in the rotorod test in which offspring exposed to 260 mg Al/kg/day had a higher number of rotations (which occur when the animals lost its footing, clung to the rod, and rotated with it for a full turn) (Golub and Germann 2001). Neurobehavioral alterations that have occurred at similar dose levels include decreased responsiveness to auditory or air-puff startle (Golub et al. 1992b, 1995), decreased thermal sensitivity (Golub et al. 1992a), increased negative geotaxis latency (Golub et al. 1992a), and increased foot splay (Donald et al. 1989). Additionally, one study found significant impairment in performance of the water maze test in offspring of mice exposed to 130 mg Al/kg/day on gestation day 1 through lactation day 21 (Golub and Germann 2001). Colomina et al. (2005) did not find alterations in this test in rats exposed to 53 mg Al/kg/day; however, this study did not run probe tests, which showed significant alterations in the Golub and Germann (2001) study. Other studies have utilized passive avoidance tests or operant training tests to evaluate potential impairment of cognitive function. However, the interpretation of the results of these tests is complicated by an increase in food motivation in aluminum exposed mice (Golub and Germann 1998).

In addition to the neurodevelopmental effects, there is also strong evidence that gestational and/or lactational exposure can cause other developmental effects. Aluminum does not appear to result in an increase in the occurrence of malformations and anomalies and does not typically affect birth weight. Gestation and/or lactation exposure can result in significant decreases in pup body weight gain in rats and mice (Colomina et al. 2005; Golub and Germann 2001; Golub et al. 1992a). The decreases in pup body weight are often associated with decreases in maternal body weight during the lactation phase of the study; however, decreases in body weight have also been observed in a cross-fostering study when gestation-exposed pups were nursed by control mice (Golub et al. 1992a). Other studies involving gestation and lactation exposure to aluminum did not find changes in pup growth in mice (Donald et al. 1989; Golub and Germann 1998; Golub et al. 1995). In rats, a delay in physical maturation, particularly delays in vagina opening, testes descent, and incisor eruption, has been reported at 53 mg Al/kg/day (Colomina et al. 2005).

[underlined: Agency Contacts (Chemical Managers)]: Sam Keith, Dennis Jones, Zemoria Rosemond

## Aluminum Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aluminum
CAS Numbers: | 7429–90-5
Date: | June 2008
Profile Status: | Final
Route: | [ ] Inhalation [X] Oral
Duration: | [ ] Acute [ ] Intermediate [X] Chronic
Graph Key: | 56
Species: | Mouse

[underlined: Minimal Risk Level:] 1 [X] mg/kg/day [ ] ppm

[underlined: Reference]: Golub MS, Germann SL, Han B, 2000. Lifelong feeding of a high aluminum diet to mice. Toxicology 150:107–117.10996667

[underlined: Experimental design]: Groups of 8 male and 10 female Swiss Webster mice were exposed to 7 or 1,000 μg Al/g diet as aluminum lactate in a purified diet. The investigators estimated adult doses of <1 and 100 mg/kg/day. The mice were exposed to aluminum from conception (via feeding the dams) through 24 months of age. Body weight, food intake, and clinical signs were determined during the last 6 months of the study. Neurobehavioral test battery (foot splay, temperature sensitivity, negative geotaxis, and grip strength), 1 hour spontaneous activity, and auditory startle tests were conducted at 18 and 24 months.

In a companion study, groups of 6–9 male and female Swiss Webster mice or 7 male and female C57BL/6J mice (number per sex were not reported) were exposed to 7 or 1,000 μg Al/g diet as aluminum lactate in a purified diet (<1 and 100 mg/kg/day) from conception (via feeding the dams) through 24 months of age. Body weight, food intake, and clinical signs were determined during the last 6 months of the study. Neurobehavioral test battery (foot splay, temperature sensitivity, negative geotaxis, and grip strength) and Morris maze testing were at 22–23 months of age.

[underlined: Effect noted in study and corresponding doses]: In the principal study, no significant alterations in mortality were observed. A significant decrease in body weight was observed in the female mice (approximately 20%). In the males, there was a significant increase in body weight (approximately 10%). No significant alterations in food intake were observed in either sex. However, food intake/g body weight was significantly higher in the aluminum exposed mice. No significant alterations in the occurrence of clinical signs or indications of neurodegenerative syndromes were found. Significant increases in relative spinal cord, heart, and kidney weights were found. Significant alterations in negative geotaxis and tail withdrawal time in the temperature sensitivity test (males only) were observed at 18 months. At 24 months, significant alterations in forelimb and hindlimb grip strength and temperature sensitivity were found in male and female mice. Forelimb and hindlimb grip strength was decreased and thermal sensitivity was decreased, as evidenced by an increase in tail withdrawal times. Auditory startle response tests could not be completed in the older mice. Similarly, vertical spontaneous movement could not be measured; no effect on horizontal movement was found.

In the companion study, no alterations in neurobehavioral battery test performance were observed; the investigators note that this may be due to the small number of animals per group. In general, aluminum-exposed mice performed better on the water maze test than controls.

[underlined: Dose and end point used for MRL derivation]: A LOAEL of 100 mg Al/kg/day for decreased forelimb and hindlimb grip strength and decreased thermal sensitivity. A benchmark dose approach for deriving an MRL was not utilized because the Golub et al. (2000) study only tested one aluminum group.

[ ] NOAEL [X] LOAEL

[underlined: Uncertainty Factors used in MRL derivation]:

- [X] 3 for use of a minimal LOAEL
- [X] 10 for extrapolation from animals to humans
- [X] 10 for human variability

Modifying Factors used in MRL derivation:

- [X] 0.3 to account for possible differences in the bioavailability of the aluminum lactate used in the Golub and Germann (2001) study and the bioavailability of aluminum from drinking water and a typical U.S. diet.

No studies were identified that estimated the bioavailability of aluminum lactate following long-term dietary exposure; however, a bioavailability of 0.63% was estimated in rabbits receiving a single dose of aluminum lactate (Yokel and McNamara 1988). Yokel and McNamara (2001) and Powell and Thompson (1993) suggested that the bioavailability of aluminum from the typical U.S. diet was 0.1%; the bioavailability of aluminum from drinking water ranges from 0.07 to 0.39% (Hohl et al. 1994; Priest et al. 1998; Stauber et al. 1999; Steinhausen et al. 2004). These data suggest that aluminum lactate has a higher bioavailability than aluminum compounds typically found in drinking water or the diet.

[underlined: Was a conversion factor used from ppm in food or water to a mg/body weight dose]? No (doses corresponding to food ppm levels were reported by investigators).

[underlined: If an inhalation study in animals, list conversion factors used in determining human equivalent dose]: Not applicable.

[underlined: Was a conversion used from intermittent to continuous exposure]? Not applicable.

[underlined: Other additional studies or pertinent information that lend support to this MRL]: A small number of animal studies examined the chronic toxicity of aluminum. Schroeder and Mitchener (1975a, 1975b) examined the systemic toxicity of aluminum following lifetime exposure of rats and mice to very low doses of aluminum sulfate in the drinking water. Although the levels of aluminum in diet were not reported, they are assumed to be low because the animals were fed a low-metal diet in metal-free environmental conditions. Studies conducted by Roig et al. (2006) and Golub et al. (2000) primarily focused on the neurotoxicity of aluminum following lifetime exposure (gestation day 1 through 24 months of age). In the Golub et al. (2000) study, significant decreases in forelimb and hindlimb grip strength, and a decrease in thermal sensitivity were observed in mice exposed to 100 mg Al/kg/day; negative geotaxis was significantly altered at 18 months, but not at 24 months. No effect on horizontal activity was observed. A 10% increase in body weight and a 20% decrease in body weight were observed in the males and females, respectively. In a companion study by this group, no significant cognitive impairments were found in the Morris water maze test; in fact, aluminum-exposed mice performed better than controls in the learning tasks. Roig et al. (2006) also found no significant alterations in performance on the Morris water maze in rats exposed to 100 mg Al/kg/day as aluminum nitrate in the drinking water (with added citric acid). Although significant differences were found between the two aluminum groups (50 and 100 mg Al/kg/day), this was primarily due to the improved performance (as compared to controls, no significant differences) in the 50 mg Al/kg/day group. Roig et al. (2006) also found no significant alterations in open field activity.

Additional support for the selection of these end points, and neurotoxicity in general, comes from a number of intermediate-duration studies that indicate that this is one of most sensitive targets of aluminum toxicity (Colomina et al. 2005; Donald et al. 1989; Golub and Germann 2001; Golub et al. 1992a, 1995).

[underlined: Agency Contacts (Chemical Managers)]: Sam Keith, Dennis Jones, Zemoria Rosemond