# CHAPTER 8 REFERENCES

Abalis IM, Eldefrawi ME, Eldefrawi AT. 1986. Effects of insecticides on GABA-induced chloride influx into rat brain microsacs. J Toxicol Environ Health 18(1):13–23. 10.1080/15287398609530844.3009836
Abdel Hamid ER, Sharaf NE, Ahmed HH, . 2020. In utero exposure to organochlorine pesticide residues and their potential impact on birth outcomes and fetal gender. Environ Sci Pollut Res Int 27(27):33703–33711. 10.1007/s11356-020-09411-x.32533481
Ackerman LB. 1980. Overview of human exposure to dieldrin residues in the environment and current trends of residue levels in tissue. Pestic Monit J 14(2):64–69.7232105
Adeshina F, Todd EL. 1990. Organochlorine compounds in human adipose tissue from north Texas. J Toxicol Environ Health 29(2):147–156. 10.1080/15287399009531379.1688952
Ahmad N, Harsas W, Marolt RS, . 1988. Total DDT and dieldrin content of human adipose tissue. Bull Environ Contam Toxicol 41(6):802–808. 10.1007/bf02021037.3233379
Ahmed FE, Hart RW, Lewis NJ. 1977a. Pesticide induced DNA damage and its repair in cultured human cells. Mutat Res 42(2):161–174. 10.1016/s0027-5107(77)80020-1.190533
Ahmed FE, Lewis NJ, Hart RW. 1977b. Pesticide induced ouabain resistant mutants in Chinese hamster V79 cells. Chem Biol Interact 19(3):369–374. 10.1016/0009-2797(77)90059-x.413633
Ahmed NA, Rawi SM, el-Behary MH. 1986. Effect of dieldrin injection on the level of certain amino acids and some enzymes in rat brain. Comp Biochem Physiol C 85(2):437–442. 10.1016/0742-8413(86)90222-7.2879704
Al-Antary TM, Alawi MA, Othman MA, . 2018. Persistent organic pesticide residues in human milk samples from southern governorates of Jordan in 2016/2017. Fresenius Environ Bull 27(1):9935.
Alavanja MC, Hofmann JN, Lynch CF, . 2014. Non-Hodgkin lymphoma risk and insecticide, fungicide and fumigant use in the agricultural health study. PLoS ONE 9(10):e109332. 10.1371/journal.pone.0109332.25337994
Al-Hachim GM. 1971. Effect of aldrin on the condition avoidance response and electroshock seizure threshold of offspring from aldrin-treated mother. Psychopharmacologia 21(4):370–373. 10.1007/bf02419059.5098935
Allen-Gil SM, Landers DH, Wade TL, . 1997. Heavy metal, organochlorine pesticide and polychlorinated biphenyl contamination in Arctic ground squirrels (Spermophilus parryi) in northern Alaska. Arctic 50(4):323–333. 10.14430/arctic1114.
Al-Omar MA, Abdul-Jalil FH, Al-Ogaily NH, . 1986. A follow-up study of maternal milk contamination with organochlorine insecticide residues. Environ Pollut Ser A Ecol Biol 42(1):79–91. 10.1016/0143-1471(86)90046-2.
Alvarado-Hernandez DL, Montero-Montoya R, Serrano-Garcia L, . 2013. Assessment of exposure to organochlorine pesticides and levels of DNA damage in mother-infant pairs of an agrarian community. Environ Mol Mutagen 54(2):99–111. 10.1002/em.21753.23355095
AMA. 1962. Semi-annual tabulation of reports submitted to the Registry on Blood Dyscrasias of the Study Group on Blood Dyscrasias. American Medical Association. AMA Vol. 6.
Amoateng-Adjepong Y, Sathiakumar N, Delzell E, . 1995. Mortality among workers at a pesticide manufacturing plant. J Occup Environ Med 37(4):471–478. 10.1097/00043764-199504000-00020.7670904
Anderson D, Styles JA. 1978. The bacterial mutation test. Six tests for carcinogenicity. Br J Cancer 37(6):924–930. 10.1038/bjc.1978.134.354673
Arruda JA, Cringan MS, Layher WG, . 1988. Pesticides in fish tissue and water from Tuttle Creek Lake, Kansas. Bull Environ Contam Toxicol 41(4):617–624. 10.1007/bf02021009.3224183
Ashwood-Smith MJ, Trevino J, Ring R. 1972. Mutagenicity of dichlorvos. Nature 240(5381):418–420. 10.1038/240418a0.4564322
Atkinson R, Carter WPL. 1984. Kinetics and mechanisms of the gas-phase reactions of ozone with organic compounds under atmospheric conditions. Chem Rev 84(5):437–470. 10.1021/cr00063a002.
Atlas E, Giam CS. 1988. Ambient concentration and precipitation scavenging of atmospheric organic pollutants. Water Air Soil Pollut 38:19–36. 10.1007/BF00279583.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Fed Regist 54(174):37618–37634.
ATSDR. 2007. Health consultation: Springdale Creek Apartments. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/SpringdaleCreekApts/SpringdaleCreekHC090507.pdf. December 11, 2019.
ATSDR. 2012. Health consultation: Surface soil and vapor intrusion Paone property. Atlanta, GA: Agency for Toxic Substances and Disease Registry. http://www.floridahealth.gov/environmental-health/hazardous-waste-sites/_documents/p/paone112612.pdf. December 11, 2019.
ATSDR. 2019. Aldrin/dieldrin. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry.
Avar P, Czegledi-Janko G. 1970. Occupational exposure to aldrin: Clinical and laboratory findings. Br J Ind Med 27(3):279–282. 10.1136/oem.27.3.279.4194425
Babot Z, Vilaro MT, Sunol C. 2007. Long-term exposure to dieldrin reduces gamma-aminobutyric acid type A and N-methyl-D-aspartate receptor function in primary cultures of mouse cerebellar granule cells. J Neurosci Res 85(16):3687–3695. 10.1002/jnr.21433.17663462
Bachowski S, Xu Y, Stevenson DE, . 1998. Role of oxidative stress in the selective toxicity of dieldrin in the mouse liver. Toxicol Appl Pharmacol 150(2):301–309. 10.1006/taap.1998.8372.9653061
Badawi AF, Cavalieri EL, Rogan EG. 2000. Effect of chlorinated hydrocarbons on expression of cytochrome P450 1A1, 1A2 and 1B1 and 2- and 4-hydroxylation of 17beta-estradiol in female Sprague-Dawley rats. Carcinogenesis 21(8):1593–1599.10910964
Baldwin MK, Robinson J, Parke DV. 1972. A comparison of the metabolism of HEOD (dieldrin) in the CF1 mouse with that in the CFE rat. Food Cosmet Toxicol 10(3):333–351. 10.1016/s0015-6264(72)80252-9.5045677
Baldwin MK, Bennett D, Beyon KI. 1977. The concentrations of aldrin and dieldrin and their photoisomers in the atmosphere. Pestic Sci 8:431–445.
Bandyopadhyay SK, Tiwari RK, Mitra A, . 1982b. Effects of L-ascorbic acid supplementation on dieldrin toxicity in rats. Arch Toxicol 50(3–4):227–232. 10.1007/bf00310854.7149987
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Baron RL, Walton MS. 1971. Dynamics of HEOD (dieldrin) in adipose tissue of the rat. Toxicol Appl Pharmacol 18(4):958–963. 10.1016/0041-008x(71)90241-9.5570244
Battersby NS, Wilson V. 1988. Evaluation of a serum bottle technique for assessing the anaerobic biodegradability of organic chemicals under methanogenic conditions. Chemosphere 17(12):2441–2460. 10.1016/0045-6535(88)90155-5.
Bauer-Hofmann R, Buchmann A, Wright AS, . 1990. Mutations in the Ha-ras proto-oncogene in spontaneous and chemically induced liver tumours of the CF1 mouse. Carcinogenesis 11(10):1875–1877. 10.1093/carcin/11.10.1875.2119910
Bauer-Hofmann R, Buchmann A, Mahr J, . 1992. The tumour promoters dieldrin and phenobarbital increase the frequency of c-Ha-ras wild-type, but not of c-Ha-ras mutated focal liver lesions in male C3H/He mice. Carcinogenesis 13(3):477–481. 10.1093/carcin/13.3.477.1312398
Beall ML, Nash RG. 1969. Crop seedling uptake of DDT, dieldrin, endrin, and heptachlor from soils. Agron J 61:571–575. 10.2134/agronj1969.00021962006100040027x.
Beall ML, Nash RG. 1971. Organochlorine insecticide residues in soybean plant tops: Root vs. vapor sorption. Agron J 63:460–464. 10.2134/agronj1971.00021962006300030034x.
Becker PR, Mackey EA, Demiralp R, . 1997. Concentrations of chlorinated hydrocarbons and trace elements in marine mammal tissues archived in the U.S. national biomonitoring specimen bank. Chemosphere 34(9–10):2067–2098. 10.1016/s0045-6535(97)00069-6.9159906
Bedford CT, Hutson DH. 1976. The comparative metabolism in rodents of the isomeric insecticides dieldrin and endrin. Chem Ind 10:440–447.
Bennett GW, Ballee DL, Hall RC, . 1974. Persistence and distribution of chlordane and dieldrin applied as termiticides. Bull Environ Contam Toxicol 11(1):64–69. 10.1007/bf01685030.4433785
Béranger R, Hardy EM, Binter AC, . 2020. Multiple pesticides in mothers’ hair samples and children’s measurements at birth: Results from the French national birth cohort (ELFE). Int J Hyg Environ Health 223(1):22–33. 10.1016/j.ijheh.2019.10.010.31708466
Bergersen EP. 1987. Aldrin, dieldrin, and mercury profiles in recent lake sediments at the Rocky Mountain Arsenal, Colorado. Arch Environ Contam Toxicol 16:61–67. 10.1007/BF01055360.
Bhatnagar P, Kumar S, Lal R. 1988. Uptake and bioconcentration of dieldrin, dimethoate and permethrin by Tetrahymena pyriformis. Water Air Soil Pollut 40(3–4):345–349. 10.1007/BF00163738.
Bhatnagar VK, Patel JS, Variya MR, . 1992. Levels of organochlorine insecticides in human blood from Ahmedabad (rural), India. Bull Environ Contam Toxicol 48(2):302–307. 10.1007/bf00194388.1537002
Bidleman TF. 1988. Atmospheric processes. Environ Sci Technol 22(4):361–367. 10.1021/es00169a002.
Bidleman TF. 1999. Atmospheric transport and air-surface exchange of pesticides. Water Air Soil Pollut 115(1/4):115–166. 10.1023/a:1005249305515.
Black AM. 1974. Self poisoning with dieldrin: A case report and pharmacokinetic discussion. Anaesth Intensive Care 2(4):369–374. 10.1177/0310057X7400200413.4614682
Bloomquist JR. 1992. Intrinsic lethality of chloride-channel-directed insecticides and convulsants in mammals. Toxicol Lett 60(3):289–298. 10.1016/0378-4274(92)90287-t.1375788
Bloomquist JR. 1993. Toxicology, mode of action and target site-mediated resistance to insecticides acting on chloride channels. Comp Biochem Physiol C 106(2):301–314. 10.1016/0742-8413(93)90138-b.7904908
Bloomquist JR, Soderlund DM. 1985. Neurotoxic insecticides inhibit GABA-dependent chloride uptake by mouse brain vesicles. Biochem Biophys Res Commun 133(1):37–43. 10.1016/0006-291x(85)91838-8.3000377
Bloomquist JR, Adams PM, Soderlund DM. 1986. Inhibition of gamma-aminobutyric acid-stimulated chloride flux in mouse brain vesicles by polychlorocycloalkane and pyrethroid insecticides. Neurotoxicology 7(3):11–20.2434890
Bonner MR, Freeman LE, Hoppin JA, . 2017. Occupational exposure to pesticides and the incidence of lung cancer in the agricultural health study. Environ Health Perspect 125(4):544–551. 10.1289/ehp456.27384818
Botello AV, Diaz G, Rueda L, . 1994. Organochlorine compounds in oysters and sediments from coastal lagoons of the Gulf of Mexico. Bull Environ Contam Toxicol 53(2):238–245. 10.1007/bf00192039.8086706
Bradman MA, Harnly ME, Draper W, . 1997. Pesticide exposures to children from California’s Central Valley: Results of a pilot study. J Expo Anal Environ Epidemiol 7(2):217–234.9185013
Bradman A, Whitaker D, Quiros L, . 2007. Pesticides and their metabolites in the homes and urine of farmworker children living in the Salinas Valley, CA. J Expo Sci Environ Epidemiol 17(4):331–349. 10.1038/sj.jes.7500507.16736054
Braune B, Muir D, DeMarch B, . 1999. Spatial and temporal trends of contaminants in Canadian Arctic freshwater and terrestrial ecosystems: A review. Sci Total Environ 230(1–3):145–207. 10.1016/s0048-9697(99)00038-8.10466229
Briggs GG. 1981. Theoretical and experimental relationships between soil adsorption, octanol-water partition coefficients, water solubilities, bioconcentration factors, and the parachor. J Agric Food Chem 29(5):1050–1059. 10.1021/jf00107a040.
Brock JW, Melnyk LJ, Caudill SP, . 1998. Serum levels of several organochlorine pesticides in farmers correspond with dietary exposure and local use history. Toxicol Ind Health 14(1–2):275–289. 10.1177/074823379801400117.9460180
Brown DP. 1992. Mortality of workers employed at organochlorine pesticide manufacturing plants - An update. Scand J Work Environ Health 18(3):155–161. 10.5271/sjweh.1593.1615289
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30. 10.1089/hwm.1988.5.1.
Brown VK, Hunter CG, Richardson A. 1964. A blood test diagnostic of exposure to aldrin and dieldrin. Br J Ind Med 21:283–286. 10.1136/oem.21.4.283.14249897
Brown LM, Blair A, Gibson R, . 1990. Pesticide exposures and other agricultural risk factors for leukemia among men in Iowa and Minnesota. Cancer Res 50(20):6585–6591.2208120
Buck WB, Van Note W. 1968. Aldrin poisoning resulting in dieldrin residues in meat and milk. J Am Vet Med Assoc 153:1472–1475.5693921
Budavari S, O’Neil MJ, Smith A, . 2001. Aldrin. In: The Merck index: An encyclopedia of chemicals, drugs, and biologicals. 13^th^ ed. Whitehouse Stadium, NJ: Merck and Co., Inc., 546–547.
Buisson RSK, Kirk PWW, Lester JN. 1988. The behavior of selected chlorinated organic micropollutants in the activated sludge process: A pilot plant study. Water Air Soil Pollut 37(3–4):419–432. 10.1007/BF00192951.
Buisson RSK, Kirk PWW, Lester JN. 1990. Fate of selected chlorinated organic compounds during semi-continuous anaerobic sludge digestion. Arch Environ Contam Toxicol 19:428–432. 10.1007/BF01054988.
Burt GS. 1975. Use of behavioral techniques in the assessment of environmental contaminants. In: Weiss B, Laties VG, eds. Behavioral toxicology. New York, NY: Plenum Press, 241–263.
Bus JS, Leber AP. 2001. Miscellaneous chlorinated hydrocarbon pesticides. In: Patty’s toxicology. 5^th^ ed. New York, NY: John Wiley and Sons, Inc., 635–649. 10.1002/0471435139.tox069.
Bush PB, Neary DG, Taylor JW, . 1986. Effects of insecticide use in a pine seed orchard on pesticide levels in fish. J Am Water Resour Assoc 22(5):817–827. 10.1111/j.1752-1688.1986.tb00756.x.
Cabral JR, Hall RK, Bronczyk SA, . 1979. A carcinogenicity study of pesticide dieldrin in hamsters. Cancer Lett 6(4–5):241–246. 10.1016/s0304-3835(79)80040-3.436118
Cabrera-Rodríguez R, Luzardo OP, Almeida-González M, . 2020. Database of persistent organic pollutants in umbilical cord blood: Concentration of organochlorine pesticides, PCBs, BDEs and polycyclic aromatic hydrocarbons. Data Brief 28:104918. 10.1016/j.dib.2019.104918.31879698
Calabrese EJ. 1978. Developmental processes. In: Pollutants and high risk groups: The biological basis of increased human susceptibility to environmental and occupational pollutants. New York, NY: John Wiley and Sons Inc., 4–33.
Calder IC, Maynard EJ, Turczynowicz L. 1993. Aldrin contamination at a school in South Australia. Bull Environ Contam Toxicol 51(2):185–192. 10.1007/bf00198879.8353380
CalEPA. 1995. Sampling for pesticide residues in California well water: 1995 Update of the well inventory data base. California Environmental Protection Agency.
Cameron HL, Foster WG. 2009. Developmental and lactational exposure to dieldrin alters mammary tumorigenesis in Her2/neu transgenic mice. PLoS ONE 4(1):e4303. 10.1371/journal.pone.0004303.19173004
Cantor KP, Blair A, Everett G, . 1992. Pesticides and other agricultural risk factors for non-Hodgkin’s lymphoma among men in Iowa and Minnesota. Cancer Res 52(9):2447–2455.1568215
Cantor KP, Strickland PT, Brock JW, . 2003. Risk of non-Hodgkin’s lymphoma and prediagnostic serum organochlorines: Beta-hexachlorocyclohexane, chlordane/heptachlor-related compounds, dieldrin, and hexachlorobenzene. Environ Health Perspect 111(2):179–183. 10.1289/ehp.4347.12573902
Carlson JN, Rosellini RA. 1987. Exposure to low doses of the environmental chemical dieldrin causes behavioral deficits in animals prevented from coping with stress. Psychopharmacology (Berl) 91(1):122–126. 10.1007/bf00690940.3029791
Caro JH, Taylor AW. 1971. Pathways of loss of dieldrin from soils under field conditions. J Agric Food Chem 19(2):379–384. 10.1021/jf60174a032.5546170
Castro TF, Yoshida T. 1971. Degradation of organochlorine insecticides in flooded soils in the Philippines. J Agric Food Chem 19(6):1168–1170. 10.1021/jf60178a041.5132645
CDC. 2019. Fourth national report on human exposure to environmental chemical. Updated table, March 2018, volume two. Atlanta, GA: Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/pdf/FourthReport_UpdatedTables_Volume1_Jan2019-508.pdf. December 11, 2019.
Chan CH, Perkins LH. 1989. Monitoring of trace organic contaminants in atmospheric precipitation. J Great Lakes Res 15(3):465–475. 10.1016/s0380-1330(89)71502-1.
Chata C, Palazzi P, Grova N, . 2019. Blood pharmacokinetic of 17 common pesticides in mixture following a single oral exposure in rats: implications for human biomonitoring and exposure assessment. Arch Toxicol 93(10):2849–2862. 10.1007/s00204-019-02546-y.31428841
Chatterjee S, Ray A, Bagchi P, . 1988a. Suppression of testicular steroidogenesis in rats by the organochlorine insecticide aldrin. Environ Pollut 51(2):87–94. 10.1016/0269-7491(88)90198-4.15092629
Chatterjee S, Ray A, Deb C, . 1988b. Effect of aldrin on accessory sex glands and plasma testosterone levels in rats. Andrologia 20(6):472–476.3228213
Chatterjee S, Ray A, Ghosh S, . 1988c. Effect of aldrin on spermatogenesis, plasma gonadotrophins and testosterone, and testicular testosterone in the rat. J Endocrinol 119(1):75–81. 10.1677/joe.0.1190075.3142959
Chatterjee S, Ray A, Bagchi P, . 1992. Estrogenic effects of aldrin and quinalphos in rats. Bull Environ Contam Toxicol 48(1):125–130. 10.1007/bf00197494.1581669
Chen Z, Zabik MJ, Leavitt RA. 1984. Comparative study of thin film photodegradative rates for 36 pesticides. In Eng Chem Prod Res Dev 23(1):5–11. 10.1021/i300013a002.
Chen D, Grimsrud TK, Langseth H, . 2020. Prediagnostic serum concentrations of organochlorine pesticides and non-Hodgkin lymphoma: A nested case-control study in the Norwegian Janus Serum Bank Cohort. Environ Res 187:109515. 10.1016/j.envres.2020.109515.32445944
Chernoff N, Kavlock RJ, Kathrein JR, . 1975. Prenatal effects of dieldrin and photodieldrin in mice and rats. Toxicol Appl Pharmacol 31(2):302–308. 10.1016/0041-008x(75)90165-9.1129800
Chipman JK, Walker CH. 1979. The metabolism of dieldrin and two of its analogues: The relationship between rates of microsomal metabolism and rates of excretion of metabolites in the male rat. Biochem Pharmacol 28(8):1337–1345. 10.1016/0006-2952(79)90435-0.444300
Cicchetti R, Argentin G. 2003. The role of oxidative stress in the in vitro induction of micronuclei by pesticides in mouse lung fibroblasts. Mutagenesis 18(2):127–132.12621067
Cicchetti R, Bari M, Argentin G. 1999. Induction of micronuclei in bone marrow by two pesticides and their differentiation with CREST staining: An in vivo study in mice. Mutat Res 439(2):239–248. 10.1016/s1383-5718(98)00185-5.10023071
CITI. 1992. Biodegradation and bioaccumulation data of existing chemicals based on the CSCL Japan. Chemical Inspection and Testing Institute. 4–19, 14–20.
Clark DE, Ivie GW, Camp BJ. 1981. Effects of dietary hexachlorobenzene on in vivo biotransformation, residue deposition, and elimination of certain xenobiotics by rats. J Agric Food Chem 29(3):600–608. 10.1021/jf00105a041.7251991
Clary T, Ritz B. 2003. Pancreatic cancer mortality and organochlorine pesticide exposure in California, 1989-1996. Am J Ind Med 43(3):306–313. 10.1002/ajim.10188.12594778
Clayton GD, Clayton FE. 1994. Dieldrin. In: Patty’s industrial hygiene and toxicology. 4^th^ ed. New York, NY: John Wiley and Sons, Inc., 1517–1523.
Cleveland FP. 1966. A summary of work on aldrin and dieldrin toxicity at the Kettering Laboratory. Arch Environ Health 13(2):195–198. 10.1080/00039896.1966.10664532.5968501
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131. 10.1177/074823378500100408.3843496
Cliath MM, Spencer WF. 1971. Movement and persistence of dieldrin and lindane in soil as influenced by placement and irrigation. Soil Sci Soc Am J 35(5):791–795. 10.2136/sssaj1971.03615995003500050044x.
Cole LM, Casida JE. 1986. Polychlorocycloalkane insecticide-induced convulsions in mice in relation to disruption of the GABA-regulated chloride ionophore. Life Sci 39(20):1855–1862. 10.1016/0024-3205(86)90295-x.2430161
Cole LK, Metcalf RL, Sanborn JR. 1976. Environmental fate of insecticides in terrestrial model ecosystems. Int J Environ Stud 10:7–14.
Cole RH, Frederick RE, Healy RP, . 1984. Preliminary findings of the priority pollutant monitoring project of the nationwide urban runoff program. J Water Pollut Control Fed 56:898–908.
Connell DW. 1989. Biomagnification by aquatic organisms - A proposal. Chemosphere 19(10–11):1573–1584. 10.1016/0045-6535(89)90501-8.
Costella JC, Virgo BB. 1980. Is dieldrin-induced congenital inviability mediated by central nervous system hyperstimulation or by altered carbohydrate metabolism. Can J Physiol Pharmacol 58(6):633–637. 10.1139/y80-104.7427783
Crebelli R, Bellincampi D, Conti G, . 1986. A comparative study on selected chemical carcinogens for chromosome malsegregation, mitotic crossing-over and forward mutation induction in Aspergillus nidulans. Mutat Res 172(2):139–149. 10.1016/0165-1218(86)90070-4.3531838
Crosby DG, Moilanen KW. 1974. Vapor-phase photodecomposition of aldrin and dieldrin. Arch Environ Contam Toxicol 2(1):62–74. 10.1007/bf01985801.4828554
Custer TW, Custer CM, Hines RK, . 1999. Organochlorine contaminants and reproductive success of double-crested cormorants from Green Bay, Wisconsin, USA. Environ Toxicol Chem 18(6):1209–1217. 10.1002/etc.5620180620.
Custer CM, Custer TW, Coffey M. 2000. Organochlorine chemicals in tree swallows nesting in pool 15 of the upper Mississippi River. Bull Environ Contam Toxicol 64:341–346. 10.1007/s001280000005.10757656
Davies K. 1988. Concentrations and dietary intake of selected organochlorines, including PCBs, PCDDs and PCDFs in fresh food composites grown in Ontario, Canada. Chemosphere 17(2):263–276. 10.1016/0045-6535(88)90219-6.
Davies D, Mes J. 1987. Comparison of the residue levels of some organochlorine compounds in breast milk of the general and indigenous Canadian populations. Bull Environ Contam Toxicol 39(5):743–749. 10.1007/bf01855849.3120831
Davis KJ, Fitzhugh OG. 1962. Tumorigenic potential of aldrin and dieldrin for mice. Toxicol Appl Pharmacol 4:187–189. 10.1016/0041-008X(62)90056-X.13883935
Davison KL. 1973. Dieldrin-^14^C balance in rats, sheep and chickens. Bull Environ Contam Toxicol 10:16–24. 10.1007/BF01684749.
De Flora S, Zanacchi P, Camoirano A, . 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133(3):161–198. 10.1016/0165-1110(84)90016-2.6374443
De Flora S, Camoirano A, Izzotti A, . 1989. Photoactivation of mutagens. Carcinogenesis 10(6):1089–1097. 10.1093/carcin/10.6.1089.2655963
de Jong G. 1991. Long-term health effects of aldrin and dieldrin. A study of exposure, health effects and mortality of workers engaged in the manufacture and formulation of the insecticides aldrin and dieldrin. Toxicol Lett Suppl:1–203.
de Jong G, Swaen GM, Slangen JJ. 1997. Mortality of workers exposed to dieldrin and aldrin: A retrospective cohort study. Occup Environ Med 54(10):702–707. 10.1136/oem.54.10.702.9404316
De Roos AJ, Zahm SH, Cantor KP, . 2003. Integrative assessment of multiple pesticides as risk factors for non-Hodgkin’s lymphoma among men. Occup Environ Med 60(9):E11.12937207
De Roos AJ, Hartge P, Lubin JH, . 2005. Persistent organochlorine chemicals in plasma and risk of non-Hodgkin’s lymphoma. Cancer Res 65(23):11214–11226. 10.1158/0008-5472.CAN-05-1755.16322272
de Solla SR, Bishop CA, Lickers H, . 2001. Organochlorine pesticides, PCBs, dibenzodioxin, and furan concentrations in common snapping turtle eggs (Chelydra serpentina serpentina) in Akwesasne, Mohawk Territory, Ontario, Canada. Arch Environ Contam Toxicol 40(3):410–417. 10.1007/s002440010191.11443374
de Vlieger M, Robinson J, Baldwin MK, . 1968. The organochlorine insecticide content of human tissues. Arch Environ Health 17(5):759–767. 10.1080/00039896.1968.10665317.4176803
Dean BJ, Doak SM, Somerville H. 1975. The potential mutagenicity of dieldrin (HEOD) in mammals. Food Cosmet Toxicol 13(3):317–323. 10.1016/s0015-6264(75)80292-6.1098983
Decloitre F, Chauveau J, Benoit A, . 1975. Metabolism et fixation in vitro par le DNA de thymus de veau et le proteines microsomiques de foie de rat de quelques pesticides organochlores et organophosphores. C R Acad Sci Hebd Seances Acad Sci D 280:1027–1030.51693
Deichmann WB, Keplinger M, Sala F, . 1967. Synergism among oral carcinogens. IV. The simultaneous feeding of four tumorigens to rats. Toxicol Appl Pharmacol 11(1):88–103. 10.1016/0041-008X(67)90030-0.6056159
Deichmann WB, Dressler I, Keplinger M, . 1968. Retention of dieldrin in blood, liver, and fat of rats fed dieldrin for six months. IMS Ind Med Surg 37(11):837–839.5246707
Deichmann WB, MacDonald WE, Blum E, . 1970. Tumorigenicity of aldrin, dieldrin and endrin in the albino rat. IMS Ind Med Surg 39(10):426–434.5273430
Deichmann WB, MacDonald WE, Beasley AG, . 1971. Subnormal reproduction in beagle dogs induced by DDT and aldrin. IMS Ind Med Surg 40(2):10–20.
den Tonkelaar EM, van Esch GJ. 1974. No-effect levels of organochlorine pesticides based on induction of microsomal liver enzymes in short-term toxicity experiments. Toxicology 2(4):371–380. 10.1016/0300-483x(74)90030-4.4137085
Dennis LK, Lynch CF, Sandler DP, . 2010. Pesticide use and cutaneous melanoma in pesticide applicators in the Agricultural Health Study. Environ Health Perspect 118(6):812–817. 10.1289/ehp.0901518.20164001
DeVault DS. 1985. Contaminants in fish from Great Lakes harbors and tributary mouths. Arch Environ Contam Toxicol 14:587–594. 10.1007/BF01055389.
DeVault DS, Milton Clark J, Lahvis G, . 1988. Contaminants and trends in Fall Run Coho salmon. J Great Lakes Res 14(1):23–33. 10.1016/s0380-1330(88)71529-4.
Dewailly E, Ayotte P, Bruneau S, . 2000. Susceptibility to infections and immune status in Inuit infants exposed to organochlorines. Environ Health Perspect 108(3):205–211. 10.1289/ehp.00108205.10706525
Ding JY, Wu SC. 1993. Laboratory studies of the effects of dissolved organic material on the adsorption of organochlorine pesticides by sediments and transport in rivers. Water Sci Technol 28(8–9):199–208. 10.2166/wst.1993.0619.
Ding JY, Wu SC. 1995. Partition coefficients of organochlorine pesticides on soil and on the dissolved organic matter in water. Chemosphere 30(12):2259–2266. 10.1016/0045-6535(95)00099-t.
Dingle JHP, Palmer WA, Black RR. 1989. Residues of DDT and dieldrin in the subcutaneous fat and butterfat of cattle. Aust J Exp Agric 29:497–501. 10.1071/EA9890497.
Ditraglia D, Brown DP, Namekata T, . 1981. Mortality study of workers employed at organochlorine pesticide manufacturing plants. Scand J Work Environ Health 7 Suppl 4:140–146.7330625
Dix KM, van der Pauw CL, McCarthy WV. 1977. Toxicity studies with dieldrin: Teratological studies in mice dosed orally with HEOD. Teratology 16(1):57–62. 10.1002/tera.1420160110.898091
Dobbs AJ, Williams N. 1983. Indoor air pollution from pesticides used in wood remedial treatments. Environ Pollut Ser B Chem Phys 6(4):271–296. 10.1016/0143-148x(83)90014-9.
Dobbs RA, Wang L, Govind R. 1989. Sorption of toxic organic compounds on wastewater solids: Correlation with fundamental properties. Environ Sci Technol 23(9):1092–1097. 10.1021/es00067a004.
DOE. 2018a. Table 3: Protective Action Criteria (PAC) Rev. 29a based on applicable 60-minute AEGLs, ERPGs, or TEELs. The chemicals are listed by CASRN. Oak Ridge, TN: U.S. Department of Energy. https://edms3.energy.gov/pac/docs/Revision_29A_Table3.pdf. April 12, 2020.
DOE. 2018b. Protective Action Criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A. Oak Ridge, TN: U.S. Department of Energy. https://edms3.energy.gov/pac/. April 12, 2020.
Donaldson GM, Shutt JL, Hunter P. 1999. Organochlorine contamination in bald eagle eggs and nestlings from the Canadian Great Lakes. Arch Environ Contam Toxicol 36(1):70–80. 10.1007/s002449900444.9828264
Dulout FN, Pastori MC, Olivero OA, . 1985. Sister-chromatid exchanges and chromosomal aberrations in a population exposed to pesticides. Mutat Res 143(4):237–244. 10.1016/0165-7992(85)90087-9.4022025
Dureja P, Walia S, Mukerjee SK. 1986. Amine-induced photodehalogenation of photoisomers of aldrin, dieldrin and endrin. Indian J Chem 25B(7):741–742.
Dwivedi N, Mahdi AA, Deo S, . 2021. Assessment of genotoxicity and oxidative stress in pregnant women contaminated to organochlorine pesticides and its correlation with pregnancy outcome. Environ Res 204(Pt B):112010. 10.1016/j.envres.2021.112010.34520748
Edwards JW, Priestly BG. 1994. Effect of occupational exposure to aldrin on urinary D-glucaric acid, plasma dieldrin, and lymphocyte sister chromatid exchange. Int Arch Occup Environ Health 66(4):229–234. 10.1007/bf00454360.7843832
Eichelberger JW, Lichtenberg JJ. 1971. Persistence of pesticides in river water. Environ Sci Technol 5(6):541–544. 10.1021/es60053a002.
Eisenreich SJ, Looney BB, Thornton JD. 1981. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Eisenreich SJ, Capel PD, Robbins JA, . 1989. Accumulation and diagenesis of chlorinated hydrocarbons in lacustrine sediments. Environ Sci Technol 23(9):1116–1126. 10.1021/es00067a009.
El-Aaser AB, Reid E, Stevenson DE. 1972. Alkaline phosphatase patterns in Dieldrin-treated dogs. Hoppe Seylers Z Physiol Chem 353(4):667–673. 10.1515/bchm2.1972.353.1.667.4340860
Elbeit IOD, Cotton DE, Wheelock V. 1983. Persistence of pesticides in soil leachates: Effect of pH ultra-violet irradiation and temperature. Int J Environ Stud 21:251–259.
Elgar KE. 1975. The dissipation and accumulation of aldrin and dieldrin residues in soil. Environ Qual Saf 3:250–257.
Elliot J. 1975. Monitoring of selected ecological components of the environment in four Alabama counties (1972-1974). In: Papers of environmental chemistry and human and animal health proceedings, 4^th^ annual conference, Auburn University. Auburn, AL: Alabama Cooperative Extension Service, 233–279.
Elliott JE, Machmer MM, Wilson LK, . 2000. Contaminants in ospreys from the Pacific Northwest: II. Organochlorine pesticides, polychlorinated biphenyls, and mercury, 1991-1997. Arch Environ Contam Toxicol 38(1):93–106. 10.1007/s002449910012.10556376
El-Saeid MH, Hassanin AS, Bazeyad AY. 2021. Levels of pesticide residues in breast milk and the associated risk assessment. Saudi J Biol Sci 28(7):3741–3744. 10.1016/j.sjbs.2021.04.062.34220226
Engel LS, Hill DA, Hoppin JA, . 2005. Pesticide use and breast cancer risk among farmers’ wives in the Agricultural Health Study. Am J Epidemiol 161(2):121–135. 10.1093/aje/kwi022.15632262
Ennaceur S, Gandoura N, Driss MR. 2008. Distribution of polychlorinated biphenyls and organochlorine pesticides in human breast milk from various locations in Tunisia: levels of contamination, influencing factors, and infant risk assessment. Environ Res 108(1):86–93. 10.1016/j.envres.2008.05.005. https://www.ncbi.nlm.nih.gov/pubmed/18614165.18614165
EPA. 1974. Consolidated aldrin/dieldrin hearing. U.S. Environmental Protection Agency. Fed Regist 39:37246–37251. https://www.loc.gov/item/fr039203/. January 10, 2020.
EPA. 1977. Evaluation of selected pesticides as chemical mutagens: In vitro and in vivo studies. Washington, DC: U.S. Environmental Protection Agency. EPA600177028. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100SHSP.txt. July 21, 2020.
EPA. 1980. Ambient water quality criteria for aldrin/dieldrin. Washington, DC: U.S. Environmental Protection Agency. EPA440580019. PB8111730OWRS. https://www.epa.gov/sites/production/files/2019-03/documents/ambient-wqc-aldrin-1980.pdf. December 12, 2019.
EPA. 1981. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. SW-889. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000KAVZ.txt. December 11, 2019.
EPA. 1985. Status of organic contaminants in Lake Huron: Atmosphere, water, algae, fish, herring gull eggs, and sediment. Chicago, IL: U.S. Environmental Protection Agency. http://name.umdl.umich.edu/4740146.0001.001. July 21, 2020.
EPA. 1986a. Guidance for the reregistration of pesticide products containing aldrin as the active ingredient. Washington, DC: U.S. Environmental Protection Agency. Case No. 0172. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101LR1A.txt. December 12, 2019.
EPA. 1986b. Superfund record of decision: Toftdahl Drums, WA. Washington, DC: U.S. Environmental Protection Agency. EPARODR1086009. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91000WIO.txt. December 12, 2019.
EPA. 1986c. Broad scan analysis of the FY82 national human adipose tissue survey specimens. Volume III. Semi-volatile organic compounds. Washington, DC: U.S. Environmental Protection Agency. EPA5605860037. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000HPHA.txt. December 12, 2019.
EPA. 1987a. Carcinogenicity assessment of aldrin and dieldrin. Washington, DC: U.S. Environmental Protection Agency. EPA600687006. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=30000Y8A.txt. December 12, 2019.
EPA. 1987b. List (phase 1) of hazardous constituents for ground-water monitoring. U.S. Environmental Protection Agency. Fed Regist 52:25942–25952. https://www.epa.gov/sites/production/files/2016-03/documents/52fr25942.pdf. December 12, 2019.
EPA. 1987c. Superfund record of decision: Gallaway Ponds, TN. Washington, DC: U.S. Environmental Protection Agency. EPARODR0486013. PB87189080. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91002B7W.txt. December 12, 2019.
EPA. 1988a. Hazardous waste management system: Identification and listing of hazardous waste. Fed Regist 53:13382–13393. https://www.epa.gov/sites/production/files/2016-03/documents/53fr34079.pdf. December 12, 2019.
EPA. 1988b. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600687008. PB888179874. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=34855. February 26, 2020.
EPA. 1989a. Chapman Chemical Co.: Notice of intent to cancel registration. U.S. Environmental Protection Agency. Fed Regist 54:8814–8816. https://www.loc.gov/item/fr054040/. July 21, 2020.
EPA. 1989b. Hydrolysis rate constants for enhancing property-reactivity relationships. Athens, GA: U.S. Environmental Protection Agency. EPA600389043. PB89220479. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=91013LBH.txt. December 12, 2019.
EPA. 1990a. Discarded commercial chemical products, off-specification species, container residues, and spill residues thereof. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 261.33. https://www.govinfo.gov/content/pkg/CFR-2012-title40-vol27/pdf/CFR-2012-title40-vol27-sec261-33.pdf. December 12, 2019.
EPA. 1990b. Title III list of lists: Consolidated list of chemicals subject to reporting under the emergency planning and community right-to-know act (Title III of the Superfund amendments and reauthorization act of 1986). Washington, DC: U.S. Environmental Protection Agency. EPA560490011. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000L66V.txt. December 12, 2019.
EPA. 1994. Method 8080A: Organochlorine pesticides and polychlorinated biphenyls by gas chromatography. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2015-12/documents/8081b.pdf. December 12, 2019.
EPA. 2001. Occurrence of unregulated contaminants in public water systems - a national summary. Washington, DC: U.S. Environmental Protection Agency. EPA815P00002. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P1005ONL.txt. December 11, 2019.
EPA. 2003. Health effects support document for aldrin/dieldrin. Washington, DC: U.S. Environmental Protection Agency. EPA822R03001. https://www.epa.gov/sites/production/files/2014-09/documents/support_cc1_aldrin-dieldrin_healtheffects.pdf. December 12, 2019.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001. https://ofmpub.epa.gov/apex/guideme_ext/guideme_ext/guideme/file/ry_2012_rfi.pdf. July 21, 2020.
EPA. 2005b. Provisional peer review toxicity values for aldrin (CASRN 309-00-2). Cincinnati, OH: U.S. Environmental Protectio Agency. EPA690R05002F. https://cfpub.epa.gov/ncea/pprtv/documents/Aldrin.pdf. December 13, 2019.
EPA. 2007a. Ecological soil screening levels for dieldrin (interim final). Washington, DC: U.S. Environmental Protection Agency. OSWER Directive 9285.7-56. https://www.epa.gov/sites/production/files/2015-09/documents/eco-ssl_dieldrin.pdf. July 23, 2020.
EPA. 2007b. Method 1699: Pesticides in water, soil, sediment, biosolids, and tissue by HRGC/HRMS. Washington, DC: U.S. Environmental Protection Agency. EPA821R08001. https://www.epa.gov/sites/production/files/2015-10/documents/method_1699_2007.pdf. December 11, 2019.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F09004. https://www.epa.gov/sites/production/files/2016-06/documents/npwdr_complete_table.pdf. December 13, 2019.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/sites/production/files/2018-03/documents/dwtable2018.pdf. December 13, 2019.
EPA. 2018b. Acute Exposure Guideline Levels (AEGLs) values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. December 13, 2019.
Epstein SS. 1975. The carcinogenicity of dieldrin. Part I. Sci Total Environ 4(1):1–52. 10.1016/0048-9697(75)90013-3 1096299
Epstein SS, Arnold E, Andrea J, . 1972. Detection of chemical mutagens by the dominant lethal assay in the mouse. Toxicol Appl Pharmacol 23(2):288–325. 10.1016/0041-008x(72)90192-5.5074577
Eye JD. 1968. Aqueous transport of dieldrin residues in soils. J Water Pollut Control Fed 40(8):R316–R332.
Fahrig R. 1974. Comparative mutagenicity studies with pesticides. IARC Sci Publ 10:161–181.
Farb RM, Sanderson T, Moore BG, . 1973. Interaction: The effect of selected mycotoxins on the tissue distribution and retention of aldrin and dieldrin in the neonatal rat. In: Inter-American conference on toxicology and occcupational medicine. New York, NY: Intercontinental Medical Book Corp, 179–187.
FDA. 1991. FDA monitoring program. Residues in foods--1990. J Assoc Off Anal Chem 74(5):121A–141A.
FDA. 1995. Food and Drug Administration pesticide program. Residue monitoring-1994. J AOAC Int 78(5):117A–142A. 10.1093/jaoac/78.5.117A.
FDA. 2006. Total diet study market baskets 1991-3 through 2003-4. U.S. Food and Drug Administration. https://www.fda.gov/media/77958/download. December 11, 2019.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Feldmann RJ, Maibach HI. 1974. Percutaneous penetration of some pesticides and herbicides in man. Toxicol Appl Pharmacol 28(1):126–132. 10.1016/0041-008x(74)90137-9.4853576
Fitzhugh OG, Nelson AA, Quaife ML. 1964. Chronic oral toxicity of aldrin and dieldrin in rats and dogs. Food Cosmet Toxicol 2:551–562.14249972
Flower KB, Hoppin JA, Lynch CF, . 2004. Cancer risk and parental pesticide application in children of Agricultural Health Study participants. Environ Health Perspect 112(5):631–635. 10.1289/ehp.6586.15064173
Foster WG, Mirshokraei P, Holloway AC, . 2008. Developmental and lactational exposure to environmentally relevant concentrations of dieldrin does not alter pregnancy outcome and mammary gland morphology in BALB/c mice. Environ Res 108(1):21–27. 10.1016/j.envres.2008.05.001.18573492
Fournier M, Chevalier G, Nadeau D, . 1988. Virus-pesticide interactions with murine cellular immunity after sublethal exposure to dieldrin and aminocarb. J Toxicol Environ Health 25(1):103–118. 10.1080/15287398809531192.3418741
Freedman B. 1989. Pesticides. In: Environmental ecology the impacts of pollution and other stresses on ecosystem structure and function. San Diego, CA: Academic Press, Inc., 180–224.
Freitag D, Ballhorn L, Geyer H, . 1985. Environmental hazard profile of organic chemicals. Chemosphere 14(10):1589–1616. 10.1016/0045-6535(85)90014-1.
Fries GF. 1972. Degradation of chlorinated hydrocarbons under anaerobic conditions. Adv Chem 111:256–270. 10.1021/ba-1972-0111.ch013.
Furusawa N. 2002. Distribution of aldrin and its epoxide (dieldrin) in egg-forming tissues and eggs of laying hens following an oral application. J Environ Sci Health B 37(2):123–129. 10.1081/pfc-120002984.11990366
Gaines TB. 1960. The acute toxicity of pesticides to rats. Toxicol Appl Pharmacol 2:88–99. 10.1016/0041-008x(60)90074-0.13825957
Galloway SM, Armstrong MJ, Reuben C, . 1987. Chromosome aberrations and sister chromatid exchanges in Chinese hamster ovary cells: Evaluations of 108 chemicals. Environ Mol Mutagen 10 Suppl 10:1–175. 10.1002/em.2850100502.3319609
Gammon MD, Wolff MS, Neugut AI, . 2002. Environmental toxins and breast cancer on Long Island. II. Organochlorine compound levels in blood. Cancer Epidemiol Biomarkers Prev 11(8):686–697.12163320
Gannon H, Bigger JH. 1958. The conversion of aldrin and heptachlor to their epoxides in soil. J Econ Entomol 51:1–7.
Gant DB, Eldefrawi ME, Eldefrawi AT. 1987. Cyclodiene insecticides inhibit GABAA receptor-regulated chloride transport. Toxicol Appl Pharmacol 88(3):313–321. 10.1016/0041-008x(87)90206-7.3033845
Garrettson LK, Curley A. 1969. Dieldrin: Studies in a poisoned child. Arch Environ Health 19(6):814–822. 10.1080/00039896.1969.10666935.5351682
Gartrell MJ, Craun JC, Podrebarac DS, . 1986a. Pesticides, selected elements, and other chemicals in adult total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):146–159.3949687
Gartrell MJ, Craun JC, Podrebarac DS, . 1986b. Pesticides, selected elements, and other chemicals in infant and toddler total diet samples, October 1980-March 1982. J Assoc Off Anal Chem 69(1):123–145.3949685
Georgian L. 1975. The comparative cytogenetic effects of aldrin and phosphamidon. Mutat Res 31(2):103–108. 10.1016/0165-1161(75)90072-2 1117881
Geyer H, Scheunert I, Korte F. 1986. Bioconcentration potential of organic environmental chemicals in humans. Regul Toxicol Pharmacol 6(4):313–347. 10.1016/0273-2300(86)90002-4.3101145
Geyer HJ, Scheunert I, Korte F. 1987. Correlation between the bioconcentration potential of organic environmental chemicals in humans and their n-octanol/water partition coefficients. Chemosphere 16(1):239–252. 10.1016/0045-6535(87)90128-7.
Glastonbury JR, Walker RI, Kennedy DJ, . 1987. Dieldrin toxicity in housed merino sheep. Aust Vet J 64(5):145–148. 10.1111/j.1751-0813.1987.tb09665.x.3632491
Glatt H, Jung R, Oesch F. 1983. Bacterial mutagenicity investigation of epoxides: Drugs, drug metabolites, steroids and pesticides. Mutat Res 111(2):99–118. 10.1016/0027-5107(83)90056-8.6355833
Glotfelty DE. 1978. The atmosphere as a sink for applied pesticides. J Air Pollut Control Assoc 28(9):917–921. 10.1080/00022470.1978.11490579.
Goel MR, Shara MA, Stohs SJ. 1988. Induction of lipid peroxidation by hexachlorocyclohexane, dieldrin, TCDD, carbon tetrachloride, and hexachlorobenzene in rats. Bull Environ Contam Toxicol 40(2):255–262. 10.1007/bf01881048.2450608
Good EE, Ware GW. 1969. Effects of insecticides on reproduction in the laboratory mouse. IV. Endrin and dieldrin. Toxicol Appl Pharmacol 14(1):201–203. 10.1016/0041-008x(69)90180-x.5813270
Graham MJ, Williams FM, Rettier AE, . 1987. Aldrin metabolism in the skin: In vitro and in vivo studies. In: Shroot B., Schaefer H, eds. 7th Symposium on advances in skin pharmacology, skin pharmacokinetics, Nice, France, September 26-28, 1986. New York, NY: S. Karger, 252–255.
Grayson BT, Fosbraey LA. 1982. Determination of the vapour pressure of pesticides. Pestic Sci 13(3):269–278. 10.1002/ps.2780130308.
Griffin DE, Hill WE. 1978. In vitro breakage of plasmid DNA by mutagens and pesticides. Mutat Res 52(2):161–169. 10.1016/0027-5107(78)90138-0.368611
Griffith J, Duncan RC. 1985. Serum organochlorine residues in Florida citrus workers compared to the National Health and Nutrition Examination Survey sample. Bull Environ Contam Toxicol 35(3):411–417. 10.1007/bf01636531.4041654
Guerin TF, Kennedy IR. 1992. Distribution and dissipation of endosulfan and related cyclodienes in sterile aqueous systems: Implications for studies on biodegradation. J Agric Food Chem 40(11):2315–2323. 10.1021/jf00023a052.
Guicherit R, Schulting FL. 1985. The occurrence of organic chemicals in the atmosphere of the Netherlands. Sci Total Environ 43(3):193–219. 10.1016/0048-9697(85)90129-9.4012295
Guillette LJ, Brock JW, Rooney AA, . 1999. Serum concentrations of various environmental contaminants and their relationship to sex steroid concentrations and phallus size in juvenile American alligators. Arch Environ Contam Toxicol 36(4):447–455. 10.1007/pl00006617.10227864
Gun RT, Pisaniello DL, Hann C, . 1992. Organochlorine pesticide exposure and uptake following treatment of domestic premises: Data from the first 6 months of follow-up. Int J Environ Health Res 2:52–59.
Gunderson EL. 1988. FDA Total Diet Study, April 1982-April 1984, dietary intakes of pesticides, selected elements, and other chemicals. J Assoc Off Anal Chem 71(6):1200–1209.3240978
Gupta PC. 1975. Neurotoxicity of chronic chlorinated hydrocarbon insecticide poisoning - A clinical and electroencephalographic study in man. Indian J Med Res 63(4):601–606.55381
Gupta HCL, Kavdia VS. 1979. Dissipation of aldrin residues in clay loam soil under the cover of root crops. Ind J Plant Protection 7:43–49.
Hallberg GR. 1989. Pesticides pollution of groundwater in the humid United States. Agric Ecosyst Environ 26(3–4):299–367. 10.1016/0167-8809(89)90017-0.
Hamilton HE, Morgan DP, Simmons A. 1978. A pesticide (dieldrin)-induced immunohemolytic anemia. Environ Res 17(2):155–164. 10.1016/0013-9351(78)90018-x.318510
Hansch C, Leo A, Hoekman D. 1995. Aldrin. In: Exploring QSAR: Hydrophobic, electronic, and steric constants. Washington, DC: American Chemical Society, 96.
Hardee DD, Gutenmann WH, Lisk DJ, . 1964. Zonal accumulation of dieldrin in soil and alfalfa residues. J Econ Entomol 57(4):583–585. 10.1093/jee/57.4.583.
Harr JR, Claeys RR, Bone JF, . 1970. Dieldrin toxidosis: Rat reproduction. Am J Vet Res 31(1):181–189.5414277
Hatcher JM, Richardson JR, Guillot TS, . 2007. Dieldrin exposure induces oxidative damage in the mouse nigrostriatal dopamine system. Exp Neurol 204(2):619–630. 10.1016/j.expneurol.2006.12.020.17291500
Haworth S, Lawlor T, Mortelmans K, . 1983. Salmonella mutagenicity test results for 250 chemicals. Environ Mutagen 5(Suppl 1):3–142.
Hayes WJ. 1974. Distribution of dieldrin following a single oral dose. Toxicol Appl Pharmacol 28(3):485–492. 10.1016/0041-008x(74)90233-6.4851411
Hayes WJ. 1982. Dieldrin. In: Pesticides studied in man. Baltimore, MD: The Williams & Wilkins Co., 234–247.
Hayes WJ, Curley A. 1968. Storage and excretion of dieldrin and related compounds: Effect of occupational exposure. Arch Environ Health 16(2):155–162. 10.1080/00039896.1968.10665037.5646438
Hearon SE, Wang M, Phillips TD. 2020. Strong adsorption of dieldrin by parent and processed montmorillonite clays. Environ Toxicol Chem 39(3):517–525. 10.1002/etc.4642.31756776
Heath DF, Vandekar M. 1964. Toxicity and metabolism of dieldrin in rats. Br J Ind Med 21:269–279. 10.1136/oem.21.4.269.14249895
Hergenrather J, Hlady G, Wallace B, . 1981. Pollutants in breast milk of vegetarians. N Engl J Med 304(13):792. 10.1056/NEJM198103263041322.7464895
Heusinkveld HJ, Westerink RH. 2012. Organochlorine insecticides lindane and dieldrin and their binary mixture disturb calcium homeostasis in dopaminergic PC12 cells. Environ Sci Technol 46(3):1842–1848. 10.1021/es203303r.22191981
Hill WH, McCarty PL. 1967. Anaerobic degradation of selected chlorinated hydrocarbon pesticides. J Water Pollut Control Fed 39(8):1259–1277.6074484
Hindin E, May DS, Dunstan GH. 1964. Collection and analysis of synthetic organic pesticides from surface and ground water. Residue Rev 7:132–156.4865261
Hodge HC, Boyce AM, Deichmann WB, . 1967. Toxicology and no-effect levels of aldrin and dieldrin. Toxicol Appl Pharmacol 10(3):613–675. 10.1016/0041-008x(67)90100-7.4964063
Hoff RM, Strachan WMJ, Sweet CW, . 1996. Atmospheric deposition of toxic chemicals to the Great Lakes: A review of data through 1994. Atmos Environ 30(20):3505–3527. 10.1016/1352-2310(96)00046-5.
Holt RL, Cruse S, Greer ES. 1986. Pesticide and polychlorinated biphenyl residues in human adipose tissue from Northeast Louisiana. Bull Environ Contam Toxicol 36(5):651–655. 10.1007/bf01623564.2423161
Hoogendam I, Versteeg JP, de Vlieger M. 1962. Electroencephalograms in insecticide toxicity. Arch Environ Health 4:86–94. 10.1080/00039896.1962.10663120.13908754
Hoogendam I, Versteeg JP, de Vlieger M. 1965. Nine years’ toxicity control in insecticide plants. Arch Environ Health 10:441–448. 10.1080/00039896.1965.10664026.14247341
Høyer AP, Grandjean P, Jorgensen T, . 1998. Organochlorine exposure and risk of breast cancer. Lancet 352(9143):1816–1820. 10.1016/s0140-6736(98)04504-8.9851382
Høyer AP, Jorgensen T, Rank F, . 2001. Organochlorine exposures influence on breast cancer risk and survival according to estrogen receptor status: A Danish cohort-nested case-control study. BMC Cancer 1:8.11518544
Høyer AP, Gerdes AM, Jorgensen T, . 2002. Organochlorines, p53 mutations in relation to breast cancer risk and survival. A Danish cohort-nested case-controls study. Breast Cancer Res Treat 71(1):59–65. 10.1023/a:1013340327099.11859874
Huestis SY, Servos MR, Michael Whittle D, . 1996. Temporal and age-related trends in levels of polychlorinated biphenyl congeners and organochlorine contaminants in Lake Ontario lake trout (Salvelinus namaycush). J Great Lakes Res 22(2):310–330. 10.1016/s0380-1330(96)70958-9.
Hundley HK, Cairns T, Luke MA, . 1988. Pesticide residue findings by the Luke method in domestic and imported foods and animal feeds for fiscal years 1982-1986. J Assoc Off Anal Chem 71(5):875–892.3235407
Hunt PF, Stevenson DE, Thorpe E, . 1975. Letters to the editor. Food Cosmet Toxicol 13:597–599.1201838
Hunter CG, Robinson J. 1967. Pharmacodynamics of dieldrin (HEOD). I. Ingestion by human subjects for 18 months. Arch Environ Health 15(5):614–626. 10.1080/00039896.1967.10664977.6066267
Hunter CG, Robinson J. 1968. Aldrin, dieldrin and man. Food Cosmet Toxicol 6(2):253–260. 10.1016/0015-6264(68)90206-x.5671153
Hunter CG, Robinson J, Roberts M. 1969. Pharmacodynamics of dieldrin (HEOD). Ingestion by human subjects for 18 to 24 months, and postexposure for eight months. Arch Environ Health 18(1):12–21. 10.1080/00039896.1969.10665367.5782491
Hunter J, Maxwell JD, Stewart DA, . 1972. Increased hepatic microsomal enzyme activity from occupational exposure to certain organochlorine pesticides. Nature 237(5355):399–401. 10.1038/237399a0.4557326
Hutson DH. 1976. Comparative metabolism of dieldrin in the rat (CFE) and in two strains of mouse (CF1 and LACG). Food Cosmet Toxicol 14(6):577–591. 10.1016/s0015-6264(76)80012-0.1017774
IARC. 1974a. Evaluation of the carcinogenic risk of chemicals to humans. Aldrin. Lyon, France: International Agency for Research on Cancer. IARC Monogr 5:25–38. https://publications.iarc.fr/23. July 21, 2020.
IARC. 1974b. Evaluation of the carcinogenic risk of chemicals to humans. Dieldrin. Lyon, France: International Agency for Research on Cancer. IARC Monogr 5:125–156. https://publications.iarc.fr/23. July 21, 2020.
IARC. 2019. Pentachlorophenol and some related compounds. IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: International Agency for Research on Cancer. Vol. 117, http://publications.iarc.fr/_publications/media/download/5717/3507e6ef7631cd3e073e5cb65415daa0b524989c.pdf. December 11, 2019.
Iatropoulos MJ, Milling WF, Muller WF, . 1975. Absorption, transport and organotropism of dichlorobiphenyl (DCB), dieldrin, and hexachlorobenzene (HCB) in rats. Environ Res 10(3):384–389. 10.1016/0013-9351(75)90033-x.1213019
Ibarluzea JM, Fernandez MF, Santa-Marina L, . 2004. Breast cancer risk and the combined effect of environmental estrogens. Cancer Causes Control 15(6):591–600. 10.1023/b:caco.0000036167.51236.86.15280638
Ikeda T, Nagata K, Shono T, . 1998. Dieldrin and picrotoxinin modulation of GABA(A) receptor single channels. Neuroreport 9(14):3189–3195.9831449
IRIS. 1987. Integrated risk information system (IRIS) chemical assessment summary: Aldrin; CASRN 309-00-2. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0130_summary.pdf. December 12, 2019.
IRIS. 1988. Integrated risk information system (IRIS) chemical assessment summary: Dieldrin; CASRN 60-57-1. U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0225_summary.pdf. December 12, 2019.
Jager KW. 1970. Aldrin, dieldrin, endrin and telodrin: An epidemiological and toxicological study of long-term occupational exposure. Amsterdam, Netherlands: Elsevier Publishing Company.
Jagnow G, Haider K. 1972. Evolution of ^14^CO_2_ from soil incubated with dieldrin-^14^C and the action of soil bacteria on labelled dieldrin. Soil Biol Biochem 4(1):43–49. 10.1016/0038-0717(72)90041-7.
Jamaluddin S, Poddar MK. 2001a. Role of brain regional GABA: Aldrin-induced stimulation of locomotor activity in rat. Neurochem Res 26(4):439–451.11495356
Jamaluddin S, Poddar MK. 2001b. Aldrin-induced stimulation of locomotor activity and brain regional glutamate. Methods Find Exp Clin Pharmacol 23(4):183–189.11676226
Jamaluddin S, Poddar MK. 2003. Brain regional gamma-aminobutyric acid (GABA) and locomotor activity: Effect of long-term aldrin exposure. Pol J Pharmacol 55(3):371–382.14506316
Jone C, Trosko JE, Aylsworth CF, . 1985. Further characterization of the in vitro assay for inhibitors of metabolic cooperation in the Chinese hamster V79 cell line. Carcinogenesis 6(3):361–366. 10.1093/carcin/6.3.361.3978751
Jorgenson JL. 2001. Aldrin and dieldrin: A review of research on their production, environmental deposition and fate, bioaccumulation, toxicology, and epidemiology in the United States. Environ Health Perspect 109 Suppl 1:113–139. 10.1289/ehp.01109s1113.11250811
Joy RM. 1982. Mode of action of lindane, dieldrin and related insecticides in the central nervous system. Neurobehav Toxicol Teratol 4(6):813–823.6188963
Jury WA, Winer AM, Spencer WF, . 1987. Transport and transformation of organic chemicals in the soil-air-water ecosystem. Environ Contam Toxicol 99:119–164.
Kailani MH, Arar S, Alawideh S. 2020. Organochlorine pesticides (OCPs) content in human gallbladder stones and gallbladder tissues as an indicator for pollution. Fresenius Environ Bull 29(8):7041–7064.
Kamendulis LM, Kolaja KL, Stevenson DE, . 2001. Comparative effects of dieldrin on hepatic ploidy, cell proliferation, and apoptosis in rodent liver. J Toxicol Environ Health 62(2):127–141. 10.1080/009841001455535.
Kanthasamy AG, Kitazawa M, Yang Y, . 2008. Environmental neurotoxin dieldrin induces apoptosis via caspase-3-dependent proteolytic activation of protein kinase C delta (PKCdelta): Implications for neurodegeneration in Parkinson’s disease. Molecular Brain 1:12. 10.1186/1756-6606-1-12.18945348
Kao CC, Que DE, Bongo SJ, . 2019a. Residue levels of organochlorine pesticides in breast milk and its associations with cord blood thyroid hormones and the offspring’s neurodevelopment. Int J Environ Res Public Health 16(8) 10.3390/ijerph16081438.
Kao CC, Chen CC, Avelino JL, . 2019b. Infants’ neurodevelopmental effects of PM2.5 and persistent organohalogen pollutants exposure in southern Taiwan. Aerosol and Air Quality Research 19(12):2793–2803. 10.4209/aaqr.2019.10.0550.
Kazantzis G, McLaughlin AI, Prior PF. 1964. Poisoning in industrial workers by the insecticide aldrin. Br J Ind Med 21:46–51. 10.1136/oem.21.1.46.14106135
Kazen C, Bloomer A, Welch R, . 1974. Persistence of pesticides on the hands of some occupationally exposed people. Arch Environ Health 29(6):315–318. 10.1080/00039896.1974.10666605.4279630
Keplinger ML, Deichmann WB, Sala F. 1970. Effects of combinations of pesticides on reproduction in mice. In: Pesticides symposia: Collection of papers presented at inter-American conferences on toxicology and occupational medicine, University of Miami School of Medicine. Miami, FL: Halos and Associates, 125–138.
Khairy M. 1960. Effects of chronic dieldrin ingestion on the muscular efficiency of rats. Br J Ind Med 17:146–148. 10.1136/oem.17.2.146.14408763
Kirk PWW, Lester JN. 1988. The behavior of chlorinated organics during activated sludge treatment and anaerobic digestion. Water Sci Technol 20:353–359. 10.2166/wst.1988.0306.
Kitazawa M, Anantharam V, Kanthasamy AG. 2001. Dieldrin-induced oxidative stress and neurochemical changes contribute to apoptotic cell death in dopaminergic cells. Free Radic Biol Med 31(11):1473–1485.11728820
Kitazawa M, Anantharam V, Kanthasamy AG. 2003. Dieldrin induces apoptosis by promoting caspase-3-dependent proteolytic cleavage of protein kinase Cdelta in dopaminergic cells: relevance to oxidative stress and dopaminergic degeneration. Neuroscience 119(4):945–964. http://www.ncbi.nlm.nih.gov/pubmed/12831855.12831855
Kitselman CD. 1953. Long term studies on dogs fed aldrin and dieldrin in sublethal dosages, with reference to the histopathological findings and reproduction. J Am Vet Med Assoc 132:28–30.
Klaunig JE, Ruch RJ. 1987. Strain and species effects on the inhibition of hepatocyte intercellular communication by liver tumor promoters. Cancer Lett 36(2):161–168. 10.1016/0304-3835(87)90087-5.3621148
Klaunig JE, Goldblatt PJ, Hinton DE, . 1984. Carcinogen induced unscheduled DNA synthesis in mouse hepatocytes. Toxicol Pathol 12(2):119–125. 10.1177/019262338401200202.11478312
Klaunig JE, Ruch RJ, Weghorst CM, . 1990. Role of inhibition of intercellular communication in hepatic tumor promotion. In Vitro Toxicol 3:91–107.
Klaunig JE, Xu Y, Bachowski S, . 1995. Oxidative stress in nongenotoxic carcinogenesis. Toxicol Lett 82–83:683–691.
Klaunig JE, Xu Y, Isenberg JS, . 1998. The role of oxidative stress in chemical carcinogenesis. Environ Health Perspect 106 Suppl 1:289–295. 10.1289/ehp.98106s1289.9539021
Klein AK, Link JD, Ives NF. 1968. Isolation and purification of metabolites found in the urine of male rats fed aldrin and dieldrin. J AOAC Int 51:895–898.
Klevay LM. 1970. Dieldrin excretion by the isolated perfused rat liver: A sexual difference. Toxicol Appl Pharmacol 17(3):813–815. 10.1016/0041-008x(70)90057-8.5495997
Kloskowski R, Scheunert I, Klein W, . 1981. Laboratory screening of distribution, conversion and mineralization of chemicals in the soil-plant-system and comparison to outdoor experimental data. Chemosphere 10(10):1089–1100. 10.1016/0045-6535(81)90178-8.
Kochmanski J, VanOeveren SE, Patterson JR, . 2019. Developmental dieldrin exposure alters DNA methylation at genes related to dopaminergic neuron development and Parkinson’s disease in mouse midbrain. Toxicol Sci 10.1093/toxsci/kfz069.
Kohli KK, Maggon KK, Venkitasubramanian TA. 1977. Induction of mixed function oxidases on oral administration of dieldrin. Chem Biol Interact 17(3):249–255. 10.1016/0009-2797(77)90089-8.880695
Kolaja KL, Stevenson DE, Johnson JT, . 1995a. Hepatic effects of dieldrin and phenobarbital in male B6C3F1 mice and Fisher 344 rats: species selective induction of DNA synthesis. Prog Clin Biol Res 391:397–408.8532732
Kolaja KL, Stevenson DE, Walborg EF, . 1995b. The effect of dieldrin and phenobarbital on preneoplastic hepatic lesion growth in male F344 rat and B6C3F1 mouse. Prog Clin Biol Res 391:409–423.8532733
Kolaja KL, Stevenson DE, Walborg EF, . 1996a. Selective dieldrin promotion of hepatic focal lesions in mice. Carcinogenesis 17(6):1243–1250.8681438
Kolaja KL, Xu Y, Walborg EF, . 1998. Vitamin E modulation of dieldrin-induced hepatic focal lesion growth in mice. J Toxicol Environ Health 53(6):479–492.
Kolpin DW, Barbash JE, Gilliom RJ. 2000. Pesticides in ground water of the United States, 1992-1996. Ground Water 38(6):858–863.
Kolpin DW, Squillace PJ, Zogorski JS, . 1997. Pesticides and volatile organic compounds in shallow urban groundwater of the United States. In: Chilton J, ed. Groundwater in the urban environment: Problems, processes and management. Iowa City, IA: U.S. Geological Survey, 469–474.
Korte F, Arent H. 1965. Metabolism of insecticides, IX (1). Isolation and identification of dieldrin metabolites from urine of rabbits after oral administration of dieldrin-14C. Life Sci 4(21):2017–2026. 10.1016/0024-3205(65)90317-6.5866617
Korte F, Kochen W. 1966. [Insecticides in metabolism. XI. Excretion, distribution and changes of aldrin-C14 and dieldrin-C14 in the rat]. Med Pharmacol Exp Int J Exp Med 15(4):404–408. (German)6012771
Koutros S, Beane Freeman LE, Lubin JH, . 2013a. Risk of total and aggressive prostate cancer and pesticide use in the Agricultural Health Study. Am J Epidemiol 177(1):59–74. 10.1093/aje/kws225.23171882
Koutros S, Berndt SI, Hughes Barry K, . 2013b. Genetic susceptibility loci, pesticide exposure and prostate cancer risk. PLoS ONE 8(4):e58195. 10.1371/journal.pone.0058195.23593118
Koutros S, Silverman DT, Alavanja MC, . 2016. Occupational exposure to pesticides and bladder cancer risk. Int J Epidemiol 45(3):792–805. 10.1093/ije/dyv195.26411407
Kowalski LA, Laitinen AM, Mortazavi-Asl B, . 2000. In vitro determination of carcinogenicity of sixty-four compounds using a bovine papillomavirus DNA-carrying C3H/10T(1/2) cell line. Environ Mol Mutagen 35(4):300–311.10861948
Krishnan K, Anderson ME, Clewell HJ, . 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic, Press Inc., 399–437.
Krohn C, Jin J, Ryan J, . 2019. Composition of soil organic matter drives total loss of dieldrin and dichlorodiphenyltrichloroethane in high-value pastures over thirty years. Sci Total Environ 691:135–145. 10.1016/j.scitotenv.2019.06.497.31319251
Krzystyniak K, Hugo P, Flipo D, . 1985. Increased susceptibility to mouse hepatitis virus 3 of peritoneal macrophages exposed to dieldrin. Toxicol Appl Pharmacol 80(3):397–408. 10.1016/0041-008x(85)90384-9.2994259
Kurata M, Hirose K, Umeda M. 1982. Inhibition of metabolic cooperation in Chinese hamster cells by organochlorine pesticides. Gann 73(2):217–221.7117752
Kutz FW, Yobs AR, Yang HSC. 1976. National pesticide monitoring programs. In: Lee RE, ed. Air pollution from pesticides and agricultural processes. Cleveland, OH: CRC Press, 95–136.
Kwok E, Atkinson R. 1995. Estimation of hydroxyl radical reaction rate constants for gas-phase organic compounds using a structure-reactivity relationship: An update. Atmos Environ 29(14):1685–1695. 10.1016/1352-2310(95)00069-b.
Lang B, Frei K, Maier P. 1986. Prostaglandin synthase dependent aldrin epoxidation in hepatic and extrahepatic tissues of rats. Biochem Pharmacol 35(20):3643–3645. 10.1016/0006-2952(86)90640-4.3094543
Lawrence LJ, Casida JE. 1984. Interactions of lindane, toxaphene and cyclodienes with brain-specific t-butylbicyclophosphorothionate receptor. Life Sci 35(2):171–178. 10.1016/0024-3205(84)90136-x.6204183
Lee WJ, Cantor KP, Berzofsky JA, . 2004a. Non-Hodgkin’s lymphoma among asthmatics exposed to pesticides. Int J Cancer 111(2):298–302. 10.1002/ijc.20273.15197786
Lee WJ, Lijinsky W, Heineman EF, . 2004b. Agricultural pesticide use and adenocarcinomas of the stomach and oesophagus. Occup Environ Med 61(9):743–749. 10.1136/oem.2003.011858.15317914
Lewis RG, Bond AE, Johnson DE, . 1988. Measurement of atmospheric concentrations of common household pesticides: A pilot study. Environ Monit Assess 10(1):59–73. 10.1007/BF00394257.24248528
Lewis RG, Fortmann RC, Camann DE. 1994. Evaluation of methods for monitoring the potential exposure of small children to pesticides in the residential environment. Arch Environ Contam Toxicol 26(1):37–46. 10.1007/bf00212792.8110022
Lichtenstein EP, Fuhremann TW, Schulz KR. 1971. Persistence and vertical distribution of DDT, lindane, and aldrin residues, 10 and 15 years after a single soil application. J Agric Food Chem 19(4):718–721. 10.1021/jf60176a023.4131508
Lin ZX, Kavanagh T, Trosko JE, . 1986. Inhibition of gap junctional intercellular communication in human teratocarcinoma cells by organochlorine pesticides. Toxicol Appl Pharmacol 83(1):10–19. 10.1016/0041-008x(86)90318-2.3952740
Lindqvist R, Enfield CG. 1992. Biosorption of dichlorodiphenyltrichloroethane and hexachlorobenzene in groundwater and its implications for facilitated transport. Appl Environ Microbiol 58(7):2211–2218. 10.1128/AEM.58.7.2211-2218.1992.1637158
Lipsky MM, Trump BF, Hinton DE. 1989. Histogenesis of dieldrin and DDT-induced hepatocellular carcinoma in Balb/c mice. J Environ Pathol Toxicol Oncol 9(1):79–93.2564434
Liu J, Morrow AL, Devaud L, . 1997a. GABA_A_ receptors mediate trophic effects of GABA on embryonic brainstem monoamine neurons in vitro. J Neurosci 17(7):2420–2428.9065503
Liu J, Morrow AL, Devaud LL, . 1997b. Regulation of GABA_A_ receptor subunit mRNA expression by the pesticide dieldrin in embryonic brainstem cultures: A quantitative, competitive reverse transcription-polymerase chain reaction study. J Neurosci Res 49(5):645–653. 10.1002/(SICI)1097-4547(19970901)49:5<645::AID-JNR15>3.0.CO;2-U.9302086
Lombardo P. 1986. The FDA Total Diet Study program. In: Kopfler FC, Craun GF, eds. Environmental epidemiology. New York, NY: Lewis Publishers, Inc., 141–148.
Lonare MK, Vemu B, Singh AK, . 2016. Cytotoxicity and oxidative stress alterations induced by aldrin in BALB/c 3t3 fibroblast cells. Proc Indian Natl Sci Acad B Biol Sci 87(4):1209–1216. 10.1007/s40011-015-0694-7.
Loose LD. 1982. Macrophage induction of T-suppressor cells in pesticide-exposed and protozoan-infected mice. Environ Health Perspect 43:89–97. 10.1289/ehp.824389.6460613
Loose LD, Silkworth JB, Charbonneau T, . 1981. Environmental chemical-induced macrophage dysfunction. Environ Health Perspect 39:79–92. 10.1289/ehp.813979.7238456
Louis LM, Lerro CC, Friesen MC, . 2017. A prospective study of cancer risk among Agricultural Health Study farm spouses associated with personal use of organochlorine insecticides. Environ Health 16(1):95. 10.1186/s12940-017-0298-1.28874165
Lovell RA, McChesney DG, Price WD. 1996. Organohalogen and organophosphorus pesticides in mixed feed rations: Findings from FDA’s domestic surveillance during fiscal years 1989-1994. J AOAC Int 79(2):544–548.8920144
Lu FC, Jessup DC, Lavallée A. 1965. Toxicity of pesticides in young versus adult rats. Food Cosmet Toxicol 3:591–596. 10.1016/s0015-6264(65)80206-1.5867575
Ludwig G, Weis J, Korte F. 1964. Excretion and distribution of aldrin-^14^C and its metabolites after oral administration for a long period of time. Life Sci 3:123–130. 10.1016/0024-3205(64)90191-2.
MacCuaig RD. 1976. The occurrence of insecticides in the blood of staff of a locust control organization. Bull Environ Contam Toxicol 15:162–170. 10.1007/BF01685155.56202
MacIntosh DL, Spengler JD, Ozkaynak H, . 1996. Dietary exposures to selected metals and pesticides. Environ Health Perspect 104(2):202–209. 10.1289/ehp.96104202.8820589
MacIntosh DL, Hammerstrom K, Ryan PB. 1999. Longitudinal exposure to selected pesticides in drinking water. Hum Ecol Risk Assess 5(3):575–588.
Majumdar SK, Kopelman HA, Schnitman MJ. 1976. Dieldrin-induced chromosome damage in mouse bone-marrow and WI-38 human lung cells. J Hered 67(5):303–307. 10.1093/oxfordjournals.jhered.a108736.1010933
Majumdar SK, Maharam LG, Viglianti GA. 1977. Mutagenicity of dieldrin in the Salmonella-microsome test. J Hered 68(3):184–185. 10.1093/oxfordjournals.jhered.a108805.330620
Markaryan D. 1966. Cytogenic effect of some chlororganic insecticides on mouse bone-marrow cell nuclei. Genetika 2(1):132–137.
Marsalek J, Schroeter H. 1988. Annual loadings of toxic contaminants in urban runoff from the Canadian Great Lakes Basin. Water Pollut Res J Can 23(3):360–378. 10.2166/wqrj.1988.026.
Marshall TC, Dorough HW, Swim HE. 1976. Screening of pesticides for mutagenic potential using Salmonella typhimurium mutants. J Agric Food Chem 24(3):560–563. 10.1021/jf60205a013.818141
Martin DB, Hartman WA. 1985. Organochlorine pesticides and polychlorinated biphenyls in sediment and fish from Wetlands in the north central United States. J Assoc Off Anal Chem 68(4):712–717.3928593
Mathur V, Bhatnagar P, Sharma RG, . 2002. Breast cancer incidence and exposure to pesticides among women originating from Jaipur. Environ Int 28(5):331–336.12437282
Matsumura F, Ghiasuddin SM. 1983. Evidence for similarities between cyclodiene type insecticides and picrotoxinin in their action mechanisms. J Environ Sci Health B 18(1):1–14. 10.1080/03601238309372355.6187794
Matsumura F, Patil KC, Boush GM. 1970. Formation of “photodieldrin” by microorganisms. Science 170(3963):1206–1207. 10.1126/science.170.3963.1206.5478193
Matthews HB, Matsumura F. 1969. Metabolic fate of dieldrin in the rat. J Agric Food Chem 17(4):845–852. 10.1021/jf60164a044.
Matthews HB, McKinney JD, Lucier GW. 1971. Dieldrin metabolism, excretion, and storage in male and female rats. J Agric Food Chem 19(6):1244–1248. 10.1021/jf60178a035.5132657
Maule A, Plyte S, Quirk AV. 1987. Dehalogenation of organochlorine insecticides by mixed anaerobic microbial populations. Pestic Biochem Physiol 27(2):229–236. 10.1016/0048-3575(87)90050-2.
McDougall KW, Wan H, Harris CR. 1994. The stability of dieldrin, aldrin, lindane, chlorpyrifos and prothiofos in stored roof water. J Environ Sci Health B B29(2):293–301.
McDuffie HH, Pahwa P, McLaughlin JR, . 2001. Non-Hodgkin’s lymphoma and specific pesticide exposures in men: Cross-Canada study of pesticides and health. Cancer Epidemiol Biomarkers Prev 10(11):1155–1163.11700263
McFall JA, Antoine SR, DeLeon IR. 1985. Organics in the water column of Lake Pontchartrain. Chemosphere 14(9):1253–1265. 10.1016/0045-6535(85)90146-8.
McGregor DB, Brown AG, Howgate S, . 1991. Responses of the L5178Y mouse lymphoma cell forward mutation assay. V: 27 coded chemicals. Environ Mol Mutagen 17(3):196–219.1902415
McLean JE, Sims RC, Doucette WJ, . 1988. Evaluation of mobility of pesticides in soil using U.S. EPA methodology. J Environ Eng (New York) 114:689–703. 10.1061/(ASCE)0733-9372(1988)114:3(689).
Mehendale HM, El-Bassiouni EA. 1975. Uptake and disposition of aldrin and dieldrin by isolated perfused rabbit lung. Drug Metab Dispos 3(6):543–556.1232
Mehrotra BD, Ravichandra Reddy S, Desaiah D. 1988. Effect of subchronic dieldrin treatment on calmodulin-regulated Ca^2+^ pump activity in rat brain. J Toxicol Environ Health 25(4):461–469. 10.1080/15287398809531224.2974087
Mehrotra BD, Moorthy KS, Reddy SR, . 1989. Effects of cyclodiene compounds on calcium pump activity in rat brain and heart. Toxicology 54(1):17–29. 10.1016/0300-483x(89)90075-9.2536969
Meierhenry EF, Ruebner BH, Gershwin ME, . 1983. Dieldrin-induced mallory bodies in hepatic tumors of mice of different strains. Hepatology 3(1):90–95.6295910
Mes J. 1994. Temporal changes in some chlorinated hydrocarbon residue levels of Canadian breast milk and infant exposure. Environ Pollut 84(3):261–268. 10.1016/0269-7491(94)90137-6.15091697
Mes J, Davies DJ, Doucet J, . 1993. Levels of chlorinated hydrocarbon residues in Canadian human breast milk and their relationship to some characteristics of the donors. Food Addit Contam 10(4):429–441. 10.1080/02652039309374166.8405582
Metcalf RL, Kapoor IP, Lu PY, . 1973. Model ecosystem studies of the environmental fate of six organochlorine pesticides. Environ Health Perspect 4:35–44. 10.1289/ehp.730435.4124493
Miao Y, Rong M, Li M, . 2021. Serum concentrations of organochlorine pesticides, biomarkers of oxidative stress, and risk of breast cancer. Environ Pollut 286:117386. 10.1016/j.envpol.2021.117386.34051689
Michalowicz J, Mokra K, Rosiak K, . 2013. Chlorobenzenes, lindane and dieldrin induce apoptotic alterations in human peripheral blood lymphocytes (in vitro study). Environ Toxicol Pharmacol 36(3):979–988. 10.1016/j.etap.2013.08.014.24077485
Miller MA, Madenjian CP, Masnado RG. 1992. Patterns of organochlorine contamination in lake trout from Wisconsin waters of the Great Lakes. J Great Lakes Res 18(4):742–754. 10.1016/s0380-1330(92)71333-1.
Millet M, Wortham H, Sanusi A, . 1997. Atmospheric contamination by pesticides: Determination in the liquid, gaseous and particulate phases. Environ Sci Pollut Res Int 4(3):172–180. 10.1007/BF02986327.19002404
Morgan DP, Roan CC. 1974. Liver function in workers having high tissue stores of chlorinated hydrocarbon pesticides. Arch Environ Health 29(1):14–17. 10.1080/00039896.1974.10666519.4842619
Morgan DP, Lin LI. 1978. Blood organochlorine pesticide concentrations, clinical hematology and biochemistry in workers occupationally exposed to pesticides. Arch Environ Contam Toxicol 7(4):423–447. 10.1007/bf02332069.755444
Morgan DP, Lin LI, Saikaly HH. 1980. Morbidity and mortality in workers occupationally exposed to pesticides. Arch Environ Contam Toxicol 9(3):349–382. 10.1007/bf01057414.7396557
Moriya M, Ohta T, Watanabe K, . 1983. Further mutagenicity studies on pesticides in bacterial reversion assay systems. Mutat Res 116(3–4):185–216. 10.1016/0165-1218(83)90059-9.6339892
Morrison DE, Robertson BK, Alexander M. 2000. Bioavailability to earthworms of aged DDT, DDE, DDD, and dieldrin in soil. Environ Sci Technol 34(4):709–713. 10.1021/es9909879.
Mossing ML, Redetzke KA, Applegate HG. 1985. Organochlorine pesticides in blood of persons from El Paso, Texas. J Environ Health 47:312–313.
Muir DCG, Koczanski K, Rosenberg B, . 1996. Persistent organochlorines in beluga whales (Delphinapterus leucas) from the St Lawrence River estuary - II. Temporal trends, 1982–1994. Environ Pollut 93(2):235–245. 10.1016/0269-7491(96)00008-5.15091362
Muirhead EE, Groves M, Guy R, . 1959. Acquired hemolytic anemia, exposures to insecticides and positive coombs test dependent on insecticide preparations. Vox Sang 4:277–292. 10.1111/j.1423-0410.1959.tb03629.x.14425063
Müller W, Nohynek G, Woods G, . 1975. Comparative metabolism of dieldrin - ^14^C in mouse, rat, rabbit, rhesus monkey and chimpanzee. Chemosphere 4(2):89–92. 10.1016/0045-6535(75)90019-3.
Müller W, Nohynek G, Korte F, . 1979. [Absorption, body distribution, metabolism, and excretion of dieldrin in non-human primates and other laboratory animals (author’s translation)]. Z Naturforsch C Biosci 34C(5–6):340–345. (German)156995
Murphy R, Harvey C. 1985. Residues and metabolites of selected persistent halogenated hydrocarbons in blood specimens from a general population survey. Environ Health Perspect 60:115–120. 10.1289/ehp.8560115.2411534
Murray HE, Beck JN. 1990. Concentrations of selected chlorinated pesticides in shrimp collected from the Calcasieu River/Lake Complex, Louisiana. Bull Environ Contam Toxicol 44(5):798–804. 10.1007/bf01701805.2111719
Nagata K, Narahashi T. 1994. Dual action of the cyclodiene insecticide dieldrin on the gamma-aminobutyric acid receptor-chloride channel complex of rat dorsal root ganglion neurons. J Pharmacol Exp Ther 269(1):164–171.8169820
Nagata H, Narahashi T. 1995. Multiple actions of dieldrin and lindane on the GABA_A_ receptor-chloride channel complex of rat dorsal root ganglion neurons. Pestic Sci 44:1–7.
Narahashi T, Frey JM, Ginsburg KS, . 1992. Sodium and GABA-activated channels as the targets of pyrethroids and cyclodienes. Toxicol Lett 64–65 Spec No:429–436. 10.1016/0378-4274(92)90216-7.
Narahashi T, Carter DB, Frey J, . 1995. Sodium channels and GABAA receptor-channel complex as targets of environmental toxicants. Toxicol Lett 82–83:239–245. 10.1016/0378-4274(95)03482-x.
Narahashi T, Ginsburg KS, Nagata K, . 1998. Ion channels as targets for insecticides. Neurotoxicology 19(4–5):581–590.9745915
NAS/NRC. 1989. Report of the oversight committee. Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council. 15–35.
Nash RG. 1983. Comparative volatilization and dissipation rates of several pesticides from soil. J Agric Food Chem 31(2):210–217. 10.1021/jf00116a007.
NCI. 1978a. Bioassays of aldrin and dieldrin for possible carcinogenicity. Bethesda, MD: National Cancer Institute. TR21. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr021.pdf. January 10, 2020.
NCI. 1978b. Bioassay of dieldrin for possible carcinogenicity. Bethesda, MD: National Cancer Institute. TR22. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr022.pdf. July 21, 2020.
Nerin C, Polo T, Demono C, . 1996. Determination of some organochlorine compounds in the atmosphere. Int J Anal Chem 65:83–94.
NIOSH. 1997. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. 8–9, 104–105. Publication No. 97-140.
NIOSH. 2019a. Aldrin. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0016.html. December 13, 2019.
NIOSH. 2019b. Dieldrin. NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0206.html. December 13, 2019.
NLM. 2020a. PubChem Compound summary: Aldrin. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/12310947. July 22, 2020.
NLM. 2020b. PubChem Compound summary: Dieldrin. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/969491. July 22, 2020.
Nojima K, Ohya T, Kaano S, . 1982. Studies on photochemical reactions of air pollutants. VIII. Photochemical epoxidation of olefins with NO_2_ in a solid-gas phase system. Chem Pharm Bull (Tokyo) 30(12):4500–4506.
Noren K, Meironyte D. 2000. Certain organochlorine and organobromine contaminants in Swedish human milk in perspective of past 20-30 years. Chemosphere 40(9–11):1111–1123. 10.1016/s0045-6535(99)00360-4.10739053
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. December 12, 2019.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2016a. Substances listed in the fourteenth report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. December 12, 2019.
NTP. 2016b. Genetic toxicity evaluation of aldrin in Salmonella/E. coli mutagenicity test or Ames test study 127997. Research Triangle Park, NC: National Toxicology Program. https://tools.niehs.nih.gov/cebs3/ntpViews/?studyNumber=002-01619-0001-0000-0. December 13, 2019.
NTP. 2016c. Genetic toxicity evaluation of dieldrin in Salmonella/E. coli mutagenicity test or Ames test study 127997. Research Triangle Park, NC: National Toxicology Program. http://tools.niehs.nih.gov/cebs3/ntpViews/?activeTab=detail&studyNumber=002-02021-0003-0000-0. December 13, 2019.
NTP. 2021. CASRN index. In: Report on carcinogens. 15th ed. National Toxicology Program, https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
Obata T, Yamamura HI, Malatynska E, . 1988. Modulation of gamma-aminobutyric acid-stimulated chloride influx by bicycloorthocarboxylates, bicyclophosphorus esters, polychlorocycloalkanes and other cage convulsants. J Pharmacol Exp Ther 244(3):802–806.2855243
Olson KL, Bousch GM, Matsumura F. 1980. Pre- and postnatal exposure to dieldrin: Persistent stimulatory and behavioral effects. Pestic Biochem Physiol 13:20–33.
Osaba L, Aguirre A, Alonso A, . 1999. Genotoxicity testing of six insecticides in two crosses of the Drosophila wing spot test. Mutat Res 439(1):49–61. 10.1016/s1383-5718(98)00173-9.10029675
OSHA. 2021a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1910/1910.1000TABLEZ1. December 16, 2021.
OSHA. 2021b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000. https://www.osha.gov/laws-regs/regulations/standardnumber/1915/1915.1000. December 16, 2021.
OSHA. 2022. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55. https://www.osha.gov/laws-regs/regulations/standardnumber/1926/1926.55. May 20, 2022.
Ottolenghi AD, Haseman JK, Suggs F. 1974. Teratogenic effects of aldrin, dieldrin, and endrin in hamsters and mice. Teratology 9(1):11–16. 10.1002/tera.1420090104.4204659
Pahwa P, Karunanayake CP, Dosman JA, . 2011. Soft-tissue sarcoma and pesticides exposure in men: results of a Canadian case-control study. J Occup Environ Med 53(11):1279–1286. 10.1097/JOM.0b013e3182307845.22068131
Patel TB, Rao VN. 1958. “Dieldrin” poisoning in man: A report of 20 cases observed in Bombay State. Br Med J 1(5076):919–921. 10.1136/bmj.1.5076.919.13523228
Patil KC, Matsumura F, Boush GM. 1970. Degradation of endrin, aldrin, and DDT by soil microorganisms. Appl Microbiol 19(5):879–881.4192889
Patil KC, Matsumura F, Boush GM. 1972. Metabolic transformation of DDT, dieldrin, aldrin, and endrin by marine microorganisms. Environ Sci Technol 6(7):629–632. 10.1021/es60066a012.
Pauwels A, Covaci A, Weyler J, . 2000. Comparison of persistent organic pollutant residues in serum and adipose tissue in a female population in Belgium, 1996-1998. Arch Environ Contam Toxicol 39(2):265–270. 10.1007/s002440010104.10871430
Pelletier M, Girard D. 2002. Dieldrin induces human neutrophil superoxide production via protein kinases C and tyrosine kinases. Hum Exp Toxicol 21(8):415–420. 10.1191/0960327102ht272oa.12412634
Pelletier M, Roberge CJ, Gauthier M, . 2001. Activation of human neutrophils in vitro and dieldrin-induced neutrophilic inflammation in vivo. J Leukoc Biol 70(3):367–373.11527985
Pennell KD, Hatcher JM, Caudle WM, . 2006. Elevated levels of dieldrin are associated with Parkinson’s disease. Prepr Ext Abstr Am Chem Soc 46(2):1125–1130.
Pi X, Qiao Y, Wang C, . 2020. Concentrations of organochlorine pesticides in placental tissue are not associated with risk for fetal orofacial clefts. Reprod Toxicol 98:99–106. 10.1016/j.reprotox.2020.08.013.32920085
Pick A, Joshua H, Leffkowitz M, . 1965. [Aplastic anemia following exposure to aldrin]. Medicine 68:164–167. (Hebrew)
Pico Y, Viana E, Font G, . 1995. Determination of organochlorine pesticide content in human milk and infant formulas using solid phase extraction and capillary gas chromatography. J Agric Food Chem 43(6):1610–1615. 10.1021/jf00054a036.
Polishuk ZW, Wassermann D, Wassermann M, . 1977a. Organochlorine compounds in mother and fetus during labor. Environ Res 13(2):278–284. 10.1016/0013-9351(77)90104-9.405211
Polishuk ZW, Ron M, Wasserman M, . 1977b. Pesticides in people: Organochlorine compounds in human blood plasma and milk. Pestic Monit J 10:121–129.857240
Pomes A, Rodriguez-Farre E, Sunol C. 1994. Effects of organochlorine pesticides on 36Cl- flux in primary neuronal cultures. Neurotoxicology 15(3):745–749.7531828
Probst GS, McMahon RE, Hill LE, . 1981. Chemically-induced unscheduled DNA synthesis in primary rat hepatocyte cultures: A comparison with bacterial mutagenicity using 218 compounds. Environ Mutagen 3(1):11–32. 10.1002/em.2860030103.7021142
Purdue MP, Hoppin JA, Blair A, . 2006. Occupational exposure to organochlorine insecticides and cancer incidence in the Agricultural Health Study. Int J Cancer 120(3):642–649. 10.1002/ijc.22258.
Quinsey PM, Donohue DC, Cumming FJ, . 1996. The importance of measured intake in assessing exposure of breast-fed infants to organochlorines. Eur J Clin Nutr 50(7):438–442.8862479
Quintana PJ, Delfino RJ, Korrick S, . 2004. Adipose tissue levels of organochlorine pesticides and polychlorinated biphenyls and risk of non-Hodgkin’s lymphoma. Environ Health Perspect 112(8):854–861. 10.1289/ehp.6726.15175172
Radomski JL, Deichmann WB, Clizer EE. 1968. Pesticide concentrations in the liver, brain and adipose tissue of terminal hospital patients. Food Cosmet Toxicol 6(2):209–220. 10.1016/0015-6264(68)90202-2.5671152
Ramamoorthy K, Wang F, Chen IC, . 1997. Estrogenic activity of a dieldrin/toxaphene mixture in the mouse uterus, MCF-7 human breast cancer cells, and yeast-based estrogen receptor assays: No apparent synergism. Endocrinology 138(4):1520–1527. 10.1210/endo.138.4.5056.9075711
Rami MVU, Reddy PP. 1986. Cytogenetic effects of aldrin and endosulfan in mice. IRCS J Med Sci 14:1125–1126.
RePORTER. 2019. Aldrin/dieldrin. Compounds. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. December 16, 2019.
Reuber MD. 1976. Histopathology of carcinomas of the liver in mice ingesting dieldrin or aldrin. Tumori 62(5):463–471.190743
Reuber MD. 1980. Significance of acute and chronic renal disease in Osborne-Mendel rats ingesting dieldrin or aldrin. Clin Toxicol 17(2):159–170. 10.3109/15563658008985075.7418362
Richard JJ, Junk GA, Avery MJ, . 1975. Analysis of various Iowa waters for selected pesticides: Atrazine, DDE, and dieldrin - 1974. Pestic Monit J 9:117–123.1221349
Richardson A, Robinson J. 1971. The identification of a major metabolite of HEOD (dieldrin) in human faeces. Xenobiotica 1(3):213–219. 10.3109/00498257109033170.5153711
Richardson JR, Caudle WM, Wang M, . 2006. Developmental exposure to the pesticide dieldrin alters the dopamine system and increases neurotoxicity in an animal model of Parkinson’s disease. FASEB J 20(10):1965–1697. 10.1096/fj.06-5864fje.
Richardson JR, Shalat SL, Buckley B, . 2009. Elevated serum pesticide levels and risk of Parkinson disease. Arch Toxicol 66(7):870–875. 10.1001/archneurol.2009.89.
Ritchie RJ, Ambrose S. 1996. Distribution and population of bald eagles (Haliaeetus leucocephalus) in interior Alaska. Arctic 49(2):120–128. 10.14430/arctic1190.
Ritchie JM, Vial SL, Fuortes LJ, . 2003. Organochlorines and risk of prostate cancer. J Occup Environ Med 45(7):692–702. 10.1097/01.jom.0000071510.96740.0b.12855910
Roberts JW, Camann DE. 1989. Pilot study of a cotton glove press test for assessing exposure to pesticides in house dust. Bull Environ Contam Toxicol 43(5):717–724. 10.1007/bf01701993.2804410
Robinson J, Roberts M, Baldwin M, . 1969. The pharmacokinetics of HEOD (Dieldrin) in the rat. Food Cosmet Toxicol 7(4):317–332. 10.1016/s0015-6264(69)80368-8.5823976
Rocchi P, Perocco P, Alberghini W, . 1980. Effect of pesticides on scheduled and unscheduled DNA synthesis of rat thymocytes and human lymphocytes. Arch Toxicol 45(2):101–108. 10.1007/bf01270907.7469786
Ronco AM, Marcus D, Villena F, . 1998. In vitro effect of dieldrin on Leydig cell morphology and steroidogenic function. In Vitro Mol Toxicol 11(4):299–307.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Ross CM. 1964. Sock dermatitis from dieldrin. Br J Dermatol 76:494–495. 10.1111/j.1365-2133.1964.tb15494.x.14213043
Ross RD, Crosby DG. 1975. The photooxidation of aldrin in water. Chemosphere 5:227–282.
Ross RD, Crosby DG. 1985. Photooxidant activity in natural waters. Environ Toxicol Chem 4(6):773–778. 10.1002/etc.5620040608.
Ruch RJ, Klaunig JE. 1986. Effects of tumor promoters, genotoxic carcinogens and hepatocytotoxins on mouse hepatocyte intercellular communication. Cell Biol Toxicol 2(4):469–483. 10.1007/bf00117849.2477123
Ruebner BH, Gershwin ME, Meierhenry EF, . 1984. Irreversibility of liver tumors in C3H mice. J Natl Cancer Inst 73(2):493–498.6589441
Russo M, Sobh A, Zhang P, . 2020. Functional pathway identification with CRISPR/Cas9 genome-wide gene disruption in human dopaminergic neuronal cells following chronic treatment with dieldrin. Toxicol Sci 176(2):366–381. 10.1093/toxsci/kfaa071.32421776
Saiki MK, Schmitt CJ. 1986. Organochlorine chemical residues in bluegills and common carp from the irrigated San Joaquin Valley Floor, California. Arch Environ Contam Toxicol 15(4):357–366. 10.1007/bf01066402.
Saleh MA, Abou Zied M, el-Baroty G, . 1993. Gamma aminobutyric acid radioreceptor-assay a possible biomarker for human exposure to certain agrochemicals. J Environ Sci Health B 28(6):687–699. 10.1080/03601239309372848.8270763
Saminathan H, Asaithambi A, Anantharam V, . 2011. Environmental neurotoxic pesticide dieldrin activates a non receptor tyrosine kinase to promote PKCdelta-mediated dopaminergic apoptosis in a dopaminergic neuronal cell model. Neurotoxicology 32(5):567–577. 10.1016/j.neuro.2011.06.009.21801747
Sanborn JR, Yu CC. 1973. The fate of dieldrin in a model ecosystem. Bull Environ Contam Toxicol 10(6):340–346. 10.1007/bf01721000.4149293
Sandifer SH, Cupp CM, Wilkins RT, . 1981. A case-control study of persons with elevated blood levels of dieldrin. Arch Environ Contam Toxicol 10(1):35–45. 10.1007/bf01057573.7235740
Sandler BE, Van Gelder GA, Elsberry DD, . 1969. Dieldrin exposure and vigilance behavior in sheep. Psychon Sci 15(5):261–262. 10.3758/bf03337412.
Satyanarayan S, Satyanarayan R, Satyanarayan A. 2004. Bioaccumulation kinetics and bioconcentration factor of chlorinated pesticides in tissues of Puntius ticto (Ham.). J Environ Sci Health B 39(2):321–332.15132338
Satyanarayan S, Satyanarayan R, Satyanarayan A. 2005. Bioaccumulation studies of organochlorinated pesticides in tissues of Cyprinus carpio. J Environ Sci Health B 40(3):397–412.15913013
Sauer TC, Durell GS, Brown JS, . 1989. Concentrations of chlorinated pesticides and PCBs in microlayer and seawater samples collected in open-ocean waters off the U.S. East Coast and in the Gulf of Mexico. Mar Chem 27(3–4):235–257. 10.1016/0304-4203(89)90050-9.
Sava V, Velasquez A, Song S, . 2007. Dieldrin elicits a widespread DNA repair and antioxidative response in mouse brain. J Biochem Mol Toxicol 21(3):125–135. 10.1002/jbt.20165.17623884
Savage EP, Keefe TJ, Tessari JD, . 1981. National study of chlorinated hydrocarbon insecticide residues in human milk, USA. I. Geographic distribution of dieldrin, heptachlor, heptachlor epoxide, chlordane, oxychlordane, and mirex. Am J Epidemiol 113(4):413–422. 10.1093/oxfordjournals.aje.a113109.7211826
Sawhney BL. 1989. Movement of organic chemicals through landfill and hazardous waste disposal. SSSA Spec Publ 22:448–474. 10.2136/sssaspecpub22.c18.
Saxena MC, Siddiqui MK, Bhargava AK, . 1980. Role of chlorinated hydrocarbon pesticides in abortions and premature labour. Toxicology 17(3):323–331. 10.1016/0300-483x(80)90013-x.7210017
Schecter A, Fürst P, Krüger C, . 1989a. Levels of polychlorinated dibenzofurans, dibenzodioxins, PCBS, DDT and DDE, hexachlorobenzene, dieldrin, hexachlorocyclohexanes and oxychlordane in human breast milk from the United States, Thailand, Vietnam, and Germany. Chemosphere 18(1–6):445–454. 10.1016/0045-6535(89)90154-9.
Schecter A, Fürst P, Fürst C, . 1989b. Levels of polychlorinated dibenzodioxins and dibenzofurans in cow’s milk and in soy bean derived infant formulas sold in the United States and other countries. Chemosphere 19(1–6):913–918. 10.1016/0045-6535(89)90431-1.
Schmidt JT, Rushin A, Boyda J, . 2017. Dieldrin-induced neurotoxicity involves impaired mitochondrial bioenergetics and an endoplasmic reticulum stress response in rat dopaminergic cells. Neurotoxicology 63:1–12. 10.1016/j.neuro.2017.08.007.28844784
Schmitt CJ, Zajicek JL, Ribick MA. 1985. National Pesticide Monitoring Program: Residues of organochlorine chemicals in freshwater fish, 1980-81. Arch Environ Contam Toxicol 14(2):225–260. 10.1007/bf01055615.3920980
Schroeder JC, Olshan AF, Baric R, . 2001. Agricultural risk factors for t(14;18) subtypes of non-Hodgkin’s lymphoma. Epidemiology 12(6):701–709.11679800
Shah HK, Sharma T, Banerjee BD. 2020. Organochlorine pesticides induce inflammation, ROS production, and DNA damage in human epithelial ovary cells: An in vitro study. Chemosphere 246:125691. 10.1016/j.chemosphere.2019.125691.31887490
Shakoori AR, Rasul YG, Ali SS. 1982. Effect of dieldrin feeding for six months on albino rats-biochemical and histological changes in liver. Pakistan J Z 14:191–204.
Shankland DL. 1982. Neurotoxic action of chlorinated hydrocarbon insecticides. Neurobehav Toxicol Teratol 4(6):805–811.6188962
Shannon LR. 1977. Equilibrium between uptake and elimination of dieldrin by channel catfish, Ictalurus punctatus. Bull Environ Contam Toxicol 17(3):278–283. 10.1007/bf01686080.558025
Sharma H, Zhang P, Barber DS, . 2010. Organochlorine pesticides dieldrin and lindane induce cooperative toxicity in dopaminergic neurons: Role of oxidative stress. Neurotoxicology 31(2):215–222. 10.1016/j.neuro.2009.12.007.20036686
Sharma D, Kumari S, Rani P, . 2021. Organochlorine pesticide dieldrin upregulate proximal promoter (PII) driven CYP19A1 gene expression and increases estrogen production in granulosa cells. Reprod Toxicol 10.1016/j.reprotox.2021.10.009.
Sharom MS, Miles JRW, Harris CR, . 1980. Persistence of 12 insecticides in water. Water Res 14(8):1089–1093. 10.1016/0043-1354(80)90157-8.
Shearer JJ, Sandler DP, Andreotti G, . 2021. Pesticide use and kidney function among farmers in the Biomarkers of Exposure and Effect in Agriculture study. Environ Res 199:111276. 10.1016/j.envres.2021.111276.33989625
Shirasu Y. 1975. Significance of mutagenicity testing on pesticides. Environ Qual Saf 4:226–231.811466
Shirasu Y, Moriya M, Kato K, . 1976. Mutagenicity screening of pesticides in the microbial system. Mutat Res 40(1):19–30. 10.1016/0165-1218(76)90018-5.814455
Shunthirasingham C, Gawor A, Hung H, . 2016. Atmospheric concentrations and loadings of organochlorine pesticides and polychlorinated biphenyls in the Canadian Great Lakes Basin (GLB): Spatial and temporal analysis (1992-2012). Environ Pollut 217:124–133. 10.1016/j.envpol.2016.01.039.26846187
Sittig M. 1980. Aldrin/dieldrin. In: Pesticide manufacturing and toxic materials control encyclopedia. Park Ridge, NJ: Noyes Data Corporation, 38–44, 301–305.
Sittig M. 1985. Aldrin/dieldrin. In: Handbook of toxic and hazardous chemicals and carcinogens. 2^nd^ ed. Park Ridge, NJ: Nyes Publications, 51–53, 338–341.
Slotkin TA, Seidler FJ. 2008. Developmental neurotoxicants target neurodifferentiation into the serotonin phenotype: Chlorpyrifos, diazinon, dieldrin and divalent nickel. Toxicol Appl Pharmacol 233(2):211–219. 10.1016/j.taap.2008.08.020.18835401
Slotkin TA, Seidler FJ. 2009a. Oxidative and excitatory mechanisms of developmental neurotoxicity: Transcriptional profiles for chlorpyrifos, diazinon, dieldrin, and divalent nickel in PC12 cells. Environ Health Perspect 117(4):587–596. 10.1289/ehp.0800251.19440498
Slotkin TA, Seidler FJ. 2009b. Protein kinase C is a target for diverse developmental neurotoxicants: Transcriptional responses to chlorpyrifos, diazinon, dieldrin and divalent nickel in PC12 cells. Brain Res 1263:23–32. 10.1016/j.brainres.2009.01.049.19368821
Smith RM, Cunningham WL, van Gelder GA, . 1976. Dieldrin toxicity and successive discrimination reversal in squirrel monkeys (Saimiri sciureus). J Toxicol Environ Health 1(5):737–747. 10.1080/15287397609529372.818400
Soto AM, Chung KL, Sonnenschein C. 1994. The pesticides endosulfan, toxaphene, and dieldrin have estrogenic effects on human estrogen-sensitive cells. Environ Health Perspect 102(4):380–383. 10.1289/ehp.94102380.7925178
Soto AM, Sonnenschein C, Chung KL, . 1995. The E-SCREEN assay as a tool to identify estrogens: An update on estrogenic environmental pollutants. Environ Health Perspect 103 Suppl 7:113–122. 10.1289/ehp.95103s7113.
Spalding RF, Junk GA, Richard JJ. 1980. Pesticides in ground water beneath irrigated farmland in Nebraska, August 1978. Pestic Monit J 14(2):70–73.7232106
Spiotta EJ. 1951. Aldrin poisoning in man: Report of a case. AMA Arch Ind Hyg Occup Med 4(6):560–566.14877315
Stacey CI, Tatum T. 1985. House treatment with organochlorine pesticides and their levels in human milk - Perth, Western Australia. Bull Environ Contam Toxicol 35(2):202–208. 10.1007/bf01636499.4027424
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4(2):131–142. 10.1002/etc.5620040202.
Stedeford T, Cardozo-Pelaez F, Nemeth N, . 2001. Comparison of base-excision repair capacity in proliferating and differentiated PC 12 cells following acute challenge with dieldrin. Free Radic Biol Med 31(10):1272–1278.11705706
Stehr-Green PA. 1989. Demographic and seasonal influences on human serum pesticide residue levels. J Toxicol Environ Health 27(4):405–421. 10.1080/15287398909531312.2760935
Stern AH. 2014. Hazard identification of the potential for dieldrin carcinogenicity to humans. Environ Res 131:188–214. 10.1016/j.envres.2014.02.007.24727642
Stevens RJJ, Neilson MA. 1989. Inter- and intralake distributions of trace organic contaminants in surface waters of the Great Lakes. J Great Lakes Res 15(3):377–393. 10.1016/s0380-1330(89)71494-5.
Stevenson DE, Kehrer JP, Kolaja KL, . 1995. Effect of dietary antioxidants on dieldrin-induced hepatotoxicity in mice. Toxicol Lett 75(1–3):177–183. 10.1016/0378-4274(94)03178-a.7863524
Stevenson DE, Walborg EF, North DW, . 1999. Monograph: Reassessment of human cancer risk of aldrin/dieldrin. Toxicol Lett 109(3):123–186. 10.1016/s0378-4274(99)00132-0.10555138
Strachan WMJ. 1988. Toxic contaminants in rainfall in Canada: 1984. Environ Toxicol Chem 7(11):871–877. 10.1002/etc.5620071103.
Strandberg B, Bandh C, van Bavel B, . 2000. Organochlorine compounds in the Gulf of Bothnia: sediment and benthic species. Chemosphere 40(9–11):1205–1211.10739063
Strassman SC, Kutz FW. 1977. Insecticide residues in human milk from Arkansas and Mississippi, 1973-74. Pestic Monit J 10(4):130–133.854395
Street JC, Chadwick RW. 1967. Stimulation of dieldrin metabolism by DDT. Toxicol Appl Pharmacol 11(1):68–71. 10.1016/0041-008x(67)90027-0.6056156
Stubin AI, Brosnan TM, Porter KD, . 1996. Organic priority pollutants in New York City municipal wastewaters: 1989-1993. Water Environ Res 68(6):1037–1044.
Sun F, Anantharam V, Latchoumycandane C, . 2005. Dieldrin induces ubiquitin-proteasome dysfunction in alpha-synuclein overexpressing dopaminergic neuronal cells and enhances susceptibility to apoptotic cell death. J Pharmacol Exp Ther 315(1):69–79. 10.1124/jpet.105.084632.15987830
Sundaram KS, Damodaran VN, Venkitasubramanian TA. 1978a. Absorption of dieldrin through monkey & dog skin. Indian J Exp Biol 16(1):101–103.
Sundaram KS, Damodaran VN, Venkitasubramanian TA. 1978b. Absorption of dieldrin through skin. Indian J Exp Biol 16(9):1004–1007.721147
Suskind RR. 1959. The cutaneous appraisal of several fabrics treated with dieldrin. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Suzuki M, Yamato Y, Watanabe T. 1974. Photodieldrin residues in field soils. Bull Environ Contam Toxicol 12(3):275–280. 10.1007/bf01709119.4433874
Swaen GM, de Jong G, Slangen JJ, . 2002. Cancer mortality in workers exposed to dieldrin and aldrin: an update. Toxicol Ind Health 18(2):63–70. 10.1191/0748233702th132oa.12868794
Swann RL, Laskowski DA, McCall PJ, . 1983. A rapid method for the estimation of the environmental parameters octanol/water partition coefficient, soil sorption constant, water to air ratio, and water solubility. Residue Rev 85:17–28.
Swenberg JA, Petzold GL, Harbach PR. 1976. In vitro DNA damage/alkaline elution assay for predicting carcinogenic potential. Biochem Biophys Res Commun 72(2):732–738. 10.1016/s0006-291x(76)80100-3.985507
Syversen U, Waldum HL, Slordahl KW, . 2000. Synergistic effect of the pesticides toxaphene and dieldrin on bone mineral density in rats. J Bone Miner Res 15(Suppl 1):S451.
Szeto SY, Price PM. 1991. Persistence of pesticide residues in mineral and organic soils in the Fraser Valley of British Columbia. J Agric Food Chem 39(9):1679–1684. 10.1021/jf00009a027.
Takei GH, Kauahikaua SM, Leong GH. 1983. Analyses of human milk samples collected in Hawaii for residues of organochlorine pesticides and polychlorobiphenyls. Bull Environ Contam Toxicol 30(5):606–613. 10.1007/bf01610182.6407553
Tennekes HA, Wright AS, Dix KM. 1979. The effects of dieldrin, diet and other environmental components on enzyme function and tumour incidence in livers of CF-1 mice. Arch Toxicol Suppl (2):197–212.
Tennekes HA, Edler L, Kunz HW. 1982. Dose-response analysis of the enhancement of liver tumour formation in CF-1 mice by dieldrin. Carcinogenesis 3(8):941–945.7127675
Tennekes HA, Wright AS, Dix KM, . 1981. Effects of dieldrin, diet, and bedding on enzyme function and tumor incidence in livers of male CF-1 mice. Cancer Res 41(9 Pt 1):3615–3620.7260918
Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. Environmental behavior of organic compounds. New York, NY: McGraw-Hill, 15–34.
Thorpe E, Walker AI. 1973. The toxicology of dieldrin (HEOD). II. Comparative long-term oral toxicity studies in mice with dieldrin, DDT, phenobarbitone, -BHC and -BHC. Food Cosmet Toxicol 11(3):433–442.4125578
Tomlin CDS. 1997. Aldrin. In: The Pesticide manual. 11^th^ ed. Farnham, Surrey: British Crop Protection Council, 1283, 1310.
Travis CC, Arms AD. 1988. Bioconcentration of organics in beef, milk, and vegetation. Environ Sci Technol 22(3):271–274. 10.1021/es00168a005.22288859
Treon JF, Cleveland FP. 1955. Toxicity of certain chlorinated hydrocarbon insecticides for laboratory animals, with special reference to aldrin and dieldrin. J Agric Food Chem 3(5):402–408. 10.1021/jf60051a002.
Treon JF, Gahegen T, Coomer J. 1952. The immediate toxicity of aldrin, dieldrin and compound 49-RL-5, a possible contaminant of impure aldrin. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Larson EE, Cappel J. 1957. The toxic effects sustained by animals subjected to the inhalation of air containing products of the sublimination of technical aldrin at various temperatures. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Cleveland CM, Shaffer KL, . 1951a. The toxicity of aldrin, dieldrin, and DDT when fed to rats over the period of six months. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Dutra FR, Shaffer KL, . 1951b. The toxicity of aldrin and dieldrin when fed to dogs for variable periods. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Cleveland CM, Shaffer FE, . 1953a. The toxicity of aldrin, dieldrin, and DDT when fed to rats over the period of twenty-seven weeks. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Hartman L, Gahegen T, . 1953b. The immediate and cumulative toxicity of aldrin, dieldrin and DDT when maintained in contact with the skin of rabbits. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Boyd J, Berrymanm G, . 1954a. Final report on the effects on the reproductive capacity of three generations of rats being fed on diets containing aldrin, dieldrin or DDT. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Cleveland FP, Stemmer KL, . 1954b. The physiological effects of feeding rats on diets containing aldrin, dieldrin of DDT in various concentrations over the period of two years. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Treon JF, Cleveland CM, Stemmer KL, . 1955. The toxicity of aldrin when fed to suckling dogs, and the toxicity of aldrin, dieldrin, DDT and lindane when incorporated in the diets of older dogs over a period of more than fifteen months. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
TRI20. 2021. TRI explorer: Providing access to EPA’s toxics release inventory data. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://www.epa.gov/enviro/tri-customized-search. November 8, 2021.
Trosko JE, Jone C, Chang CC. 1987. Inhibition of gap junctional-mediated intercellular communication in vitro by aldrin, dieldrin, and toxaphene: A possible cellular mechanism for their tumor-promoting and neurotoxic effects. Mol Toxicol 1(1):83–93.3449752
Trotter WJ, Dickerson R. 1993. Pesticide residues in composited milk collected through the U.S. Pasteurized Milk Network. J AOAC Int 76(6):1220–1225.8286959
Trotter WJ, Corneliussen PE, Laski RR, . 1989. Levels of polychlorinated biphenyls and pesticides in bluefish before and after cooking. J Assoc Off Anal Chem 72(3):501–503.2501293
Tully DB, Cox VT, Mumtaz MM, . 2000. Six high-priority organochlorine pesticides, either singly or in combination, are nonestrogenic in transfected HeLa cells. Reprod Toxicol 14(2):95–102. 10.1016/s0890-6238(00)00060-5.10825672
USGS. 1985. Pesticides in the Nations rivers, 1975-1980, and implications for future monitoring. U.S. Geological Survey. Water Supply Paper 2271. https://pubs.usgs.gov/wsp/2271/report.pdf. December 12, 2019.
USGS. 2006. Pesticides in the Nation’s streams and ground water, 1992-2001. Reston, VA: U.S. Geological Survey. Circular 1291. https://pubs.er.usgs.gov/publication/cir1291. December 11, 2019.
Usha Rani MV, Reddi OS, Reddy PP. 1980. Mutagenicity studies involving aldrin, endosulfan, dimethoate, phosphamidon, carbaryl and ceresan. Bull Environ Contam Toxicol 25(2):277–282. 10.1007/BF01985524.6775717
Uversky VN, Li J, Fink AL. 2001. Pesticides directly accelerate the rate of alpha-synuclein fibril formation: A possible factor in Parkinson’s disease. FEBS Lett 500(3):105–108.11445065
Vale C, Fonfria E, Bujons J, . 2003. The organochlorine pesticides gamma-hexachlorocyclohexane (lindane), alpha-endosulfan and dieldrin differentially interact with GABA(A) and glycine-gated chloride channels in primary cultures of cerebellar granule cells. Neuroscience 117(2):397–403.12614680
van Amelsvoort LG, Slangen JJ, Tsai SP, . 2009. Cancer mortality in workers exposed to dieldrin and aldrin: Over 50 years of follow up. Int Arch Occup Environ Health 82(2):217–225. 10.1007/s00420-008-0325-1.18427830
Van Gelder GA. 1975. Behavioral toxicologic studies of dieldrin, DDT, and ruelene in sheep. In: Weiss B, Laties VG, eds. Behavioral toxicology. New York, NY: Plenum Press, 217–239.
Van Oostdam J, Donaldson SG, Feeley M, . 2005. Human health implications of environmental contaminants in Arctic Canada: A review. Sci Total Environ 351–352:165–246. 10.1016/j.scitotenv.2005.03.034.
Van Raalte HG. 1977. Human experience with dieldrin in perspective. Ecotoxicol Environ Saf 1(2):203–210. 10.1016/0147-6513(77)90036-7.361371
van Ravenzwaay B, Kunz W. 1988. Quantitative aspects of accelerated nuclear polyploidization and tumour formation in dieldrin treated CF-1 mouse liver. Br J Cancer 58(1):52–56. 10.1038/bjc.1988.160.2844220
van Sittert NJ, de Jong G. 1987. Evaluation of liver function with biochemical tests of operators engaged in aldrin and dieldrin manufacturing. Shell Oil Company.
Van Wijnen JH, Strijkel A. 1988. Health risk assessment of residents living on harbour sludge. Int Arch Occup Environ Health 61:77–87.3198287
Verschueren K. 2001. Aldrin. In: Handbook of environmental data on organic chemicals. 4^th^ ed. New York, NY: John Wiley and Sons, Inc., 83.
Versteeg JP, Jager KW. 1973. Long-term occupational exposure to the insecticides aldrin, dieldrin, endrin, and telodrin. Br J Ind Med 30(2):201–202. 10.1136/oem.30.2.201.4703092
Virgo BB, Bellward GD. 1975. Effects of dietary dieldrin on reproduction in the Swiss-Vancouver (SWV) mouse. Environ Physiol Biochem 5(6):440–450.1213033
Virgo BB, Bellward GD. 1977. Effects of dietary dieldrin on offspring viability, maternal behaviour, and milk production in the mouse. Res Commun Chem Pathol Pharmacol 17(3):399–409.897335
Voerman S, Besemer AFH. 1970. Residues of dieldrin, lindane, DDT, and parathion in a light sandy soil after repeated application throughout a period of 15 years. J Agric Food Chem 18(4):717–719. 10.1021/jf60170a041.
Wade MJ, Moyer JW, Hine CH. 1979. Mutagenic action of a series of epoxides. Mutat Res 66(4):367–371. 10.1016/0165-1218(79)90047-8.379632
Wade MH, Trosko JE, Schindler M. 1986. A fluorescence photobleaching assay of gap junction-mediated communication between human cells. Science 232(4749):525–528. 10.1126/science.3961495.3961495
Wade MG, Desaulniers D, Leingartner K, . 1997. Interactions between endosulfan and dieldrin on estrogen-mediated processes in vitro and in vivo. Reprod Toxicol 11(6):791–798. 10.1016/s0890-6238(97)00062-2.9407589
Wagner SR, Greene FE. 1978. Dieldrin-induced alterations in biogenic amine content of rat brain. Toxicol Appl Pharmacol 43(1):45–55. 10.1016/s0041-008x(78)80031-3.625764
Walker AI, Thorpe E, Stevenson DE. 1973. The toxicology of dieldrin (HEOD). I. Long-term oral toxicity studies in mice. Food Cosmet Toxicol 11(3):415–432.4353861
Walker AI, Stevenson DE, Robinson J, . 1969. The toxicology and pharmacodynamics of dieldrin (HEOD): Two-year oral exposures of rats and dogs. Toxicol Appl Pharmacol 15(2):345–373. 10.1016/0041-008X(69)90034-9.5804749
Wallace JC, Brzuzy LP, Simonich SL, . 1996. Case study of organochlorine pesticides in the indoor air of a home. Environ Sci Technol 30(9):2715–2718. 10.1021/es950849t.
Walton MS, Bastone VB, Baron RL. 1971. Subchronic toxicity of photodieldrin, a photodecomposition product of dieldrin. Toxicol Appl Pharmacol 20(1):82–88. 10.1016/0041-008x(71)90091-3.5110828
Wang Z, Wu Q, Li X, . 2020. Constitutive androstane receptor (CAR) mediates dieldrin-induced liver tumorigenesis in mouse. Arch Toxicol 94(8):2873–2884. 10.1007/s00204-020-02781-8.32435917
Ward EM, Schulte P, Grajewski B, . 2000. Serum organochlorine levels and breast cancer: a nested case-control study of Norwegian women. Cancer Epidemiol Biomarkers Prev 9(12):1357–1367.11142422
Warnick SL, Carter JE. 1972. Some findings in a study of workers occupationally exposed to pesticides. Arch Environ Health 25(4):265–270. 10.1080/00039896.1972.10666172.5055677
Weaver L, Gunnerson CG, Breidenbach AW, . 1965. Chlorinated hydrocarbon pesticides in major U.S. river basins. Public Health Rep 80:481–493.14299201
Wedemeyer G. 1968. Partial hydrolysis of dieldrin by Aerobacter aerogenes. Appl Microbiol 16(4):661–662.5647526
Weisbrod AV, Shea D, Moore MJ, . 2000. Organochlorine exposure and bioaccumulation in the endangered Northwest Atlantic right whale (Eubalaena glacialis) population. Environ Toxicol Chem 19(3):654–666. 10.1002/etc.5620190318.
Weiss G. 1986. Aldrin. In: Hazardous chemicals data book. 2^nd^ ed. Park Ridge, NJ: Noyes Data Corporation, 58, 373.
Weisskopf MG, Knekt P, O’Reilly EJ, . 2010. Persistent organochlorine pesticides in serum and risk of Parkinson disease. Neurology 74(13):1055–1061. 10.1212/WNL.0b013e3181d76a93.20350979
WHO. 1989. Environmental Health Criteria 91: Aldrin and dieldrin. Geneva, Switzerland: World Health Organization. http://www.inchem.org/documents/ehc/ehc/ehc91.htm. December 12, 2019.
WHO. 2010. WHO Guidelines for indoor air quality: Selected pollutants. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. December 13, 2019.
WHO. 2017. Guidelines for drinking-water quality: Fourth edition incorporating the first addendum. Geneva, Switzerland: World Health Organization. https://www.who.int/water_sanitation_health/publications/drinking-water-quality-guidelines-4-including-1st-addendum/en/. December 13, 2019.
Williams DT, LeBel GL, Junkins E. 1988. Organohalogen residues in human adipose autopsy samples from six Ontario municipalities. J Assoc Off Anal Chem 71(2):410–414.3384793
Willis GH, McDowell LL. 1987. Pesticide persistence on foliage. Rev Environ Contam Toxicol 100:23–73. 10.1007/978-1-4612-4804-0_2.
Willis GH, Parr JF, Smith S, . 1972. Volatilization of dieldrin from fallow soil as affected by different soil water regimes. J Environ Qual 1:193–196.
Winger PV, Schultz DP, Johnson WW. 1990. Environmental contaminant concentrations in biota from the lower Savannah River, Georgia and South Carolina. Arch Environ Contam Toxicol 19(1):101–117. 10.1007/bf01059818.2331144
Witherup S, Stemmer KL, Roberts JL, . 1961. Prolonged cutaneous contact of wool impregnated with dieldrin. Cincinnati, OH: The Kettering Laboratory in the Department of Preventive Medicine and Industrial Health.
Wolff T, Deml E, Wanders H. 1979. Aldrin epoxidation, a highly sensitive indicator specific for cytochrome P-450-dependent mono-oxygenase activities. Drug Metab Dispos 7(5):301–305.40770
Wong DT, Terriere LC. 1965. Epoxidation of aldrin, isodrin, and heptachlor by rat liver microsomes. Biochem Pharmacol 14:375–377. 10.1016/0006-2952(65)90210-8.14314340
Woolley D, Zimmer L, Dodge D, . 1985. Effects of lindane-type insecticides in mammals: Unsolved problems. Neurotoxicology 6(2):165–192.
Worthing CR, Walker SB. 1983. Aldrin/dieldrin. In: The pesticide manual: A world compendium. 7th ed. Suffolk, Great Britain: The Lavenham Press Limited, 120, 4580.
WQP. 2021. Water Quality Portal data: Aldrin and dieldrin. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. December 15, 2021.
Wright AS, Potter D, Wooder MF, . 1972. The effects of dieldrin on the subcellular structure and function of mammalian liver cells. Food Cosmet Toxicol 10(3):311–332. 10.1016/s0015-6264(72)80251-7.4339899
Wright AS, Donninger C, Greenland RD, . 1978. The effects of prolonged ingestion of dieldrin on the livers of male rhesus monkeys. Ecotoxicol Environ Saf 1(4):477–502. 10.1016/0147-6513(78)90016-7.214292
Yamazaki K, Itoh S, Araki A, . 2020. Associations between prenatal exposure to organochlorine pesticides and thyroid hormone levels in mothers and infants: The Hokkaido study on environment and children’s health. Environ Res 189:109840. 10.1016/j.envres.2020.109840.32979988
Yin S, Sun Y, Yu J, . 2021. Prenatal exposure to organochlorine pesticides is associated with increased risk for neural tube defects. Sci Total Environ 770:145284. 10.1016/j.scitotenv.2021.145284.33515890
Zabik ME, Booren A, Zabik MJ, . 1996. Pesticide residues, PCBs and PAHs in baked, charbroiled, salt boiled and smoked Great Lakes lake trout. Food Chem 55(3):231–239. 10.1016/0308-8146(95)00115-8.
Zhang J, Li C, Yin S, . 2021. Environmental exposure to organochlorine pesticides and its association with the risk of hearing loss in the Chinese adult population: A case-control study. Sci Total Environ 767:145153. 10.1016/j.scitotenv.2021.145153. http://www.ncbi.nlm.nih.gov/pubmed/33636793.33636793