# VERSION HISTORY

Date | Description
June 2022 | Final toxicological profile released
July 2021 | Draft for public comment toxicological profile released
September 2002 | Final toxicological profile released
April 1993 | Final toxicological profile released
December 1989 | Final toxicological profile released