# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding aldrin or dieldrin in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for aldrin and dieldrin.

Table 7-1 Regulations and Guidelines Applicable to Aldrin/Dieldrin

Agency | Description | Information | Reference
Air
EPA | RfC | Not evaluated | IRIS 1987, 1988
WHO | Air quality guidelines | Not listed | WHO 2010
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 1-Day health advisory (10-kg child) | | EPA 2018a
EPA | Aldrin | 0.0003 mg/L | EPA 2018a
EPA | Dieldrin | 0.0005 mg/L | EPA 2018a
EPA | 10-Day health advisory (10-kg child) | | EPA 2018a
EPA | Aldrin | 0.0003 mg/L | EPA 2018a
EPA | Dieldrin | 0.0005 mg/L | EPA 2018a
EPA | DWEL | | EPA 2018a
EPA | Aldrin | 0.001 mg/L | EPA 2018a
EPA | Dieldrin | 0.002 mg/L | EPA 2018a
EPA | Lifetime health advisory | No data | EPA 2018a
EPA | 10^−4^ Cancer risk | | EPA 2018a
EPA | Aldrin | 0.0002 mg/L | EPA 2018a
EPA | Dieldrin | 0.0002 mg/L | EPA 2018a
EPA | National primary drinking water regulations | No data | EPA 2009
EPA | RfD
EPA | Aldrin | 3×10^−5^ mg/kg/day | IRIS 1987
EPA | Dieldrin | 5×10^−5^ mg/kg/day | IRIS 1988
EPA | Provisional peer reviewed toxicity value | | EPA 2005b
EPA | Provisional subchronic RfD | | EPA 2005b
EPA | Aldrin | 4 ×10^−5^ mg/kg/day | EPA 2005b
WHO | Drinking water quality guidelines | | WHO 2017
WHO | Guideline value, aldrin and dieldrin combined | 0.00003 mg/L | WHO 2017
WHO | Provisional tolerable daily intake, aldrin and dieldrin combined | 0.1 µg/kg body weight | WHO 2017
FDA | Substances Added to Food | Not listed^a^ | FDA 2022
Cancer
HHS | Carcinogenicity classification | No data | NTP 2021
EPA | Carcinogenicity classification | | IRIS 1987, 1988
EPA | Aldrin and dieldrin | B2^b^ | IRIS 1987, 1988
EPA | Inhalation unit risk | | IRIS 1987, 1988
EPA | Aldrin | 4.9×10^−3^ per µg/m^3^ | IRIS 1987, 1988
EPA | Dieldrin | 4.6×10^−3^ per µg/m^3^ | IRIS 1987, 1988
EPA | Oral slope factor | | IRIS 1987, 1988
EPA | Aldrin | 1.7×10^1^ per mg/kg-day | IRIS 1987, 1988
EPA | Dieldrin | 1.6×10^1^ per mg/kg-day | IRIS 1987, 1988
IARC | Carcinogenicity classification | | IARC 2019
IARC | Dieldrin, and aldrin metabolized to dieldrin | Group 2A^c^ | IARC 2019
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards and construction | | OSHA 2021a, 2021b, 2022
OSHA | Aldrin and dieldrin | 0.25 mg/m^3^ ^d^ | OSHA 2021a, 2021b, 2022
NIOSH | REL (up to 10-hour TWA) | | NIOSH 2019a, 2019b
NIOSH | Aldrin and dieldrin | 0.25 mg/m^3^ ^d,e^ | NIOSH 2019a, 2019b
| IDLH
| Aldrin | 25 mg/m^3^ ^e^ | NIOSH 2019a
| Dieldrin | 50 mg/m^3^ ^e^ | NIOSH 2019b
Emergency Criteria
EPA | AEGLs-air | No data | EPA 2018b
DOE | PACs-air | | DOE 2018a
DOE | Aldrin | | DOE 2018a
DOE | PAC-1^f^ | 0.91 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 10 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 100 mg/m^3^ | DOE 2018a
DOE | Dieldrin | | DOE 2018a
DOE | PAC-1^f^ | 0.3 mg/m^3^ | DOE 2018a
DOE | PAC-2^f^ | 6.8 mg/m^3^ | DOE 2018a
DOE | PAC-3^f^ | 450 mg/m^3^ | DOE 2018a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited in food, delisted color additives, and some substances “no longer FEMA GRAS.”

b B2: probable human carcinogen.

c Group 2A: probably carcinogenic to humans.

d Skin designation.

e Potential occupational carcinogen.

f Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2018b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; DWEL = drinking water equivalent level; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; LOAEL = lowest-observed-adverse-effect level; NIOSH = National Institute for Occupational Safety and Health; NOAEL = no-observed-adverse-effect level; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TWA = time-weighted average; WHO = World Health Organization