# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of aldrin/dieldrin is located in Table 4-1.

Table 4-1 Chemical Identity of Aldrin and Dieldrin^a^

Characteristic | Information
Chemical name | Aldrin | Dieldrin
Synonym(s) and registered trade name(s) | 1,2,3,4,10,10-Hexachloro-1,4,4α 5,8,8α-hexahydro-exo-1,4-endo-5,8-dimethanonaphthalene; HHDN^b^ Aldrec; Aldrex; Drinox; Octalene; Seedrin; Compound 118 | 1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4α,5,6,7,8,8α-octa-hydro-1,4-endo,exo-5,8-dimethanonaphthalene; HEOD^b^ Alvit; Dieldrix; Octalox; Quintox; Red Shield^c^
Chemical formula | C_12_H_8_Cl_6_ | C_12_H_8_Cl_6_O
Chemical structure | Chemical structure | Chemical structure
CAS Registry Number | 309-00-2 | 60-57-1

a All information obtained from NLM (2020a, 2020b), except where noted.

b Tomlin 1997

c EPA 2007a

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding the physical and chemical properties of aldrin/dieldrin is located in Table 4-2.

Table 4-2 Physical and Chemical Properties of Aldrin and Dieldrin^a^

Property | Aldrin | Dieldrin
Molecular weight | 364.91 | 380.91
Color | White (pure); tan to brown (technical grade) | White (pure); light brown (technical grade)
Physical state | Crystalline solid^b^ | Crystalline solid^b^
Melting point | 104–105.5°C^c^;; 49–60°C (technical grade)^c^ | 176–177°C^c^;; 95°C (technical grade)^d^
Boiling point | Decomposes^e^ | Decomposes^e^
Density | 1.6 g/mL at 20°C^f^ | 1.75 g/mL at 25°C^f^
Odor | Mild chemical odor^e^ | Mild chemical odor^e^
Odor threshold:
Water | No data | No data
Air | 0.017 mg/kg^c^ | 0.041 mg/kg^c^
Solubility:
Water at 20°C | 0.011 mg/L^g^ | 0.110 mg/L^g^
Organic solvents | Very soluble in most organic solvents^b^ | Moderately soluble in common organic solvents except aliphatic petroleum solvents and methyl alcohol^b^
Partition coefficients:
Log K_ow_ | 6.50^h^ | 6.2^c^
Log K_oc_ | 7.67^i^ | 6.67^i^
Vapor pressure at 20°C | 7.5×10^−5^ mmHg^b^ | 3.1×10^−6^ mmHg^b^
Henry’s law constant at 25°C | 4.9×10^−5^ atm-m^3^/mol^j^ | 5.2×10^−6^ atm-m^3^/mol^j^
Autoignition temperature | No data | No data
Flashpoint | No data | No data
Flammability limits | Nonflammable^f^ | Nonflammable^f^
Conversion factors | 1 ppm=14.96 mg/m^3^ at 25°C, 1 atm | 1 ppm=15.61 mg/m^3^ at 25°C, 1 atm^k^
Explosive limits | Stable^f^ | Stable^f^

a All information obtained from NLM (2020a, 2020b) unless otherwise noted.

b Budavari et al. 2001.

c Verschueren 2001.

d Hayes 1982.

e NIOSH 1997.

f Weiss 1986.

g Bus and Leber 2001.

h Hansch et al. 1995.

i Briggs 1981.

j Guerin and Kennedy 1992.

k EPA 1987a.