# APPENDIX C FRAMEWORK FOR ATSDR’S SYSTEMATIC REVIEW OF HEALTH EFFECTS DATA FOR ALDRIN AND DIELDRIN

To increase the transparency of ATSDR’s process of identifying, evaluating, synthesizing, and interpreting the scientific evidence on the health effects associated with exposure to aldrin/dieldrin, ATSDR utilized a slight modification of NTP’s Office of Health Assessment and Translation (OHAT) systematic review methodology (NTP 2013, 2015; Rooney et al. 2014). ATSDR’s framework is an eight-step process for systematic review with the goal of identifying the potential health hazards of exposure to aldrin and dieldrin:

- Step 1. Problem Formulation
- Step 2. Literature Search and Screen for Health Effects Studies
- Step 3. Extract Data from Health Effects Studies
- Step 4. Identify Potential Health Effect Outcomes of Concern
- Step 5. Assess the Risk of Bias for Individual Studies
- Step 6. Rate the Confidence in the Body of Evidence for Each Relevant Outcome
- Step 7. Translate Confidence Rating into Level of Evidence of Health Effects
- Step 8. Integrate Evidence to Develop Hazard Identification Conclusions

The systematic review for this profile is divided into three sections:

1. Steps 1, 2, and 3 for aldrin and dieldrin (Sections C.1, C.2, and C.3)
2. Steps 4, 5, 6, 7, and 8 for aldrin (Sections C.4, C.5, C.6, C.7, and C.8)
3. Steps 4, 5, 6, 7, and 8 for dieldrin (Sections C.9, C.10, C.11, C.12, and C.13)

## C.1 PROBLEM FORMULATION

The objective of the toxicological profile and this systematic review was to identify the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to aldrin and dieldrin. The inclusion criteria used to identify relevant studies examining the health effects of aldrin/dieldrin are presented in Table C-1.

Data from human and laboratory animal studies were considered relevant for addressing this objective. Human studies were divided into two broad categories: observational epidemiology studies and controlled exposure studies. The observational epidemiology studies were further divided: cohort studies (retrospective and prospective studies), population studies (with individual data or aggregate data), and case-control studies.

Table C-1 Inclusion Criteria for Identifying Health Effects Studies

Species; Human; Laboratory mammals
Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data)
Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer

## C.2 LITERATURE SEARCH AND SCREEN FOR HEALTH EFFECTS STUDIES

A literature search and screen was conducted to identify studies examining the health effects of aldrin/dieldrin. The literature search framework for the toxicological profile is discussed in detail in Appendix B.

### C.2.1 Literature Search

As noted in Appendix B, the current literature search was intended to update the draft toxicological profile for aldrin/dieldrin released for public comment in 2021. See Appendix B for the databases searched and the search strategy.

A total of 593 records relevant to all sections of the toxicological profile were identified (after duplicate removal).

### C.2.2 Literature Screening

As described in Appendix B, a two-step process was used to screen the literature search to identify relevant studies examining the health effects of aldrin/dieldrin.

Title and Abstract Screen. In the Title and Abstract Screen step, 593 records were reviewed; 22 documents were considered to meet the health effects inclusion criteria in Table C-1 and were moved to the next step in the process.

Full Text Screen. In the second step in the literature screening process for the systematic review, a full text review of 154 health effect documents (documents identified in the update literature search and documents cited in older versions of the profile) was performed. From those 154 documents, 226 studies were included in the qualitative review.

## C.3 EXTRACT DATA FROM HEALTH EFFECTS STUDIES

Relevant data extracted from the individual studies selected for inclusion in the systematic review were collected in customized data forms. A summary of the type of data extracted from each study is presented in Table C-2. For references that included more than one experiment or species, data extraction records were created for each experiment or species.

Table C-2 Data Extracted From Individual Studies

Citation
Chemical form
Route of exposure (e.g., inhalation, oral, dermal)
Specific route (e.g., gavage in oil, drinking water)
Species
Strain
Exposure duration category (e.g., acute, intermediate, chronic)
Exposure duration
Frequency of exposure (e.g., 6 hours/day, 5 days/week)
Exposure length
Number of animals or subjects per sex per group
Dose/exposure levels
Parameters monitored
Description of the study design and method
Summary of calculations used to estimate doses (if applicable)
Summary of the study results
Reviewer’s comments on the study
Outcome summary (one entry for each examined outcome)
No-observed-adverse-effect level (NOAEL) value
Lowest-observed-adverse-effect level (LOAEL) value
Effect observed at the LOAEL value

A summary of the extracted data for each study is presented in the Supplemental Document for Aldrin/Dieldrin and overviews of the results are presented in Sections 2.2–2.18 of the profile. Results from oral exposure studies are summarized in the Table 2-1 (Levels of Significant Exposure to Aldrin) and Table 2-2 (Levels of Significant Exposure to Dieldrin). Limited information regarding the effects of inhalation or dermal exposure to aldrin or dieldrin mainly involves evaluation of acute lethality. Results from animal studies that employed inhalation or dermal exposure routes are summarized in the appropriate sections of Chapter 2 but are not presented in tables summarizing levels of significant exposure.

## C.4 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—ALDRIN

Overviews of the potential health effect outcomes for aldrin identified in human and animal studies are presented in Tables C-3 and C-4, respectively. Multiple occupational cohorts were evaluated for possible associations between aldrin and/or dieldrin exposure and risk of death from selected noncancer or cancer endpoints. Cohorts with potential exposure to both aldrin and dieldrin are included in sections C.4–C-8 for aldrin and Sections C.9–C.13 for dieldrin. Studies in which the reported exposure was to aldrin during its production or use are assumed to have primarily involved the inhalation exposure route and exposure duration was considered to be chronic unless otherwise indicated. Other human studies involving aldrin include case-control studies, self-reported use, and individual case reports. Data from human studies evaluating possible associations between serum dieldrin levels and selected health outcomes are presented in sections C.9–C.13 under the assumption that exposures were to dieldrin, although some exposures may have been to aldrin because dieldrin is readily formed from aldrin in biological systems. Animal studies of aldrin predominantly employed the oral exposure route. Collectively, the animal studies examined a number of endpoints. The most sensitive endpoints (outcomes) were body weight, hepatic, neurological, reproductive, and developmental. Animal studies evaluating these potential outcomes were carried through Steps 4–8 of the systematic review. Human studies evaluating potential hepatic, neurological, reproductive, and developmental outcomes were also carried through Steps 4–8 of the systematic review. No human studies evaluated body weight.

Table C-3 Overview of the Health Outcomes for Aldrin Evaluated in Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 6 | 5 | 1 | 1 | | 4 | 2 | 1 | | | | 3 | | 1 | | 14
Cohort | | 2 | | | | | | | | | | | 2 | | | | 4
Case control | | | | | | | | | | | | | 1 | | 2 | | 3
Case control
Population | | | | | | | | | | | | | | | | | 6
Population | | | | | | | | | | | | | | | | | 1
Case series | | | | | 1 | | | | | | | | 2
Case series | | | | | 1 | | | | | | | | 2
Oral studies
Cohort
Case control
Population
Case series | | | | | | | | 1 | | | | | 2 | 1
Case series | | | | | | | | 1 | | | | | 2 | 1
Dermal studies
Cohort
Case control
Population
Case series

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

Table C-4 Overview of the Health Outcomes for Aldrin Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Intermediate-duration
Chronic-duration
Oral studies
Acute-duration | | | | | | | 1 | | | | | | 8 | | 3
Acute-duration | | | | | | | 1 | | | | | | 8 | | 3
Intermediate-duration | 3 | | | 1 | | | 3 | 1 | | | | | 2 | 2 | 2
Intermediate-duration | 1 | | | 1 | | | 2 | 0 | | | | | 2 | 2 | 2
Chronic-duration | 7 | 2 | 2 | 2 | 3 | 2 | 6 | 4 | 2 | 2 | 2 | | 3 | | 1 | | 2
Chronic-duration | 2 | 0 | 0 | 0 | 1 | 0 | 4 | 2 | 0 | 0 | 0 | | 3 | | 1 | | 2
Dermal studies
Acute-duration | | | | | | | | | | | | | 1
Acute-duration | | | | | | | | | | | | | 1
Intermediate-duration
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5–9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.5 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES—ALDRIN

### C.5.1 Risk of Bias Assessment—Aldrin

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies are presented in Tables C-5, C-6, and C-7, respectively. Each risk of bias question was answered on a four-point scale:

- Definitely low risk of bias (++)
- Probably low risk of bias (+)
- Probably high risk of bias (-)
- Definitely high risk of bias (− −)

In general, “definitely low risk of bias” or “definitely high risk of bias” were used if the question could be answered with information explicitly stated in the study report. If the response to the question could be inferred, then “probably low risk of bias” or “probably high risk of bias” responses were typically used.

Table C-5 Risk of Bias Questionnaire for Observational Epidemiology Studies

Selection bias; Were the comparison groups appropriate?
Confounding bias; Did the study design or analysis account for important confounding and modifying variables?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-6 Risk of Bias Questionnaire for Human-Controlled Exposure Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were the research personnel and human subjects blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

Table C-7 Risk of Bias Questionnaire for Experimental Animal Studies

Selection bias; Was administered dose or exposure level adequately randomized?; Was the allocation to study groups adequately concealed?
Performance bias; Were experimental conditions identical across study groups?; Were the research personnel blinded to the study group during the study?
Attrition/exclusion bias; Were outcome data complete without attrition or exclusion from analysis?
Detection bias; Is there confidence in the exposure characterization?; Is there confidence in outcome assessment?
Selective reporting bias; Were all measured outcomes reported?

After the risk of bias questionnaires were completed for the health effects studies, the studies were assigned to one of three risk of bias tiers based on the responses to the key questions listed below and the responses to the remaining questions.

- Is there confidence in the exposure characterization? (only relevant for observational studies)
- Is there confidence in the outcome assessment?
- Does the study design or analysis account for important confounding and modifying variables? (only relevant for observational studies)

First Tier. Studies placed in the first tier received ratings of “definitely low” or “probably low” risk of bias on the key questions AND received a rating of “definitely low” or “probably low” risk of bias on the responses to at least 50% of the other applicable questions.

Second Tier. A study was placed in the second tier if it did not meet the criteria for the first or third tiers.

Third Tier. Studies placed in the third tier received ratings of “definitely high” or “probably high” risk of bias for the key questions AND received a rating of “definitely high” or “probably high” risk of bias on the response to at least 50% of the other applicable questions.

The results of the risk of bias assessment for the different types of aldrin health effects studies (observational epidemiology studies and animal experimental studies) are presented in Tables C-8 and C-9, respectively.

Table C-8 Summary of Risk of Bias Assessment for Aldrin—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Comparison groups appropriate? | Study design or analysis account for important confounding and modifying variables?^*^ | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization?^*^ | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic effects
Cohort
de Jong 1991 | + | − | + | − | + | + | Second
Hoogendam et al. 1965 | + | − | + | − | + | + | Second
Hunter et al. 1972 | + | − | + | − | + | + | Second
Jager 1970 | + | − | + | − | + | + | Second
van Sittert and de Jong 1987 | + | − | + | − | + | + | Second
Outcome: Neurological effects
Cohort
de Jong 1991 | + | − | + | − | + | + | Second
Hoogendam et al. 1962 | NA | − | + | − | + | + | Second
Hoogendam et al. 1965 | NA | − | + | − | + | + | Second
Case-Control
Zhang et al. 2021 | ++ | − | + | − | + | + | Second
Case reports
Avar and Czegledi-Janko 1970 | NA | − | + | − | + | + | Second
Gupta 1975 | NA | − | + | − | + | + | Second
Kazantzis et al. 1964 | NA | − | + | − | + | + | Second
Spiotta 1951 | NA | + | + | − | + | + | Second
Outcome: Reproductive effects
Population-based case-control
Saxena et al. 1980 | + | − | + | − | + | + | Second
Outcome: Developmental effects
Case-control
Pi et al. 2020 | + | − | + | − | + | + | Second
Yin et al. 2021 | + | − | + | − | + | + | Second
Cross-sectional
Dwivedi et al. 2021 | NA | − | + | − | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

Table C-9 Summary of Risk of Bias Assessment for Aldrin—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization? | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Body weight
Oral intermediate exposure
Treon et al. 1951a rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1953a rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1955 dog | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Deichmann et al. 1967 rat | + | + | + | + | + | + | + | + | + | First
Deichmann et al. 1970 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 dog | + | + | + | + | + | + | + | + | + | First
NCI 1978a rat | ++ | + | + | + | + | + | + | + | + | First
NCI 1978a mouse | ++ | + | + | + | + | + | + | + | + | First
Treon et al. 1955 dog | + | + | + | + | + | + | + | + | + | First
Outcome: Hepatic effects
Oral acute exposure
Treon et al. 1951a rat | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Treon et al. 1951a rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1951b dog | + | + | + | + | + | + | + | + | + | First
Treon et al. 1953a rat | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Deichmann et al. 1970 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 dog | + | + | + | + | + | + | + | + | + | First
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First
NCI 1978a rat | ++ | + | + | + | + | + | + | + | + | First
NCI 1978a mouse | ++ | + | + | + | + | + | + | + | + | First
Outcome: Neurological effects
Oral acute exposure
Jamaluddin and Poddar 2001a rat | + | + | + | + | + | + | + | + | + | First
Jamaluddin and Poddar 2001b rat | + | + | + | + | + | + | + | + | + | First
Jamaluddin and Poddar 2003 rat | + | + | + | + | + | + | + | + | + | First
Mehrotra et al. 1989 rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1951a rat | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Treon et al. 1951b dog | + | + | + | + | + | + | + | + | + | First
Treon et al. 1955 dog | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First
NCI 1978a rat | ++ | + | + | + | + | + | + | + | + | First
NCI 1978a mouse | ++ | + | + | + | + | + | + | + | + | First
Dermal acute exposure
Treon et al. 1953b rabbit | + | + | + | + | + | + | + | + | + | First
Outcome: Reproductive effects
Oral intermediate exposure
Keplinger et al. 1970 mouse | + | + | + | + | + | + | + | + | + | First
Treon et al. 1954a rat | + | + | + | + | + | + | + | + | + | First
Outcome: Developmental effects
Oral acute exposure
Al-Hachim 1971 mouse | + | + | + | + | + | + | + | + | + | First
Ottolenghi et al. 1974 mouse | + | + | + | + | + | + | + | + | + | First
Ottolenghi et al. 1974 hamster | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Keplinger et al. 1970 mouse | + | + | + | + | + | + | + | + | + | First
Treon et al. 1954a rat | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.6 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—ALDRIN

Confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome. ATSDR did not evaluate the confidence in the body of evidence for carcinogenicity; rather, the Agency defaulted to the cancer weight-of-evidence assessment of other agencies including HHS, EPA, and IARC. The confidence in the body of evidence for an association or no association between exposure to aldrin and a particular outcome was based on the strengths and weaknesses of individual studies. Four descriptors were used to describe the confidence in the body of evidence for effects or when no effect was found:

- High confidence: the true effect is highly likely to be reflected in the apparent relationship
- Moderate confidence: the true effect may be reflected in the apparent relationship
- Low confidence: the true effect may be different from the apparent relationship
- Very low confidence: the true effect is highly likely to be different from the apparent relationship

Confidence in the body of evidence for a particular outcome was rated for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.6.1 Initial Confidence Rating—Aldrin

In ATSDR’s modification to the OHAT approach, the body of evidence for an association (or no association) between exposure to aldrin and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. The presence of these key features of study design was determined for individual studies using four “yes or no” questions, which were customized for epidemiology, human controlled exposure, or experimental animal study designs. Separate questionnaires were completed for each outcome assessed in a study. The key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies are presented in Tables C-10, C-11, and C-12, respectively. The initial confidence in the study was determined based on the number of key features present in the study design:

- High Initial Confidence: Studies in which the responses to the four questions were “yes”.
- Moderate Initial Confidence: Studies in which the responses to only three of the questions were “yes”.
- Low Initial Confidence: Studies in which the responses to only two of the questions were “yes”.
- Very Low Initial Confidence: Studies in which the response to one or none of the questions was “yes”.

Table C-10 Key Features of Study Design for Observational Epidemiology Studies

Exposure was experimentally controlled
Exposure occurred prior to the outcome
Outcome was assessed on individual level rather than at the population level
A comparison group was used

Table C-11 Key Features of Study Design for Human Controlled Exposure Studies

A comparison group was used or the subjects served as their own control
A sufficient number of subjects were tested
Appropriate methods were used to measure outcomes (i.e., clinically-confirmed outcome versus self-reported)
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

Table C-12 Key Features of Study Design for Experimental Animal Studies

A concurrent control group was used
A sufficient number of animals per group were tested
Appropriate parameters were used to assess a potential adverse effect
Appropriate statistical analyses were performed and reported or the data were reported in such a way to allow independent statistical analysis

The presence or absence of the key features and the initial confidence levels for studies examining hepatic, neurological, and reproductive outcomes in the observational epidemiology studies; and body weight, hepatic, neurological, reproductive, and developmental outcomes in animal experimental studies are presented in Tables C-13 and C-14, respectively.

Table C-13 Presence of Key Features of Study Design for Aldrin—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Developmental
Case-control
Pi et al. 2020 | No | Yes | Yes | Yes | Moderate
Yin et al. 2021 | No | Yes | Yes | Yes | Moderate
Cross-sectional
Dwivedi et al. 2021 | No | Yes | Yes | No | Low
Outcome: Hepatic effects
Cohort
de Jong 1991 | No | Yes | Yes | Yes | Moderate
Hoogendam et al. 1965 | No | Yes | Yes | No | Low
Hunter et al. 1972 | No | Yes | Yes | Yes | Moderate
Jager 1970 | No | Yes | Yes | Yes | Moderate
van Sittert and de Jong 1987 | No | Yes | Yes | Yes | Moderate
Outcome: Neurological effects
Cohort
de Jong 1991 | No | Yes | Yes | Yes | Moderate
Hoogendam et al. 1962 | No | Yes | Yes | No | Low
Hoogendam et al. 1965 | No | Yes | Yes | No | Low
Case-control
Zhang et al. 2021 | No | Yes | Yes | Yes | Moderate
Case reports
Avar and Czegledi-Janko 1970 | No | Yes | Yes | No | Low
Gupta 1975 | No | Yes | Yes | No | Low
Kazantzis et al. 1964 | No | Yes | Yes | No | Low
Spiotta 1951 | No | Yes | Yes | No | Low
Outcome: Reproductive effects
Population-based case-control
Saxena et al. 1980 | No | Yes | Yes | Yes | Moderate

Table C-14 Presence of Key Features of Study Design for Aldrin—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Body weight effects
Oral intermediate exposure
Treon et al. 1951a rat | Yes | Yes | Yes | Yes | High
Treon et al. 1953a rat | Yes | Yes | Yes | Yes | High
Treon et al. 1955 dog | Yes | No | Yes | No | Low
Oral chronic exposure
Deichmann et al. 1967 rat | Yes | Yes | Yes | Yes | High
Deichmann et al. 1970 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 dog | Yes | No | Yes | Yes | Moderate
NCI 1978a rat | Yes | Yes | Yes | Yes | High
NCI 1978a mouse | Yes | Yes | Yes | Yes | High
Treon et al. 1955 dog | Yes | No | Yes | No | Low
Outcome: Hepatic effects
Oral acute exposure
Treon et al. 1951a rat | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Treon et al. 1951a rat | Yes | Yes | Yes | Yes | High
Treon et al. 1951b dog | Yes | No | No | No | Very low
Treon et al. 1953a rat | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Deichmann et al. 1970 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 dog | Yes | No | Yes | Yes | Moderate
Kitselman 1953 dog | Yes | No | No | No | Very low
NCI 1978a rat | Yes | Yes | Yes | Yes | High
NCI 1978a mouse | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Oral acute exposure
Jamaluddin and Poddar 2001a rat | Yes | No | Yes | Yes | Moderate
Jamaluddin and Poddar 2001b rat | Yes | No | Yes | Yes | Moderate
Jamaluddin and Poddar 2003 rat | Yes | No | Yes | Yes | Moderate
Mehrotra et al. 1989 rat | Yes | No | Yes | Yes | Moderate
Treon et al. 1951a rat | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Treon et al. 1951b dog | Yes | No | No | No | Very low
Treon et al. 1955 dog | Yes | No | Yes | No | Low
Oral chronic exposure
Kitselman 1953 dog | Yes | No | No | No | Very low
NCI 1978a rat | Yes | Yes | Yes | No | Moderate
NCI 1978a mouse | Yes | Yes | Yes | No | Moderate
Dermal acute exposure
Treon et al. 1953b rabbit
Outcome: Reproductive effects
Oral intermediate exposure
Keplinger et al. 1970 mouse | Yes | Yes | Yes | Yes | High
Treon et al. 1954a rat | Yes | Yes | Yes | Yes | High
Outcome: Developmental effects
Oral acute exposure
Al-Hachim 1971 mouse | Yes | No | Yes | Yes | Moderate
Ottolenghi et al. 1974 mouse | Yes | No | Yes | Yes | Moderate
Ottolenghi et al. 1974 hamster | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Keplinger et al. 1970 mouse | Yes | Yes | Yes | Yes | High
Treon et al. 1954a rat | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Kitselman 1953 dog | Yes | No | No | No | Very low

A summary of the initial confidence ratings for each outcome is presented in Table C-15. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-15.

Table C-15 Initial Confidence Rating for Aldrin Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Body weight effects
Oral intermediate exposure
Animal studies
Treon et al. 1951a rat | High | High
Treon et al. 1953a rat | High | High
Treon et al. 1955 dog | Low | High
Oral chronic exposure
Animal studies
Deichmann et al. 1967 rat | High | High
Deichmann et al. 1970 rat | Moderate | High
Fitzhugh et al. 1964 rat | Moderate | High
Fitzhugh et al. 1964 dog | Very low | High
NCI 1978a rat | High | High
NCI 1978a mouse | High | High
Treon et al. 1955 dog | High | High
Outcome: Hepatic effects
Inhalation chronic exposure
Human studies
de Jong 1991 | Moderate | Moderate
Hoogendam et al. 1965 | Low | Moderate
Hunter et al. 1972 | Moderate | Moderate
Jager 1970 | Moderate | Moderate
van Sittert and de Jong 1987 | Moderate | Moderate
Oral acute exposure
Animal studies
Treon et al. 1951a rat | Moderate | Moderate
Oral intermediate exposure
Animal studies
Treon et al. 1951a rat | High | High
Treon et al. 1951b dog | Very low | High
Treon et al. 1953a rat | High | High
Oral chronic exposure
Animal studies
Deichmann et al. 1970 rat | High | High
Fitzhugh et al. 1964 rat | Moderate | High
Fitzhugh et al. 1964 dog | Moderate | High
Kitselman 1953 dog | Very low | High
NCI 1978a rat | High | High
NCI 1978a mouse | High | High
Outcome: Neurological effects
Inhalation acute exposure
Human studies
Kazantzis et al. 1964 | Low | Low
Inhalation chronic exposure
Human studies
Avar and Czegledi-Janko 1970 | Low | Moderate
de Jong 1981 | Moderate | Moderate
Hoogendam et al. 1962 | Low | Moderate
Hoogendam et al. 1965 | Low | Moderate
Oral acute exposure
Human studies
Spiotta 1951 | Low | Low
Animal studies
Jamaluddin and Poddar 2001a rat | Moderate | Moderate
Jamaluddin and Poddar 2001b rat | Moderate | Moderate
Jamaluddin and Poddar 2003 rat | Moderate | Moderate
Mehrotra et al. 1989 rat | Moderate | Moderate
Treon et al. 1951a rat | Moderate | Moderate
Oral intermediate exposure
Human studies
Gupta 1975 | Low | Low
Animal studies
Treon et al. 1951b dog | Very low | Low
Treon et al. 1955 dog | Low | Low
Oral chronic exposure
Human studies
Zhang et al. 2021 | Moderate | Moderate
Animal studies
Kitselman 1953 dog | Very low | Moderate
NCI 1978a rat | Moderate | Moderate
NCI 1978a mouse | Moderate | Moderate
Dermal acute exposure
Animal studies
Treon et al. 1953b rabbit
Outcome: Reproductive effects
Oral intermediate exposure
Human studies
Saxena et al. 1980 | Moderate | Moderate
Animal studies
Keplinger et al. 1970 mouse | High | High
Treon et al. 1954a rat | High | High
Oral chronic exposure
Human studies
Saxena et al. 1980 | High | High
Outcome: Developmental effects
Oral acute exposure
Animal studies
Al-Hachim 1971 mouse | Moderate | Moderate
Ottolenghi et al. 1974 mouse | Moderate | Moderate
Ottolenghi et al. 1974 hamster | Moderate | Moderate
Oral intermediate exposure
Animal studies
Keplinger et al. 1970 mouse | High | High
Treon et al. 1954a rat | High | High
Oral chronic exposure
Human studies
Dwivedi et al. 2021 | Low | Moderate
Pi et al. 2020 | Moderate | Moderate
Yin et al. 2021 | Moderate | Moderate
Animal Studies
Kitselman 1953 dog | Very low | Very low

### C.6.2 Adjustment of the Confidence Rating—Aldrin

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The nine properties of the body of evidence that were considered are listed below. The summaries of the assessment of the confidence in the body of evidence for body weight, hepatic, neurological, reproductive, and developmental effects are presented in Table C-16. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with aldrin exposure is presented in Table C-17.

Five properties of the body of evidence were considered to determine whether the confidence rating should be downgraded:

- Risk of bias. Evaluation of whether there is substantial risk of bias across most of the studies examining the outcome. This evaluation used the risk of bias tier groupings for individual studies examining a particular outcome (Tables C-8 and C-9). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for risk of bias:
  ○ No downgrade if most studies are in the risk of bias first tier
  ○ Downgrade one confidence level if most studies are in the risk of bias second tier
  ○ Downgrade two confidence levels if most studies are in the risk of bias third tier
- Unexplained inconsistency. Evaluation of whether there is inconsistency or large variability in the magnitude or direction of estimates of effect across studies that cannot be explained. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for unexplained inconsistency:
  ○ No downgrade if there is little inconsistency across studies or if only one study evaluated the outcome
  ○ Downgrade one confidence level if there is variability across studies in the magnitude or direction of the effect
  ○ Downgrade two confidence levels if there is substantial variability across studies in the magnitude or direct of the effect
- Indirectness. Evaluation of four factors that can affect the applicability, generalizability, and relevance of the studies:
  ○ Relevance of the animal model to human health—unless otherwise indicated, studies in rats, mice, and other mammalian species are considered relevant to humans
  ○ Directness of the endpoints to the primary health outcome—examples of secondary outcomes or nonspecific outcomes include organ weight in the absence of histopathology or clinical chemistry findings in the absence of target tissue effects
  ○ Nature of the exposure in human studies and route of administration in animal studies—inhalation, oral, and dermal exposure routes are considered relevant unless there are compelling data to the contrary
  ○ Duration of treatment in animal studies and length of time between exposure and outcome assessment in animal and prospective human studies—this should be considered on an outcome-specific basis
  Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for indirectness:
  ○ No downgrade if none of the factors are considered indirect
  ○ Downgrade one confidence level if one of the factors is considered indirect
  ○ Downgrade two confidence levels if two or more of the factors are considered indirect
- Imprecision. Evaluation of the narrowness of the effect size estimates and whether the studies have adequate statistical power. Data are considered imprecise when the ratio of the upper to lower 95% CIs for most studies is ≥10 for tests of ratio measures (e.g., odds ratios) and ≥100 for absolute measures (e.g., percent control response). Adequate statistical power is determined if the study can detect a potentially biologically meaningful difference between groups (20% change from control response for categorical data or risk ratio of 1.5 for continuous data). Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be downgraded for imprecision:
  ○ No downgrade if there are no serious imprecisions
  ○ Downgrade one confidence level for serious imprecisions
  ○ Downgrade two confidence levels for very serious imprecisions
- Publication bias. Evaluation of the concern that studies with statistically significant results are more likely to be published than studies without statistically significant results.
  ○ Downgrade one level of confidence for cases where there is serious concern with publication bias

Four properties of the body of evidence were considered to determine whether the confidence rating should be upgraded:

- Large magnitude of effect. Evaluation of whether the magnitude of effect is sufficiently large so that it is unlikely to have occurred as a result of bias from potential confounding factors.
  ○ Upgrade one confidence level if there is evidence of a large magnitude of effect in a few studies, provided that the studies have an overall low risk of bias and there is no serious unexplained inconsistency among the studies of similar dose or exposure levels; confidence can also be upgraded if there is one study examining the outcome, provided that the study has an overall low risk of bias
- Dose response. Evaluation of the dose-response relationships measured within a study and across studies. Below are the criteria used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence of a monotonic dose-response gradient
  ○ Upgrade one confidence level for evidence of a non-monotonic dose-response gradient where there is prior knowledge that supports a non-monotonic dose-response and a non-monotonic dose-response gradient is observed across studies
- Plausible confounding or other residual biases. This factor primarily applies to human studies and is an evaluation of unmeasured determinants of an outcome such as residual bias towards the null (e.g., “healthy worker” effect) or residual bias suggesting a spurious effect (e.g., recall bias). Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level for evidence that residual confounding or bias would underestimate an apparent association or treatment effect (i.e., bias toward the null) or suggest a spurious effect when results suggest no effect
- Consistency in the body of evidence. Evaluation of consistency across animal models and species, consistency across independent studies of different human populations and exposure scenarios, and consistency across human study types. Below is the criterion used to determine whether the initial confidence in the body of evidence for each outcome should be upgraded:
  ○ Upgrade one confidence level if there is a high degree of consistency in the database

Table C-16 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Body weight effects:
Animal studies | High | No adjustments | High
Hepatic effects:
Human studies | Moderate | Downgrade one confidence level; all studies in risk of bias second tier | Low
Animal studies | High | No adjustments | High
Neurological effects:
Human studies | Moderate | Downgrade one confidence level; all studies in risk of bias second tier | Low
Animal studies | Moderate | No adjustments | Moderate
Reproductive effects:
Human studies | Moderate | Downgrade one confidence level; all studies in risk of bias second tier | Low
Animal studies | High | No adjustments | High
Developmental effects:
Human | Moderate | Downgrade one confidence level; all studies in risk of bias second tier | Low
Animal studies | High | No adjustments | High

Table C-17 Confidence in the Body of Evidence for Aldrin

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Body weight effects | | High
Hepatic effects | Low | High
Neurological effects | Low | Moderate
Reproductive effects | Low | High
Developmental effects | Low | High

## C.7 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—ALDRIN

In the seventh step of the systematic review of the health effects data for aldrin, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted. The level of evidence for health effects was rated on a five-point scale:

- High level of evidence: High confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Moderate level of evidence: Moderate confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Low level of evidence: Low confidence in the body of evidence for an association between exposure to the substance and the health outcome
- Evidence of no health effect: High confidence in the body of evidence that exposure to the substance is not associated with the health outcome
- Inadequate evidence: Low or moderate confidence in the body of evidence that exposure to the substance is not associated with the health outcome OR very low confidence in the body of evidence for an association between exposure to the substance and the health outcome

A summary of the level of evidence of health effects for aldrin is presented in Table C-18.

Table C-18 Level of Evidence of Health Effects for Aldrin

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hepatic effects | Low | Health effect | Moderate
Neurological effects | Low | Health effect | Moderate
Reproductive effects | Low | Health effect | Low
Developmental effects | Low | Health effect | Low
Animal studies
Body weight effects | High | Health effect | High
Hepatic effects | High | Health effect | High
Neurological effects | Moderate | Health effect | Moderate
Reproductive effects | High | Health effect | High
Developmental effects | High | Health effect | High

## C.8 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—ALDRIN

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. For health effects, there were four hazard identification conclusion categories:

- Known to be a hazard to humans
- Presumed to be a hazard to humans
- Suspected to be a hazard to humans
- Not classifiable as to the hazard to humans

The initial hazard identification was based on the highest level of evidence in the human studies and the level of evidence in the animal studies; if there were no data for one evidence stream (human or animal), then the hazard identification was based on the one data stream (equivalent to treating the missing evidence stream as having low level of evidence). The hazard identification scheme is presented in Figure C-1 and described below:

- Known: A health effect in this category would have:
  ○ High level of evidence for health effects in human studies AND a high, moderate, or low level of evidence in animal studies.
- Presumed: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND high or moderate level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND high level of evidence in animal studies
- Suspected: A health effect in this category would have:
  ○ Moderate level of evidence in human studies AND low level of evidence in animal studies OR
  ○ Low level of evidence in human studies AND moderate level of evidence in animal studies
- Not classifiable: A health effect in this category would have:
  ○ Low level of evidence in human studies AND low level of evidence in animal studies

Figure C-1 Hazard Identification Scheme

Figure C-1 description

Other relevant data such as mechanistic or mode-of-action data were considered to raise or lower the level of the hazard identification conclusion by providing information that supported or opposed biological plausibility.

Two hazard identification conclusion categories were used when the data indicated that there may be no health effect in humans:

- Not identified to be a hazard in humans
- Inadequate to determine hazard to humans

If the human level of evidence conclusion of no health effect was supported by the animal evidence of no health effect, then the hazard identification conclusion category of “not identified” was used. If the human or animal level of evidence was considered inadequate, then a hazard identification conclusion category of “inadequate” was used. As with the hazard identification for health effects, the impact of other relevant data was also considered for no health effect data.

The hazard identification conclusions for aldrin are listed below and summarized in Table C-19.

Presumed Health Effects

- Body weight effects
  ○ No human studies evaluated body weight effects.
  ○ Depressed body weight or actual body weight loss have been reported in intermediate- and chronic-duration oral studies in laboratory animals (Deichmann et al. 1970; Fitzhugh et al. 1964; Treon et al. 1955).
- Hepatic effects
  ○ Human studies evaluating hepatic endpoints have not provided convincing evidence of aldrin-induced liver effects.
  ○ Increased liver weight and histopathologic hepatic changes have been observed in laboratory animals following oral exposure to aldrin (Fitzhugh et al. 1964; Treon et al. 1951a, 1955).
- Neurological effects
  ○ Various clinical signs and abnormal EEGs have been observed among workers involved in the production of aldrin or its use as an insecticide (Avar and Czegledi-Janko 1970; Hoogendam et al. 1965; Jager 1970; Kazantzis et al. 1964; Patel and Rao 1958). Neurological effects were observed in individuals inadvertently ingesting wheat containing aldrin and lindane (Gupta 1975). A study in a general population did not find evidence that aldrin exposure was related to hearing loss (Zhang et al. 2021).
  ○ Increased locomotor activity was observed in rats following single or repeated oral exposure to aldrin (Jamaluddin and Poddar 2001a, 2001b, 2003). Repeated oral dosing of laboratory animals with aldrin has resulted in increased locomotor activity, convulsions, tremors, and neuronal degeneration (Jamaluddin and Poddar 2001a, 2001b, 2003; Kitselman 1953; NCI 1978a, 1978b; Treon et al. 1951b; Walker et al. 1969).
- Reproductive effects
  ○ A limited human study reported significantly higher aldrin blood levels in a group of women who had premature labor or spontaneous abortion when compared to a group of controls (Saxena et al. 1980).
  ○ A variety of adverse reproductive effects were reported in dogs administered aldrin orally for 14 months prior to mating (Deichmann et al. 1971).
- Developmental effects
  ○ Studies did not find associations between aldrin blood levels and neural tube defects (Yin et al. 2021) or orofacial clefts (Pi et al. 2020). One study found an inverse correlation between maternal blood dieldrin and birth weight (Dwivedi et al. 2021).
  ○ Increased postnatal mortality has been one of the most consistent developmental findings reported for aldrin and dieldrin (Deichmann et al. 1971; Harr et al. 1970; Kitselman 1953; Treon et al. 1954a; Virgo and Bellward 1975). Aldrin or dieldrin exposure during gestation has resulted in some evidence of external malformations or skeletal anomalies in animals (Chernoff et al. 1975; Ottolenghi et al. 1974).

Table C-19 Hazard Identification Conclusions for Aldrin

Outcome | Hazard identification
Body weight effects | Presumed health effect in humans
Hepatic effects | Presumed health effect in humans
Neurological effects | Presumed health effect in humans
Reproductive effects | Presumed health effect in humans
Developmental effects | Presumed health effect in humans

## C.9 IDENTIFY POTENTIAL HEALTH EFFECT OUTCOMES OF CONCERN—DIELDRIN

Overviews of the potential health effect outcomes for dieldrin identified in human and animal studies are presented in Tables C-20 and C-21, respectively. Multiple cohorts were evaluated for possible associations between aldrin and/or dieldrin exposure and risk of death from selected noncancer or cancer endpoints. Cohorts with potential exposure to both aldrin and dieldrin are included in sections C.4–C-8 for aldrin and Sections C.9–C.13 for dieldrin. Studies involving production or use are assumed to have primarily involved the inhalation exposure route; exposure duration was considered to be chronic unless otherwise indicated. Other human studies involving dieldrin include case-control studies, self-reported use, and individual case reports. Data from human studies evaluating possible associations between serum dieldrin levels and selected health outcomes are presented in Sections C.9–C.13 under the assumption that exposures were to dieldrin, although some exposures may have been to aldrin because dieldrin is readily formed from aldrin in biological systems. Animal studies of dieldrin predominantly employed the oral exposure route. Collectively, these studies examined a number of endpoints. The most sensitive endpoints (outcomes) were hepatic, neurological, reproductive, and developmental. Animal studies examining these potential outcomes were carried through Steps 4–8 of the systematic review. Human studies evaluating potential hepatic, neurological, and developmental outcomes were also carried through Steps 4–8 of the systematic review. No human studies evaluated reproductive outcomes.

Table C-20 Overview of the Health Outcomes for Dieldrin Evaluated In Human Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological | Neurological | Reproductive | Developmental | Other Noncancer | Caner
Inhalation studies
Cohort | | 7 | 7 | 2 | 3 | | 8 | 2 | 1 | | 1 | | 3 | | 1 | | 15
Cohort | | 2 | 0 | 0 | 0 | | 0 | 0 | 0 | | 1 | | 2 | | 1 | | 2
Case control | | | | | | | | | | | | | 1 | | | | 11
Case control | | | | | | | | | | | | | 1 | | | | 5
Population | | | | | | | | | | | | | | | 4 | | 8
Population | | | | | | | | | | | | | | | 2
Case series | | | | | | | | | | | | 1 | 1
Case series | | | | | | | | | | | | 1 | 1
Oral studies
Cohort
Case control | | | | | | | | | | | | | 2
Case control | | | | | | | | | | | | | 2
Population | | | | | | | | | | | | | | | | | 1
Population
Case series | | | 1 | | 1 | | 3 | 1 | | | | 1 | 2 | | | | 1
Case series | | | 1 | | | | 3 | | | | | 1 | 2 | | | | 1
Dermal studies
Cohort
Case control
Population | | | | | | | | | | | | 1
Population | | | | | | | | | | | | 1
Case series | | | | | | | | | 1
Case series | | | | | | | | | 1

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

Table C-21 Overview of the Health Outcomes for Dieldrin Evaluated in Experimental Animal Studies

| Body weight | Respiratory | Cardiovascular | Gastrointestinal | Hematological | Musculoskeletal | Hepatic | Renal | Dermal | Ocular | Endocrine | Immunological^a^ | Neurological^a^ | Reproductive^a^ | Developmental | Other Noncancer | Caner
Inhalation studies
Acute-duration
Intermediate-duration
Chronic-duration
Oral studies
Acute-duration | 4 | | | | | | 4 | | | | | 3 | 8 | | 5
Acute-duration | 3 | | | | | | 4 | | | | | 3 | 8 | | 4
Intermediate-duration | 2 | | | 1 | | | 7 | 3 | | | | 1 | 5 | 3 | 3
Intermediate-duration | 0 | | | 1 | | | 5 | 2 | | | | 1 | 5 | 2 | 3
Chronic-duration | 8 | 4 | 5 | 4 | 4 | 6 | 9 | 7 | 4 | 3 | 4 | | 7 | | 1 | | 9
Chronic-duration | 0 | 1 | 1 | 1 | 1 | 2 | 5 | 3 | 1 | 0 | 0 | | 6 | | 1 | | 8
Dermal studies
Acute-duration | | | | | | | | | | | | | 1
Acute-duration | | | | | | | | | | | | | 1
Intermediate-duration | | | 1 | | | | 1 | | 1
Intermediate-duration | | | 0 | | | | 0 | | 0
Chronic-duration

Number of studies examining endpoint | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10
Number of studies reporting outcome | 0 | 1 | 2 | 3 | 4 | 5-9 | ≥10

a Number of studies examining endpoint includes study evaluating histopathology, but not evaluating function.

## C.10 ASSESS THE RISK OF BIAS FOR INDIVIDUAL STUDIES— DIELDRIN

### C.10.1 Risk of Bias Assessment—Dieldrin

The risk of bias of individual studies was assessed using OHAT’s Risk of Bias Tool (NTP 2015). The risk of bias questions for observational epidemiology studies, human-controlled exposure studies, and animal experimental studies were presented above in Tables C-5, C-6, and C-7, respectively. As described in Section C.5.1, each risk of bias question was answered on a four-point scale and studies were assigned to one of three risk of bias tiers.

The results of the risk of bias assessment for the different types of dieldrin health effects studies (observational epidemiology, human controlled-exposure studies, and animal experimental studies) are presented in Tables C-22, C-23, and C-24, respectively.

Table C-22 Summary of Risk of Bias Assessment for Dieldrin—Observational Epidemiology Studies

Reference | Risk of bias criteria and ratings | | | | | | Risk of bias tier
Reference | Selection bias | Confounding bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Comparison groups appropriate? | Study design or analysis account for important confounding and modifying variables?^*^ | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization?^*^ | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic effects
Cohort
de Jong 1991 | + | − | + | − | + | + | Second
Hoogendam et al. 1965 | + | − | + | − | + | + | Second
Hunter et al. 1972 | + | − | + | − | + | + | Second
Jager 1970 | + | − | + | − | + | + | Second
Morgan and Lin 1978 | − | − | + | − | + | + | Second
Morgan and Roan 1974 | + | − | + | − | + | + | Second
van Sittert and de Jong 1987 | + | − | + | − | + | + | Second
Warnick and Carter 1972 | + | − | + | − | + | + | Second
Case series
Black 1974 | NA | NA | + | − | + | + | Second
Garrettson and Curley 1969 | NA | NA | + | − | + | + | Second
Radomski et al. 1968 | + | NA | + | − | + | + | Second
Outcome: Neurological effects
Cohort
de Jong 1991 | + | − | + | − | + | + | Second
Hoogendam et al. 1962 | NA | − | + | − | + | + | Second
Hoogendam et al. 1965 | + | − | + | − | + | + | Second
Case-control
Sandifer et al. 1981 | + | − | + | − | + | + | Second
Weisskopf et al. 2010 | + | − | + | − | + | + | Second
Case series
Black 1974 | NA | NA | + | − | + | + | Second
Garrettson and Curley 1969 | NA | NA | + | − | + | + | Second
Patel and Rao 1958 | NA | NA | + | − | + | + | Second
Pennell et al. 2006 | NA | − | + | − | + | + | Second
Outcome: Developmental effects
Cohort
Beranger et al. 2020 | NA | − | + | − | + | + | Second
Yamazaki et al. 2020 | NA | − | + | − | + | + | Second
Cross-sectional
Abdel Hamid et al. 2020 | NA | − | + | − | + | +
Dwivedi et al. 2021 | NA | − | + | − | + | + | Second
Kao et al. 2019a | NA | − | + | − | + | + | Second

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

Table C-23 Summary of Risk of Bias Assessment for Dieldrin—Human Controlled-Exposure Studies

Reference | Risk of bias criteria and ratings | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | Attrition / exclusion bias | Detection bias | | Selective reporting bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately randomized | Researchers, human subjects blinded to study group?* | Outcome data complete without attrition or exclusion? | Confidence in the exposure characterization?* | Confidence in the outcome assessment?* | All measured outcomes reported? | Risk of bias tier
Outcome: Hepatic effects
Oral chronic exposure
Hunter and Robinson 1967 | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First
Outcome: Neurological effects
Oral chronic exposure
Hunter and Robinson 1967 | ++ | ++ | ++ | ++ | ++ | ++ | ++ | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

Table C-24 Summary of Risk of Bias Assessment for Dieldrin—Experimental Animal Studies

Reference | Risk of bias criteria and ratings | | | | | | | | | Risk of bias tier
Reference | Selection bias | | Performance bias | | Attrition/exclusion bias | Detection bias | | Selective reporting bias | Other bias | Risk of bias tier
Reference | Administered dose or exposure level adequately randomized? | Allocation to study groups adequately concealed? | Experimental conditions identical across study groups? | Research personnel blinded to the study group during the study? | Outcome data complete without attrition or exclusion from analysis? | Confidence in the exposure characterization? | Confidence in the outcome assessment?^*^ | All measured outcomes reported? | Study design or analysis account for important confounding and modifying variables? | Risk of bias tier
Outcome: Hepatic effects
Oral acute exposure
Chernoff et al. 1975 mouse | + | + | + | + | + | + | + | + | + | First
Goel et al. 1988 rat | + | + | + | + | + | + | + | + | + | First
Kohli et al. 1977 rat | + | + | + | + | + | + | + | + | + | First
Wright et al. 1972 mouse | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Ahmed et al. 1986 rat | + | + | + | + | + | + | + | + | + | First
Bandyopadhyay et al. 1982b rat | + | + | + | + | + | + | + | + | + | First
Shakoori et al. 1982 rat | + | + | + | + | + | + | + | + | + | First
Stevenson et al. 1995 mouse | + | + | + | + | + | + | + | + | + | First
Treon et al. 1951a rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1951b dog | + | + | + | + | + | + | + | + | + | First
Treon et al. 1953a rat | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Deichmann et al. 1970 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 rat | + | + | + | + | + | + | + | + | + | First
Fitzhugh et al. 1964 dog | + | + | + | + | + | + | + | + | + | First
Harr et al. 1970 rat | + | + | + | + | + | + | + | + | + | First
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First
NCI 1978a rat | + | + | + | + | + | + | + | + | + | First
NCI 1978a mouse | + | + | + | + | + | + | + | + | + | First
Walker et al. 1973 rat | + | + | + | + | + | + | + | + | + | First
Walker et al. 1973 dog | + | + | + | + | + | + | + | + | + | First
Outcome: Neurological effects
Oral acute exposure
Burt 1975 rat (16.7 mg/kg) | + | + | + | + | + | + | + | + | + | First
Burt 1975 rat (2.5, 5 mg/kg) | + | + | + | + | + | + | + | + | + | First
Burt 1975 rat (8.4, 16.7 mg/kg) | + | + | + | + | + | + | + | + | + | First
Foster et al. 2008 mouse | + | + | + | + | + | + | + | + | + | First
Foster et al. 2008 mouse rep | + | + | + | + | + | + | + | + | + | First
Mehrotra et al. 1989 rat | + | + | + | + | + | + | + | + | + | First
Sandler et al. 1969 sheep | + | + | + | + | + | + | + | + | + | First
Woolley et al. 1985 rat | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Burt 1975 rat | + | + | + | + | + | + | + | + | + | First
NCI 1978b rat | + | + | + | + | + | + | + | + | + | First
Smith et al. 1976 monkey | + | + | + | + | − | + | + | + | + | First
Treon et al. 1951b dog | + | + | + | + | + | + | + | + | + | First
Van Gelder 1975 sheep | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Khairy 1960 rat | + | + | + | + | + | + | + | + | + | First
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First
NCI 1978a mouse | + | + | + | + | + | + | + | + | + | First
NCI 1978b rat | + | + | + | + | + | + | + | + | + | First
Walker et al. 1969 rat | ++ | + | + | + | + | + | + | + | + | First
Walker et al. 1969 dog | ++ | + | + | + | + | + | + | + | + | First
Walker et al. 1973 mouse 128 weeks | ++ | + | + | + | + | + | + | + | + | First
Dermal acute exposure
Treon et al. 1953b rabbit | + | + | + | + | + | + | + | + | + | First
Outcome: Reproductive effects
Oral intermediate exposure
Good and Ware 1969 mouse | + | + | + | + | + | + | + | + | + | First
Treon et al. 1954a rat | + | + | + | + | + | + | + | + | + | First
Virgo and Bellward 1975 mouse | + | + | + | + | + | + | + | + | + | First
Outcome: Developmental effects
Oral acute exposure
Carlson and Rosellini 1987 rat | + | + | + | + | + | + | + | + | + | First
Chernoff et al. 1975 mouse | + | + | + | + | + | + | + | + | + | First
Dix et al. 1977 mouse | + | + | + | + | + | + | + | + | + | First
Ottolenghi et al. 1974 mouse | + | + | + | + | + | + | + | + | + | First
Ottolenghi et al. 1974 hamster | + | + | + | + | + | + | + | + | + | First
Oral intermediate exposure
Harr et al. 1970 rat | + | + | + | + | + | + | + | + | + | First
Treon et al. 1954a rat | + | + | + | + | + | + | + | + | + | First
Virgo and Bellward 1975 mouse | + | + | + | + | + | + | + | + | + | First
Oral chronic exposure
Kitselman 1953 dog | + | + | + | + | + | + | + | + | + | First

++ = definitely low risk of bias; + = probably low risk of bias; − = probably high risk of bias; − − = definitely high risk of bias; na = not applicable

* Key question used to assign risk of bias tier

## C.11 RATE THE CONFIDENCE IN THE BODY OF EVIDENCE FOR EACH RELEVANT OUTCOME—DIELDRIN

As discussed in greater detail in Section C.6, confidences in the bodies of human and animal evidence were evaluated independently for each potential outcome for each type of study: case-control, case series, cohort, population, human-controlled exposure, and experimental animal. In the absence of data to the contrary, data for a particular outcome were collapsed across animal species, routes of exposure, and exposure durations. If species (or strain), route, or exposure duration differences were noted, then the data were treated as separate outcomes.

### C.11.1 Initial Confidence Rating—Dieldrin

As discussed in greater detail in Section C.6.1, the body of evidence for an association (or no association) between exposure to dieldrin and a particular outcome was given an initial confidence rating based on the key features of the individual studies examining that outcome. Refer to Tables C-10, C-11, and C-12, respectively, for the key features for observational epidemiology (cohort, population, and case-control) studies, human controlled exposure studies, and experimental animal studies.

The presence or absence of the key features and the initial confidence levels for studies examining hepatic and neurological outcomes observed in the observational epidemiology studies; human controlledexposure studies; and hepatic, neurological, reproductive, and developmental outcomes in animal experimental studies are presented in Tables C-25, C-26, and C-27, respectively.

Table C-25 Presence of Key Features of Study Design for Dieldrin—Observational Epidemiology Studies

Reference | Key features | | | | Initial study confidence
Reference | Controlled exposure | Exposure prior to outcome | Outcomes assessed on an individual level | Comparison group | Initial study confidence
Outcome: Hepatic effects
Cohort
de Jong 1991 | No | Yes | Yes | Yes | Moderate
Hoogendam et al. 1965 | No | Yes | Yes | No | Low
Hunter et al. 1972 | No | Yes | Yes | Yes | Moderate
Jager 1970 | No | Yes | Yes | Yes | Moderate
Morgan and Lin 1978 | No | Yes | Yes | No | Low
Morgan and Roan 1974 | No | Yes | Yes | Yes | Moderate
van Sittert and de Jong 1987 | No | Yes | Yes | Yes | Moderate
Warnick and Carter 1972 | No | Yes | Yes | Yes | Moderate
Case series
Black 1974 | No | Yes | Yes | NA | Low
Garrettson and Curley 1969 | No | Yes | Yes | NA | Low
Radomski et al. 1968 | No | Yes | Yes | Yes | Moderate
Outcome: Neurological effects
Cohort
de Jong 1991 | No | Yes | Yes | Yes | Moderate
Hoogendam et al. 1962 | No | Yes | Yes | No | Low
Hoogendam et al. 1965 | No | Yes | Yes | No | Low
Case-control
Sandifer et al. 1981 | No | Yes | Yes | Yes | Moderate
Weisskopf et al. 2010 | No | Yes | Yes | Yes | Moderate
Case series
Black 1974 | No | Yes | Yes | NA | Low
Garrettson and Curley 1969 | No | Yes | Yes | NA | Low
Patel and Rao 1958 | No | Yes | Yes | NA | Low
Pennell et al. 2006 | No | Yes | Yes | NA | Low
Outcome: Developmental effects
Cohort
Beranger et al. 2020 | No | Yes | Yes | NA | Low
Yamazaki et al. 2020 | No | Yes | Yes | NA | Low
Cross-sectional
Abdel Hamid et al. 2020 | No | Yes | Yes | NA | Low
Dwivedi et al. 2021 | No | Yes | Yes | NA | Low
Kao et al. 2019a | No | Yes | Yes | NA | Low

Table C-26 Presence of Key Features of Study Design for Dieldrin—Human Controlled-Exposure Studies

Reference | Key features | | | | Initial study confidence
Reference | Comparison group or subjects as own controls | Sufficient number of subjects | Appropriate methods to measure outcomes | Appropriate statistics or adequate data for independent statistical analysis | Initial study confidence
Outcome: Hepatic effects
Oral chronic exposure
Hunter and Robinson 1967 | Yes | No | No | No | Very low
Outcome: Neurological effects
Oral chronic exposure
Hunter and Robinson 1967 | Yes | No | No | No | Very low

Table C-27 Presence of Key Features of Study Design for Dieldrin—Experimental Animal Studies

Reference | Key feature | | | | Initial study confidence
Reference | Concurrent control group | Sufficient number of animals per group | Appropriate parameters to assess potential effect | Adequate data for statistical analysis | Initial study confidence
Outcome: Hepatic effects
Oral acute exposure
Chernoff et al. 1975 rat | Yes | Yes | No | Yes | Moderate
Chernoff et al. 1975 mouse | Yes | Yes | No | Yes | Moderate
Goel et al. 1988 rat | Yes | No | No | Yes | Low
Kohli et al. 1977 rat | Yes | Yes | No | Yes | Moderate
Wright et al. 1972 mouse | Yes | Yes | Yes | No | Moderate
Oral intermediate exposure
Ahmed et al. 1986 rat | Yes | Yes | No | Yes | Moderate
Bandyopadhyay et al. 1982b rat | Yes | Yes | No | Yes | Moderate
Shakoori et al. 1982 rat | Yes | Yes | No | Yes | Moderate
Stevenson et al. 1995 mouse
Treon et al. 1951a rat | Yes | Yes | Yes | No | Moderate
Treon et al. 1951b dog | Yes | No | No | No | Very low
Treon et al. 1953a rat | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Deichmann et al. 1970 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 rat | Yes | Yes | Yes | Yes | High
Fitzhugh et al. 1964 dog | Yes | No | Yes | Yes | Moderate
Harr et al. 1970 rat | Yes | No | Yes | Yes | Moderate
Kitselman 1953 dog | Yes | No | No | No | Very low
NCI 1978a rat | Yes | Yes | Yes | Yes | High
NCI 1978a mouse | Yes | Yes | Yes | Yes | High
Walker et al. 1969 rat | Yes | Yes | Yes | Yes | High
Walker et al. 1969 dog | Yes | Yes | Yes | Yes | High
Outcome: Neurological effects
Oral acute exposure
Burt 1975 rat (16.7 mg/kg) | Yes | Yes | No | Yes | Moderate
Burt 1975 rat (2.5, 5 mg/kg) | Yes | Yes | No | Yes | Moderate
Burt 1975 rat (8.4, 16.7 mg/kg) | Yes | Yes | No | Yes | Moderate
Foster et al. 2008 mouse | Yes | Yes | No | No | Low
Foster et al. 2008 mouse rep | Yes | Yes | No | No | Low
Mehrotra et al. 1989 rat | Yes | No | Yes | Yes | Moderate
Sandler et al. 1969 sheep | No | No | No | No | Very low
Woolley et al. 1985 rat | No | No | No | No | Very low
Oral intermediate exposure
Burt 1975 rat | Yes | Yes | No | Yes | Moderate
NCI 1978b rat | Yes | Yes | No | No | Low
Smith et al. 1976 monkey | Yes | No | Yes | No | Low
Treon et al. 1951b dog | Yes | No | No | No | Very low
Van Gelder 1975 sheep
Oral chronic exposure
Khairy 1960 rat | Yes | No | No | No | Very low
Kitselman 1953 dog | Yes | No | No | No | Very low
NCI 1978a rat | Yes | Yes | Yes | No | Moderate
NCI 1978a mouse | Yes | Yes | Yes | No | Moderate
NCI 1978b rat | Yes | Yes | Yes | No | Moderate
Walker et al. 1969 rat | Yes | Yes | Yes | No | Moderate
Walker et al. 1969 dog | Yes | Yes | Yes | No | Moderate
Walker et al. 1973 mouse 128 weeks | Yes | Yes | Yes | No | Moderate
Dermal acute exposure
Treon et al. 1953b rabbit
Outcome: Reproductive effects
Oral intermediate exposure
Good and Ware 1969 mouse | Yes | Yes | Yes | Yes | High
Treon et al. 1954a rat | Yes | Yes | Yes | Yes | High
Virgo and Bellward 1975 mouse | Yes | Yes | Yes | Yes | High
Outcome: Developmental effects
Oral acute exposure
Carlson and Rosellini 1987 rat
Chernoff et al. 1975 rat | Yes | Yes | Yes | Yes | High
Chernoff et al. 1975 mouse | Yes | Yes | Yes | Yes | High
Dix et al. 1977 mouse
Ottolenghi et al. 1974 mouse | Yes | No | Yes | Yes | Moderate
Ottolenghi et al. 1974 hamster | Yes | No | Yes | Yes | Moderate
Oral intermediate exposure
Harr et al. 1970 rat | Yes | No | Yes | Yes | Moderate
Treon et al. 1954a rat | Yes | Yes | Yes | Yes | High
Virgo and Bellward 1975 mouse | Yes | Yes | Yes | Yes | High
Oral chronic exposure
Kitselman 1953 dog | Yes | No | No | No | Very low

A summary of the initial confidence ratings for each outcome is presented in Table C-28. If individual studies for a particular outcome and study type had different study quality ratings, then the highest confidence rating for the group of studies was used to determine the initial confidence rating for the body of evidence; any exceptions were noted in Table C-28.

Table C-28 Initial Confidence Rating for Dieldrin Health Effects Studies

| Initial study confidence | Initial confidence rating
Outcome: Hepatic effects
Inhalation chronic exposure
Human studies
de Jong 1991 | Moderate | Moderate
Hoogendam et al. 1965 | Low | Moderate
Hunter et al. 1972 | Moderate | Moderate
Jager 1970 | Moderate | Moderate
Morgan and Lin 1978 | Low | Moderate
Morgan and Roan 1974 | Moderate | Moderate
van Sittert and de Jong 1987 | Moderate | Moderate
Warnick and Carter 1972 | Moderate | Moderate
Oral acute exposure
Human studies
Black 1974 | Low | Low
Garrettson and Curley 1969 | Low | Low
Animal studies
Chernoff et al. 1975 rat | Moderate | Moderate
Chernoff et al. 1975 mouse | Moderate | Moderate
Goel et al. 1988 rat | Low | Moderate
Kohli et al. 1977 rat | Moderate | Moderate
Wright et al. 1972 mouse | Moderate | Moderate
Oral intermediate exposure
Animal studies
Ahmed et al. 1986 rat | Moderate | High
Bandyopadhyay et al. 1982b rat | Moderate | High
Shakoori et al. 1982 rat | Moderate | High
Stevenson et al. 1995 mouse | | High
Treon et al. 1951a rat | Moderate | High
Treon et al. 1951b dog | Very low | High
Treon et al. 1953a rat | High | High
Oral chronic exposure
Human studies
Radomski et al. 1968 | Moderate | Moderate
Animal studies
Deichmann et al. 1970 rat | High | High
Fitzhugh et al. 1964 rat | Moderate | High
Fitzhugh et al. 1964 dog | Moderate | High
Harr et al. 1970 rat | Moderate | High
Kitselman 1953 dog | Very low | High
NCI 1978a rat | High | High
NCI 1978a mouse | High | High
Walker et al. 1969 rat | High | High
Walker et al. 1969 dog | High | High
Outcome: Neurological effects
Inhalation acute exposure
Human studies
Patel and Rao 1958 | Low | Low
Inhalation chronic exposure
Human studies
de Jong 1991 | Moderate | Moderate
Hoogendam et al. 1962 | Low | Moderate
Hoogendam et al. 1965 | Low | Moderate
Sandifer et al. 1981 | Moderate | Moderate
Oral acute exposure
Human studies
Black 1974 | Low | Low
Garrettson and Curley 1969 | Low | Low
Animal studies
Burt 1975 rat (16.7 mg/kg) | Moderate | Moderate
Burt 1975 rat (2.5, 5 mg/kg) | Moderate | Moderate
Burt 1975 rat (8.4, 16.7 mg/kg) | Moderate | Moderate
Foster et al. 2008 mouse | Low | Moderate
Foster et al. 2008 mouse rep | Low | Moderate
Mehrotra et al. 1989 rat | Moderate | Moderate
Sandler et al. 1969 sheep | Very low | Moderate
Woolley et al. 1985 rat | Very low | Moderate
Oral intermediate exposure
Animal studies
Burt 1975 rat | Moderate | Moderate
NCI 1978b rat | Low | Moderate
Smith et al. 1976 monkey | Low | Moderate
Treon et al. 1951b dog | Very low | Moderate
Van Gelder 1975 sheep | | Moderate
Oral chronic exposure
Human studies
Pennell et al. 2006 | Low | Moderate
Weisskopf et al. 2010 | Moderate | Moderate
Animal studies
Khairy 1960 rat | Very low | Moderate
Kitselman 1953 dog | Very low | Moderate
NCI 1978a rat | Moderate | Moderate
NCI 1978a mouse | Moderate | Moderate
NCI 1978b rat | Moderate | Moderate
Walker et al. 1969 rat | Moderate | Moderate
Walker et al. 1969 dog | Moderate | Moderate
Walker et al. 1973 mouse 128 weeks | Moderate | Moderate
Dermal acute exposure
Animal studies
Treon et al. 1953b rabbit
Outcome: Reproductive effects
Oral intermediate exposure
Animal studies
Good and Ware 1969 mouse | High | High
Treon et al. 1954a rat | High | High
Virgo and Bellward 1975 mouse | High | High
Outcome: Developmental effects
Oral acute exposure
Animal studies
Carlson and Rosellini 1987 rat | | High
Chernoff et al. 1975 rat | High | High
Chernoff et al. 1975 mouse | High | High
Dix et al. 1977 mouse | | High
Ottolenghi et al. 1974 mouse | Moderate | High
Ottolenghi et al. 1974 hamster | Moderate | High
Oral intermediate exposure
Animal studies
Harr et al. 1970 rat | Moderate | High
Treon et al. 1954a rat | High | High
Virgo and Bellward 1975 mouse | High | High
Oral chronic exposure
Human Studies
Abdel Hamid et al. 2020 | Low | Low
Beranger et al. 2020 | Low | Low
Dwivedi et al. 2021 | Low | Low
Kao et al. 2019a | Low | Low
Yamazaki et al. 2020 | Low | Low
Animal studies
Kitselman 1953 dog | Very low | Very low

### C.11.2 Adjustment of the Confidence Rating—Dieldrin

The initial confidence rating was then downgraded or upgraded depending on whether there were substantial issues that would decrease or increase confidence in the body of evidence. The five properties of the body of evidence that were considered to determine whether the confidence rating should be downgraded and the four properties of the body of evidence that were considered to determine whether the confidence rating should be upgraded are described above in Section C.6.2. The summaries of the assessment of the confidence in the body of evidence for hepatic effects, neurological effects, reproductive effects, and developmental effects are presented in Table C-29. If the confidence ratings for a particular outcome were based on more than one type of human study, then the highest confidence rating was used for subsequent analyses. An overview of the confidence in the body of evidence for all health effects associated with dieldrin exposure is presented in Table C-30.

Table C-29 Adjustments to the Initial Confidence in the Body of Evidence

| Initial confidence | Adjustments to the initial confidence rating | Final confidence
Outcome: Hepatic effects
Human studies | Moderate | Downgrade one confidence level; most studies in risk of bias second tier | Low
Animal studies | High | No adjustments | High
Outcome: Neurological effects
Human studies | Moderate | Downgrade one confidence level; most studies in risk of bias second tier | Low
Animal studies | Moderate | No adjustments | Moderate
Outcome: Reproductive effects
Animal studies | High | No adjustments | High
Outcome: Developmental effects
Human studies | Low | Downgrade one confidence level; studies in risk of bias second tier | Very low
Animal studies | High | No adjustments | High

Table C-30 Confidence in the Body of Evidence for Dieldrin

Outcome | Confidence in body of evidence
Outcome | Human studies | Animal studies
Hepatic effects | Low | High
Neurological effects | Low | Moderate
Reproductive effects | | High
Developmental effects | Low | High

## C.12 TRANSLATE CONFIDENCE RATING INTO LEVEL OF EVIDENCE OF HEALTH EFFECTS—DIELDRIN

As described in Section C.7, the confidence in the body of evidence for specific outcomes was translated to a level of evidence rating. The level of evidence rating reflected the confidence in the body of evidence and the direction of the effect (i.e., toxicity or no toxicity); route-specific differences were noted.

A summary of the level of evidence of health effects for dieldrin is presented in Table C-31.

Table C-31 Level of Evidence of Health Effects for Dieldrin

Outcome | Confidence in body of evidence | Direction of health effect | Level of evidence for health effect
Human studies
Hepatic effects | Low | Health effect | Moderate
Neurological effects | Low | Health effect | Moderate
Developmental effects | Very low | Heath effect | Low
Animal studies
Hepatic effects | High | Health effect | High
Neurological effects | Moderate | Health effect | Moderate
Reproductive effects | High | Health effect | High
Developmental effects | High | Health effect | High

## C.13 INTEGRATE EVIDENCE TO DEVELOP HAZARD IDENTIFICATION CONCLUSIONS—DIELDRIN

The final step involved the integration of the evidence streams for the human studies and animal studies to allow for a determination of hazard identification conclusions. Refer to Section C.8 for the four hazard identification conclusion categories for health effects, the hazard characterization scheme (see Figure C-1), and the hazard identification conclusion categories.

The hazard identification conclusions for dieldrin are listed below and summarized in Table C-32.

Presumed Health Effects

- Hepatic effects
  ○ Human studies evaluating hepatic endpoints have not provided convincing evidence of aldrin-induced liver effects.
  ○ Increased liver weight and histopathologic hepatic changes have been observed in laboratory animals following chronic-duration oral exposure to dieldrin (Ahmed et al. 1986; Fitzhugh et al. 1964; Harr et al. 1970; Kitselman 1953; Shakoori et al. 1982; Thorpe and Walker 1973; Treon et al. 1951a; Walker et al. 1969).
- Neurological effects
  ○ Various clinical signs and abnormal EEGs have been observed among workers involved in the production of dieldrin or its use as an insecticide (Avar and Czegledi-Janko 1970; Black 1974; Garrettson and Curley 1969; Hoogendam et al. 1965; Jager 1970; Kazantzis et al. 1964; Patel and Rao 1958). Neurological effects were observed in individuals inadvertently or intentionally ingesting dieldrin-containing solutions (Black 1974; Garrettson and Curley 1969).
  ○ Oral dosing of laboratory animals with dieldrin has resulted in neurological effects such as increased locomotor activity, impaired operant behavior, impaired learning, convulsions, tremors, and neuronal degeneration (Burt 1975; Carlson and Rosellini 1987; Kitselman 1953; Mehrotra et al. 1989; NCI 1978a; Sandler et al. 1969; Smith et al. 1976; Van Gelder 1975; Wagner and Greene 1978; Woolley et al. 1985).
- Reproductive effects
  ○ No human studies evaluated reproductive endpoints.
  ○ Decreased fertility was observed in studies of laboratory animals administered dieldrin orally (Keplinger et al. 1970; Treon et al. 1954a; Virgo and Bellward 1975).
- Developmental effects
  ○ Studies evaluating birth outcomes found an inverse association between maternal blood dieldrin and birth weight (Dwivedi et al. 2021), a positive association between maternal hair dieldrin and birth length (Beranger et al. 2020) and no association between maternal blood dieldrin and infant gender (Abdel Hamid et al. 2020). A neurodevelopmental study found that higher infant language scores were associated with higher breast milk levels of dieldrin (Kao et al. 2019a). No associations were observed between maternal serum levels and infant thyroid hormone levels (Yamazaki et al. 2020).
  ○ Increased postnatal mortality has been one of the most consistent developmental findings reported for aldrin and dieldrin (Deichmann et al. 1971; Harr et al. 1970; Kitselman 1953; Treon et al. 1954a; Virgo and Bellward 1975). Aldrin or dieldrin exposure during gestation has resulted in some evidence of external malformations or skeletal anomalies in animals (Chernoff et al. 1975; Ottolenghi et al. 1974).

Table C-32 Hazard Identification Conclusions for Dieldrin

Outcome | Hazard identification
Hepatic effects | Presumed health effect in humans
Neurological effects | Presumed health effect in humans
Reproductive effects | Presumed health effect in humans
Developmental effects | Presumed health effect in humans