# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR ALDRIN/DIELDRIN

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to aldrin or dieldrin.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen was conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for aldrin/dieldrin. ATSDR primarily focused on peer-reviewed articles without publication date or language restrictions. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of aldrin/dieldrin have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of aldrin/dieldrin are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen

Health Effects; Species; Human; Laboratory mammals; Route of exposure; Inhalation; Oral; Dermal (or ocular); Parenteral (these studies will be considered supporting data); Health outcome; Death; Systemic effects; Body weight effects; Respiratory effects; Cardiovascular effects; Gastrointestinal effects; Hematological effects; Musculoskeletal effects; Hepatic effects; Renal effects; Dermal effects; Ocular effects; Endocrine effects; Immunological effects; Neurological effects; Reproductive effects; Developmental effects; Other noncancer effects; Cancer
Toxicokinetics; Absorption; Distribution; Metabolism; Excretion; PBPK models; Biomarkers; Biomarkers of exposure; Biomarkers of effect; Interactions with other chemicals; Potential for human exposure; Releases to the environment; Air; Water; Soil; Environmental fate; Transport and partitioning; Transformation and degradation; Environmental monitoring; Air; Water; Sediment and soil; Other media; Biomonitoring; General populations; Occupation populations

### B.1.1 Literature Search

The current literature search was intended to update the draft toxicological profile for aldrin/dieldrin released for public comment in 2021; thus, the literature search was restricted to studies published between January 2018 and October 2021. The following main databases were searched in October 2021:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for aldrin/dieldrin. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to aldrin/dieldrin were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
10/2021 | ((“Aldrin”[mh] OR 309-00-2[rn] OR “Dieldrin”[mh] OR 60-57-1[rn]) OR ((“(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4:5,8-dimethanonaphthalene”[tw] OR “(1R, 4S, 4aS, 5S, 8R, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4:5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexachloro-1,4-endo-exo-5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1a, 4a, 4ab, 5a, 8a, 8ab)-1,4:5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)1,4 ,5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-1,4,5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4,5,8-endo, endodimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4:5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4-endo-exo-5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-endo-1,4-exo-5,8-dimethanonaphthalene”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1.alpha.,4.alpha.,4a.beta.,5.alpha.,8.alpha.,8a.beta.)-”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1.alpha.,4.alpha.,4a.beta.,5.alpha.,8.alpha.,8a.beta.)-”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(alpha, 4alpha, 4beta, 5alpha, 8alpha, 8abeta)-”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexa-chloro-1,4,4a, 5,8,8a, -hexahydro-,(1.alpha.,4.alpha.,4a.beta.,5.alpha.,8.alpha.,8a.beta.)-”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro (1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-”[tw] OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8beta)-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro1,4,4a, 5,8,8a-hexahydro-(1.alpha.,4.alpha.,4a.beta.,5.alpha.,8.alpha.,8a.beta.)-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1.alpha.,4.alpha.,4a.beta.,5.alpha.,8.alpha.,8a.beta.)-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1R, 4S, 4aS, 5S, 8R, 8aR)-rel-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8ahexahydro-, endo, exo-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)”[tw] OR “Aldocit”[tw] OR “Aldrex”[tw] OR “Aldrin”[tw] OR “Aldrite”[tw] OR “Aldron”[tw] OR “Aldrosol”[tw] OR “Algran”[tw] OR “Altox”[tw] OR “Andrex”[tw] OR “Complex Hydrocarbon Adrex 30”[tw] OR “Compound 118”[tw] OR “Hexachlorohexahydro-endo-exo-dimethanonaphthalene”[tw] OR “HHDN”[tw] OR “Isodrin”[tw] OR “Kortofin”[tw] OR “NA 2761”[tw] OR “NA 2762”[tw] OR “Octalene”[tw] OR “SD 2794”[tw] OR “Seedrin”[tw] OR “Soilgrin”[tw] OR “Tatuzinho”[tw] OR “Tipula”[tw] OR (“dimethanonaphthalene”[tw] AND “hexachloro”[tw] AND “hexahydro”[tw])) OR (“(1a.alpha.,2.beta.,2a.alpha.,3.beta.,6.beta.,6a.alpha.,7.beta.,7a.alpha.)-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-dimethanonaphth[2,3-b]oxirene”[tw] OR “(1a.alpha.,2.beta.,2a.alpha.,3.beta.,6.beta.,6a.alpha.,7.beta.,7a.alpha.)Octahydro-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-2,7:3,6-dimethanonaphth[2,3-b]oxirene”[tw] OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-dimethanonaphth(2,3-b)oxirene”[tw] OR “(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-Dimethanonaphth(2,3-b)oxirene”[tw] OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-dimethanonaphth[2,3-b]oxirene”[tw] OR “(1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,6,7,8,8a-octahydro-6,7-epoxy-1,4:5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR-octahydro-6,7-epoxy-1,4:5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4-endo, exo-5,8-dimethanonaphthalene”[tw] OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-endo-1,4-exo-5,8-dimethanonaphthalene”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro, endo, exo-”[tw] OR “1,4:5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-, endo, exo-”[tw] OR “1,8,9,10,11,11-Hexachloro-4,5-exo epoxy-2,3-7,6-endo-2,1-7,8-exo-tetracyclo(6.2.1.1 3,6.0 2,7)dodec-9-ene”[tw] OR “2,7:3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a.alpha.,2.beta.,2a.alpha.,3.beta.,6.beta.,6a.alpha.,7.beta.,7a.alpha.)-”[tw] OR “2,7:3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7a-alpha)-”[tw] OR “2,7:3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7aoctahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-”[tw] OR “2,7:3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a.alpha.,2.beta.,2a.alpha.,3.beta.,6.beta.,6a.alpha.,7.beta.,7a.alpha.)-”[tw] OR “2,7:3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-”[tw] OR “2,7:3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-”[tw] OR “2,7:3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-”[tw] OR “3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-dimethanonaphth(2,3-b)oxirene”[tw] OR “Alvit”[tw] OR “Compound 497”[tw] OR “Dieldren”[tw] OR “Dieldrex”[tw] OR “Dieldrin”[tw] OR “Dieldrite”[tw] OR “Dielmoth”[tw] OR “Dildrin”[tw] OR “Dorytox”[tw] OR “endo, exo-1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4:5,8-dimethanonaphthalene”[tw] OR “endo, exo-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7:3,6-dimethenapth(2,3-b)oxirene”[tw] OR “HEOD”[tw] OR “Hexachloroepoxyoctahydro-endo, exo-dimethanonaphthalene”[tw] OR “Illoxol”[tw] OR “Insecticide No. 497”[tw] OR “Insectlack”[tw] OR “Kombi-Albertan”[tw] OR “Moth Snub D”[tw] OR “NA 2761”[tw] OR “Octalox”[tw] OR “Panoram D-31”[tw] OR “Red Shield”[tw] OR “SD 3417”[tw] OR “Shelltox”[tw] OR “Termitox”[tw] OR (“dimethanonaphth”[tw] AND “oxirene”[tw] AND “hexachloro”[tw] AND “octahydro”[tw]) OR (“dimethanonaphthalene”[tw] AND “hexachloro”[tw] AND “octahydro”[tw] AND “epoxy”[tw])))) AND (2018:3000[dp] OR 2019/04/01:3000[edat] OR 2019/04/01:3000[crdt] OR 2019/04/01:3000[mhda])
NTRL
10/2021 | “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexachloro-1,4-endo-exo-5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “Aldrex” OR “Aldrin” OR “Aldron” OR “Altox” OR “Compound 118” OR “HHDN” OR “Isodrin” OR “Octalene” OR “Tipula” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4-endo-exo-5,8-dimethanonaphthalene” OR “Alvit” OR “Dieldren” OR “Dieldrex” OR “Dieldrin” OR “HEOD” OR “Hexachloroepoxyoctahydro-endo, exo-dimethanonaphthalene” OR “Shelltox”; “(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “(1R, 4S, 4aS, 5S, 8R, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1a, 4a, 4ab, 5a, 8a, 8ab)-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)1,4 ,5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-1,4,5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4,5,8-endo, endodimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-endo-1,4-exo-5,8-dimethanonaphthalene” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(alpha, 4alpha, 4beta, 5alpha, 8alpha, 8abeta)-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexa-chloro-1,4,4a, 5,8,8a, -hexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro (1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8beta)-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha,8 alpha ,8a beta )-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1R, 4S, 4aS, 5S, 8R, 8aR)-rel-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10hexachloro-1,4,4a, 5,8,8a-hexahydro-, endo, exo-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-” OR “Aldocit” OR “Aldrite” OR “Aldrosol” OR “Algran” OR “Andrex” OR “Complex Hydrocarbon Adrex 30” OR “Hexachlorohexahydro-endo-exo-dimethanonaphthalene” OR “Kortofin” OR “NA 2761” OR “NA 2762” OR “SD 2794” OR “Seedrin” OR “Soilgrin” OR “Tatuzinho”; “(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )Octahydro-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth(2,3-b)oxirene” OR “(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-Dimethanonaphth(2,3-b)oxirene” OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,6,7,8,8a-octahydro-6,7-epoxy-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR-octahydro-6,7-epoxy-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4-endo, exo-5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-endo-1,4-exo-5,8-dimethanonaphthalene” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro, endo, exo-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-, endo, exo-” OR “1,8,9,10,11,11-Hexachloro-4,5-exo epoxy-2,3-7,6-endo-2,1-7,8-exo-tetracyclo(6 2 1 1 3,6 0 2,7)dodec-9-ene” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth(2,3-b)oxirene” OR “Compound 497” OR “Dieldrite” OR “Dielmoth” OR “Dildrin” OR “Dorytox” OR “endo, exo-1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4 5,8-dimethanonaphthalene” OR “endo, exo-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethenapth(2,3-b)oxirene” OR “Illoxol” OR “Insecticide No 497” OR “Insectlack” OR “Kombi-Albertan” OR “Moth Snub D” OR “NA 2761” OR “Octalox” OR “Panoram D-31” OR “Red Shield” OR “SD 3417” OR “Termitox”
Toxcenter
10/2021 | FILE ‘TOXCENTER’ ENTERED AT 15:42:58 ON 26 OCT 2021; CHARGED TO COST=EH038.12.01.LB.04; L1 10552 SEA FILE=TOXCENTER 309-00-2; L2 18530 SEA FILE=TOXCENTER 60-57-1; L3 21610 SEA FILE=TOXCENTER L1 OR L2; L4 21283 SEA FILE=TOXCENTER L3 NOT PATENT/DT; L5 21251 SEA FILE=TOXCENTER L4 NOT TSCATS/FS; L6 726 SEA FILE=TOXCENTER L5 AND ED>=20190401; ACT TOXQUERY/Q; ---------; L7 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L8 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L9 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L10 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L11 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L12 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L13 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L14 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L15 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L16 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L17 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L18 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L19 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L20 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L21 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L22 QUE (ENDOCRIN? AND DISRUPT?); L23 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L24 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L25 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L26 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L27 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L28 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L29 QUE (NEPHROTOX? OR HEPATOTOX?); L30 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L31 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L32 QUE L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29 OR L30 OR L31; L33 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L34 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L35 QUE L32 OR L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; ---------; L38 468 SEA FILE=TOXCENTER L6 AND L37; L39 28 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 93 SEA FILE=TOXCENTER L38 AND BIOSIS/FS; L41 347 SEA FILE=TOXCENTER L38 AND CAPLUS/FS; L42 0 SEA FILE=TOXCENTER L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 407 DUP REM L39 L40 L41 (61 DUPLICATES REMOVED); ANSWERS ‘1-407’ FROM FILE TOXCENTER; L*** DEL 28 S L38 AND MEDLINE/FS; L*** DEL 28 S L38 AND MEDLINE/FS; L44 28 SEA FILE=TOXCENTER L43; L*** DEL 93 S L38 AND BIOSIS/FS; L*** DEL 93 S L38 AND BIOSIS/FS; L45 82 SEA FILE=TOXCENTER L43; L*** DEL 347 S L38 AND CAPLUS/FS; L*** DEL 347 S L38 AND CAPLUS/FS; L46 297 SEA FILE=TOXCENTER L43; L47 379 SEA FILE=TOXCENTER (L44 OR L45 OR L46) NOT MEDLINE/FS D SCAN L47

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
10/2021 | Compounds searched: 309-00-2, 60-57-1
NTP
10/2021 | 309-00-2 60-57-1 “aldrin” “dieldrin”; “Isodrin”; “Aldrex” “Aldron” “Altox”; “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4:5,8-dimethanonaphthalene”; “Compound 118” “HHDN” “Octalene” “Tipula”; “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexachloro-1,4-endo-exo-5,8-dimethanonaphthalene”; “Alvit” “Dieldren”; “Dieldrex” “HEOD” “Shelltox” “Hexachloroepoxyoctahydro-endo, exo-dimethanonaphthalene”; “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4-endo-exo-5,8-dimethanonaphthalene”
Regulations.gov
10/2021 | Documents and Dockets: limited to EPA, Notices, posted 01/01/2018-present; aldrin; dieldrin; 309-00-2; 60-57-1; HHDN; isodrin; dimethanonaphthalene
NIH RePORTER
12/2021 | Search Criteria Fiscal Year: Active ProjectsText Search: “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexachloro-1,4-endo-exo-5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “Aldrex” OR “Aldrin” OR “Aldron” OR “Altox” OR “Compound 118” OR “HHDN” OR “Isodrin” OR “Octalene” OR “Tipula” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4-endo-exo-5,8-dimethanonaphthalene” OR “Alvit” OR “Dieldren” OR “Dieldrex” OR “Dieldrin” OR “HEOD” OR “Hexachloroepoxyoctahydro-endo, exo-dimethanonaphthalene” OR “Shelltox” (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria Fiscal Year: Active ProjectsText Search: “(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “(1R, 4S, 4aS, 5S, 8R, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1a, 4a, 4ab, 5a, 8a, 8ab)-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)1,4 ,5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-1,4,5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-1,4,5,8-endo, endodimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1,4,4a, 5,8,8a-hexahydro-endo-1,4-exo-5,8-dimethanonaphthalene” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8-ahexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(alpha, 4alpha, 4beta, 5alpha, 8alpha, 8abeta)-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexa-chloro-1,4,4a, 5,8,8a, -hexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro (1alpha, 4alpha, 4abeta, 5beta, 8beta, 8abeta)-” OR “1,4,5,8-Dimethanonaphthalene, 1,2,3,4,10,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8beta)-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1 alpha ,4 alpha ,4a beta ,5 alpha ,8 alpha ,8a beta )-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro1,4,4a, 5,8,8a-hexahydro-,(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-,(1R, 4S, 4aS, 5S, 8R, 8aR)-rel-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-, endo, exo-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-1,4,4a, 5,8,8a-hexahydro-(1alpha, 4alpha, 4abeta, 5alpha, 8alpha, 8abeta)-” OR “Aldocit” OR “Aldrite” OR “Aldrosol” OR “Algran” OR “Andrex” OR “Complex Hydrocarbon Adrex 30” OR “Hexachlorohexahydro-endo-exo-dimethanonaphthalene” OR “Kortofin” OR “NA 2761” OR “NA 2762” OR “SD 2794” OR “Seedrin” (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria Fiscal Year: Active ProjectsText Search: “(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )Octahydro-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth(2,3-b)oxirene” OR “(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-Dimethanonaphth(2,3-b)oxirene” OR “(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth[2,3-b]oxirene” OR “(1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR)-1,2,3,4,10,10-Hexachloro-1,4,4a, 5,6,7,8,8a-octahydro-6,7-epoxy-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-1R, 4S, 4aS, 5R, 6R, 7S, 8S, 8aR-octahydro-6,7-epoxy-1,4 5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4-endo, exo-5,8-dimethanonaphthalene” OR “1,2,3,4,10,10-Hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-endo-1,4-exo-5,8-dimethanonaphthalene” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro, endo, exo-” OR “1,4 5,8-Dimethanonaphthalene, 1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-, endo, exo-” OR “1,8,9,10,11,11-Hexachloro-4,5-exo epoxy-2,3-7,6-endo-2,1-7,8-exo-tetracyclo(6 2 1 1 3,6 0 2,7)dodec-9-ene” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “2,7 3,6-Dimethanonaphth(2,3-b)oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-” OR “Soilgrin” OR “Tatuzinho” (advanced)Limit to: Project Title, Project Terms, Project Abstracts; Search Criteria Fiscal Year: Active ProjectsText Search: “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1a alpha ,2 beta ,2a alpha ,3 beta ,6 beta ,6a alpha ,7 beta ,7a alpha )-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aR, 2R, 2aS, 3S, 6R, 6aR, 7S, 7aS)-rel-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “2,7 3,6-Dimethanonaphth[2,3-b]oxirene, 3,4,5,6,9,9-hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-,(1aalpha, 2beta, 2aalpha, 3beta, 6beta, 6aalpha, 7beta, 7aalpha)-” OR “3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethanonaphth(2,3-b)oxirene” OR “Compound 497” OR “Dieldrite” OR “Dielmoth” OR “Dildrin” OR “Dorytox” OR “endo, exo-1,2,3,4,10,10-hexachloro-6,7-epoxy-1,4,4a, 5,6,7,8,8a-octahydro-1,4 5,8-dimethanonaphthalene” OR “endo, exo-3,4,5,6,9,9-Hexachloro-1a, 2,2a, 3,6,6a, 7,7a-octahydro-2,7 3,6-dimethenapth(2,3-b)oxirene” OR “Illoxol” OR “Insecticide No 497” OR “Insectlack” OR “Kombi-Albertan” OR “Moth SnubD” OR “NA 2761” OR “Octalox” OR “Panoram D-31” OR “Red Shield” OR “SD 3417” OR “Termitox” (advanced)Limit to: Project Title, Project Terms, Project Abstracts
Other | Identified throughout the assessment process

The 2021 results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 582
- Number of records identified from other strategies: 11
- Total number of records to undergo literature screening: 593

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on aldrin/dieldrin:

- Title and abstract screen
- Full text screen

Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 593
- Number of studies considered relevant and moved to the next step: 64

Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 64
- Number of studies cited in the pre-public draft of the toxicological profile: 579
- Total number of studies cited in the profile: 592

A summary of the results of the literature search and screening is presented in Figure B-1.

Figure B-1 October 2021 Literature Search Results and Screen for Aldrin/Dieldrin

Figure B-1 description