# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: The acute-duration inhalation data were not considered adequate for derivation of an acute-duration inhalation MRL for aldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. Available data from experimental animals are restricted to findings of death and respiratory effects (mucous membrane irritation) among rats, mice, rabbits, and cats acutely exposed to aldrin vapor generated by sublimating aldrin at 200°C (Treon et al. 1957). The Treon et al. (1957) study was not considered an adequate basis for an MRL for aldrin because the study examined a limited number of endpoints and lacked exposure concentration-response data. Given the limitations of the only available acute inhalation study, the database was not considered adequate for derivation of an acute-duration inhalation MRL for aldrin.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The intermediate-duration inhalation data were not considered adequate for derivation of an intermediate-duration inhalation MRL for aldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The chronic-duration inhalation data were not considered adequate for derivation of a chronic-duration inhalation MRL for aldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.002 mg/kg/day (2 µg/kg/day)
Critical Effect: | Neurodevelopmental toxicity in offspring
Reference: | Al-Hachim 1971
Point of Departure: | 2 mg/kg/day (LOAEL)
Uncertainty Factor: | 1,000
LSE Graph Key: | 7
Species: | Mouse

MRL Summary: An acute-duration oral MRL of 0.002 mg/kg/day (2 µg/kg/day) has been derived for aldrin. The MRL is based on a LOAEL of 2 mg/kg/day for neurodevelopmental effects (increased electroconvulsive shock threshold) in offspring of maternal mice administered aldrin by gavage during the third trimester of pregnancy (Al-Hachim 1971). The study did not identify a NOAEL. The LOAEL of 2 mg/kg/day was divided by a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response data were available for humans. Table A-1 summarizes results from candidate acute-duration oral studies in experimental animals.

Table A-1 Summary of Selected NOAELs and LOAELs from Candidate Acute-Duration Studies in Experimental Animals Orally Exposed to Aldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Charles Foster rat | Once; (GO) | ND | 2 | Increased locomotor activity; peak effect at 2 hours postdosing | Jamaluddin and Poddar 2001a
Charles Foster rat | Up to 30 days; 1 time/day; (GO) | ND | 2 | Increased locomotor activity; peak effect at day 12 | Jamaluddin and Poddar 2001b
Charles Foster rat | Up to 30 days; 1 time/day; (GO) | ND | 2 | Increased locomotor activity; peak effect at day 12 | Jamaluddin and Poddar 2003
Sprague-Dawley rat | 3 days; 1 time/day; (GO) | ND | 10 | Tremors, convulsions | Mehrotra et al. 1989
Developmental effects
ICR/Ha Swiss mouse | Third trimester of pregnancy; (GO) | ND | 2^a^ | Depressed pup body weight, increased seizure threshold | Al-Hachim 1971

a Used to derive an acute-duration oral MRL for aldrin.

(GO) = gavage in oil vehicle; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Four studies identified the lowest LOAEL (2 mg/kg for single dose or 2 mg/kg/day for repeated dosing) and were considered potential candidate principal studies for deriving an acute-duration oral MRL for aldrin. Jamaluddin and Poddar (2001a, 2001b) observed increased locomotor activity in rats dosed at 2 mg aldrin/kg; the effect peaked at 2 hours following single gavage dosing of aldrin. In two other gavage studies of rats administered aldrin at 2 mg/kg/day for up to 30 days, increased locomotor activity was observed as well; the peak effect occurred at treatment day 12 (Jamaluddin and Poddar 2001b, 2003). Al-Hachim (1971) observed depressed pup body weight and increased electroshock seizure threshold in pups from maternal mice gavaged with aldrin during the third trimester of pregnancy.

Selection of the Principal Study: Jamaluddin and Poddar presented mean locomotor activity ± standard error of the mean numerically (Jamaluddin and Poddar 2001a) or graphically (Jamaluddin and Poddar 2001b, 2003) using 6–8 separate observations per group. Benchmark dose (BMD) analysis is precluded because the actual numbers of animals contributing to the reported levels of locomotor activity were not available. The studies of Al-Hachim (1971) and Jamaluddin and Poddar (2001a, 2001b, 2003) identified a common LOAEL (2 mg/kg/day). The study of Al-Hachim (1971) was selected as a representative principal study for deriving an acute-duration oral MRL for aldrin. A NOAEL/LOAEL approach to deriving an acute-duration oral MRL for aldrin based on results from either Jamaluddin and Poddar (2001a, 2001b, 2003) or Al-Hachim (1971) would result in the same MRL value.

Summary of the Principal Study:

Al-Hachim GM. 1971. Effect of aldrin on the condition avoidance response and electroshock seizure threshold of offspring from aldrin-treated mother. Psychopharmacologia 21:370–373.5098935

Groups of pregnant ICR/Ha Swiss mice (7/group) were treated with aldrin (grade and purity not specified) by gavage (in corn oil vehicle) at 0, 2, or 4 mg/kg/day during the 3^rd^ trimester of pregnancy. The study report stated that the dams were treated daily for 7 consecutive days, but also stated that each pregnant animal received 5-7 doses. Offspring were weaned at 30 days of age and culled to 10 mice/exposure group. Beginning at 30 days of age, each pup was weighed daily for 7 days and tested daily for conditioned avoidance responses (number of responses out of 16 trials of daily training for 7 days). At 38 days of age, each pup was tested for electroshock seizure threshold.

Mean body weights of the low- and high-dose offspring were 18 and 8% less, respectively, than controls. Aldrin had no effect on the acquisition of a conditioned avoidance response but did significantly raise the electroshock seizure threshold in low- and high-dose groups (38 and 34% higher, respectively, than controls). Table A-2 presents summary data for body weight and electroshock seizure threshold.

Table A-2 Body Weight and Electroshock Seizure Threshold Data for Mouse Pups Following Maternal Gavage Administration of Aldrin During the Third Trimester of Pregnancy

Test | Dose (mg/kg/day) | | | p-value (%)
Test | 0 | 2 | 4 | p-value (%)
Body weight (g) | 19.1±0.58^a^ | 15.7±0.47 | 17.6±0.7 | 0.5
Electroshock seizure threshold (volts) | 79.9±5.4 | 109.1±10.88 | 106.0±4.0 | 0.5

a Mean ± SEM for 10 pups/group.

Source: Al-Hachim 1971

Selection of the Point of Departure for the MRL: Initially, a BMD approach to deriving an acute-duration oral MRL for aldrin was considered. The body weight data are not amenable to BMD analysis because, although the 2 mg/kg/day dose level resulted in 18% depressed mean pup body weight, the higher dose level (4 mg/kg/day) only resulted in 8% depressed mean pup body weight. Although the electroshock seizure threshold was higher in the 2 mg/kg/day dose group compared to the 4 mg/kg/day dose group (indicating lack of adequate fit of BMD models to the dataset), all continuous models in EPA’s Benchmark Dose Software (BMDS; version 3.1.2) were applied to the dataset using a benchmark response (BMR) of 1 standard deviation from the control mean in the absence of information to suggest an alternative BMR. None of the models provided adequate fit to the data. Therefore, a NOAEL/LOAEL approach was implemented to derive an acute-duration oral MRL for aldrin. The LOAEL of 2 mg/kg/day for increased seizure threshold was selected as the representative critical effect level for deriving an acute-duration oral MRL for aldrin.

Uncertainty Factor: The LOAEL of 2 mg/kg/day was divided by an uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ uncertainty factor 2 mg/kg/day ÷ 1,000 = 0.002 mg/kg/day ( 2 μg/kg/day )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Administration of aldrin by gavage caused an increased incidence of webbed feet in mice following gavage administration of aldrin to pregnant dams on GD 9 at 25 mg/kg; increased fetal mortality was noted in hamsters following gavage administration of aldrin to pregnant hamsters on GD 7, 8, or 9 at 50 mg/kg/day (Ottolenghi et al. 1974). These results support the developmental toxicity of aldrin. The neurodevelopmental effect is consistent with evidence showing that the central nervous system is a target of aldrin toxicity in adult animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate

MRL Summary: The intermediate-duration oral data were not considered adequate for derivation of an intermediate-duration oral MRL for aldrin.

Rationale for Not Deriving an MRL: No dose-response data are available for humans. Table A-3 summarizes results from candidate intermediate-duration oral studies in experimental animals.

Table A-3 Summary of Selected NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Experimental Animals Orally Exposed to Aldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
Dog | Up to 37 days; 5 days/week; 1 ×/day; (C) | ND | 1.5 | Depressed body weight gain at lethal dose level | Treon et al. 1951b
Gastrointestinal effects
Dog | Up to 9 months; (F) | ND | 0.89 | Vomiting | Treon et al. 1951b
Hepatic effects
Carworth rat | 6 months; (F) | 0.53 | 2.6 | Increased liver weight; liver lesions | Treon et al. 1951a
Dog | Up to 9 months; (F) | ND | 1.25 | Degenerative liver lesions | Treon et al. 1951b
Neurological effects
Dog | Up to 9 months; (F) | ND | 0.89 | Hypersensitivity, tremors, twitching, convulsions, neuronal degeneration in brain | Treon et al. 1951b
Dog | Up to 37 days; 5 days/week; 1 ×/day; (C) | ND | 1.5 | Lethargy, intoxication | Treon et al. 1951b
Reproductive effects
Carworth rat | 3 generations; (F) | 0.26 | 1.3 | 40% decreased number of litters from first parental mating | Treon et al. 1954a
Swiss mouse | 6 generations | ND | 0.56 | Decreased number of pregnant dams | Keplinger et al. 1970
Developmental effects
Carworth rat | 3 generations; (F) | | 0.26 | 3.2-fold increased mortality of F1a pups | Treon et al. 1954a
Swiss mouse | 6 generations | ND | 0.56 | Decreased pup survival to PPD 4 | Keplinger et al. 1970

(C) = capsule; (F) = food; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PPD = postpartum day

An intermediate-duration oral MRL was not derived for aldrin due to lack of appropriate effect levels. In intermediate-duration oral studies, the lowest NOAEL of 0.26 mg/kg/day was associated with a serious LOAEL of 1.3 mg/kg/day for 40% decreased number of litters from first parental mating in a 3-generation reproductive/developmental toxicity study (Treon et al. 1954a). However, the 3-generation study also identified a serious LOAEL of 0.26 mg/kg/day (the lowest dose level tested) for 3.2-fold increased mortality of F1a pups. Keplinger et al. (1970) identified a serious LOAEL of 0.56 mg/kg/day for decreased number of pregnant mice and decreased survival of pups to postpartum day 4 in a 6-generation reproductive/developmental toxicity study. An intermediate-duration oral MRL for aldrin was not derived because the lowest level tested (0.26 mg/kg/day in the 3-generation study) represents a serious LOAEL, and it is ATSDR practice to not base MRLs on serious LOAELs.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Aldrin
CAS Numbers: | 309-00-2
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.00004 mg/kg/day (0.04 µg/kg/day)
Critical Effect: | Increased liver weight and histological alterations in liver
Reference: | Fitzhugh et al. 1964
Point of Departure: | 0.037 mg/kg/day (LOAEL)
Uncertainty Factor: | 1,000
LSE Graph Key: | 23
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.00004 mg/kg/day (0.04 µg/kg/day) has been derived for aldrin. The MRL is based on a LOAEL of 0.037 mg/kg/day for increased liver weight and hepatic histological alterations (enlarged centrilobular hepatocytes with cytoplasmic oxyphilia, and peripheral migration of basophilic granules) in rats receiving aldrin from the food for 2 years (Fitzhugh et al. 1964). The study did not identify a NOAEL. The LOAEL of 0.037 mg/kg/day was divided by a total uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response data were available for humans. Table A-4 summarizes results from candidate chronic-duration oral studies in experimental animals that identified the lowest NOAELs and/or LOAELs.

Table A-4 Summary of Selected NOAELs and LOAELs from Candidate Chronic-Duration Studies in Experimental Animals Orally Exposed to Aldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
Dog | Up to 25 months; 6 days/week; 1 time/day; (C) | 0.2 | 0.5 | Body weight loss | Fitzhugh et al. 1964
Hematological effects
Dog | Up to 25 months; 6 days/week; 1 time/day; (C) | 0.5 | 1 | Reduced bone marrow cellularity | Fitzhugh et al. 1964
Hepatic effects
Osborne-Mendel rat | 2 years; (F) | ND | 0.037^a^ | 23–31% increased liver weight; liver histopathology (enlarged centrilobular hepatocytes with cytoplasmic oxyphilia, and peripheral migration of basophilic granules) | Fitzhugh et al. 1964
Dog | Up to 25 months; 6 days/week; 1 time/day; (C) | 0.5 | 1 | Fatty degenerative hepatic changes | Fitzhugh et al. 1964
Osborne-Mendel rat | 31 months; (F) | 1.4 | 2.1 | Increased liver weight in males | Deichmann et al. 1970
Renal effects
Dog | Up to 25 months; 6 days/week; 1 time/day; (C) | 0.5 | 1 | Fatty degenerative renal changes | Fitzhugh et al. 1964
Neurological effects
B6C3F1 mouse | 80 weeks; (F) | ND | 0.5 | Hyperexcitability | NCI 1978a
Osborne-Mendel rat | 74 weeks; (F) | ND | 2.1 | Hyperexcitability | NCI 1978a

a Used to derive a chronic-duration oral MRL for aldrin.

(C) = capsule; (F) = food; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

The 2-year oral rat study of Fitzhugh et al. (1964) identified the lowest LOAEL (0.037 mg/kg/day for increased liver weight and histopathology). Dose-related increasing incidence and severity of histopathologic liver lesions were reported at doses ≥0.15 mg/kg/day. The lesions were described as “enlarged centrilobular hepatic cells, with cytoplasmic oxyphilia somewhat increased, and peripheral migration of the basophilic granules.” NOAELs and/or LOAELs identified in the other studies summarized in Table A-4 range from 0.2 to 2.1 mg/kg/day. Therefore, hepatotoxicity was selected as the critical effect for deriving a chronic-duration oral MRL for aldrin.

Selection of the Principal Study: As shown in Table A-4, the 2-year oral rat study of Fitzhugh et al. (1964) identified the lowest LOAEL (0.037 mg/kg/day for increased liver weight and histopathologic liver lesions) among candidate principal studies. Therefore, the 2-year oral rat study of Fitzhugh et al. (1964) was selected as the principal study.

Summary of the Principal Study:

Fitzhugh OG, Nelson AA, Quaife ML. 1964. Chronic oral toxicity of aldrin and dieldrin in rats and dogs. Food Cosmet Toxicol 2:551–562.14249972

Groups of weanling Osborne-Mendel rats (12/sex/group) were administered aldrin (recrystallized and ≥99% purity; in 1% corn oil vehicle) in the diet at 0, 0.5, 2, 10, 50, 100, or 150 ppm for up to 2 years (Fitzhugh et al. 1964). Rats were monitored for survival, clinical signs, and body weight. Rats that survived to terminal sacrifice at week 104 were processed for gross examination and organ weights (heart, liver, spleen, kidney, testis). Rats that died prior to terminal sacrifice were subjected to gross examination only. Histopathologic examinations were performed on most rats. Only liver, kidney, and testes (and tumors and gross abnormalities) were examined for most rats; a selected few rats were subjected to more comprehensive histopathologic examination.

Estimated aldrin doses in the 0.5, 2, 10, 50, 100, and 150 ppm groups of Osborne-Mendel rats were 0.037, 0.15, 0.73, 3.65, 7.3, and 11 mg/kg/day, respectively, for combined sexes (calculations performed using EPA [1988b] chronic reference values for food intake [0.033 kg] and body weight [0.452 kg]). Significantly decreased survival was noted at the two highest dose levels (7.3 and 11 mg/kg/day). There were no significant treatment-related effects on body weight. Male and female rats exhibited significantly increased relative liver weight at all aldrin exposure concentrations except 2 ppm (generally dose-related and ranged from 23 to >50% higher than that of controls), as shown in Table A-5. Histopathologic liver lesions (described as enlarged centrilobular hepatocytes with cytoplasmic oxyphilia somewhat increased, and peripheral migration of basophilic granules) were noted with increasing severity in a dose-related manner, as shown in Table A-6. Occasional increased relative spleen and kidney weights were observed among aldrin-treated female rats, but these changes did not exhibit dose-response characteristics. The study authors noted “exaggeration” of the usual type of kidney lesion, but did not provide quantitative data, thus precluding assignment of NOAEL or LOAEL values.

Table A-5 Mean Relative Liver Weight in Osborne-Mendel Rats Administered Aldrin in the Food for up to 2 Years

Concentration in food (ppm) | Dose^a^ (mg/kg/day) | Number of animals | | Liver weight (g/kg body weight)
Concentration in food (ppm) | Dose^a^ (mg/kg/day) | Males | Females | Males | Females
0 | 0 | 10 | 7 | 22.94 | 24.55
0.5 | 0.037 | 9 | 10 | 28.28^b^ | 32.27^c^
2 | 0.15 | 9 | 10 | 23.59 | 30.17^b^
10 | 0.73 | 11 | 8 | 26.12^b^ | 33.20^b^
50 | 3.65 | 9 | 4 | 28.86^c^ | 38.14^b^
100 | 7.3 | 8 | 0 | 34.61^c^ | −
150 | 11.0 | 3 | 2 | 34.49^d^ | 59.49^c^

a Doses estimated using EPA (1988b) chronic reference values for food intake (0.033 kg) and body weight (0.452 kg) for the Osborne-Mendel rat (combined sexes).

b Significantly different from controls at 95% confidence limit.

c Significantly different from controls at 99% confidence limit.

d Statistical significance not stated in study report, presumably due to the low number of high-dose rats evaluated.

Source: Reprinted from Fitzhugh et al. (1964) with permission from Elsevier.

Table A-6 Incidences of Nonneoplastic Liver Lesions in Osborne-Mendel Rats Administered Aldrin in the Food for up to 2 Years

Concentration in food (ppm) | Dose^a^ (mg/kg/day) | Severity of liver lesion
Concentration in food (ppm) | Dose^a^ (mg/kg/day) | None | Trace | Very slight | Slight | Slight-to-moderate and moderate | Greater than moderate
0 | 0 | 16 | 1 | 0 | 0 | 0 | 0
0.5 | 0.037 | 15 | 4 | 0 | 0 | 0 | 0
2 | 0.15 | 10 | 8 | 0 | 1 | 0 | 0
10 | 0.73 | 11 | 3 | 7 | 1 | 0 | 0
50 | 3.65 | 0 | 0 | 0 | 6 | 10 | 2
100 | 7.3 | 0 | 0 | 0 | 0 | 5 | 6
150 | 11.0 | 0 | 0 | 0 | 0 | 2 | 7

a Doses estimated using EPA (1988b) chronic reference values for food intake (0.033 kg) and body weight (0.452 kg) for the Osborne-Mendel rat (combined sexes).

Source: Reprinted from Fitzhugh et al. (1964) with permission from Elsevier.

Selection of the Point of Departure for the MRL: A BMD approach was initially considered to derive a chronic-duration oral MRL for aldrin. However, BMD analysis is precluded by the lack of reported variance in the liver weight data and uncertainty in the degree of severity associated with an adverse effect for the reported liver lesion data. Therefore, a NOAEL/LOAEL approach was taken to derive a chronic-duration oral MRL for aldrin based on the LOAEL of 0.037 mg/kg/day for increased mean relative liver weight. For the Fitzhugh et al. (1964) study, the dietary concentrations were converted to estimated doses using EPA (1988b) chronic reference values for food intake (0.033 kg) and body weight (0.452 kg) for the rat:

Dose ( mg/kg/day ) = ( concentration of aldrin in food × food intake ) ÷ body weight ( 0.5 mg/kg food [ 0.5 ppm ] × 0.033 kg food/day ) ÷ 0.452 kg = 0.037 mg/kg/day

Uncertainty Factor: The LOAEL of 0.037 mg/kg/day was divided by an uncertainty factor of 1,000:

- 10 for use of a LOAEL
- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = LOAEL ÷ uncertainty factor 0.037 mg/kg/day ÷ 1,000 = 0.00004 mg/kg/day ( 0.04 μg/kg/day )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Two other chronic-duration oral toxicity studies identified the liver as a target of aldrin toxicity. Increased liver weight was observed in male rats receiving aldrin from the food for 31 months at an estimated dose of 2.1 mg/kg/day; the NOAEL was 1.4 mg/kg/day (Deichmann et al. 1970). Fatty degenerative hepatic changes were reported in dogs administered aldrin in capsule for up to 25 months at 1 mg/kg/day; the NOAEL was 0.5 mg/kg/day (Fitzhugh et al. 1964).

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: The acute-duration inhalation data were not considered adequate for derivation of an acute-duration inhalation MRL for dieldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No acute-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: The intermediate-duration inhalation data were not considered adequate for derivation of an intermediate-duration inhalation MRL for dieldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No intermediate-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The chronic-duration inhalation data were not considered adequate for derivation of a chronic-duration inhalation MRL for dieldrin.

Rationale for Not Deriving an MRL: No exposure concentration-response data are available for humans. No chronic-duration inhalation data were located for experimental animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: The acute-duration oral data were not considered adequate for derivation of an acute-duration oral MRL for dieldrin.

Rationale for Not Deriving an MRL: No adequate dose-response data are available for humans. Severe signs of neurotoxicity were reported in humans inadvertently or intentionally ingesting relatively large doses of dieldrin (Black 1974; Garrettson and Curley 1969). Table A-7 summarizes results from potential candidate acute-duration oral studies in experimental animals that identified the lowest NOAELs and/or LOAELs.

Table A-7 Summary of Selected NOAELs and LOAELs from Potential Candidate Acute-Duration Studies in Experimental Animals Orally Exposed to Dieldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Body weight effects
CD rat | GDs 7–16; 1 time/day; (GO) | 3 | 6 | 32% depressed maternal body weight gain | Chernoff et al. 1975
CD-1 mouse | GDs 7–16; 1 time/day; (GO) | 3 | 6 | Essentially no maternal body weight gain | Chernoff et al. 1975
Hepatic effects
CD-1 mouse | GDs 7–16; 1 time/day; (GO) | 1.5 | 3 | 25% increased mean maternal liver weight | Chernoff et al. 1975
Immunological effects
BALB/c mouse | 2 weeks; (F) | ND | 0.09 | Impaired antigen processing by macrophages | Loose et al. 1981
Neurological effects
Sprague-Dawley rat | Once; (GO) | ND | 0.5 | Impaired escape behavior | Carlson and Rosellini 1987
Wistar rat | Once; (GO) | ND | 2.5 | Disrupted operant behavior | Burt 1975
Developmental effects
CD-1 mouse | GDs 7–16; 1 time/day; (GO) | 1.5 | 3 | Supernumerary ribs | Chernoff et al. 1975

(F) = food; GD = gestation days; (GO) = gavage in oil vehicle; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

Depressed maternal body weight gain or no gain were observed in studies of rats and mice administered dieldrin by gavage at 6 mg/kg/day during GDs 7–16; the NOAEL was 3 mg/kg/day for each species (Chernoff et al. 1975). Other effects in the mice treated at 3 mg/kg/day included increased maternal liver weight and increased incidences of supernumerary ribs in fetuses. Disruption of operant behavior at 2.5 mg dieldrin/kg/day (Burt 1975), and impaired responses in an inescapable foot shock stress paradigm at 0.5 mg dieldrin/kg/day (Carlson and Rosellini 1987) were reported in rats administered dieldrin once by gavage. Loose et al. (1981) reported impaired antigen processing by macrophages from mice that had been administered dieldrin in the food for 2 weeks at 1 ppm (estimated dose of 0.09 mg/kg/day based on EPA [1988b] reference values for food intake and body weight); the study did not identify a NOAEL. However, no additional data were located to provide support to an adverse effect level as low as 0.09 mg/kg/day for immunotoxicity and the immune system has not been identified as a sensitive target of dieldrin toxicity in humans. Thus, the lowest LOAEL was 0.5 mg/kg/day for neurological effects identified in the Carlson and Rosellini (1987) study; the study did not identify a NOAEL. The database was not considered suitable for derivation of an acute-duration oral MRL because the lowest LOAEL was considered a serious LOAEL, and it is ATSDR practice to not use a serious LOAEL as a point of departure for an MRL.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.0001 mg/kg/day (0.1 µg/kg/day)
Critical Effect: | Neurotoxicity
Reference: | Smith et al. 1976
Point of Departure: | 0.01 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
LSE Graph Key: | 31
Species: | Monkey

MRL Summary: An intermediate-duration oral MRL of 0.0001 mg/kg/day (0.1 µg/kg/day) has been derived for dieldrin. The MRL is based on a NOAEL of 0.01 mg/kg/day and a LOAEL of 0.1 mg/kg/day for impaired task learning in monkeys administered dieldrin orally for 55 days (Smith et al. 1976). The NOAEL of 0.01 mg/kg/day was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response data were available for humans. Table A-8 summarizes results from candidate intermediate-duration oral studies in experimental animals that identified the lowest NOAELs and/or LOAELs.

Table A-8 Summary of Selected NOAELs and LOAELs from Candidate Intermediate-Duration Studies in Experimental Animals Orally Exposed to Dieldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Dog | Up to 9 months; (F) | ND | 0.73 | Degenerative liver lesions | Treon et al. 1951b
Immunological effects
BALB/c mouse | 3, 6, or 18 weeks; (F) | ND | 0.18 | Increased lethality following tumor implantation | Loose et al. 1981
Neurological effects
Squirrel monkey | 55 days; 1 time/day; (F) | 0.01^a^ | 0.1 | Learning deficit | Smith et al. 1976
Wistar rat | 60–120 days; (F) | 0.046 | 0.46 | Disrupted operant behavior | Burt 1975
Dog | Up to 9 months; (F) | ND | 0.73 | Hypersensitivity, tremors, twitching convulsions prior to death; neuronal degeneration in brain | Treon et al. 1951b
Reproductive effects
Swiss-Vancouver mouse | 4 weeks premating through PPD 28; (F) | 1 | 2 | 18% of bred females did not become pregnant | Virgo and Bellward 1975
Carworth rat | 3 generations; (F) | ND | 0.26 | 34% decreased number of litters from first parental mating | Treon et al. 1954a
Developmental effects
Swiss-Vancouver Mouse | 4 weeks premating through PPD 28; (F) | 0.5 | 1 | Increased pup mortality | Virgo and Bellward 1975
Carworth rat | 3 generations; (F) | 0.26 | 1.3 | 1.9-fold increased 5-day mortality of F3a pups | Treon et al. 1954a

a Used to derive an intermediate-duration oral MRL for dieldrin.

(F) = food; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level; PPD = postpartum day

Degenerative liver lesions and neurological effects (hypersensitivity, tremors, twitching convulsions prior to death; neuronal degeneration in brain) were reported in dogs receiving dieldrin from the food for up to 9 months at an estimated dose of 0.73 mg/kg/day, the lowest exposure level tested (Treon et al. 1951b). Decreased fertility and increased pup mortality were observed in a study in which mouse dams received dieldrin from the diet at estimated doses of 2 and 1 mg/kg/day, respectively for 4 weeks prior to mating, during gestation, and up to postpartum day 28; respective NOAELs were 1 and 0.5 mg/kg/day (Virgo and Bellward 1975). In a 3-generation study, decreased numbers of litters were reported at an estimated dieldrin dose of 0.26 mg/kg/day, the lowest exposure level tested; increased pup mortality occurred at 1.3 mg/kg/day with a NOAEL of 0.26 mg/kg/day (Treon et al. 1954a). Increased mortality following tumor implantation (an indication of a compromised immune system) was reported in mice receiving dieldrin from the diet for up to 18 weeks at an estimated dose of 0.18 mg/kg/day (the lowest exposure level tested) (Loose et al. 1981). Among candidate critical effects for deriving an intermediate-duration oral MRL for dieldrin, the lowest LOAEL was 0.1 mg/kg/day for learning deficit in monkeys administered dieldrin in marshmallows for 55 days; the NOAEL was 0.01 mg/kg/day (Smith et al. 1976). Therefore, dieldrin treatment-related neurotoxicity was selected as the critical effect.

Selection of the Principal Study: The intermediate-duration oral study in monkeys (Smith et al. 1976) was selected as the principal study for deriving an intermediate-duration oral MRL for dieldrin because it identified the lowest LOAEL (0.1 mg/kg/day) among candidate principal studies.

Summary of the Principal Study:

Smith RM, Cunningham WL Jr, Van Gelder GA. 1976. Dieldrin toxicity and successive discrimination reversal in squirrel monkeys, Saimiri sciureus. J Toxicol Environ Health 1:737–747 818400

Dieldrin (technical grade, purity not specified) dissolved in ethanol was injected into marshmallows fed to squirrel monkeys at doses of 0, 0.01, or 0.1 mg dieldrin/kg/day for 55 days. Monkeys were evaluated for performance in a visual nonspatial successive discrimination reversal task. After 55 days, the group receiving the low dose was switched to the high dose, and the group receiving the high dose was switched to the control diet for 54 days to test effects in task maintenance. The high-dose group (0.1 mg/kg/day) exhibited impaired learning of the task (acquisition). There was no evidence of impaired learning in the low-dose group (0.01 mg/kg/day).

Selection of the Point of Departure for the MRL: A BMD approach to deriving an intermediate-duration oral MRL for dieldrin based on neurological effects in the monkey study of Smith et al. (1976) was initially considered. However, although mean number of reversals (the index for evaluating the visual nonspatial successive discrimination reversal task) were reported for each monkey (two controls, two low-dose, and three high-dose animals), the small numbers of animals preclude quantitative evaluation of the data. Therefore, a NOAEL/LOAEL approach was implemented. The NOAEL of 0.01 mg/kg/day served as the point of departure for deriving an intermediate-duration oral MRL for dieldrin.

Calculations

Intermittent Exposure: Not applicable.

Uncertainty Factor: The NOAEL of 0.01 mg/kg/day was divided by an uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ uncertainty factor 0.01 mg/kg/day ÷ 100 = 0.0001 mg/kg/day ( 0.1 μg/kg/day )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Neurological effects (hypersensitivity, tremors, twitching convulsions, and neuronal degeneration in brain tissue) were observed in dogs administered dieldrin orally for up to 9 months at 0.73–1.85 mg/kg/day, the lowest dose range tested (Treon et al. 1951b). Dieldrin is a known neurotoxicant to humans and animals.

Agency Contacts (Chemical Managers): Carolyn Harper

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Dieldrin
CAS Numbers: | 60-57-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.00005 mg/kg/day (0.05 µg/kg/day)
Critical Effect: | Hepatotoxicity
Reference: | Walker et al. 1969
Point of Departure: | 0.005 mg/kg/day (NOAEL)
Uncertainty Factor: | 100
LSE Graph Key: | 52
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.00005 mg/kg/day (0.05 µg/kg/day) has been derived for dieldrin. The MRL is based on a NOAEL of 0.005 mg/kg/day and LOAEL of 0.05 mg/kg/day for increased liver weight in female rats administered dieldrin orally for 2 years (Walker et al. 1969). The NOAEL of 0.005 mg/kg/day was divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: No adequate exposure-response data were available for humans. Table A-9 summarizes results from candidate chronic-duration oral studies in experimental animals that identified the lowest NOAELs and/or LOAELs.

Table A-9 Summary of Selected NOAELs and LOAELs from Candidate Chronic-Duration Studies in Experimental Animals Orally Exposed to Dieldrin

Species | Exposure scenario | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Hepatic effects
Osborne-Mendel rat | 2 years; (F) | ND | 0.037 | 34% increased relative liver weight in females; dose-related increasing incidence and severity of liver lesions | Fitzhugh et al. 1964
Carworth Farm E rat | 2 years; (F) | 0.005^a^ F | 0.05 F | 13% increased relative liver weight in females; parenchymal cell changes at 0.5 mg/kg/day | Walker et al. 1969
Neurological effects
Carworth Farm E rat | 2 years; (F) | 0.05 | 0.5 | Tremors, occasional convulsions | Walker et al. 1969
B6C3F1 mouse | 80 weeks; (F) | ND | 0.43 | Hyperexcitability, tremors | NCI 1978a

a Used to derive a chronic-duration oral MRL for dieldrin.

(F) = food; LOAEL = lowest-observed-adverse-effect level; ND = not determined; NOAEL = no-observed-adverse-effect level

The liver represents the most sensitive target of dieldrin toxicity. Therefore, liver toxicity was selected as the critical effect for deriving a chronic-duration oral MRL for dieldrin.

Selection of the Principal Study: LOAELs for increased relative liver weight were relatively similar in two chronic-duration rat studies (0.037 mg/kg/day in the study of Fitzhugh et al. 1964 and 0.05 mg/kg/day in the study of Walker et al. 1969). The study of Walker et al. (1969) was selected as the principal study for deriving a chronic-duration oral MRL for dieldrin because the study also identified a NOAEL of 0.005 mg/kg/day.

Summary of the Principal Study:

Walker AIT, Stevenson DE, Robinson J, . 1969. The toxicology and pharmacodynamics of dieldrin (HEOD): Two-year oral exposures of rats and dogs. Toxicol Appl Pharmacol 15:345–373.5804749

Groups of Carworth Farms E (CFE) rats (25/sex/group) were administered dieldrin (>99% purity) in the diet at 0.1, 1.0, or 10 ppm for 2 years. The study authors stated that intake of 1 ppm at 7 months of age was equivalent to 0.0475 mg dieldrin/kg/day in males and 0.0582 mg dieldrin/kg/day in females. On this basis, estimated average doses to the 0.1, 1.0, and 10 ppm groups (sexes combined) were 0.005, 0.05, and 0.5 mg/kg/day, respectively. Controls consisted of 45 rats/sex. Additional groups of 15 rats/sex were similarly treated and 5/sex/group were sacrificed after 26, 52, and 78 weeks on treatment. Rats were monitored for survival, clinical signs, body weight, and food intake. At death or sacrifice, blood samples were collected for hematology and clinical chemistry. Major organ weights were recorded, and gross and histopathologic examinations were performed.

Effects in the rats included increased absolute and relative liver weights in females at 0.05 and 0.5 mg/kg/day. Liver parenchymal cell changes, “considered to be characteristic of exposure to organochlorine insecticide” but not otherwise specified, were increased in high-dose females; total incidences during 2 years of exposure were 0/23, 0/23, 0/23, and 6/23 females at dose levels of 0, 0.005, 0.05, and 0.5 mg/kg/day, respectively. In males, these liver parenchymal changes were only observed in one high-dose animal. Two of the 0.5 mg/kg/day females and one control female also showed focal hyperplasia of the hepatic parenchymal cells, forming microscopic nodules. Other types of hepatic lesions (focal parenchymal necrosis, proliferated ductules, focal fibrosis and/or cystic hyperplasia of intrahepatic bile ducts) were seen in a few rats of both sexes but were dispersed among the test and control groups (5/23, 0/23, 2/23, and 5/23 in females and 4/43, 0/23, 1/23, and 2/23 in males at 0, 0.1, 1, and 10 ppm, respectively) and not considered treatment-related. There were no indications of dieldrin-related changes in serum AP or ALT. Irritability, tremors, and occasional convulsions (characteristic signs of dieldrin neurotoxicity) occurred at 0.5 mg/kg/day. These behavioral changes usually occurred during handling, did not progress after 3 months of exposure, and did not affect well-being. Males receiving 0.05 mg/kg/day (but not 0.5 mg/kg/day) exhibited decreases in hemoglobin, packed cell volume, and red blood cells. The biological significance of these findings is unknown.

Relative liver weight data from the 2-year rat study of Walker et al. (1969) are summarized in Table A-10.

Table A-10 Mean Relative Liver Weight in Osborne-Mendel Rats Administered Dieldrin in the Food for up to 2 Years

Concentration in food (ppm) | Dose (mg/kg/day) | Number of animals | | Mean relative liver weight (g/100 g body weight)
Concentration in food (ppm) | Dose (mg/kg/day) | Males | Females | Males | Females
0 | 0 | 18 | 18 | 3.66±0.126^a^ | 4.08±0.147
0.1 | 0.005 | 15 | 13 | 3.72±0.138 | 4.33±0.173
1.0 | 0.05 | 14 | 10 | 3.70±0.143 | 4.61±0.198^b^
10 | 0.5 | 10 | 9 | 3.77±0.119 | 4.84±0.208^c^

a The study report did not define the measure of variance to the mean values.

b Significantly different from controls at 95% confidence limit.

c Significantly different from controls at 99% confidence limit.

Source: Walker et al. 1969

The critical effect was increased liver weight in the female rats (Walker et al. 1969); the study identified a NOAEL of 0.005 mg/kg/day and a LOAEL of 0.05 mg/kg/day for increased relative liver weight.

Selection of the Point of Departure for the MRL: A BMD approach to deriving a chronic-duration oral MRL for dieldrin was initially considered. However, although the study report included mean relative liver weight for each group of rats, the measure of variance associated with the mean was not defined. The absence of a defined measure of variance (e.g., standard deviation, standard error of the mean, etc.) precludes a BMD approach. Therefore, a NOAEL/LOAEL approach was implemented to derive a chronic-duration oral MRL for dieldrin; the NOAEL of 0.005 mg/kg/day served as the point of departure.

Uncertainty Factor: The NOAEL of 0.005 mg/kg/day was divided by an uncertainty factor of 100:

- 10 for extrapolation from animals to humans
- 10 for human variability

MRL = NOAEL ÷ uncertainty factor 0.005 mg/kg/day ÷ 100 = 0.00005 mg/kg/day ( 0.05 μg/kg/day )

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Fitzhugh et al. (1964) observed increased liver weight in rats receiving dieldrin from the food for 2 years at an estimated LOAEL of 0.037 mg/kg/day, the lowest dose level tested. Acute-and intermediate-duration oral studies in experimental animals have also reported dieldrin treatment-related liver effects at relatively low oral doses (Chernoff et al. 1975; Treon et al. 1951b).

Agency Contacts (Chemical Managers): Carolyn Harper