# CHAPTER 8 REFERENCES

Ahmed AE, Patel K. 1981. Acrylonitrile: In vivo metabolism in rats and mice. Drug Metab Dispos 9(3):219–222.6113929
Ahmed AE, Farooqui MYH. 1982. Comparative toxicities of aliphatic nitriles. Toxicol Lett 12(2–3):157–163. 10.1016/0378-4274(82)90179-5.6287676
Ahmed AE, Farooqui MY, Upreti RK, . 1982. Distribution and covalent interactions of [1-14C]acrylonitrile in the rat. Toxicology 23(2–3):159–175. 10.1016/0300-483x(82)90095-6.7112591
Ahmed AE, Farooqui MYH, Upreti RK, . 1983. Comparative toxicokinetics of 2,3-14C-and 1-14C-acrylonitrile in the rat. J Appl Toxicol 3(1):39–47. 10.1002/jat.2550030109.6875175
Ahmed AE, Abdel-Aziz AH, Abdel-Rahman SZ, . 1992. Pulmonary toxicity of acrylonitrile: covalent interaction and effect on replicative and unscheduled DNA synthesis in the lung. Toxicology 76(1):1–14. 10.1016/0300-483x(92)90013-5.1475791
Ahmed AE, Nouraldeen AM, Abdel-Rahman SZ, . 1996. Role of glutathione modulation in acrylonitrile-induced gastric DNA damage in rats. Arch Toxicol 70(10):620–627. 10.1007/s002040050320.8870954
Albertini RJ, Kirman CR, Strother DE. 2023. Acrylonitrile’s genotoxicity profile: mutagenicity in search of an underlying molecular mechanism. Crit Rev Toxicol 53(2):69–116. 10.1080/10408444.2023.2179912.37278976
Alexander DD, Pastula ST, Riordan AS. 2021. Epidemiology of lung cancer among acrylonitrile-exposed study populations: A meta-analysis. Regul Toxicol Pharmacol 122:104896. 10.1016/j.yrtph.2021.104896.33617939
Amacher DE, Turner GN. 1985. Tests for gene mutational activity in L5178Y/TK assay system. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 487–496.
AN Group. 1990. Public comments on scientific and technical issues on the draft toxicological profile for acrylonitrile. Submitted to Agency for Toxic Substances and Disease Registry.
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, replacement. New York, NY: Marcel Dekker, Inc., 9–25.
Anderson D, Cross MF. 1985. Suitability of the P388F mouse lymphoma system for detecting potential carcinogens and mutagens. Food Chem Toxicol 23(1):115–118. 10.1016/0278-6915(85)90229-7.4038675
Arni P. 1985. Induction of various genetic effects in the yeast Saccharomyces cerevisiae strain D7. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 217–224.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry. Fed Reg 54(174):37618–37634. https://www.govinfo.gov/content/pkg/FR-1989-09-11/pdf/FR-1989-09-11.pdf. July 5, 2022.
ATSDR. 2005. Public health assessment for Conrail Rail Yard, Indiana. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/ConrailRailYd/ConrailRailYardPHA081105.pdf. October 11, 2022.
ATSDR. 2007. Health consultation for Laugh and Learn Daycare, Ohio. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/LaughandLearnDaycare/LaughAndLearnDaycareHC061807.pdf. October 11, 2022.
ATSDR. 2008. Health consultation for Schuylkill Haven MGP Site, Pennsylvania. Atlanta, GA: Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/HAC/pha/SchuylkillHavenMGPSite/Schuylkill_Haven_MGP_Site%20HC%209-30-2008.pdf. October 11, 2022.
ATSDR. 2022. Acrylonitrile. Full SPL data. Substance priority list (SPL) resource page. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources/index.html. June 1, 2023.
Bader M, Wrbitzky R. 2006. Follow-up biomonitoring after accidental exposure to acrylonitrile:- implications for protein adducts as a dose monitor for short-term exposures. Toxicol Lett 162(2–3):125–131. 10.1016/j.toxlet.2005.09.034.16280213
Banerjee S, Segal A. 1986. In vitro transformation of C3H/10T1/2 and NIH/3T3 cells by acrylonitrile and acrylamide. Cancer Letters 32(3):293–304. 10.1016/0304-3835(86)90182-5.3768855
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486. 10.1016/0273-2300(88)90047-5.3222488
Barrows ME, Petrocelli SR, Macek KJ, . 1978. Bioconcentration and elimination of selected water pollutants by bluegill sunfish. Am Chem Soc Div Environ Chem 18:345–346.
Baxter RA. 1979. Evaluation and control of industrial exposure to acrylonitrile. Ann Occup Hyg 22(4):429–435. 10.1093/annhyg/22.4.429.547802
Beliles RP, Paulin HJ, Makris NG, . 1980. Three-generation reproduction study of rats receiving acrylonitrile in drinking water. Chemical Manufacturers Association. Submitted to the U.S. Environmental Protection Agency under TSCA section FYI. LBI Project No 2660. OTS00000730. FYIAX03800073. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00000730.xhtml. July 5, 2022.
Benn T, Osborne K. 1998. Mortality of United Kingdom acrylonitrile workers-an extended and updated study. Scand J Work Environ Health 24(Suppl 2):17–24.9714510
Bigner DD, Bigner SH, Burger PC, . 1986. Primary brain tumors in Fischer 344 rats chronically exposed to acrylonitrile in their drinking water. Food Chem Toxicol 24(2):129–137. 10.1016/0278-6915(86)90347-9.3957160
Bio/Dynamics. 1980a. Initial submission: 24-Month oral toxicity/carcinogenicity study with acrylonitrile administered to Spartan rats in drinking water (final report) with cover letter dated 072492. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. BDN-77-28. OTS0544562. 88-920005779. 8EHQ-0792-7133. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0544562.xhtml. July 5, 2022.
Bio/Dynamics. 1980b. Initial submission: 24-Month oral toxicity/carcinogenicity study with acrylonitrile administered in drinking water to Fischer 344 rats (final report) with cover letter dated 072492. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. BDN-77-27. OTS0544560. 88-920005777. 8EHQ-0792-7131. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0544560.xhtml. July 5, 2022.
Bio/Dynamics. 1980c. Initial submission: Twenty-four month oral toxicity/carcinogenicity study of acrylonitrile administered by intubation to Spartan rats (final report) with cover letter dated 072492. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. BDN-77-29. OTS0544558. 88-920005775. 8EHQ-0792-7129. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0544558.xhtml. July 5, 2022.
Bjorge C, Brunborg G, Wiger R, . 1996. A comparative study of chemically induced DNA damage in isolated human and rat testicular cells. Reprod Toxicol 10(6):509–519. 10.1016/s0890-6238(96)00138-4.8946565
Blair A, Stewart PA, Zaebst DD, . 1998. Mortality of industrial workers exposed to acrylonitrile. Scand J Work Environ Health 24(Suppl 2):25–41.9714511
Brat SV, Williams GM. 1982. Hepatocyte-mediated production of sister chromatid exchange in co-cultured cells by acrylonitrile: Evidence for extra cellular transport of a stable reactive intermediate. Cancer Letters 17(2):213–216. 10.1016/0304-3835(82)90034-9.7165873
Brazdil JF. 2012. Acrylonitrile. In: Ullmann’s encyclopedia of industrial chemistry. Weinheim, Germany: Wiley-VCH Verlag GmbH & Co., online. 10.1002/14356007.a01_177.pub3.
Brooks TM, Gonzalez LP, Calvert R, . 1985. The induction of mitotic gene conversion in the yeast Saccharomyces cerevisiae strain JD. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 225–228.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: a review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Burka LT, Sanchez IM, Ahmed AE, . 1994. Comparative metabolism and disposition of acrylonitrile and methacrylonitrile in rats. Arch Toxicol 68(10):611–618. 10.1007/BF03208340.7857200
Butterworth BE, Eldridge SR, Sprankle CS, . 1992. Tissue-specific genotoxic effects of acrylamide and acrylonitrile. Environ Mol Mutagen 20(3):148–155. 10.1002/em.2850200303.1396605
Carls N, Schiestl RH. 1994. Evaluation of the yeast DEL assay with 10 compounds selected by the International Program on Chemical Safety for the evaluation of short-term tests for carcinogens. Mutat Res 320(4):293–303. 10.1016/0165-1218(94)90082-5.7508555
CDC. 2022. Biomonitoring data tables for environmental chemicals. Centers for Disease Control and Prevention. https://www.cdc.gov/exposurereport/data_tables.html. October 11, 2022.
CEC. 1983. Reports of the scientific committee for food (thirteenth series). Luxembourg: Commission of the European Communities. PB83172759. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB83172759.xhtml. October 3, 2024.
Chang CM, Hsia MT, Stoner GD, . 1990. Acrylonitrile-induced sister-chromatid exchanges and DNA single-strand breaks in adult human bronchial epithelial cells. Mutat Res 241(4):355–360. 10.1016/0165-1218(90)90065-a.2377173
Chen JL, Walrath J, O’Berg MT, . 1987. Cancer incidence and mortality among workers exposed to acrylonitrile. Am J Ind Med 11(2):157–163. 10.1002/ajim.4700110205.3826078
Chen M, Carmella SG, Sipe C, . 2019. Longitudinal stability in cigarette smokers of urinary biomarkers of exposure to the toxicants acrylonitrile and acrolein. PloS one 14(1):e0210104. 10.1371/journal.pone.0210104.30608961
Cherry AB, Gabaccia AJ, Senn HW. 1956. The assimilation behavior of certain toxic organic compounds in natural water. Sewage Ind Wastes 28:1137–1146.
Chinchilla D, Kilheeney H, Vitello LB, . 2014. Kinetic and equilibrium studies of acrylonitrile binding to cytochrome c peroxidase and oxidation of acrylonitrile by cytochrome c peroxidase compound I. Biochem Biophys Res Commun 443(1):200–204. 10.1016/j.bbrc.2013.11.084.24291498
Clewell HJ. 1995. The application of physiologically based pharmacokinetic modeling in human health risk assessment of hazardous substances. Toxicol Lett 79(1–3):207–217. 10.1016/0378-4274(95)03372-r.7570658
Collins JJ, Acquavella JF. 1998. Review and meta-analysis of studies of acrylonitrile workers. Scand J Work Environ Health 24(Suppl 2):71–80.9714515
Collins JJ, Page LC, Caporossi JC, . 1989. Mortality patterns among employees exposed to acrylonitrile. J Occup Med 31(4):368–371.2715845
Crespi CL, Ryan CG, Seixas GM, . 1985. Tests for mutagenic activity using mutation assays at two loci in the human lymphoblast cell lines TK6 and AHH-1. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 497–516.
Dang Y, Li Z, Luo B, . 2017. Protective effects of apigenin against acrylonitrile-induced subchronic sperm injury in rats. Food Chem Toxicol 109(Pt 1):517–525. 10.1016/j.fct.2017.09.025.28963002
De Jesús VR, Zhang L, Bhandari D, . 2021. Characterization of acrylonitrile exposure in the United States based on urinary n-acetyl-S-(2-cyanoethyl)-L-cysteine (2CYEMA): NHANES 2011-2016. J Expo Sci Environ Epidemiol 31(2):377–385. 10.1038/s41370-020-00286-1.33424026
De Meester C, Poncelet F, Roberfroid M, . 1978. Mutagenicity of acrylonitrile. Toxicology 11(1):19–27. 10.1016/s0300-483x(78)90239-1.360488
De Smedt T, De Cremer K, Vleminckx C, . 2014. Acrylonitrile exposure in the general population following a major train accident in Belgium: a human biomonitoring study. Toxicol Lett 231(3):344–351. 10.1016/j.toxlet.2014.09.009.25223249
Delzell E, Monson RR. 1982. Mortality among rubber workers: VI: Men with potential exposure to acrylonitrile. J Occup Med 24:767–769.7143123
DiGeronimo MJ, Antoine AD. 1976. Metabolism of acetonitrile and propionitrile by Norcardia rhodochrous LL100-21. Appl Environ Microbiol 31:900–906. 10.1128/aem.31.6.900-906.1976.938041
DOE. 2024a. Protective action criteria (PAC) based on AEGLs, ERPGs, or TEELs. U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDocs. September 13, 2024.
DOE. 2024b. Definition of PACs (AEGLs, ERPGs or TEELs). U.S. Department of Energy. https://edms3.energy.gov/pac/TeelDef. September 13, 2024.
Donberg PA, Odelson DA, Klecka GM, . 1992. Biodegradation of acrylonitrile in soil. Environ Toxicol Chem 11(11):1583–1594. 10.1002/etc.5620111108.
DOT. 1972. Reclassification of materials listed as transportation health hazards. Washington DC: U.S. Department of Transportation. PB214270. Report No. TSA-20-72-3. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB214270.xhtml. July 5, 2022.
Dudley HC, Neal PA. 1942. Toxicology of acrylonitrile (vinyl cyanide): I. A study of the acute toxicity. J Ind Hyg Toxicol 24:27–36.
El-Masri HA, Mumtaz MM, Yushak ML. 2004. Application of physiologically-based pharmacokinetic modeling to investigate the toxicological interaction between chlorpyrifos and parathion in the rat. Environ Toxicol Pharmacol 16(1–2):57–71. 10.1016/j.etap.2003.10.002.21782694
Emmert B, Bunger J, Keuch K, . 2006. Mutagenicity of cytochrome P450 2E1 substrates in the Ames test with the metabolic competent S. typhimurium strain YG7108pin3ERb5. Toxicology 228(1):66–76. 10.1016/j.tox.2006.08.013.16978761
EPA. 1978. Investigation of selected potential environmental contaminants: acrylonitrile. Washington, DC: U.S. Environmental Protection Agency. PB285881. EPA560278003. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB285881.xhtml. July 5, 2022.
EPA. 1979. Environmental monitoring near industrial sites acrylonitrile. Washington, DC: U.S. Environmental Protection Agency. PB295928. EPA560679003. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9100AOC9.txt. August 8, 2022.
EPA. 1980a. Human exposure to atmospheric concentrations of selected chemicals. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB81193278.
EPA. 1980b. Ambient water quality criteria for acrylonitrile. Washington, DC: U.S. Environmental Protection Agency. PB81111285. EPA440580017. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=00001L40.txt. July 5, 2022.
EPA. 1980c. Fate of toxic and hazardous materials in the air environment. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB80221948. EPA600380084. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB80221948.xhtml. August 8, 2022.
EPA. 1981. Engineering handbook for hazardous waste incineration. Washington, DC: U.S. Environmental Protection Agency. SW889. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=2000KAVZ.txt. July 15, 2022.
EPA. 1982a. Aquatic fate process data for organic priority pollutants. Washington, DC: U.S. Environmental Protection Agency. PB87169090. EPA440481014. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB87169090.xhtml. August 8, 2022.
EPA. 1982b. Management of hazardous waste leachate, September 1982. Cincinnati, OH: U.S. Environmental Protection Agency. PB91181578. SW871R. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB91181578.xhtml. August 8, 2022.
EPA. 1982c. Intermedia priority pollutant guidance documents. Washington, DC: U.S. Environmental Protection Agency. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=20015VOW.txt. August 8, 2022.
EPA. 1983a. Health assessment document for acrylonitrile. Washington, DC: U.S. Environmental Protection Agency. PB84149152. EPA600882007F. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB84149152.xhtml. July 7, 2022.
EPA. 1983b. Volatile organic chemicals in the atmosphere: An assessment of available data. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB83195503. EPA600383027A. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB83195503.xhtml. August 8, 2022.
EPA. 1984. Locating and estimating air emissions from sources of acrylonitrile. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB84200609. EPA450484007a. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB84200609.xhtml. August 8, 2022.
EPA. 1985. Health and environmental effects profile for acrylonitrile. Cincinnati, OH: U.S. Environmental Protection Agency. PB88170832. EPA600X85372. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB88170832.xhtml. August 8, 2022.
EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. PB88179874. EPA600687008. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=34855. September 21, 2022.
EPA. 1990. Method 1624, Revision C: Volatile organic compounds by isotope dilution GCMS. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/201509/documents/method_1624c_1990.pdf. September 22, 2022.
EPA. 1992. Soil sorption of volatile and semivolatile organic compounds in a mixture. Ada, OK: U.S. Environmental Protection Agency. PB93181188. EPA600J93130. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/PB93181188.xhtml. August 8, 2022.
EPA. 1994a. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. U.S. Environmental Protection Agency. PB2000500023. EPA600890066F. https://www.epa.gov/risk/methods-derivation-inhalation-reference-concentrations-and-application-inhalation-dosimetry. July 5, 2022.
EPA. 1994b. Method 8031: Acrylonitrile by gas chromatography. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-12/documents/8031.pdf. September 22, 2022.
EPA. 1994c. Method 8316: Acrylamide, acrylonitrile and acrolein by high performance liquid chromatography (HPLC). U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-07/documents/epa-8316.pdf. September 22, 2022.
EPA. 1995. Method 524.2: Measurement of purgeable organic compounds in water by capillary column gas chromatography/mass spectrometry. Cincinnati, OH: U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2015-06/documents/epa-524.2.pdf. September 22, 2022.
EPA. 2017. 2017 National Emissions Inventory (NEI) data: Acrylonitrile. U.S. Environmental Protection Agency. https://www.epa.gov/air-emissions-inventories/2017-national-emissionsinventory-nei-data. July 15, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protection Agency. EPA822S12001. https://www.epa.gov/system/files/documents/2022-01/dwtable2018.pdf. June 15, 2022.
EPA. 2018b. Compiled AEGL values. U.S. Environmental Protection Agency. https://www.epa.gov/sites/production/files/2018-08/documents/compiled_aegls_update_27jul2018.pdf. April 12, 2020.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2018d. Method 8260D: Volatile organic compounds by gas chromatography/mass spectrometry. U.S. Environmental Protection Agency. https://www.epa.gov/sites/default/files/2017-04/documents/method_8260d_update_vi_final_03-13-2017.pdf. August 8, 2022.
EPA. 2020a. Chemical Data Reporting. Acrylonitrile. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2020. July 15, 2022.
EPA. 2020b. Benchmark Dose Software (BMDS). Version 3.2 User Guide. U.S. Environmental Protection Agency. EPA600R20216. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P10103T2.txt. August 8, 2022.
EPA. 2022a. Air Quality System database. Annual summary data: Acrylonitrile. U.S. Environmental Protection Agency. https://aqs.epa.gov/aqsweb/airdata/download_files.html. July 15, 2022.
EPA. 2022b. Acrylonitrile. Pesticide product and label system. Version 2.4.2. U.S. Environmental Protection Agency. https://ordspub.epa.gov/ords/pesticides/f?p=PPLS:1. July 15, 2022.
EPA. 2022c. Acrylonitrile. Substance Registry Services. U.S. Environmental Protection Agency. https://sor.epa.gov/sor_internet/registry/substreg/LandingPage.do. July 15, 2022.
EPA. 2022d. Toxic chemical release inventory reporting forms and instructions: Revised 2021 version. U.S. Environmental Protection Agency. EPA740B22002. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2021_rfi.pdf. August 22, 2023.
EPA. 2023. National primary drinking water regulations. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 141. https://www.govinfo.gov/content/pkg/CFR-2023-title40-vol25/pdf/CFR-2023-title40-vol25-part141.pdf. May 3, 2024.
Farooqui MYH, Ahmed AE. 1982. Molecular interaction of acrylonitrile and potassium cyanide with rat blood. Chem Biol Interact 38(2):145–159. 10.1016/0009-2797(82)90036-9.7055848
Farooqui MY, Ahmed AE. 1983. The effects of acrylonitrile on hemoglobin and red cell metabolism. J Toxicol Environ Health 12(4–6):695–707. 10.1080/15287398309530461.6668618
FDA. 2022. Indirect food additives: Polymers; acrylonitrile/styrene copolymers. Food and Drug Administration. Code of Federal Regulations. 21 CFR 3. https://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfcfr/CFRSearch.cfm?CFRPart=177. August 8, 2022.
FDA. 2024. Vinyl acetate. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/index.cfm?set=FoodSubstances&id=VINYLACETATE. September 23, 2024.
Fechter LD. 2004. Promotion of noise-induced hearing loss by chemical contaminants. J Toxicol Environ Health A 67(8–10):727–740. 10.1080/15287390490428206.15192865
Fechter LD, Klis SF, Shirwany NA, . 2003. Acrylonitrile produces transient cochlear function loss and potentiates permanent noise-induced hearing loss. Toxicol Sci 75(1):117–123. 10.1093/toxsci/kfg169.12832658
Fennell TR, Kedderis GL, Sumner SC. 1991. Urinary metabolites of [1,2,3-13C]acrylonitrile in rats and mice detected by 13C nuclear magnetic resonance spectroscopy. Chem Res Toxicol 4(6):678–687. 10.1021/tx00024a013.1807451
Friedman MA, Beliles RP. 2002. Three-generation reproduction study of rats receiving acrylonitrile in drinking water. Toxicol Lett 132(3):249–261. 10.1016/s0378-4274(02)00075-9.12044706
Fujikawa K, Ryo H, Kondo S. 1985. The Drosophila reversion assay using the unstable zeste-white somatic eye color system. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 319–324.
Gagnaire F, Marignac B, Bonnet P. 1998. Relative neurotoxicological properties of five unsaturated aliphatic nitriles in rats. J Appl Toxicol 18(1):25–31. 10.1002/(sici)1099-1263(199801/02)18:1<25::aid-jat466>3.0.co;2-v.9526831
Gallagher GT, Maull EA, Kovacs K, . 1988. Neoplasms in rats ingesting acrylonitrile for two years. J Am Coll Toxicol 7(5):603–616. 10.3109/10915818809019537.
Gargas ML, Andersen ME, Teo SK, . 1995. A physiologically based dosimetry description of acrylonitrile and cyanoethylene oxide in the rat. Toxicol Appl Pharmacol 134(2):185–194. 10.1006/taap.1995.1183.7570594
Garner RC, Campbell J. 1985. Tests for the induction of mutations to ouabain or 6-thioguanine resistance in mouse lymphoma L5178Y cells. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 525–529.
Ghanayem BI, Ahmed AE. 1982. In vivo biotransformation and biliary excretion of 1-14C-acrylonitrile in rats. Arch Toxicol 50(2):175–185. 10.1007/BF00373400.7125911
Ghanayem BI, Ahmed AE. 1983. Acrylonitrile-induced gastrointestinal hemorrhage and the effects of metabolism modulation in rats. Toxicol Appl Pharmacol 68(2):290–296. 10.1016/0041-008x(83)90013-3.6602400
Ghanayem BI, Farooqui MY, Elshabrawy O, . 1991. Assessment of the acute acrylonitrile-induced neurotoxicity in rats. Neurotoxicol Teratol 13(5):499–502. 10.1016/0892-0362(91)90056-3.1758402
Ghanayem BI, Elwell MR, Eldridge SR. 1997. Effects of the carcinogen, acrylonitrile, on forestomach cell proliferation and apoptosis in the rat: Comparison with methacrylonitrile. Carcinogenesis 18(4):675–680. 10.1093/carcin/18.4.675.9111199
Ghanayem BI, Nyska A, Haseman JK, . 2002. Acrylonitrile is a multisite carcinogen in male and female B6C3F1 mice. Toxicol Sci 68(1):59–68. 10.1093/toxsci/68.1.59.12075111
Gilbert SG, Miltz J, Giacin JR. 1980. Transport considerations of potential migrants from food packaging materials. J Food Process Preserv 4(1–2):27–49. 10.1111/j.1745-4549.1980.tb00594.x.
Glauert HP, Kennan WS, Sattler GL, . 1985. Assays to measure the induction of unscheduled DNA synthesis in cultured hepatocytes. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 371–373.
Grunske F. 1949. [Health care and occupational medicine. Ventox and Ventox intoxication]. Deutsche Medizinische Wochenschrift 74:1081–1083. (German)
Guengerich FP, Geiger LE, Hogy LL, . 1981. In vitro metabolism of acrylonitrile to 2-cyanoethylene oxide, reaction with glutathione, and irreversible binding to proteins and nucleic acids. Cancer Res 41(12 Pt 1):4925–4933.6272984
Gut I, Nerudova J, Kopecky J, . 1975. Acrylonitrile biotransformation in rats, mice, and Chinese hamsters as influenced by the route of administration and by phenobarbital, SKF 525-A, cysteine, dimercaprol, or thiosulfate. Arch Toxicol 33(2):151–161. 10.1007/BF00353240.1242300
Gut I, Nerudova J, Frantik E, . 1984. Acrylonitrile inhalation in rats: I. Effect on intermediary metabolism. J Hyg Epidemiol Microbiol Immunol 28(4):369–376.
Gut I, Nerudova J, Stiborova A, . 1985. Acrylonitrile inhalation in rats: II. Excretion of thioethers and thiocyanate in urine. J Hyg Epidemiol Microbiol Immunol 29(1):9–13.
Hardisty JF, Quast JF, Howroyd PC, . 2002. Histopathology peer review and scientific advisory group (SAG) review of neoplasms involving the brain of rats. The Acrylonitrile Group, Inc. Submitted to the Agency for Toxic Substances and Disease Registry. Study No.: HET K-001688-(11), HET K-001688-(12). https://downloads.regulations.gov/ATSDR-2023-0004-0012/attachment_3.pdf. October 3, 2024.
Hardy A, Benford D, Halldorsson T, . 2017. Update: use of the benchmark dose approach in risk assessment. EFSA J 15(1):e04658. 10.2903/j.efsa.2017.4658.32625254
Harris GW, Kleindienst TE, Pitts JN. 1981. Rate constants for the reaction of OH radicals with CH_3_CN, C_2_H_5_CN and CH_2_ = CH-CN in the temperature range 298-424 K. Chem Phys Lett 80:479–483. 10.1016/0009-2614(81)85061-0.
Hashimoto S, Bandow H, Akimoto H, . 1984. Products and mechanism for the OH radical initiated oxidation of acrylonitrile, methacrylonitrile and allylcyanide in the presence of NO. Int J Chem Kinet 16:1385–1399. 10.1002/kin.550161110.
Hogy LL, Guengerich FP. 1986. In vivo interaction of acrylonitrile and 2-cyanoethylene oxide with DNA in rats. Cancer Res 46(8):3932–3938.2425936
Houthuijs D, Remijn B, Willems H, . 1982. Biological monitoring of acrylonitrile exposure. Am J Ind Med 3(3):313–320. 10.1002/ajim.4700030306.7171088
Huizer D, Ragas AM, Oldenkamp R, . 2014. Uncertainty and variability in the exposure reconstruction of chemical incidents-the case of acrylonitrile. Toxicol Lett 231(3):337–343. 10.1016/j.toxlet.2014.07.019.25050995
Humiston CG, Frauson LO, Quast JF, . 1975. A 90-day oral toxicity study incorporating acrylonitrile in the drinking water of rats. Midland, MI: Dow Chemical Company.
IARC. 1979. Acrylonitrile, acrylic and modacrylic fibres, and acrylonitrile-butadiene-styrene and styrene-acrylonitrile copolymers. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Volume 19: Some monomers, plastics and synthetic elastomers, and acrolein. Vol. 19. Lyon, France: International Agency for Research on Cancer. https://publications.iarc.fr/Book-And-Report-Series/Iarc-Monographs-On-The-Identification-Of-Carcinogenic-Hazards-To-Humans/Some-Monomers-Plastics-And-Synthetic-Elastomers-And-Acrolein-1979. August 8, 2022.
IRIS. 2002. Acrylonitrile; CASRN 107-13-1. Integrated Risk Information System. Chemical assessment summary. U.S. Environmental Protection Agency. https://iris.epa.gov/static/pdfs/0206_summary.pdf. June 25, 2022.
Jacob S, Ahmed AE. 2004. Species difference in the disposition of acrylonitrile: quantitative whole-body autoradiographic study in rats and mice. Toxicol Ind Health 20(1–5):9–19. 10.1191/0748233704th188oa.15807404
Jakubowski M, Linhart I, Pielas G, . 1987. 2-Cyanoethylmercapturic acid (CEMA) in the urine as a possible indicator of exposure to acrylonitrile. Br J Ind Med 44(12):834–840. 10.1136/oem.44.12.834.3689720
Johannsen FR, Levinskas GJ. 2002a. Chronic toxicity and oncogenic dose-response effects of lifetime oral acrylonitrile exposure to Fischer 344 rats. Toxicol Lett 132(3):221–247. 10.1016/s0378-4274(02)00074-7.12044705
Johannsen FR, Levinskas GJ. 2002b. Comparative chronic toxicity and carcinogenicity of acrylonitrile by drinking water and oral intubation to Spartan Sprague-Dawley rats. Toxicol Lett 132(3):197–219. 10.1016/s0378-4274(02)00073-5.12044704
Kaneko K, Omae K. 1992. Effect of chronic exposure to acrylonitrile on subjective symptoms. Keio J Med 41(1):25–32. 10.2302/kjm.41.25.1583816
Kanerva L, Jolanki R, Alanko K, . 1999. Patch-test reactions to plastic and glue allergens. Acta Derm Venereol 79(4):296–300. 10.1080/000155599750010706.10429988
Kedderis GL, Batra R, Held SD, . 1993. Rodent tissue distribution of 2-cyanoethylene oxide, the epoxide metabolite of acrylonitrile. Toxicol Lett 69(1):25–30. 10.1016/0378-4274(93)90141-j.8356564
Kedderis GL, Teo SK, Batra R, . 1996. Refinement and verification of the physiologically based dosimetry description for acrylonitrile in rats. Toxicol Appl Pharmacol 140(2):422–435. 10.1006/taap.1996.0239.8887460
Kenaga EE. 1980. Predicted bioconcentration factors and soil sorption coefficients of pesticides and other chemicals. Ecotoxicol Environ Saf 4:26–38. 10.1016/0147-6513(80)90005-6.7379718
Khudoley VV, Mizgireuv I, Pliss GB. 1987. The study of mutagenic activity of carcinogens and other chemical agents with Salmonella typhimurium assays: Testing of 126 compounds. Arch Geschwulstforsch 57:453–462.3435224
Kincannon DF, Stover EL, Nichols V, . 1983. Removal mechanisms for toxic priority pollutants. J Water Pollut Control Fed 55:157–163.
Kiplinger GR. 2005. Acute inhalation toxicity study of acrylonitrile in albino rats. Innovene. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8(e). WIL-54200. OTS0601033. 8EHQ-0805-16067. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0601033.xhtml. October 3, 2024.
Kirman CR, Hays SM, Kedderis GL, . 2000. Improving cancer dose-response characterization by using physiologically based pharmacokinetic modeling: an analysis of pooled data for acrylonitrile-induced brain tumors to assess cancer potency in the rat. Risk Anal 20(1):135–151. 10.1111/0272-4332.00013.10795346
Klein E, Weaver JW, Webre BG. 1957. Solubility of acrylonitrile in aqueous bases and alkali salts. Ind Eng Chem 2:72–75. 10.1021/i460002a020.
Kobets T, Iatropoulos MJ, Williams GM. 2022. Acrylonitrile induction of rodent neoplasia: Potential mechanism of action and relevance to humans. Toxicol Res Appl 6:1–33. 10.1177/23978473211055363.
Kolenda-Roberts HM, Harris N, Singletary E, . 2013. Immunohistochemical characterization of spontaneous and acrylonitrile-induced brain tumors in the rat. Toxicol Pathol 41(1):98–108. 10.1177/0192623312452492.22821367
Koutros S, Lubin JH, Graubard BI, . 2019. Extended mortality follow-up of a cohort of 25,460 workers exposed to acrylonitrile. Am J Epidemiol 188(8):1484–1492. 10.1093/aje/kwz086.30927363
Langvardt PW, Putzig CL, Braun WH, . 1980. Identification of the major urinary metabolites of acrylonitrile in the rat. J Toxicol Environ Health 6(2):273–282. 10.1080/15287398009529851.7392095
Lawrence N, McGregor DB. 1985. Assays for the induction of morphological transformation in C3H/lOT1/2 cells in culture with and without S9-mediated metabolic activation. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 651–658.
Lee CG, Webber TD. 1985. The induction of gene mutations in the mouse lymphoma L5178Y/K+/- assay and the Chinese hamster V79/HGPRT assay. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 547–554.
Leng G, Gries W. 2014. Biomonitoring following a chemical incident with acrylonitrile and ethylene in 2008. Toxicol Lett 231(3):360–364. 10.1016/j.toxlet.2014.06.027.24960063
Leonard A, Garny V, Poncelet F, . 1981. Mutagenicity of acrylonitrile in mouse. Toxicol Lett 7(4–5):329–334. 10.1016/0378-4274(81)90056-4.7222109
Lickly TD, Markham DA, Rainey ML. 1991. The migration of acrylonitrile from acrylonitrile/butadiene/styrene polymers into food-simulating liquids. Food Chem Toxicol 29(1):25–29. 10.1016/0278-6915(91)90059-G.1999304
Lijinsky W, Andrews AW. 1980. Mutagenicity of vinyl compounds in Salmonella typhimurium. Teratog Carcinog Mutagen 1(3):259–267. 10.1002/tcm.1770010303.6119816
Linhart I, Smejkal J, Novak J. 1988. N-acetyl-S-(1-cyano-2-hydroxyethyl)-L-cysteine, a new urinary metabolite of acrylonitrile and oxiranecarbonitrile. Arch Toxicol 61(6):484–488. 10.1007/BF00293695.3190446
Lipscomb JC, Teuschler LK, Swartout J, . 2003. The impact of cytochrome P450 2E1-dependent metabolic variance on a risk-relevant pharmacokinetic outcome in humans. Risk Anal 23(6):1221–1238. 10.1111/j.0272-4332.2003.00397.x.14641897
Lorz H. 1950. [Percutaneous poisoning with acrylonitrile]. Deutsche Medizinische Wochenschrift 75:1087–1088. (German)14773309
Luo YS, He QK, Sun MX, . 2022. Acrylonitrile exposure triggers ovarian inflammation and decreases oocyte quality probably via mitochondrial dysfunction induced apoptosis in mice. Chem Biol Interact 360:109934. 10.1016/j.cbi.2022.109934.35429547
Major J, Hudak A, Kiss G, . 1998. Follow-up biological and genotoxicological monitoring of acrylonitrile- and dimethylformamide-exposed viscose rayon plant workers. Environ Mol Mutagen 31(4):301–310. 10.1002/(sici)1098-2280(1998)31:4<301::aid-em1>3.0.co;2-l.9654238
Maltoni C, Ciliberti A, Di Maio V. 1977. Carcinogenicity bioassays on rats of acrylonitrile administered by inhalation and by ingestion. Med Lav 68(6):401–411.613212
Maltoni C, Ciliberti A, Cotti G, . 1988. Long-term carcinogenicity bioassays on acrylonitrile administered by inhalation and by ingestion to Sprague-Dawley rats. Ann N Y Acad Sci 534:179–202. 10.1111/j.1749-6632.1988.tb30111.x.3389655
Marsh GM, Zimmerman SD. 2015. Mortality among chemical plant workers exposed to acrylonitrile: 2011 follow-up. J Occup Environ Med 57(2):134–145. 10.1097/jom.0000000000000369.25612296
Marsh GM, Gula MJ, Youk AO, . 1999. Mortality among chemical plant workers exposed to acrylonitrile and other substances. Am J Ind Med 36(4):423–436. 10.1002/(sici)1097-0274(199910)36:4<423::aid-ajim3>3.0.co;2-m.10470007
Mastrangelo G, Serena R, Marzia V. 1993. Mortality from tumours in workers in an acrylic fibre factory. Occup Med 43(3):155–158. 10.1093/occmed/43.3.155.
Matsushima T, Muramatsu M, Haresaku M. 1985. Mutation tests on Salmonella typhimurium by the preincubation method. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 181–186.
Matthews EJ, DelBalzo T, Rundell JO. 1985. Assays for morphological transformation and mutation to ouabain resistance of Balb/c-3T3 cells in culture. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 639–650.
Mills EJ, Stack VT. 1954. Biological oxidation of synthetic organic chemicals. In: Proceedings of the eighth industrial waste conference, May 4, 5 and 6, 1953. Lafayette, IN: Purdue University, 492–517.
Mills EJ, Stack VT. 1955. Acclimation of microorganisms for the oxidation of pure organic chemicals. In: Proceedings of the ninth industrial waste conference, May 10, 11 and 12, 1954. Lafayette, IN: Purdue University, 449–464.
Moldoveanu SC. 2010. Analysis of acrylonitrile and alpha-methacrylonitrile in vapor phase of mainstream cigarette smoke using a charcoal trap for collection. Beitr Tab Int 24(3):145–156. 10.2478/cttr-2013-0892.
Moore RR, Hardisty JF. 2014. Immunohistochemical characterization of brain tumors: A two-year toxicity and oncogenicity study with acrylonitrile following inhalation exposure of rats, (Quast etal. 1980). The Acrylonitrile Group, Inc. Submitted to the Agency for Toxic Substances and Disease Registry. Study No.: HET K-001688-(11). https://downloads.regulations.gov/ATSDR-2023-0004-0013/attachment_1.pdf. October 3, 2024.
Muller G, Verkoyen C, Soton N, . 1987. Urinary excretion of acrylonitrile and its metabolites in rats. Arch Toxicol 60(6):464–466. 10.1007/BF00302391.3662822
Mumtaz MM, Ray M, Crowell SR, . 2012a. Translational research to develop a human PBPK models tool kit-volatile organic compounds (VOCs). J Toxicol Environ Health A 75(1):6–24. 10.1080/15287394.2012.625546.22047160
Mumtaz M, Fisher J, Blount B, . 2012b. Application of physiologically based pharmacokinetic models in chemical risk assessment. J Toxicol 2012:904603. 10.1155/2012/904603.22523493
Munshi HB, Rao KVS, Iyer RM. 1989. Rate constants of the reactions of ozone with nitriles, acrylates and terpenes in gas phase. Atmos Environ 23(9):1971–1976. 10.1016/0004-6981(89)90522-2.
Murray FJ, Schwetz BA, Nitschke KD, . 1978. Teratogenicity of acrylonitrile given to rats by gavage or by inhalation. Food Cosmet Toxicol 16(6):547–551. 10.1016/s0015-6264(78)80222-3.730081
Muto T, Sakurai H, Omae K, . 1992. Health profiles of workers exposed to acrylonitrile. Keio J Med 41(3):154–160. 10.2302/kjm.41.154.1434310
Myhr B, Bowers L, Caspary WJ. 1985. Assays for the induction of gene mutations at the thymidine kinase locus in L5178Y mouse lymphoma cells in culture. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 555–568.
NAS/NRC. 2006. Human biomonitoring for environmental chemicals. Washington, DC: The National Academies Press, National Research Council. 10.17226/11700.
Neely WB, Branson DR, Blau GE. 1974. Partition coefficient to measure bioconcentration potential of organic chemicals in fish. Environ Sci Technol 8:1113–1115. 10.1021/es60098a008.
Nemec MD, Kirkpatrick DT, Sherman J, . 2008. Two-generation reproductive toxicity study of inhaled acrylonitrile vapors in Crl:CD(SD) rats. Int J Toxicol 27(1):11–29. 10.1080/10915810701876463.
NIOSH. 2016. Immediately dangerous to life or health (IDLH) value profile. Acrylonitrile. National Institute for Occupational Safety and Health. DHHS (NIOSH) Publication 2016-167. https://www.cdc.gov/niosh/docs/2016-167/pdfs/2016-167.pdf?id=10.26616/NIOSHPUB2016167. June 27, 2022.
NIOSH. 2019. Acrylonitrile. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0014.html. June 25, 2022.
NITE. 2022. Acrylonitrile. Japanese CHEmicals Collaborative Knowledge database (JCHECK). Japanese National Institute of Technology and Evaluation. https://www.nite.go.jp/chem/jcheck/search.action?request_locale=en. July 15, 2022.
NLM. 2022. PubChem compound summary: Acrylonitrile. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/7855. August 8, 2022.
NTP. 2001. Toxicology and carcinogenesis studies of acrylonitrile (CAS No. 107-13-1) in B6C3F1 mice (gavage studies). Research Triangle Park, NC: National Toxicology Program. NTP TR 506. NIH Publication No. 02-4440. https://ntp.niehs.nih.gov/ntp/htdocs/lt_rpts/tr506.pdf. July 5, 2022.
NTP. 2013. Draft OHAT approach for systematic review and evidence integration for literature-based health assessments - February 2013. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/evaluationprocess/draftohatapproach_february2013.pdf. July 5, 2022.
NTP. 2015. OHAT risk of bias rating tool for human and animal studies. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/ohat/pubs/riskofbiastool_508.pdf. March 19, 2019.
NTP. 2021. Acrylonitrile. Report on carcinogens. 15^th^ ed. National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/profiles/acrylonitrile.pdf. June 25, 2022.
Obe G, Hille A, Jonas R, . 1985. Tests for the induction of sister-chromatid exchanges in human peripheral lymphocytes in culture. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 439–442.
O’Berg MT. 1980. Epidemiologic study of workers exposed to acrylonitrile. J Occup Med 22(4):245–252.7365560
O’Berg MT, Chen JL, Burke CA, . 1985. Epidemiologic study of workers exposed to acrylonitrile: an update. J Occup Med 27(11):835–840. 10.1097/00043764-198511000-00018.4067690
OSHA. 2001. OSHA method 37: Acrylonitrile. Salt Lake City, UT: Occupational Safety and Health Administration. https://www.osha.gov/sites/default/files/methods/osha37.pdf. September 1, 2022.
OSHA. 2023a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Acrylonitrile. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1045. https://www.gpo.gov/fdsys/pkg/CFR-2023-title29-vol6/pdf/CFR-2023-title29-vol6-sec1910-1045.pdf. September 29, 2024.
OSHA. 2023b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Acrylonitrile. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1045. https://www.gpo.gov/fdsys/pkg/CFR-2023-title29-vol7/pdf/CFR-2023-title29-vol7-sec1915-1045.pdf. September 29, 2024.
OSHA. 2023c. Safety and health regulations for construction. Subpart Z - Toxic and hazardous substances. Acrylonitrile. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.1145. https://www.gpo.gov/fdsys/pkg/CFR-2023-title29-vol8/pdf/CFR-2023-title29-vol8-sec1926-1145.pdf. September 29, 2024.
Osterman-Golkar SM, MacNeela JP, Turner MJ, . 1994. Monitoring exposure to acrylonitrile using adducts with N-terminal valine in hemoglobin. Carcinogenesis 15(12):2701–2707.8001224
Parent RA, Casto BC. 1979. Effect of acrylonitrile on primary Syrian golden hamster embryo cells in culture: Transformation and DNA fragmentation. J Natl Cancer Inst 62(4):1025–1029. 10.1093/jnci/62.4.1025.285274
Perocco P, Pane G, Bolognesi S, . 1982. Increase of sister chromatid exchange and unscheduled synthesis of deoxyribonucleic acid by acrylonitrile in human lymphocytes in vitro. Scand J Work Environ Health 8(4):290–293. 10.5271/sjweh.2464.7170626
Pilon D, Roberts AE, Rickert DE. 1988a. Effect of glutathione depletion on the irreversible association of acrylonitrile with tissue macromolecules after oral administration to rats. Toxicol Appl Pharmacol 95(2):311–320. 10.1016/0041-008x(88)90167-6.3420618
Pilon D, Roberts AE, Rickert DE. 1988b. Effect of glutathione depletion on the uptake of acrylonitrile vapors and on its irreversible association with tissue macromolecules. Toxicol Appl Pharmacol 95(2):265–278. 10.1016/0041-008x(88)90163-9.2458635
Ploemen JP, Wormhoudt LW, Haenen GR, . 1997. The use of human in vitro metabolic parameters to explore the risk assessment of hazardous compounds: the case of ethylene dibromide. Toxicol Appl Pharmacol 143(1):56–69. 10.1006/taap.1996.8004.9073592
Pouyatos B, Gearhart CA, Fechter LD. 2005. Acrylonitrile potentiates hearing loss and cochlear damage induced by moderate noise exposure in rats. Toxicol Appl Pharmacol 204(1):46–56. 10.1016/j.taap.2004.08.015.15781293
Pouyatos B, Gearhart CA, Nelson-Miller A, . 2009. Selective vulnerability of the cochlear Basal turn to acrylonitrile and noise. J Toxicol 2009:908596. 10.1155/2009/908596.20130768
Priston RAJ, Dean BJ. 1985. Tests for the induction of chromosome aberrations, polyploidy and sister chromatid exchanges in rat liver (RL) cells. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 387–395.
Probst GS, Hill LE. 1985. Tests for the induction of DNA repair synthesis in primary cultures of adult rat hepatocytes. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 381–386.
Pu X, Kamendulis LM, Klaunig JE. 2006. Acrylonitrile-induced oxidative DNA damage in rat astrocytes. Environ Mol Mutagen 47(8):631–638. 10.1002/em.20249.16917936
Pu X, Kamendulis LM, Klaunig JE. 2009. Acrylonitrile-induced oxidative stress and oxidative DNA damage in male Sprague-Dawley rats. Toxicol Sci 111(1):64–71. 10.1093/toxsci/kfp133.19546159
Quast JF. 2002. Two-year toxicity and oncogenicity study with acrylonitrile incorporated in the drinking water of rats. Toxicol Lett 132(3):153–196. 10.1016/s0378-4274(02)00072-3.12044703
Quast JF, Humiston CG, Schwetz BA, . 1975. A six-month oral toxicity study incorporating acrylonitrile in the drinking water of purebred beagle dogs. Dow Chemical Company.
Quast JF, Schuetz DJ, Balmer MF, . 1980a. Initial submission: 2-year toxicity and oncogenicity study with acrylonitrile following inhalation exposure in rats (final report) with cover letter dated 080392. Rohm & Haas Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8E. OTS0545173. 88920006574. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0545173.xhtml. May 5, 2022.
Quast JF, Wade CE, Humiston CG, . 1980b. Initial submission: A two-year toxicity & oncogenicity study with acrylonitrile incorporated in the drinking water of rats (final report) with cover letter dated 061792. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. OTS0540235. 88920003736. 8EHQ06925090. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0540235.xhtml. July 5, 2022.
Quast JF, Schuetz DJ, Balmer MF. 1983. Initial submission: Acrylonitrile inhalation exposure study in rats: Results after six and 12 months (final report) with cover letter dated 102591. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA section 8E. OTS0534645. 88920000195. 8EHQ010911547. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0534645.xhtml. July 7, 2022.
Rabello-Gay MN, Ahmed AE. 1980. Acrylonitrile: In vivo cytogenetic studies in mice and rats. Mutat Res 79(3):249–255. 10.1016/0165-1218(80)90072-5.6783897
Radimer GF, Davis JH, Ackerman AB. 1974. Fumigant-induced toxic epidermal necrolysis. Arch Dermatol 110(1):103–104. 10.1001/archderm.1974.01630070067017.4420523
Recio L, Skopek TR. 1988. Mutagenicity of acrylonitrile and its metabolite 2-cyanoethylene oxide in human lymphoblasts in vitro. Mutat Res 206(2):297–305. 10.1016/0165-1218(88)90174-7.3173396
RePORTER. 2024. Acrylonitrile. National Institutes of Health, Research Portfolio Online Reporting Tools. http://projectreporter.nih.gov/reporter.cfm. September 25, 2024.
Robbiano L, Allavena A, Bagarolo C, . 1994. Comparison in human and rat hepatocytes of the DNA-damaging activity of five chemicals probably carcinogenic to humans. Toxicol Vitro 8(1):131–137. 10.1016/0887-2333(94)90217-8.
Roberts AE, Lacy SA, Pilon D, . 1989. Metabolism of acrylonitrile to 2-cyanoethylene oxide in F-344 rat liver microsomes, lung microsomes, and lung cells. Drug Metab Dispos 17(5):481–486.2573490
Roberts AE, Kedderis GL, Turner MJ, . 1991. Species comparison of acrylonitrile epoxidation by microsomes from mice, rats and humans: relationship to epoxide concentrations in mouse and rat blood. Carcinogenesis 12(3):401–404. 10.1093/carcin/12.3.401.2009586
Rogaczewska T, Piotrowski J. 1968. Experimental evaluation of the absorption routes of acrylonitrile in man. Medycyna Pracy 19:349–354.
Rooney AA, Boyles AL, Wolfe MS, . 2014. Systematic review and evidence integration for literature-based environmental health science assessments. Environ Health Perspect 122(7):711–718. 10.1289/ehp.1307972.24755067
Roudabush RL, Terhaar CJ, Fassett DW, . 1965. Comparative acute effects of some chemicals on the skin of rabbits and guinea pigs. Toxicol Appl Pharmacol 7(4):559–565. 10.1016/0041-008x(65)90041-4.5839391
Rouisse L, Chakrabarti S, Tuchweber B. 1986. Acute nephrotoxic potential of acrylonitrile in Fischer-344 rats. Res Commun Chem Pathol Pharmacol 53(3):347–360.3775103
Roy WR, Griffin RA. 1985. Mobility of organic solvents in water saturated soil materials. Environ Geol Water Sci 7:241–247. 10.1007/BF02509925.
Ruiz P, Ray M, Fisher J, . 2011. Development of a human Physiologically Based Pharmacokinetic (PBPK) Toolkit for environmental pollutants. Int J Mol Sci 12(11):7469–7480. 10.3390/ijms12117469.22174611
Saillenfait AM, Sabate JP. 2000. Comparative developmental toxicities of aliphatic nitriles: in vivo and in vitro observations. Toxicol Appl Pharmacol 163(2):149–163. 10.1006/taap.1999.8839.10698673
Saillenfait AM, Langonne I, Sabate JP, . 1992. Embryotoxicity of acrylonitrile in whole-embryo culture. Toxicol Vitro 6(3):253–260. 10.1016/0887-2333(92)90039-t.
Saillenfait AM, Payan JP, Langonne I, . 1993. Modulation of acrylonitrile-induced embryotoxicity in vitro by glutathione depletion. Arch Toxicol 67(3):164–172. 10.1007/BF01973303.8494495
Sakurai H, Onodera M, Utsunomiya T, . 1978. Health effects of acrylonitrile in acrylic fibre factories. Br J Ind Med 35(3):219–225. 10.1136/oem.35.3.219.698135
Sandberg EC, Slanina P. 1980. Distribution of [1-14C] acrylonitrile in rat and monkey. Toxicol Lett 6(3):187–191. 10.1016/0378-4274(80)90190-3.6773187
Sander R. 2015. Compilation of Henry’s law constants (version 4.0) for water as solvent. Atmos Chem Phys 15(8):4399–4981. 10.5194/acp-15-4399-2015.
Sanner T, Rivedal E. 1985. Tests with the Syrian hamster embryo (SHE) cell transformation assay. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 665–671.
Sax NI. 1984. Acrylonitrile. In: Dangerous properties of industrial materials. 6^th^ ed. New York, NY: Van Nostrand Reinhold Company, 132–133.
Sax NI, Lewis RJ. 1987. Acrylonitrile. In: Hawley’s condensed chemical dictionary. 11^th^ ed. New York, NY: Van Nostrand Reinhold Company, 19.
Scélo G, Constantinescu V, Csiki I, . 2004. Occupational exposure to vinyl chloride, acrylonitrile and styrene and lung cancer risk (Europe). Cancer Causes Control 15(5):445–452. 10.1023/B:CACO.0000036444.11655.be.15286464
Sekihashi K, Yamamoto A, Matsumura Y, . 2002. Comparative investigation of multiple organs of mice and rats in the comet assay. Mutat Res 517(1–2):53–75. 10.1016/s1383-5718(02)00034-7.12034309
Sharief Y, Brown AM, Backer LC, . 1986. Sister chromatid exchange and chromosome aberration analyses in mice after in vivo exposure to acrylonitrile, styrene, or butadiene monoxide. Environ Mutagen 8(3):439–448. 10.1002/em.2860080312.3709426
Shi Y, Bai J, Dang Y, . 2021. Protection of apigenin against acrylonitrile-induced sperm and testis injury in rats: involvement of activation of ASK1-JNK/p38 signaling pathway. Toxicol Res 10(2):159–168. 10.1093/toxres/tfab017.
Silver EH, Szabo S, Cahill M, . 1987. Time-course studies of the distribution of [1-14C]Acrylonitrile in rats after intravenous administration. J Appl Toxicol 7(5):303–306. 10.1002/jat.2550070503.3680846
Simons K, De Smedt T, Stove C, . 2016. Short-term health effects in the general population following a major train accident with acrylonitrile in Belgium. Environ Res 148:256–263. 10.1016/j.envres.2016.03.031.27085497
Sram RJ, Beskid O, Binkova B, . 2004. Cytogenetic analysis using fluorescence in situ hybridization (FISH) to evaluate occupational exposure to carcinogens. Toxicol Lett 149(1–3):335–344. 10.1016/j.toxlet.2003.12.043.15093279
Staples CA, Werner AF, Hoogheem TJ. 1985. Assessment of priority pollutant concentrations in the United States using STORET database. Environ Toxicol Chem 4:131–142. 10.1002/etc.5620040202.
Stayner LT, Carreón-Valencia T, Demers PA, . 2024. Carcinogenicity of talc and acrylonitrile. Lancet Oncol 25(8):962–963. 10.1016/s1470-2045(24)00384-x.38976996
Stewart PA, Zaebst D, Zey JN, . 1998. Exposure assessment for a study of workers exposed to acrylonitrile. Scand J Work Environ Health 24(2):42–53.9714512
Stover EL, Kincannon DF. 1983. Biological treatability of specific organic compounds found in chemical industry wastewaters. J Water Pollut Control Fed 55:97–109.
Subramanian U, Ahmed AE. 1995. Intestinal toxicity of acrylonitrile: in vitro metabolism by intestinal cytochrome P450 2E1. Toxicol Appl Pharmacol 135(1):1–8. 10.1006/taap.1995.1202.7482528
Sumner SC, Selvaraj L, Nauhaus SK, . 1997. Urinary metabolites from F344 rats and B6C3F1 mice coadministered acrylamide and acrylonitrile for 1 or 5 days. Chem Res Toxicol 10(10):1152–1160. 10.1021/tx9602123.9348438
Sumner SC, Fennell TR, Moore TA, . 1999. Role of cytochrome P450 2E1 in the metabolism of acrylamide and acrylonitrile in mice. Chem Res Toxicol 12(11):1110–1116. 10.1021/tx990040k.10563837
Swaen GM, Bloemen LJ, Twisk J, . 1992. Mortality of workers exposed to acrylonitrile. J Occup Med 34(8):801–809. 10.1097/00043764-199208000-00015.1506938
Swaen GM, Bloemen LJ, Twisk J, . 1998. Mortality update of workers exposed to acrylonitrile in The Netherlands. Scand J Work Environ Health 24(Suppl 2):10–16.9714509
Swaen GM, Bloemen LJ, Twisk J, . 2004. Mortality update of workers exposed to acrylonitrile in The Netherlands. J Occup Environ Med 46(7):691–698. 10.1097/01.jom.0000128161.17144.27.15247808
Sweeney LM, Gearhart JM. 2020. Examples of physiologically based pharmacokinetic modeling applied to risk assessment. In: Fisher JW, Gearhart JM, Lin Z, eds. Physiologically based pharmacokinetic (PBPK) modeling. Academic Press 281–299. 10.1016/B978-0-12-818596-4.00011-4.
Sweeney LM, Gargas ML, Strother DE, . 2003. Physiologically based pharmacokinetic model parameter estimation and sensitivity and variability analyses for acrylonitrile disposition in humans. Toxicol Sci 71(1):27–40. 10.1093/toxsci/71.1.27.12520073
Symons JM, Kreckmann KH, Sakr CJ, . 2008. Mortality among workers exposed to acrylonitrile in fiber production: an update. J Occup Environ Med 50(5):550–560. 10.1097/JOM.0b013e318162f640.18469624
Szabo S, Bailey KA, Boor PJ, . 1977. Acrylonitrile and tissue glutathione: Differential effect of acute and chronic interactions. Biochem Biophys Res Commun 79(1):32–37. 10.1016/0006-291x(77)90056-0.921805
Szabo S, Huttner I, Kovacs K, . 1980. Pathogenesis of experimental adrenal hemorrhagic necrosis ("apoplexy"): Ultrastructural, biochemical, neuropharmacologic, and blood coagulation studies with acrylonitrile in the rat. Lab Invest 42(5):533–546.6103978
Szabo S, Silver EH, Gallagher GT, . 1983. Potentiation of duodenal ulcerogenic action of acrylonitrile by PCB or phenobarbital in the rat. Toxicol Appl Pharmacol 71(3):451–454. 10.1016/0041-008x(83)90034-0.6419390
Szabo S, Gallagher G, Silver E, . 1984. Subacute and chronic action of acrylonitrile on adrenals and gastrointestinal tract: biochemical, functional and ultrastructural studies in the rat. J Appl Toxicol 4(3):131–140. 10.1002/jat.2550040304.6747195
Tabak HH, Quave SA, Mashni CI, . 1981. Biodegradability studies with organic priority pollutant compounds. J Water Pollut Control Fed 53:1503–1518.
Tan YM, Chan M, Chukwudebe A, . 2020. PBPK model reporting template for chemical risk assessment applications. Regul Toxicol Pharmacol 115:104691. 10.1016/j.yrtph.2020.104691.32502513
Tandon R, Saxena DK, Chandra SV, . 1988. Testicular effects of acrylonitrile in mice. Toxicol Lett 42(1):55–63. 10.1016/0378-4274(88)90102-6.3388448
Tanii H, Hashimoto K. 1984. Studies on the mechanism of acute toxicity of nitriles in mice. Arch Toxicol 55(1):47–54. 10.1007/BF00316585.6732504
Tardif R, Talbot D, Gerin M, . 1987. Urinary excretion of mercapturic acids and thiocyanate in rats exposed to acrylonitrile: Influence of dose and route of administration. Toxicol Lett 39(2–3):255–261. 10.1016/0378-4274(87)90241-4.3686555
Teo SK, Kedderis GL, Gargas ML. 1994. Determination of tissue partition coefficients for volatile tissue-reactive chemicals: acrylonitrile and its metabolite 2-cyanoethylene oxide. Toxicol Appl Pharmacol 128(1):92–96. 10.1006/taap.1994.1184.8079360
Teruel MA, Blanco MB, Luque GR. 2007. Atmospheric fate of acrylic acid and acrylonitrile: Rate constants with Cl atoms and OH radicals in the gas phase. Atmos Environ 41(27):5769–5777. 10.1016/j.atmosenv.2007.02.028.
Thier R, Lewalter J, Kempkes M, . 1999. Haemoglobin adducts of acrylonitrile and ethylene oxide in acrylonitrile workers, dependent on polymorphisms of the glutathione transferases GSTT1 and GSTM1. Arch Toxicol 73(4–5):197–202. 10.1007/s002040050606.10463383
Thier R, Lewalter J, Selinski S, . 2002. Possible impact of human CYP2E1 polymorphisms on the metabolism of acrylonitrile. Toxicol Lett 128(1–3):249–255. 10.1016/s0378-4274(01)00546-x.11869835
Thiess AM, Fleig I. 1978. Analysis of chromosomes of workers exposed to acrylonitrile. Arch Toxicol 41(2):149–152. 10.1007/BF00302526.736788
TRI23. 2024. Acrylonitrile. TRI explorer: release reports. Washington, DC: Toxics Release Inventory. U.S. Environmental Protection Agency. https://enviro.epa.gov/triexplorer/tri_release.chemical. October 3, 2024.
Van Nieuwenhuyse A, Fierens S, De Smedt T, . 2014. Acrylonitrile exposure assessment in the emergency responders of a major train accident in Belgium: a human biomonitoring study. Toxicol Lett 231(3):352–359. 10.1016/j.toxlet.2014.08.013.25128591
Venitt S, Bushell CT, Osborne M. 1977. Mutagenicity of acrylonitrile (cyanoethylene) in Escherichia coli. Mutat Res 45(2):283–288. 10.1016/0027-5107(77)90028-8.339067
Verschueren K. 1983. Acrylonitrile. In: Handbook of environmental data on organic chemicals. 2^nd^ ed. New York, NY: Van Nostrand Reinhold Company, 162–165.
Vogel EW. 1985. The Drosophila somatic recombination and mutation assay (SRM) using the white-coral somatic eye color system. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 313–317.
Vogel RA, Kirkendall WM. 1984. Acrylonitrile (vinyl cyanide) poisoning: A case report. Texas Med 80(5):48–51.
Vogel EW, Nivard MJM. 1993. Performance of 181 chemicals in a Drosophila assay predominantly monitoring interchromosomal mitotic recombination. Mutagenesis 8(1):57–81. 10.1093/mutage/8.1.57.8450769
Walker VE, Fennell TR, Walker DM, . 2020a. Analysis of DNA adducts and mutagenic potency and specificity in rats exposed to acrylonitrile. Chem Res Toxicol 33(7):1609–1622. 10.1021/acs.chemrestox.0c00153.32529823
Walker VE, Walker DM, Ghanayem BI, . 2020b. Analysis of biomarkers of DNA damage and mutagenicity in mice exposed to acrylonitrile. Chem Res Toxicol 33(7):1623–1632. 10.1021/acs.chemrestox.0c00154.32529832
Wang Z, Zhilan L, Wei X. 1995. Study on acrylonitrile to teratogenesis of rats sperm. AN Group, Inc. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8(e). OTS0559911. 89000000313. 8EHQ-0900-14711. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS0559911.xhtml. October 3, 2024.
Weast RC. 1985. Acrylonitrile. In: CRC handbook of chemistry and physics. Boca Raton, FL: CRC Press, Inc., C-58.
Wheeler MW, Blessinger T, Shao K, . 2020. Quantitative risk assessment: Developing a Bayesian approach to dichotomous dose-response uncertainty. Risk Anal 40(9):1706–1722. 10.1111/risa.13537.32602232
WHO. 2000. Air quality guidelines for Europe. World Health Organization. https://www.euro.who.int/__data/assets/pdf_file/0005/74732/E71922.pdf. June 27, 2022.
WHO. 2022. Guidelines for drinking-water quality. Fourth edition incorporating the first and second addenda. World Health Organization. https://www.who.int/publications/i/item/9789240045064. June 22, 2022.
Williams GM, Tong C, Brat SV. 1985. Tests with the rat hepatocyte primary culture/DNA-repair test. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 341–345.
Williams GM, Kobets T, Duan JD, . 2017. Assessment of DNA binding and oxidative DNA damage by acrylonitrile in two rat target tissues of carcinogenicity: Implications for the mechanism of action. Chem Res Toxicol 30(7):1470–1480. 10.1021/acs.chemrestox.7b00105.28613844
Wilson RH. 1944. Health hazards encountered in the manufacture of synthetic rubber. JAMA 124(11):701–703. 10.1001/jama.1944.02850110025007.
Wilson RH, Hough GV, McCormick WE. 1948. Medical problems encountered in the manufacture of American-made rubber. Ind Med Surg 17(6):199–207.18864097
Wood SM, Buffler PA, Burau K, . 1998. Mortality and morbidity of workers exposed to acrylonitrile in fiber production. Scand J Work Environ Health 24(Suppl 2):54–62.
WQP. 2022. Acrylonitrile. Water Quality Portal database. Environmental Protection Agency (EPA); National Water Quality Monitoring Council (NWQMC); United States Geological Survey (USGS). https://www.waterqualitydata.us/. August 9, 2022.
Wurgler FE, Graff U, Frei H. 1985. Somatic mutation and recombination test in wings of Drosophila melanogaster. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam Netherlands: Elsevier Science Publishers, 325–340.
Xu DX, Zhu QX, Zheng LK, . 2003. Exposure to acrylonitrile induced DNA strand breakage and sex chromosome aneuploidy in human spermatozoa. Mutat Res 537(1):93–100. 10.1016/s1383-5718(03)00055-x.12742510
Yalkowsky SH, He Y, Jain P. 2010. Acrylonitrile. In: Handbook of aqueous solubility data. 2^nd^ ed. Boca Raton, FL: CRC Press, 46.
Yamada H, Asano Y, Hino T, . 1979. Microbiol utilization of acrylonitrile. J Ferment Technol 57:8–14.
Young JD, Slauter RW, Karbowski RJ. 1977. The pharmacokinetic and metabolic profile of r4Cacrylonitrile given to rats by three routes. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section FYI. OTS0000150-0. FYI-OTS-0677-0150. https://ntrl.ntis.gov/NTRL/dashboard/searchResults/titleDetail/OTS00001500.xhtml. September 22, 2022.
Zeiger E, Haworth S. 1985. Tests with a preincubation modification of the Salmonella/microsome assay. In: Ashby J, de Serres FJ, eds. Progress in mutation research. Vol. 5. Amsterdam The Netherlands: Elsevier Science Publishers, 187–199.