# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Mohammad Shoeb, Ph.D. (Lead)
  Obaid Faroon, D.V.M., Ph.D. (Retired)
  Custodio Muianga, M.P.H., Ph.D.
  Breanna Alman, M.P.H.
  ATSDR, Office of Innovation and Analytics, Atlanta, GA

- Lisa Ingerman, Ph.D., D.A.B.T.
  Savannah Sierco, M.S.
  SRC, Inc., North Syracuse, NY

## REVIEWERS

- Interagency Minimal Risk Level Workgroup:
  Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).
- Additional reviews for science and/or policy:
  ATSDR, Office of Community Health Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Sciences; NCEH, Division of Environmental Health Science and Practice; EPA, Office of Research and Development; EPA, Office of Water.

## PEER REVIEWERS

1. Gary M. Marsh, Ph.D., F.A.C.E.; Professor Emeritus of Biostatistics and Epidemiology; Founding Director, Center for Occupational Biostatistics & Epidemiology; Department of Biostatistics; School of Public Health; University of Pittsburgh; Pittsburgh, Pennsylvania
2. Vernon E. Walker, D.V.M., Ph.D.; Genetic Toxicology Laboratory; Department of Pathology and Laboratory Medicine; Larner College of Medicine; University of Vermont; Jericho, Vermont
3. Stella Koutros, Ph.D., M.P.H.; Investigator; National Cancer Institute; Division of Cancer Epidemiology and Genetics; Occupational and Environmental Epidemiology Branch; Bethesda, Maryland
4. Deborah Cory-Slechta, Ph.D.; Department of Environmental Medicine; University of Rochester Medical Center; Rochester, New York
5. Ivan Rusyn, M.D., Ph.D.; Professor and Chair; Department of Veterinary Integrative Biosciences; College of Vet Medicine & Biomedical Sciences, Texas A&M University; College Station, Texas

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.