# CHAPTER 7 REGULATIONS AND GUIDELINES

Pertinent international and national regulations, advisories, and guidelines regarding acrylonitrile in air, water, and other media are summarized in Table 7-1. This table is not an exhaustive list, and current regulations should be verified by the appropriate regulatory agency.

ATSDR develops MRLs, which are substance-specific guidelines intended to serve as screening levels by ATSDR health assessors and other responders to identify contaminants and potential health effects that may be of concern at hazardous waste sites. See Section 1.3 and Appendix A for detailed information on the MRLs for acrylonitrile.

Table 7-1 Regulations and Guidelines Applicable to Acrylonitrile

Agency | Description | Information | Reference
Air
EPA | RfC | 2x10^−3^ mg/m^3^ (0.001 ppm) | IRIS 2002
WHO | Air quality guidelines for Europe | | WHO 2000
WHO | Guideline | Treated as if a human carcinogen, no safe level can be recommended | WHO 2000
WHO | Lifetime unit risk; (at air concentration of 1 μg/m^3^) | 2x10^−5^ | WHO 2000
Water & Food
EPA | Drinking water standards and health advisories | | EPA 2018a
EPA | 10^−4^ Cancer risk | 0.006 mg/L | EPA 2018a
EPA | National primary drinking water regulations | Not listed | EPA 2023
EPA | RfD | Not evaluated | IRIS 2002
WHO | Drinking water quality guidelines | Not listed | WHO 2022
FDA | Substances added to food^a^ | Acrylonitrile monomer not listed | FDA 2024
Cancer
HHS | Carcinogenicity classification | Reasonably anticipated to be a human carcinogen | NTP 2021
EPA | Carcinogenicity classification | B1^b^ | IRIS 2002
EPA | Inhalation unit risk | 6.8x10^−5^ per μg/m^3^ | IRIS 2002
EPA | Oral slope factor | 5.4x10^−1^ per mg/kg/day | IRIS 2002
IARC | Carcinogenicity classification | Group 1^c^ | Stayner et al. 2024
Occupational
OSHA | PEL (8-hour TWA) for general industry, shipyards, and construction | 2 ppm | OSHA 2023a, 2023b, 2023c
OSHA | Ceiling limit (15-minute) for general industry, shipyards, and construction | 10 ppm | OSHA 2023a, 2023b, 2023c
OSHA | Dermal and eye exposure for general industry, shipyards, and construction | No skin or eye contact with liquid acrylonitrile | OSHA 2023a, 2023b, 2023c
NIOSH | REL (up to 10-hour TWA) | 1 ppm^d,e^ | NIOSH 2019
NIOSH | Ceiling limit (15-minute) | 10 ppm | NIOSH 2019
NIOSH | IDLH | 60 ppm | NIOSH 2016
Emergency Criteria
EPA | AEGLs-air | | EPA 2018b
EPA | AEGL 1^f^ | | EPA 2018b
EPA | 10-minute | 1.5 ppm | EPA 2018b
EPA | 30-minute | 1.5 ppm | EPA 2018b
EPA | 60-minute | NR^g^ | EPA 2018b
EPA | 4-hour | NR^g^ | EPA 2018b
EPA | 8-hour | NR^g^ | EPA 2018b
EPA | AEGL 2^f^ | | EPA 2018b
EPA | 10-minute | 8.6 ppm | EPA 2018b
EPA | 30-minute | 3.2 ppm | EPA 2018b
EPA | 60-minute | 1.7 ppm | EPA 2018b
EPA | 4-hour | 0.48 ppm | EPA 2018b
EPA | 8-hour | 0.26 ppm | EPA 2018b
EPA | AEGL 3^f^ | | EPA 2018b
EPA | 10-minute | 130 ppm | EPA 2018b
EPA | 30-minute | 50 ppm | EPA 2018b
EPA | 60-minute | 28 ppm | EPA 2018b
EPA | 4-hour | 9.7 ppm | EPA 2018b
EPA | 8-hour | 5.2 ppm | EPA 2018b
DOE | PACs-air | | DOE 2024a
DOE | PAC-1^h^ | 0.15 ppm | DOE 2024a
DOE | PAC-2^h^ | 1.7 ppm | DOE 2024a
DOE | PAC-3^h^ | 28 ppm | DOE 2024a

a The Substances Added to Food inventory replaces EAFUS and contains the following types of ingredients: food and color additives listed in FDA regulations, flavoring substances evaluated by FEMA or JECFA, GRAS substances listed in FDA regulations, substances approved for specific uses in food prior to September 6, 1958, substances that are listed in FDA regulations as prohibited from use in food, delisted color additives, and some substances “no longer FEMA GRAS”.

b Group B1: probable human carcinogen, based on limited evidence of carcinogenicity in humans.

c Group 1: carcinogenic to humans.

d Skin designation.

e Potential occupational carcinogen.

f Definitions of AEGL terminology are available from U.S. Environmental Protection Agency (EPA 2018c).

g NR: Not recommended due to insufficient data.

h Definitions of PAC terminology are available from U.S. Department of Energy (DOE 2024b).

AEGL = acute exposure guideline levels; DOE = Department of Energy; EAFUS = Everything Added to Food in the United States; EPA = Environmental Protection Agency; FDA = Food and Drug Administration; FEMA = Flavor and Extract Manufacturers Association of the United States; GRAS = generally recognized as safe; HHS = Department of Health and Human Services; IARC = International Agency for Research on Cancer; IDLH = immediately dangerous to life or health; IRIS = Integrated Risk Information System; JECFA = Joint FAO/WHO Expert Committee on Food Additives; NIOSH = National Institute for Occupational Safety and Health; NTP = National Toxicology Program; OSHA = Occupational Safety and Health Administration; PAC = protective action criteria; PEL = permissible exposure limit; REL = recommended exposure limit; RfC = inhalation reference concentration; RfD = oral reference dose; TLV = threshold limit value; TWA = time-weighted average; WHO = World Health Organization