# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Information regarding the chemical identity of acrylonitrile is presented in Table 4-1.

Table 4-1 Chemical Identity of Acrylonitrile

Characteristic | Information
Chemical name | Acrylonitrile
Synonym(s) and registered trade name(s) | Cyanoethylene; 2-Propenenitrile; Vinyl cyanide; Acritet, Caswell No. 010; ENT 54; Fumigrain; Ventox
Chemical formula | C_3_H_3_N
SMILES | C=CC#N
Chemical structure | Acrylonitrile chemical structure
CAS Registry Number | 107-13-1

CAS = Chemical Abstracts Service; SMILES = simplified molecular-input line-entry system

Source: NLM 2022

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Information regarding physical and chemical properties of acrylonitrile is presented in Table 4-2.

Table 4-2 Physical and Chemical Properties of Acrylonitrile

Property | Information | Reference
Molecular weight | 53.06 | Weast 1985
Color | Colorless | Verschueren 1983
Physical state | Liquid | Verschueren 1983
Melting point | -83°C | Verschueren 1983
Boiling point | 77.4°C | Verschueren 1983
Density at 20°C | 0.8060 | Verschueren 1983
Odor | Pungent (onion, garlic) | Verschueren 1983
Odor threshold:
Water | 18.6 mg/L | Verschueren 1983
Air | 47 mg/m^3^ | Verschueren 1983
Solubility:
Water at 20°C | 79,000 mg/L; 6,803 mg/L | Klein et al. 1957; Yalkowsky et al. 2010
Organic solvents | Soluble in all common organic solvents | Sax and Lewis 1987
Partition coefficients:
Log K_ow_ | 0.25 | EPA 1982a
Log K_oc_ | 1.00 and 1.10; -0.07 (estimated from Log K_ow_) | EPA 1992; EPA 1982a
Vapor pressure
at 22.8°C | 100 mm Hg | EPA 1982a
at 25°C | 109 mm Hg | NLM 2022
Henry’s law constant at 25°C | 1.18x10^−5^ atm-m^3^/mol; 8.8x10^−5^ atm-m^3^/mol (calculated from vapor pressure/water solubility) | Sander 2015; EPA 1982a
Autoignition temperature | 481°C | Sax 1984
Flashpoint | -1°C | Sax 1984
Explosive limits | 3–17% | Sax and Lewis 1987
Conversion factors | 1 ppm=2.203 mg/m^3^; 1 mg/m^3^=0.454 ppm | Verschueren 1983