# APPENDIX B LITERATURE SEARCH FRAMEWORK FOR ACRYLONITRILE

The objective of the toxicological profile is to evaluate the potential for human exposure and the potential health hazards associated with inhalation, oral, or dermal/ocular exposure to acrylonitrile.

## B.1 LITERATURE SEARCH AND SCREEN

A literature search and screen were conducted to identify studies examining health effects, toxicokinetics, mechanisms of action, susceptible populations, biomarkers, chemical interactions, physical and chemical properties, production, use, environmental fate, environmental releases, and environmental and biological monitoring data for acrylonitrile. ATSDR primarily focused on peer-reviewed articles without language restrictions. Foreign language studies are reviewed based on available English-language abstracts and/or tables (or summaries in regulatory assessments, such as International Agency for Research on Cancer [IARC] documents). If the study appears critical for hazard identification or MRL derivation, translation into English is requested. Non-peer-reviewed studies that were considered relevant to the assessment of the health effects of acrylonitrile have undergone peer review by at least three ATSDR-selected experts who have been screened for conflict of interest. The inclusion criteria used to identify relevant studies examining the health effects of acrylonitrile are presented in Table B-1.

Table B-1 Inclusion Criteria for the Literature Search and Screen^a^

Health Effects
Species
Human
Laboratory mammals
Route of exposure
Inhalation
Oral
Dermal (or ocular)
Parenteral (these studies will be considered supporting data)
Health outcome
Death
Systemic effects
Body weight effects
Respiratory effects
Cardiovascular effects
Gastrointestinal effects
Hematological effects
Musculoskeletal effects
Hepatic effects
Renal effects
Dermal effects
Ocular effects
Endocrine effects
Immunological effects
Neurological effects
Reproductive effects
Developmental effects
Other noncancer effects
Cancer
Toxicokinetics
Absorption
Distribution
Metabolism
Excretion
PBPK models
Biomarkers
Biomarkers of exposure
Biomarkers of effect
Interactions with other chemicals
Potential for human exposure
Releases to the environment
Air
Water
Soil
Environmental fate
Transport and partitioning
Transformation and degradation
Environmental monitoring
Air
Water
Sediment and soil
Other media
Biomonitoring
General populations
Occupation populations

a Physical-chemical properties are not generally obtained from literature searches, but rather from curated governmental databases such as PubChem.

### B.1.1 Literature Search

The literature search was conducted to update the Toxicological Profile for Acrylonitrile released in 1990. All literature cited in the previous (1990) toxicological profile were considered for inclusion in the updated profile. The initial literature search, which was performed in October 2021, was restricted to studies added to databases since January 1988. An updated literature search was performed after the Toxicological Profile for Acrylonitrile Draft for Public Comment was released in August 2023 to identify any additional studies added to databases between September 2021 and December 2023.

The following main databases were searched in April 2017, October 2021, and/or December 2023:

- PubMed
- National Technical Reports Library (NTRL)
- Scientific and Technical Information Network’s TOXCENTER
- National Library of Medicine’s TOXLINE (April 2017 only)

The search strategy used the chemical names, Chemical Abstracts Service (CAS) numbers, synonyms, Medical Subject Headings (MeSH) headings, and keywords for acrylonitrile. The query strings used for the literature search are presented in Table B-2.

The search was augmented by searching the Toxic Substances Control Act Test Submissions (TSCATS), NTP website, and National Institute of Health Research Portfolio Online Reporting Tools Expenditures and Results (NIH RePORTER) databases using the queries presented in Table B-3. Additional databases were searched in the creation of various tables and figures, such as the TRI Explorer, the Substance Priority List (SPL) resource page, and other items as needed. Regulations applicable to acrylonitrile were identified by searching international and U.S. agency websites and documents.

Review articles were identified and used for the purpose of providing background information and identifying additional references. ATSDR also identified reports from the grey literature, which included unpublished research reports, technical reports from government agencies, conference proceedings and abstracts, and theses and dissertations.

Table B-2 Database Query Strings

Database search date | Query string
PubMed
12/2023 | (“Acrylonitrile”[mh] AND 2021/09/01:3000[mhda]) OR ((“2-Propenenitrile”[tw] OR “Acritet”[tw] OR “Acrylon”[tw] OR “Acrylonitrile”[tw] OR “Carbacryl”[tw] OR “Cyanoethylene”[tw] OR “ENT 54”[tw] OR “Fumigrain”[tw] OR “Miller’s fumigrain”[tw] OR “NCI-C50215”[tw] OR “NSC 6362”[tw] OR “Propenenitrile”[tw] OR “TL 314”[tw] OR “Ventox”[tw] OR “Vinyl cyanide”[tw]) AND (2021/09/01:3000[edat] OR 2021/09/01:3000[crdat]))
10/2021 | ((“Acrylonitrile”[mh] AND (2015/01/01 : 3000[dp] OR 2015/01/01 : 3000[mhda])) OR (((“2-Propenenitrile”[tw] OR “Acritet”[tw] OR “Acrylon”[tw] OR “Acrylonitrile”[tw] OR “Carbacryl”[tw] OR “Cyanoethylene”[tw] OR “ENT 54”[tw] OR “Fumigrain”[tw] OR “Miller’s fumigrain”[tw] OR “NCI-C50215”[tw] OR “NSC 6362”[tw] OR “Propenenitrile”[tw] OR “TL 314”[tw] OR “Ventox”[tw] OR “Vinyl cyanide”[tw]) NOT medline[sb]) AND (2015/01/01 : 3000[dp] OR 2015/01/01 : 3000[crdat] OR 2015/01/01 : 3000[edat])))
04/2017 | ((“Acrylonitrile”[mh] AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[mhda])) OR (((“2-Propenenitrile”[tw] OR “Acritet”[tw] OR “Acrylon”[tw] OR “Acrylonitrile”[tw] OR “Carbacryl”[tw] OR “Cyanoethylene”[tw] OR “ENT 54”[tw] OR “Fumigrain”[tw] OR “Miller’s fumigrain”[tw] OR “NCI-C50215”[tw] OR “NSC 6362”[tw] OR “Propenenitrile”[tw] OR “TL 314”[tw] OR “Ventox”[tw] OR “Vinyl cyanide”[tw]) NOT medline[sb]) AND (1988/01/01 : 3000[dp] OR 1988/01/01 : 3000[crdat] OR 1988/01/01 : 3000[edat]))) OR (((“Nitriles/toxicity”[mh] OR “Nitriles/adverse effects”[mh] OR “Nitriles/poisoning”[mh] OR “Nitriles/pharmacokinetics”[mh]) OR (“Nitriles”[mh] AND (“environmental exposure”[mh] OR ci[sh])) OR (“Nitriles”[mh] AND toxicokinetics[mh:noexp]) OR (“Nitriles/blood”[mh] OR “Nitriles/cerebrospinal fluid”[mh] OR “Nitriles/urine”[mh]) OR (“Nitriles”[mh] AND (“endocrine system”[mh] OR “hormones, hormone substitutes, and hormone antagonists”[mh] OR “endocrine disruptors”[mh])) OR (“Nitriles”[mh] AND (“computational biology”[mh] OR “medical informatics”[mh] OR genomics[mh] OR genome[mh] OR proteomics[mh] OR proteome[mh] OR metabolomics[mh] OR metabolome[mh] OR genes[mh] OR “gene expression”[mh] OR phenotype[mh] OR genetics[mh] OR genotype[mh] OR transcriptome[mh] OR (“systems biology”[mh] AND (“environmental exposure”[mh] OR “epidemiological monitoring”[mh] OR analysis[sh])) OR “transcription, genetic “[mh] OR “reverse transcription”[mh] OR “transcriptional activation”[mh] OR “transcription factors”[mh] OR (“biosynthesis”[sh] AND (RNA[mh] OR DNA[mh])) OR “RNA, messenger”[mh] OR “RNA, transfer”[mh] OR “peptide biosynthesis”[mh] OR “protein biosynthesis”[mh] OR “reverse transcriptase polymerase chain reaction”[mh] OR “base sequence”[mh] OR “trans-activators”[mh] OR “gene expression profiling”[mh])) OR (“Nitriles/antagonists and inhibitors”[mh]) OR (“Nitriles/metabolism”[mh] AND (“humans”[mh] OR “animals”[mh])) OR (“Nitriles”[majr] AND cancer[sb]) OR (“Nitriles/pharmacology”[majr])) AND (“2-Propenenitrile”[tw] OR “Acritet”[tw] OR “Acrylon”[tw] OR “Acrylonitrile”[tw] OR “Carbacryl”[tw] OR “Cyanoethylene”[tw] OR “ENT 54”[tw] OR “Fumigrain”[tw] OR “Miller’s fumigrain”[tw] OR “NCI-C50215”[tw] OR “NSC 6362”[tw] OR “Propenenitrile”[tw] OR “TL 314”[tw] OR “Ventox”[tw] OR “Vinyl cyanide”[tw]) AND (1988/01/01 : 1990[dp] OR 1988/01/01 : 1990[mhda]))
Toxline
04/2017 | ( “2-propenenitrile” OR “acritet” OR “acrylon” OR “acrylonitrile” OR “carbacryl” OR “cyanoethylene” OR “ent 54” OR “fumigrain” OR “miller’s fumigrain” OR “nci-c50215” OR “nsc 6362” OR “propenenitrile” OR “tl 314” OR “ventox” OR “vinyl cyanide” OR 107-13-1 [rn] ) AND 1988:2017 [yr] AND ( ANEUPL [org] OR BIOSIS [org] OR CIS [org] OR DART [org] OR EMIC [org] OR EPIDEM [org] OR FEDRIP [org] OR HEEP [org] OR HMTC [org] OR IPA [org] OR RISKLINE [org] OR MTGABS [org] OR NIOSH [org] OR NTIS [org] OR PESTAB [org] OR PPBIB [org] ) AND NOT PubMed [org] AND NOT pubdart [org]
NTRL
12/2023 | Date limited 2020-present “2-Propenenitrile” OR “Acritet” OR “Acrylon” OR “Acrylonitrile” OR “Carbacryl” OR “Cyanoethylene” OR “ENT 54” OR “Fumigrain” OR “Miller’s fumigrain” OR “NCI-C50215” OR “NSC 6362” OR “Propenenitrile” OR “TL 314” OR “Ventox” OR “Vinyl cyanide”
10/2021 | “Acrylonitrile” OR “Propenenitrile” OR “Cyanoethylene” OR “Ventox” OR “vinyl cyanide” OR “Acritet” OR “Acrylon” OR “Carbacryl” OR “Fumigrain”
Toxcenter
12/2023 | FILE ‘TOXCENTER’ ENTERED AT 10:33:17 ON 14 DEC 2023 CHARGED TO COST=ET027.02.02.LB.01; L1 10875 SEA FILE=TOXCENTER 107-13-1; L2 7572 SEA FILE=TOXCENTER L1 NOT PATENT/DT; L3 512 SEA FILE=TOXCENTER L2 AND ED>=20210901 ACT TOXQUERY/Q; -------; L4 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L5 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT, IT); L6 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L7 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L8 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L9 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L10 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L11 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L12 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?) L13 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L14 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L15 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L16 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L17 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L18 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L19 QUE (ENDOCRIN? AND DISRUPT?); L20 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L21 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L22 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L23 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L24 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L25 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L26 QUE (NEPHROTOX? OR HEPATOTOX?); L27 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L28 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L29 QUE L4 OR L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28; L30 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L31 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L32 QUE L29 OR L30 OR L31; L33 QUE (NONHUMAN MAMMALS)/ORGN; L34 QUE L32 OR L33; L35 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L36 QUE L34 OR L35; -------; L37 256 SEA FILE=TOXCENTER L3 AND L36; L38 51 SEA FILE=TOXCENTER L37 AND MEDLINE/FS; L41 205 SEA FILE=TOXCENTER L37 NOT MEDLINE/FS; L42 229 DUP REM L38 L41 (27 DUPLICATES REMOVED); L*** DEL 51 S L37 AND MEDLINE/FS; L*** DEL 51 S L37 AND MEDLINE/FS; L43 51 SEA FILE=TOXCENTER L42; L*** DEL 205 S L37 NOT MEDLINE/FS; L*** DEL 205 S L37 NOT MEDLINE/FS; L44 178 SEA FILE=TOXCENTER L42; L45 178 SEA FILE=TOXCENTER (L43 OR L44) NOT MEDLINE/FS D SCAN L45
10/2021 | FILE ‘TOXCENTER’ ENTERED AT 14:07:09 ON 04 OCT 2021 CHARGED TO COST=EH011.13.01.01; L1 10026 SEA FILE=TOXCENTER 107-13-1; L2 9894 SEA FILE=TOXCENTER L1 NOT TSCATS/FS; L3 6886 SEA FILE=TOXCENTER L2 NOT PATENT/DT; L4 865 SEA FILE=TOXCENTER L3 AND ED>=20170401 ACT TOXQUERY/Q; -------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (NONHUMAN MAMMALS)/ORGN; L35 QUE L33 OR L34; L36 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L37 QUE L35 OR L36; -------; L38 455 SEA FILE=TOXCENTER L4 AND L37; L39 114 SEA FILE=TOXCENTER L38 AND MEDLINE/FS; L40 52 SEA FILE=TOXCENTER L38 AND BIOSIS/FS; L41 286 SEA FILE=TOXCENTER L38 AND CAPLUS/FS; L42 3 SEA FILE=TOXCENTER L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L43 411 DUP REM L39 L40 L41 L42 (44 DUPLICATES REMOVED); L*** DEL 114 S L38 AND MEDLINE/FS; L*** DEL 114 S L38 AND MEDLINE/FS; L44 114 SEA FILE=TOXCENTER L43; L*** DEL 52 S L38 AND BIOSIS/FS; L*** DEL 52 S L38 AND BIOSIS/FS; L45 38 SEA FILE=TOXCENTER L43; L*** DEL 286 S L38 AND CAPLUS/FS; L*** DEL 286 S L38 AND CAPLUS/FS; L46 256 SEA FILE=TOXCENTER L43; L*** DEL 3 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L*** DEL 3 S L38 NOT (MEDLINE/FS OR BIOSIS/FS OR CAPLUS/FS); L47 3 SEA FILE=TOXCENTER L43; L48 297 SEA FILE=TOXCENTER (L44 OR L45 OR L46 OR L47) NOT MEDLINE/FS D SCAN L48
04/2017 | (FILE ‘HOME’ ENTERED AT 11:25:12 ON 07 APR 2017); FILE ‘TOXCENTER’ ENTERED AT 11:25:35 ON 07 APR 2017 CHARGED TO COST=EH011.13.01.01; L1 8065 SEA FILE=TOXCENTER 107-13-1; L2 5660 SEA FILE=TOXCENTER L1 AND PY>1987; L3 5660 SEA FILE=TOXCENTER L2 NOT TSCATS/FS; L4 3863 SEA FILE=TOXCENTER L3 NOT PATENT/DT ACT TOXQUERY/Q; -------; L5 QUE (CHRONIC OR IMMUNOTOX? OR NEUROTOX? OR TOXICOKIN? OR BIOMARKER? OR NEUROLOG?); L6 QUE (PHARMACOKIN? OR SUBCHRONIC OR PBPK OR EPIDEMIOLOGY/ST,CT,IT); L7 QUE (ACUTE OR SUBACUTE OR LD50# OR LD(W)50 OR LC50# OR LC(W)50); L8 QUE (TOXICITY OR ADVERSE OR POISONING)/ST,CT,IT; L9 QUE (INHAL? OR PULMON? OR NASAL? OR LUNG? OR RESPIR?); L10 QUE ((OCCUPATION? OR WORKPLACE? OR WORKER?) AND EXPOS?); L11 QUE (ORAL OR ORALLY OR INGEST? OR GAVAGE? OR DIET OR DIETS OR DIETARY OR DRINKING(W)WATER?); L12 QUE (MAXIMUM AND CONCENTRATION? AND (ALLOWABLE OR PERMISSIBLE)); L13 QUE (ABORT? OR ABNORMALIT? OR EMBRYO? OR CLEFT? OR FETUS?); L14 QUE (FOETUS? OR FETAL? OR FOETAL? OR FERTIL? OR MALFORM? OR OVUM?); L15 QUE (OVA OR OVARY OR PLACENTA? OR PREGNAN? OR PRENATAL?); L16 QUE (PERINATAL? OR POSTNATAL? OR REPRODUC? OR STERIL? OR TERATOGEN?); L17 QUE (SPERM OR SPERMAC? OR SPERMAG? OR SPERMATI? OR SPERMAS? OR SPERMATOB? OR SPERMATOC? OR SPERMATOG?); L18 QUE (SPERMATOI? OR SPERMATOL? OR SPERMATOR? OR SPERMATOX? OR SPERMATOZ? OR SPERMATU? OR SPERMI? OR SPERMO?); L19 QUE (NEONAT? OR NEWBORN? OR DEVELOPMENT OR DEVELOPMENTAL?); L20 QUE (ENDOCRIN? AND DISRUPT?); L21 QUE (ZYGOTE? OR CHILD OR CHILDREN OR ADOLESCEN? OR INFANT?); L22 QUE (WEAN? OR OFFSPRING OR AGE(W)FACTOR?); L23 QUE (DERMAL? OR DERMIS OR SKIN OR EPIDERM? OR CUTANEOUS?); L24 QUE (CARCINOG? OR COCARCINOG? OR CANCER? OR PRECANCER? OR NEOPLAS?); L25 QUE (TUMOR? OR TUMOUR? OR ONCOGEN? OR LYMPHOMA? OR CARCINOM?); L26 QUE (GENETOX? OR GENOTOX? OR MUTAGEN? OR GENETIC(W)TOXIC?); L27 QUE (NEPHROTOX? OR HEPATOTOX?); L28 QUE (ENDOCRIN? OR ESTROGEN? OR ANDROGEN? OR HORMON?); L29 QUE (OCCUPATION? OR WORKER? OR WORKPLACE? OR EPIDEM?); L30 QUE L5 OR L6 OR L7 OR L8 OR L9 OR L10 OR L11 OR L12 OR L13 OR L14 OR L15 OR L16 OR L17 OR L18 OR L19 OR L20 OR L21 OR L22 OR L23 OR L24 OR L25 OR L26 OR L27 OR L28 OR L29; L31 QUE (RAT OR RATS OR MOUSE OR MICE OR GUINEA(W)PIG? OR MURIDAE OR DOG OR DOGS OR RABBIT? OR HAMSTER? OR PIG OR PIGS OR SWINE OR PORCINE OR MONKEY? OR MACAQUE?); L32 QUE (MARMOSET? OR FERRET? OR GERBIL? OR RODENT? OR LAGOMORPHA OR BABOON? OR CANINE OR CAT OR CATS OR FELINE OR MURINE); L33 QUE L30 OR L31 OR L32; L34 QUE (HUMAN OR HUMANS OR HOMINIDAE OR MAMMALS OR MAMMAL? OR PRIMATES OR PRIMATE?); L35 QUE L33 OR L34; -------; L36 2390 SEA FILE=TOXCENTER L4 AND L35; L37 577 SEA FILE=TOXCENTER L36 AND MEDLINE/FS; L38 412 SEA FILE=TOXCENTER L36 AND BIOSIS/FS; L39 1328 SEA FILE=TOXCENTER L36 AND CAPLUS/FS; L40 73 SEA FILE=TOXCENTER L36 NOT (L37 OR L38 OR L39); L41 1838 DUP REM L37 L38 L40 L39 (552 DUPLICATES REMOVED) ANSWERS ‘1-1838’ FROM FILE TOXCENTER; L*** DEL 577 S L36 AND MEDLINE/FS; L*** DEL 577 S L36 AND MEDLINE/FS; L42 577 SEA FILE=TOXCENTER L41; L*** DEL 412 S L36 AND BIOSIS/FS; L*** DEL 412 S L36 AND BIOSIS/FS; L43 207 SEA FILE=TOXCENTER L41; L*** DEL 1328 S L36 AND CAPLUS/FS; L*** DEL 1328 S L36 AND CAPLUS/FS; L44 1004 SEA FILE=TOXCENTER L41; L*** DEL 73 S L36 NOT (L37 OR L38 OR L39); L*** DEL 73 S L36 NOT (L37 OR L38 OR L39); L45 50 SEA FILE=TOXCENTER L41; L46 1261 SEA FILE=TOXCENTER (L42 OR L43 OR L44 OR L45) NOT MEDLINE/FS D SCAN L46

Table B-3 Strategies to Augment the Literature Search

Source | Query and number screened when available
TSCATS via ChemView
12/2023; 10/2021 | Compounds searched: 107-13-1
NTP
12/2023 | Date limited 2020-present; “107-13-1” “Acrylonitrile” “Propenenitrile”; “vinyl cyanide”; “Cyanoethylene” “Ventox”; “Acritet” “Acrylon” “Carbacryl” “Fumigrain”
10/2021 | Limited 2010-present; “107-13-1” “Acrylonitrile” “Propenenitrile”; “Cyanoethylene” “Ventox” “vinyl cyanide”; “Acritet” “Acrylon” “Carbacryl” “Fumigrain”
04/2017 | 107-13-1 OR Acritet OR Acrylon OR Acrylonitrile OR Carbacryl OR Cyanoethylene OR Fumigrain OR Propenenitrile OR Ventox; “Vinyl cyanide”
Regulations.gov
12/2023 | Documents limited to notices, EPA or FDA; “107-13-1”; “Acrylonitrile”; “Propenenitrile”; “vinyl cyanide”
NIH RePORTER
09/2024 | Search Criteria: Fiscal Year: Active Projects Text Search: “2-Propenenitrile” OR “Acritet” OR “Acrylon” OR “Acrylonitrile” OR “Carbacryl” OR “Cyanoethylene” OR “ENT 54” OR “Fumigrain” OR “Miller’s fumigrain” OR “NCI-C50215” OR “NSC 6362” OR “Propenenitrile” OR “TL 314” OR “Ventox” OR “Vinyl cyanide” (advanced) Limit to: Project Title, Project Terms, Project Abstracts
06/2022 | Text Search: “2-Propenenitrile” OR “Acritet” OR “Acrylon” OR “Acrylonitrile” OR “Carbacryl” OR “Cyanoethylene” OR “ENT 54” OR “Fumigrain” OR “Miller’s fumigrain” OR “NCI-C50215” OR “NSC 6362” OR “Propenenitrile” OR “TL 314” OR “Ventox” OR “Vinyl cyanide” (advanced search) Limit to: Project Title, Project Terms, Project Abstracts Fiscal Year: Active Projects
Other | Includes additional reference identified throughout the assessment process, which may include studies found by tree searching; recommended by intraagency, interagency, peer, or public reviewers; or published more recently than the date of literature search(es). Additional references include those for specific regulations or guidelines and publications found by targeted searches for specific information (e.g., searches for reviews of general [not chemical-specific] mechanisms of toxicity).

The 2021 pre-public comment search results were:

- Number of records identified from PubMed, Toxline, NTRL, and TOXCENTER (after duplicate removal): 3,933
- Number of records identified from other strategies: 75
- Total number of records to undergo literature screening: 4,008

The 2023 post-public comment search results were:

- Number of records identified from PubMed, NTRL, and TOXCENTER (after duplicate removal): 806
- Number of records identified from other strategies: 47
- Total number of records to undergo literature screening: 853

### B.1.2 Literature Screening

A two-step process was used to screen the literature search to identify relevant studies on acrylonitrile during the pre- and post-public comment drafts:

- Title and abstract screen
- Full text screen

Pre-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 4,008
- Number of studies considered relevant and moved to the next step: 257

Pre-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 257
- Number of studies cited in the previous toxicological profile: 136
- Total number of studies cited in the profile: 272

A summary of the results of the pre-public literature search and screening is presented in Figure B-1.

Figure B-1 October 2021 Pre-Public Comment Literature Search Results and Screen for Acrylonitrile^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.

Post-Public Comment Title and Abstract Screen. Within the reference library, titles and abstracts were screened manually for relevance. Studies that were considered relevant (see Table B-1 for inclusion criteria) were moved to the second step of the literature screening process. Studies were excluded when the title and abstract clearly indicated that the study was not relevant to the toxicological profile.

- Number of titles and abstracts screened: 853
- Number of studies considered relevant and moved to the next step: 99

Post-Public Comment Full Text Screen. The second step in the literature screening process was a full text review of individual studies considered relevant in the title and abstract screen step. Each study was reviewed to determine whether it was relevant for inclusion in the toxicological profile.

- Number of studies undergoing full text review: 99
- Number of studies cited in the pre-public draft of the toxicological profile: 272
- Total number of studies cited in the profile: 293

A summary of the results of the post-public comment literature search and screening is presented in Figure B-2.

Figure B-2 December 2023 Post-Public Comment Literature Search Results and Screen for Acrylonitrile^*^ * The chemistry studies category includes studies pertaining to the potential for human exposure (Table B-1). The toxicology studies category includes human and animal studies of health effects as well as studies of toxicokinetics, biomarkers, and interactions with other chemicals (Table B-1). The regulatory studies category includes those studies cited in Chapter 7.