# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1–14 days), intermediate (15–364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. LOAELs for serious health effects (such as irreparable damage to the liver or kidneys, or serious birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S106-5, Atlanta, Georgia 30329-4027.

## Acrylonitrile Acute Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Acute

MRL Summary: None of the studies identifying the lowest LOAELs were considered an adequate principal study.

Rationale for Not Deriving an MRL: Sensitive targets of toxicity can be identified from the available acute-duration inhalation database: neurotoxicity, body weight, and developmental toxicity. A summary of the NOAEL and LOAEL values for these effects is presented in Table A-1.

Table A-1 Summary of NOAEL and LOAEL Values for Sensitive Targets of Acute-duration Inhalation Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (ppm) | LOAEL (ppm) | Reference
Human; 8 hours | | 4.6 | | Jakubowski et al. 1987
Human; 20–45 minutes | Irritability | | 16–100 | Wilson et al. 1948
Monkey; 4 hours | Weakness | 65 | 90 | Dudley and Neal 1942
Rat; 8 hours/day, 5 days | Unsteady gait | | 125 | Gut et al. 1985
Dog; 4 hours | Slight salivation | | 30 | Dudley and Neal 1942
Rat; 8 hours/day, 5 days | Weight loss (magnitude not reported) | | 125 (serious LOAEL) | Gut et al. 1985
Rat; 6 hours/day, GDs 6–15 | 25% decreased maternal body weight | | 40 (serious LOAEL) | Murray et al. 1978
Rat; 6 hours/day, GDs 6–15 | Increased total number of malformations | 40 | 80 | Murray et al. 1978

GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

The inhalation database was not considered suitable for derivation of an acute-duration inhalation MRL. Although two human studies evaluated possible neurological effects, they were considered inadequate principal studies. Jakubowski et al. (1987) is a toxicokinetic study, which noted that “no subjective symptoms such as headache, nausea, or general weakness” were reported; additionally, it is not ATSDR’s practice to derive an MRL based on a free-standing NOAEL. Wilson et al. (1948) is not an experiment, rather it is a note about observations of workers; a wide range of concentrations were reported, and no information was provided on whether effects were observed at all concentrations. The lowest LOAELs reported in animal studies are 30 ppm for slight salivation in dogs (Dudley and Neal 1942) and 40 ppm for decreased maternal body weight in rats (Murray et al. 1978). The Dudley and Neal (1942) study is a poorly reported study in which observations were limited to overt signs of toxicity and was not considered an adequate principal study. The Murray et al. (1978) study cannot be used as a principal study because the lowest concentration tested is a serious LOAEL.

Agency Contacts (Chemical Managers): Mohammad Shoeb

## Acrylonitrile Intermediate Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate
MRL: | 0.0008 ppm (8x10^−4^ ppm)
Critical Effect: | Hyperplasia of nasal respiratory/transitional zone epithelium
Reference: | Nemec et al. 2008
Point of Departure: | BMCL_10-model average_ of 0.73 ppm (BMCL_HEC_ of 0.024 ppm)
Uncertainty Factor: | 30
LSE Graph Key: | 16
Species: | Rat

MRL Summary: An intermediate-duration inhalation MRL of 0.0008 ppm (8x10^−4^ ppm) was derived for acrylonitrile based on an increased incidence of hyperplasia of nasal respiratory/transitional zone epithelium in F1 male rats exposed to 15 ppm acrylonitrile for 6 hours/day, 5 days/week for 18 weeks in a 2-generation study (Nemec et al. 2008). The MRL is based on a model averaged benchmark concentration lower confidence limit 10% (BMCL_10-model average_) of 0.73 ppm, which was adjusted to continuous duration exposure and converted to a human equivalent concentration (BMCL_HEC_) of 0.024 ppm and divided by a total uncertainty factor of 30 (3 for extrapolation from animals to humans with dosimetric adjustments and 10 for human variability).

Selection of the Critical Effect: Four studies have evaluated the intermediate-duration toxicity of inhaled acrylonitrile. A summary of the lowest LOAEL values for adverse effects is presented in Table A-2. Exposure to ≤90 ppm resulted in respiratory, body weight, gastrointestinal, neurological, and developmental effects. Based on the available data, the respiratory tract appears to be the most sensitive target. The lowest LOAEL was 15 ppm for nasal lesions (Nemec et al. 2008). Nasal lesions (slight irritation of the nasal turbinates) were also reported in rats exposed to 80 ppm 6 hours/day, 5 days/week (NOAEL of 20 ppm) for 6 or 12 months (Quast et al. 1983).

Table A-2 Summary of Lowest LOAEL Values for Targets of Intermediateduration Inhalation Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (ppm) | LOAEL (ppm) | Reference
Rat; 18 weeks, 6 hours/day, 5 days/week | Hyperplasia of respiratory/transitional zone epithelium, squamous metaplasia, subacute inflammation in nasal cavity in F1 animals | 5 | 15 | Nemec et al. 2008
Rat; 12 months, 6 hours/day, 5 days/week | Decreased body weight gain in females (12%) | 20 | 80 | Quast et al. 1983
Rat; 12 months, 6 hours/day, 5 days/week | Gastric irritation | 20 | 80 | Quast et al. 1983
Rat; 24 weeks, 6 hours/day, 5 days/week | Decreased sensory nerve conduction velocity | | 25 | Gagnaire et al. 1998
Rat; 28 days, 2 hours/day, 6 days/week | Increased sperm aberrations | | 28 | Wang et al. 1995
Rat; 18 weeks, 6 hours/day, 5 days/week | Decreased F1 pup body weight on PNDs 14 and 21 (5.8–12.2%) | 45 | 90 | Nemec et al. 2008

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; PND = postnatal day

Selection of the Principal Study: The Nemec et al. (2008) study was selected as the principal study because it identified the lowest LOAEL for respiratory effects.

Summary of the Principal Study:

Nemec MD, Kirkpatrick DT, Sherman J, . 2008. Two-generation reproductive toxicity study of inhaled acrylonitrile vapors in CRL:CD(SD) rats. Int J Toxicol 27:11–29.

Groups of 25 male and 25 female Sprague Dawley rats were exposed to 0, 5, 15, 45, or 90 ppm acrylonitrile 6 hours/day, 7 days/week in a 2-generation study. The F0 rats were exposed for a 10-week premating period, during the 2 weeks of mating, 3 weeks of gestation (no exposure from GD 21 to PND 4), and 3 weeks of lactation; the F1 rats were similarly exposed beginning at 4 weeks of age. Exposure of F1 rats to 90 ppm was terminated after 16–29 exposures due to excessive toxicity. The following parameters were used to assess toxicity: body weight, parenteral food consumption, estrous cyclicity, number of stillborn and live pups, external malformations, pup body weight, plasma and red blood cell cholinesterase (10 rats/group in F0 control and 90 ppm groups and 10 rat/pup in F1 control and 5, 15, and 45 ppm groups), sperm parameters in F0 and F1 males, organ weights, and histopathology of adrenal glands, prostate, brain, pituitary, male and female reproductive tissues, lungs, and nasal cavity (0, 5, 15, and 45 ppm groups only) in F0 and F1 rats.

No compound-related deaths were noted. Signs of irritation (clear/red material around the nose, eyes, and mouth and on forelimbs) were observed in the F0 rats exposed to 90 ppm. Significant decreases in body weight gain were observed in the F0 rats exposed to 45 or 90 ppm, up to 11.8% at 90 ppm, and <10% at 45 ppm in males and at 45 and 90 ppm in females. A decrease in food consumption was also observed at these concentrations. In the F1 adults, clinical signs of toxicity (sensitivity to touch, vocalization upon handling, and evidence of local irritation), 10–15% decrease in food consumption, and decreases in body weight gain (>20% in males and 12% in females) were observed at 90 ppm. Significant decreases in body weight gain were also observed at 45 ppm but were <10%. No compound-related alterations in estrous cycle lengths, mating, gestation length, or reproductive performance were observed in the F0 or F1 rats. Slight, but statistically significant, decreases in sperm motility and percentage of progressive sperm motility were observed in the F0 male rats; the investigators noted that the values were within the range of historical controls and were not considered compound related. No significant alterations were noted in the numbers of F1 and F2 pups born, live litter sizes, or sex ratios, and postnatal survival was not affected. A slight increase in male anogenital distance was observed in F1 weanlings in the 45 and 90 ppm groups, but not in F2 pups in the 45 ppm group. Given that there are no mechanisms for increasing male anogenital distance and the effect was not observed in the F2 rats, the alteration was not considered compound-related. Significant decreases in F1 pup body weight were observed at 90 ppm on PNDs 14 and 21; the magnitudes of the decreases were 6.6–12.2% for males and 5.8–10.7% in females. Slight delays in sexual development landmarks were also observed in these animals, but this was considered secondary to the decrease in body weight. In the F2 pups, decreases in male body weight were found in the 5, 15, and 45 ppm groups on PND 28; however, the changes were not dose-related and were within historical controls.

A significant decrease (40%) in plasma cholinesterase was observed in the F0 females exposed to 90 ppm, but not in males. The investigators did not consider this to be toxicologically significant in the absence of a corresponding change in red blood cell cholinesterase levels or clinical observed functional deficits. Significant alterations in organ weights were limited to an increase in absolute liver weights in F0 males at 90 ppm and decreased absolute pituitary gland weight in F0 females at 90 ppm. Histological alterations were observed in the nasal cavity and included transitional zone epithelium in F0 males at 45 ppm, F1 males at 15 and 45 ppm, and F1 females at 15 and 45 ppm; squamous metaplasia in F1 males at 15 and 45 ppm and F1 females at 15 ppm; subacute inflammation in F1 males at 15 and 45 ppm and F1 females at 15 ppm; and degeneration of the olfactory epithelium in F0 males and females at 45 ppm and F1 males and females at 45 ppm.

Selection of the Point of Departure for the MRL: The BMCL_10_ is 0.80 ppm for hyperplasia of the respiratory/transitional zone epithelium in F1 male rats estimated using Bayesian model averaging was selected as the point of departure (POD) for the MRL.

A benchmark dose (BMD) approach was used to identify a potential POD for derivation of the intermediate-duration inhalation MRL for acrylonitrile. The incidence data for hyperplasia of respiratory/transitional zone epithelium, squamous metaplasia, and subacute inflammation of the nasal cavity of the F1 rats were amenable to BMD modeling. The incidence data (Table A-3) were fit to all available dichotomous models in EPA’s Benchmark Dose Software (BMDS, version 3.2) with extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined benchmark response (BMR), BMCL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. A BMR of 10% extra risk was used.

Table A-3 Incidence Data of Nasal Cavity Lesions in F1 Rats Exposed to Acrylonitrile

Effect | Concentration (ppm)
Effect | 0 | 5 | 15 | 45
Males
Hyperplasia | 2/10 | 6/10 | 10/10 | 10/10
Squamous metaplasia | 0/10 | 2/10 | 8/10 | 8/10
Subacute inflammation | 2/10 | 4/10 | 9/10 | 9/10
Females
Hyperplasia | 0/10 | 0/10 | 7/10 | 9/10
Squamous metaplasia | 0/10 | 0/10 | 6/10 | 4/10
Subacute inflammation | 0/10 | 0/10 | 6/10 | 3/10
Males and females combined
Hyperplasia | 2/20 | 6/20 | 17/20 | 19/20
Squamous metaplasia | 0/20 | 2/20 | 14/20 | 12/20
Subacute inflammation | 2/20 | 4/20 | 15/20 | 12/20

Source: Nemec et al. (2008)

The modeling results for hyperplasia of respiratory/transitional zone epithelium are presented in Table A-4. The Dichotomous Hill, Log-Logistic, Logistic, Log-Probit, and Probit models provided adequate fit to the male incidence data using the four model-fit criteria. However, the p-values of approximately 1 and scaled residuals of 0.0 suggest that the Log-Logistic and Log-Probit models are overfit and their BMCLs are not considered for MRL derivation. The benchmark concentration (BMC) and BMCL values for the suitable models were 1.13–3.82 and 0.66–0.69 ppm, respectively. Rather than using the results of one of these models, ATSDR opted to model average the results for the Dichotomous Hill, Logistic, and Probit models using EPA’s BMDS Bayesian Model Average feature and using equal prior weights (33.33%) as recommended by EPA (2020b). (See Section Other Additional Studies or Pertinent Information that Lend Support to this MRL for additional information on the model averaging). Using model averaging, the posterior probabilities were 0.029, 0.326, and 0.643 for the Dichotomous Hill, Logistic, and Probit models, respectively.

Although the female incidence data provided adequate fit for three of the criteria, it did not provide adequate visual fit. For the male and female combined incidence data, the Log-Logistic model had the lowest Akaike Information Criterion (AIC) estimated BMC and BMCL values of 2.87 and 1.11 ppm, respectively.

Table A-4 Results from BMD Analysis of Incidence of Hyperplasia of Respiratory/Transitional Zone Epithelium in F1 Rats Exposed to Acrylonitrile in a 2-Generation Study (Nemec et al. 2008)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-value^b^ | AIC | Concentration below BMC^d^ | Concentration above BMC^d^
Males
Dichotomous Hill | 3.82 | 0.66 | 0.975 | 29.47 | 0.00 | 0.00
Gamma^d^ | | | 1.000 | 27.47 | 0.00 | 0.00
Log-Logistic^e^ | | | 1.000 | 27.47 | 0.00 | 0.00
Multistage Degree 3^f^ | | | NA | 31.47 | 0.00 | 0.00
Multistage Degree 2^f^ | | | 0.992 | 27.50 | 0.02 | 0.02
Multistage Degree 1^f^ | | | 0.642 | 28.76 | 0.14 | 0.14
Weibull^d^ | | | 0.999 | 27.47 | 0.00 | 0.00
Logistic | 1.17 | 0.68 | 0.922 | 27.73 | 0.16 | 0.16
Log-Probit | | | 1.000 | 29.47 | 0.00 | 0.00
Probit | 1.13 | 0.69 | 0.969 | 27.57 | 0.10 | 0.10
Bayesian Model average ^g^ | 1.28 | 0.73
Males and females combined
Dichotomous Hill | | | NA | 70.29 | 3.31x10^−8^ | -1.24x10^−7^
Gamma^d^ | | | 0.088 | 71.13 | 0.113 | 0.113
Log-Logistic ^e^ ^,^ ^g^ | 2.87 | 1.11 | 0.339 | 69.12 | -0.297 | 0.0815
Multistage Degree 3^f^ | 1.29 | 0.919 | 0.244 | 69.16 | 0.148 | 0.148
Multistage Degree 2^f^ | 1.29 | 0.919 | 0.244 | 69.16 | 0.148 | 0.148
Multistage Degree 1^f^ | 1.29 | 0.919 | 0.244 | 69.16 | 0.148 | 0.148
Weibull^d^ | 1.29 | 0.919 | 0.244 | 69.16 | 0.148 | 0.148
Logistic | | | 0.000 | 73.15 | -0.226 | -0.904
Log-Probit | 2.73 | 1.02 | 0.228 | 69.67 | -0.437 | 0.0905
Probit | | | 0.003 | 75.84 | -0.334 | -1.26

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMCLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC was selected.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% extra risk); BMD = benchmark dose

The results of the BMD modeling for squamous metaplasia are presented in Table A-5. In male rats, the Gamma, Multistage 2, and Weibull models were recommended because they identified the lowest AIC. These models estimated a BMC and BMCL of 1.93 and 1.27 ppm, respectively. In female rats, the lowest AIC was identified for the Dichotomous Hill model with an estimated BMC of 8.23 ppm and BMCL of 4.75 ppm. For males and females combined, the BMC and BMCL values are 5.00 and 3.41 ppm, respectively, estimated using the dichotomous model, which had the lowest AIC.

Table A-5 Results from BMD Analysis of Incidence of Squamous Metaplasia in F1 Rats Exposed to Acrylonitrile in a 2-Generation Study (Nemec et al. 2008)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Concentration below BMC^d^ | Concentration above BMC^d^
Males
Dichotomous Hill | | | NA | 38.02 | 0.00 | 0.00
Gamma ^d^ ^,^ ^e^ | 1.93 | 1.27 | 0.250 | 35.93 | 0.00 | 0.00
Log-Logistic^f^ | 1.94 | 0.55 | 0.332 | 36.27 | 0.00 | 0.00
Multistage Degree 3^g^ | 1.93 | 1.27 | 0.250 | 35.93 | 0.00 | 0.00
Multistage Degree 2 ^g^ | 1.93 | 1.27 | 0.250 | 35.93 | 0.00 | 0.00
Multistage Degree 1^g^ | 1.93 | 1.27 | 0.128 | 37.93 | 0.00 | 0.00
Weibull ^d^ | 1.93 | 1.27 | 0.250 | 35.93 | 0.00 | 0.00
Logistic | | | 0.011 | 44.71 | -0.41 | -1.50
Log-Probit | | | 0.127 | 38.44 | 0.00 | 0.00
Probit | | | 0.011 | 44.85 | -0.38 | -1.49
Females
Dichotomous Hill ^e^ | 8.23 | 4.75 | 0.663 | 31.75 | -0.07 | 0.00
Gamma^d^ | | | 0.013 | 39.58 | -1.03 | 0.00
Log-Logistic^f^ | | | 0.081 | 36.49 | -1.21 | 0.00
Multistage Degree 3^g^ | | | 0.034 | 37.58 | -1.03 | 0.00
Multistage Degree 2^g^ | | | 0.034 | 37.58 | -1.03 | 0.00
Multistage Degree 1^g^ | | | 0.013 | 39.58 | -1.03 | 0.00
Weibull^d^ | | | 0.034 | 37.58 | -1.03 | 0.00
Logistic | | | 0.002 | 44.19 | 2.96 | -1.19
Log-Probit | | | 0.011 | 40.22 | -1.22 | 0.00
Probit | | | 0.002 | 43.90 | 2.98 | -1.12
Males and females combined
Dichotomous Hill ^e^ | 5.00 | 3.41 | 0.507 | 70.80 | 0.00 | 0.00
Gamma^d^ | | | 0.008 | 77.67 | -0.65 | 0.00
Log-Logistic ^e^ ^,^ ^f^ | | | 0.021 | 76.39 | 0.00 | 0.00
Multistage Degree 3^g^ | | | 0.008 | 77.67 | -0.65 | 0.00
Multistage Degree 2^g^ | | | 0.008 | 77.67 | -0.65 | 0.00
Multistage Degree 1^g^ | | | 0.008 | 77.67 | -0.65 | 0.00
Weibull^d^ | | | 0.008 | 77.67 | -0.65 | 0.00
Logistic | | | <0.0001 | 90.86 | -1.17 | -1.97
Log-Probit | | | 0.006 | 78.29 | 0.00 | 0.00
Probit | | | <0.0001 | 90.39 | -1.09 | -1.89

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Recommended model(s). BMDLs for models providing adequate fit differed by <3-fold; the model(s) with the lowest AIC was selected. For male rats, the Gamma, Multistage 2, and Weibull models were recommended because they identified the lowest AIC. For female rats and combined males and females, the Dichotomous Hill model was the only model providing adequate fit.

f Slope restricted to ≥1.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% extra risk); BMD = benchmark dose

All of the models providing adequate fit to the subacute inflammation male data (Gamma; Multistage 1, 2, and 3; and Weibull models) resulted in the same BMC and BMCL values of 1.50 and 0.89 ppm, respectively (Table A-6). The incidence data in females only provided fit using the dichotomous model. However, the visual fit for this model was considered poor. None of the models provided adequate fit for the male and female combined data for subacute inflammation.

Table A-6 Results from BMD Analysis of Incidence of Subacute Inflammation in F1 Rats Exposed to Acrylonitrile in a 2-Generation Study (Nemec et al. 2008)

Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Scaled residuals^c^
Model | BMC_10_^a^ (ppm) | BMCL_10_^a^ (ppm) | p-Value^b^ | AIC | Concentration below BMC^d^ | Concentration above BMC^d^
Males
Dichotomous Hill | | | NA | 44.47 | 0.00 | 0.00
Gamma ^d^ ^,^ ^e^ | 1.50 | 0.89 | 0.224 | 43.34 | -0.11 | -0.11
Log-Logistic^,f^ | | | 0.221 | 43.97 | 0.10 | 0.10
Multistage Degree 3 ^g^ | 1.50 | 0.89 | 0.224 | 43.34 | -0.11 | -0.11
Multistage Degree 2 ^g^ | 1.50 | 0.89 | 0.224 | 43.34 | -0.11 | -0.11
Multistage Degree 1 ^g^ | 1.50 | 0.89 | 0.224 | 43.34 | -0.11 | -0.11
Weibull ^d^ | 1.50 | 0.89 | 0.224 | 43.34 | -0.11 | -0.11
Logistic | | | 0.074 | 45.45 | -0.23 | -0.83
Log-Probit | | | 0.197 | 44.22 | 0.08 | 0.08
Probit | | | 0.074 | 46.14 | -0.25 | -0.97

a BMC and BMCL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMC.

d Power restricted to ≥1.

e Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the models with the lowest AIC were selected (Gamma, Multistage 1, 2, and 3, and Weibull models).

f Slope restricted to ≥1.

g Betas restricted to ≥0.

AIC = Akaike Information Criterion; BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% extra risk); BMD = benchmark dose

BMD modeling was also conducted for the altered nerve conduction velocity observed in the Gagnaire et al. (1998) study. The BMCL for sensory nerve conduction velocity was at least 10 times higher than the BMCL for hyperplasia in the nasal cavity; no models provided adequate fit for the amplitude of the sensory action potential data or motor nerve conduction velocity.

The potential PODs for the nasal lesions are presented in Table A-7.

Table A-7 Potential Points of Departure for Intermediate-Duration Inhalation MRL for Acrylonitrile

Endpoint | BMC (ppm) | BMCL (ppm)
Hyperplasia of respiratory/ transitional zone epithelium in males | 1.27 | 0.73
Hyperplasia of respiratory/ transitional zone epithelium in males and females | 2.87 | 1.11
Squamous metaplasia in males | 1.93 | 1.27
Squamous metaplasia in females | 8.23 | 4.75
Squamous metaplasia in males and females | 5.00 | 3.41
Subacute inflammation in males | 1.50 | 0.89

BMC = maximum likelihood estimate of the exposure concentration associated with the selected benchmark response; BMCL = 95% lower confidence limit on the BMC

The lowest BMCL is 0.73 ppm for hyperplasia of the respiratory/transitional zone epithelium in F1 male rats estimated using the Bayesian model average of the frequentist, restricted Dichotomous Hill, Logistic, and Probit models; this was selected as the POD for the MRL. The fit of the Bayesian Model Averaging models is illustrated in Figures A-1, A-2, and A-3.

Figure A-1 Model Averaging Estimated Probabilities for Hyperplasia of Respiratory/Transitional Zone Epithelium in F1 Male Rats Exposed to Acrylonitrile via Inhalation

Calculations

Adjustment for Intermittent Exposure: The BMCL_10-model average_ of 0.73 ppm was adjusted from intermittent exposure to account for a continuous exposure scenario:

BMCL_ADJ_ = BMCL_10_ of 0.73 ppm × ( 6 hours / 24 hours ) × ( 5 days / 7 days ) = 0.13 ppm

Human Equivalent Concentration: A HEC was calculated by multiplying the duration adjusted BMCL_ADJ_ by the regional gas dose ratio (RGDR). The RGDR for extrathoracic respiratory tract effects was calculated using the following equation:

RDGR_ET_ = ([V_E_ / SA_ET_]_A_) / ([V_E_ / SA_ET_]_H_)

Where:

- V_E_ is the minute volume and SA_ET_ is the surface area of the extrathoracic (ET) region of the respiratory tract.
- Minute volume (V_E_)
  - Human: 13.8 L/minute (EPA 1994a)
  - Rat: 0.190 L/minute; calculated using the following EPA equation:
    ln (V_E_) = b_0_ + b_1_ ln ( BW )
  - For rats, b_0_ equals −0.578 and b_1_ equals 0.821.
  ○ Because limited body weight data were reported in the study, a reference body weight of 0.267 kg (EPA 1988) was used.
- EPA (1994a) rat and human respiratory surface area reference values for the extrathoracic region:
  - Human: 200 cm^2^
  - Rat: 15.0 cm^2^

BMCL_HEC-model average_ = BMCL_ADJ_ × RGDR_ET_ BMCL_HEC-model average_ = 0.13 ppm × 0.184 = 0.024 ppm

Uncertainty Factors: The BMCL_HEC-model average_ is divided by a total uncertainty factor (UF) of 30:

- 3 UF for extrapolation from animals to humans with dosimetric adjustments
- 10 UF for human variability

MRL = BMCL_HEC-model average_ ÷ UFs 0.024 ppm ÷ ( 3 × 10 ) = 0.0008 ppm (8 × 10^− 4^ ppm)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Selection of nasal lesions in rats as the critical effect is support by studies in humans which reported nose irritation (Simons et al. 2016; Wilson 1944; Wilson et al. 1948).

EPA’s BMDS (version 3.2) includes a model-averaging solution for dichotomous incidence data of the type reported here by Nemec et al. (2008). Their implementation uses Bayesian equivalents of the frequentist models. Through a Laplacian approximation, a model-average is calculated based on a distribution of solutions from the models selected by the assessor. Discussion and recommendations for using BMD averaging are available in Wheeler et al. (2020), EPA (2020b), and Hardy et al. (2017).

Agency Contacts (Chemical Managers): Mohammad Shoeb

## Acrylonitrile Chronic Inhalation

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: The database was not considered adequate for derivation of a chronic-duration inhalation MRL for acrylonitrile. Three studies evaluated acrylonitrile toxicity in workers; the highest average exposure level of 14.1 ppm was considered a NOAEL. Because these studies identified a free-standing NOAEL, they cannot be used as the basis of an MRL. In the only chronic-duration study examining noncancer endpoints, death was observed at the lowest concentration tested and thus, the study cannot be used as the basis of an MRL.

Rationale for Not Deriving an MRL: Three studies evaluated workers at six to seven acrylic fiber manufacturing facilities in Japan (Kaneko and Omae 1992; Muto et al. 1992; Sakurai et al. 1978). The evaluation consisted of a symptom questionnaire (Kaneko and Omae 1992) or a medical examination that included a physical examination and measurement of hematological and serum clinical chemistry parameters (Muto et al. 1992; Sakurai et al. 1978). At the time of the studies, the average acrylonitrile exposure levels were ≤14.1 ppm. Increases in the prevalence of upper respiratory tract and conjunctival irritation were observed in workers at one facility; however, the investigators suggested that these effects were likely caused by exposure to high levels of acrylonitrile due to the lack of relationship with the duration of employment (Kaneko and Omae 1992) and was only found at one facility (Muto et al. 1992; Sakurai et al. 1978). No dose-related alterations in serum clinical chemistry or hematological parameters or in the physical examination results were found. These data suggest a NOAEL of 14.1 ppm.

Three studies have evaluated the chronic toxicity of inhaled acrylonitrile in laboratory animals (Maltoni et al. 1977, 1988; Quast et al. 1980a). The Maltoni et al. (1977, 1988) studies primarily focused on the carcinogenic potential of acrylonitrile. Quast et al. (1980a) reported death and glial cell tumors at the lowest concentration tested (20 ppm) and decreased body weight, nasal mucosal irritation, and focal gliosis at 80 ppm. Because death was observed at the lowest concentration, this study was not considered suitable for derivation of an MRL.

Agency Contacts (Chemical Managers): Mohammad Shoeb

## Acrylonitrile Acute Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Acute
MRL: | 0.09 mg/kg/day
Critical Effect: | Total fetal malformations
Reference: | Murray et al. 1978
Point of Departure: | BMDL_05-model average_ of 9.27 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 3
Species: | Rat

MRL Summary: An acute-duration oral MRL of 0.09 mg/kg/day was derived for acrylonitrile based on an increased incidence litters with malformations in rats administered acrylonitrile via gavage on GDs 6–15 (Murray et al. 1978). The MRL is based on a BMDL_05-model average_ of 9.27 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Several adverse effects have been reported in rats and mice following acute-duration oral exposure. The most sensitive effects appear to be neurological, specifically cholinomimetic effects and those characteristic of cyanide poisoning, forestomach thickening, and developmental toxicity. Other affected targets include body weight and hematological system. A summary of the endpoints and NOAEL/LOAEL values are presented in Table A-8.

Table A-8 Summary of Adverse Health Effects Following Acute-duration Oral Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Rat, GDs 6–15 (gavage) | Hyperexcitability and excessive salivation in dams | 25 | 65 | Murray et al. 1978
Rat, GDs 6–15 (gavage) | Decreased maternal body weight gain | 25 | 65 | Murray et al. 1978
Rat, GDs 6–15 (gavage) | Thickening of the non-glandular stomach | 25 | 65 | Murray et al. 1978
Rat, GDs 6–15 (gavage) | Decreased fetal body weight and increased incidence of short tail, short trunk, and missing vertebrae, and total malformations | 25 | 65 | Murray et al. 1978
Rat, once (gavage) | Decreased hematocrit, mean cell hemoglobin, and platelet counts | | 80 | Farooqui and Ahmed 1983
Rat, GD 10 (gavage) | Maternal weight loss | | 100 (serious LOAEL) | Saillenfait and Sabate 2000
Rat, GD 10 (gavage) | Abnormal or poor development and allantois, trunk and caudal extremity misdirected | | 100 | Saillenfait and Sabate 2000

CNS = central nervous system; GD = gestation day; LOAEL = lowest-observed-adverse-effect level; NOAEL = noobserved-adverse-effect level

The lowest LOAEL is 65 mg/kg for increased incidences of malformations, decreased fetal body weight, decreased maternal body weight, forestomach thickening, and hyperexcitability; the NOAEL for these effects is 25 mg/kg (Murray et al. 1978).

Selection of the Principal Study: The Murray et al. (1978) study was selected as the principal study because it identified the lowest LOAEL for several sensitive targets.

Summary of the Principal Study:

Murray FJ, Schwetz BA, Nitschke KD, . 1978. Teratogenicity of acrylonitrile given to rats by gavage or by inhalation. Food Cosmet Toxicol 16(6):547–551. 10.1016/s0015-6264(78)80222-3.730081

Groups of 20–38 pregnant Sprague Dawley rats were administered 0, 10, 25, or 65 mg/kg/day acrylonitrile (>99% purity) via gavage in an aqueous solution on GDs 6–15; animals were sacrificed on GD 21. The following parameters were used to assess toxicity: daily observations, body weight, food and water consumption, number of live, dead, and resorbed fetuses, fetal body weight, fetal crown rump length, and examination for external, soft tissue, and skeletal abnormalities.

Hyperexcitability and excessive salivation were observed in rats administered 65 mg/kg/day. Significant decreases in maternal body weight gain (88% on GDs 6–9 and 28% on GDs 10–15) were observed at 65 mg/kg/day. Significant decreases in food consumption were observed at 25 and 65 mg/kg/day. Thickening of the non-glandular portion of the stomach was observed in the majority of rats at the high dose and in three rats at 25 mg/kg/day. A significant increase in absolute liver weight (no effect on relative liver weight) was observed at 65 mg/kg/day. A significant decrease in the incidence of pregnancy was observed at 65 mg/kg/day. No alterations in numbers of live fetus/litter or resorptions/litter were observed. Significant decreases in fetal body weight (7%) and fetal crown-rump length (1.8%) were observed at 65 mg/kg/day. Increases in the incidences of short tails, short trunk, and missing vertebrae and total malformations were observed at 65 mg/kg/day. Some increases in malformations (short tail and missing vertebrae) were also observed at 25 mg/kg/day, but the incidence was not significantly different than controls. Sialodacryadenitis was observed in most animals in all groups, including the controls; the investigators noted that it was unlikely that this infection significantly affected the outcome since it occurred in all groups and the findings in the control group were similar to past control groups.

Selection of the Point of Departure for the MRL: The BMDL_05_ of 8.89 mg/kg/day for increased incidence of litter with malformations was selected as the POD for the MRL.

A BMD approach was used to identify a potential POD for derivation of the acute-duration oral MRL for acrylonitrile. The incidence data for litters with short tail, short trunk, and missing vertebrae and for total malformations were amenable to BMD modeling. The incidence data for malformations (Table A-9) were fit to all available dichotomous models in EPA’s BMDS (version 3.2) with extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined BMR, BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. A BMR of 5% extra risk was used. Fetal body weight data were not amenable to BMD modeling because the number of fetuses per group was not reported. Maternal body weight data were modeled using all available continuous models in EPA’s BMDS (version 3.2) using the data summarized in Table A-9. Adequate model fit criteria were the same as used for the fetal malformation modeling and a BMR of 1 standard deviation (SD) was used. BMD modeling could not be conducted for forestomach lesions because incidence data were not reported for the high-dose group. It could also not be conducted for the neurological effects because incidence data were not reported.

Table A-9 Incidence Data of Fetal Malformations and Alterations in Maternal Body Weights in Rats Administered Acrylonitrile on GDs 6–15

Effect | Dose (mg/kg/day)
Effect | 0 | 10 | 25 | 65
Litters with short tail | 1/38 | 0/35 | 2/29 | 6/17
Litters with missing vertebrae | 1/38 | 0/35 | 2/29 | 6/17
Litters with short trunk | 0/38 | 0/35 | 0/29 | 3/17
Litters with malformations | 2/38 | 0/35 | 4/29 | 6/17
Maternal body weight gain (GDs 6–9)^a^ | 18±8 | 17±7 | 16±10 | 2±9
Maternal body weight gain (GDs 10–15)^a^ | 43±11 | 42±11 | 39±12 | 31±12

a Mean (g)±standard deviation; number of dams: 43, 39, 33, and 29 for the 0, 10, 25, and 65 mg/kg/day groups, respectively.

Source: Murray et al. 1978

The modeling results for litters with fetus with short tails and litters with fetuses with missing vertebrae were the same since missing vertebrae were only observed in fetuses with short tails. The results of the BMD modeling are presented in Table A-10. All models, with the exception of the Dichotomous Hill model, provided adequate fit to the incidence data. The BMDLs were within a factor of 3; thus, the Multistage 2 Degree model was selected since it had the lowest AIC; this model estimated a BMD_05_ of 23.42 mg/kg/day and a BMDL_05_ of 13.11 mg/kg/day.

Table A-10 Results from BMD Analysis of Incidence of Litters with Short Tails and Missing Vertebrae in Rats Administered Acrylonitrile on GDs 6–15 (Murray et al. 1978)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Dichotomous Hill | | | NA | 55.20 | 0.00 | 0.67
Gamma^d^ | 26.59 | 14.09 | 0.302 | 53.51 | 0.28 | 0.58
Log-Logistic^e^ | 26.76 | 14.01 | 0.295 | 53.57 | 0.29 | 0.58
Multistage Degree 3^f^ | 27.58 | 13.41 | 0.282 | 53.68 | 0.34 | 0.56
Multistage Degree 2 ^f^ ^,^ ^g^ | 23.42 | 13.11 | 0.526 | 51.87 | -0.02 | 0.66
Multistage Degree 1^f^ | 13.46 | 7.64 | 0.126 | 55.59 | -1.36 | 0.68
Weibull^d^ | 27.26 | 13.81 | 0.289 | 53.62 | 0.33 | 0.56
Logistic | 27.74 | 19.59 | 0.496 | 52.04 | 0.34 | 0.65
Log-Probit | 53.94 | 11.22 | 0.103 | 55.14 | 0.00 | -0.11
Probit | 24.92 | 17.51 | 0.455 | 52.13 | 0.17 | 0.82

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (Multistage 2 Degree model) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _05_ = exposure dose associated with a 5% extra risk)

The BMD modeling results for number of litters with fetus having short trunks are presented in Table A-11. The Multistage 1 Degree and Multistage 2 Degree models provided adequate fit to the incidence data. The other models appeared to overfit the incidence data as evidenced by p-values of >0.95. The Multistage 2 Degree model had the lowest AIC for the models with adequate fit and was selected; BMD and BMDL values of 38.56 and 23.88 mg/kg/day, respectively, were estimated with this model.

Table A-11 Results from BMD Analysis of Incidence of Litters with Short Trunks in Rats Administered Acrylonitrile on GDs 6–15 (Murray et al. 1978)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Dichotomous Hill | | | 1.000 | 19.84 | 0.00 | 0.00
Gamma^d^ | | | 1.000 | 17.84 | 0.00 | 0.00
Log-Logistic^e^ | | | 1.000 | 17.84 | 0.00 | 0.00
Multistage Degree 3^f^ | | | 0.987 | 16.50 | -0.54 | 0.00
Multistage Degree 2 ^f^ ^,^ ^g^ | 38.56 | 23.88 | 0.802 | 19.56 | -0.80 | 0.00
Multistage Degree 1^f^ | 35.58 | 15.66 | 0.369 | 22.21 | -1.03 | 0.00
Weibull^d^ | | | 1.000 | 19.84 | 0.00 | 0.00
Logistic | | | 1.000 | 17.84 | 0.00 | 0.00
Log-Probit | | | 1.000 | 19.84 | 0.00 | 0.00
Probit | | | 1.000 | 19.84 | 0.00 | 0.00

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (Multistage 2 Degree model) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _05_ = exposure dose associated with a 5% extra risk)

The BMD modeling results for number of litters with malformations are presented in Table A-12. All models, with the exception of the Dichotomous Hill model, provided adequate fit to the incidence data. The Multistage 2 Degree model had the lowest AIC for the models with adequate fit. Rather than using the results of one of these models, ATSDR opted to model average the results for all models using EPA’s BMDS Bayesian Model Average feature and using equal prior weights as recommended by EPA (2020b). Using model averaging, the posterior probabilities were 0.15, 0.09, 0.11, 0.13,0.07,0.08, 0.28, and 0.077 for the Dichotomous Hill, Gamma, Logistic, Log-Logistic, Log-Probit, Multistage, Probit, and Weibull models, respectively. The BMD_05-model average_ was 19.77 mg/kg/day and the BMDL_05-model average_ was 9.27 mg/kg/day.

Table A-12 Results from BMD Analysis of Incidence of Litters Malformations in Rats Administered Acrylonitrile on GDs 6–15 (Murray et al. 1978)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Dichotomous Hill | 23.55 | 12.25 | 0.169 | 69.68 | 0.00 | 0.95
Gamma^d^ | 21.24 | 9.33 | 0.107 | 70.93 | 0.70 | 0.73
Log-Logistic^e^ | 20.91 | 9.35 | 0.107 | 70.97 | 0.68 | 0.74
Multistage Degree 3^f^ | 22.13 | 8.89 | 0.255 | 69.11 | 0.81 | 0.68
Multistage Degree 2 ^f^ ^,^ ^g^ | 22.13 | 8.92 | 0.255 | 69.11 | 0.81 | 0.68
Multistage Degree 1^f^ | 11.51 | 6.62 | 0.139 | 71.33 | -1.65 | 0.82
Weibull^d^ | 21.23 | 8.97 | 0.102 | 71.10 | 0.73 | 0.71
Logistic | 21.77 | 15.54 | 0.224 | 69.66 | 0.83 | 0.64
Log-Probit | 20.49 | 10.34 | 0.124 | 70.56 | 0.57 | 0.79
Probit | 19.68 | 13.99 | 0.226 | 69.62 | 0.70 | 0.78
Bayesian model average | 19.77 | 9.27

a BMD and BMDL values for models that do not provide adequate fit are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (Multistage 3 Degree model) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _05_ = exposure dose associated with a 5% extra risk)

The BMD modeling results for maternal body weight gain on GDs 6–9 are presented in Table A-13. The Exponential 3, Exponential 5, Polynomial 3 Degree, Polynomial 2 Degree, and Power models, all with constant variance, provided adequate fit. The Power model was selected since it had the lowest AIC; the model estimated a BMD_1SD_ of 49.15 mg/kg/day and a BMDL_1SD_ of 36.45 mg/kg/day.

Table A-13 Results from BMD Analysis of Maternal Body Weight Gain on GDs 6– 9 in Rats Administered Acrylonitrile on GDs 6–15 (Murray et al. 1978)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Constant Variance
Exponential 2^d^ | | | 0.001 | 1,039.38 | 2.43 | -1.18
Exponential 3^d^ | 44.62 | 34.08 | 0.620 | 1,027.80 | 0.05 | 0.32
Exponential 4^d^ | | | 0.001 | 1,039.38 | 2.43 | -1.18
Exponential 5^d^ | 44.64 | 34.08 | 0.620 | 1,027.80 | 0.04 | 0.32
Hill^d^ | | | NA | 1,029.84 | 0.00 | 0.37
Polynomial Degree 3^d^ | 50.18 | 37.04 | 0.789 | 1,027.62 | -0.01 | 0.12
Polynomial Degree 2^d^ | 47.24 | 36.61 | 0.881 | 1,025.80 | -0.04 | 0.10
Power ^d^ ^,^ ^e^ | 49.15 | 36.45 | 0.667 | 1,027.73 | -0.01 | 0.25
Linear | | | 0.064 | 1,031.06 | 1.90 | -1.08

a Values <0.1 fail to meet adequate fit.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (Power 2 Degree model) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _05_ = exposure dose associated with a 5% extra risk)

The BMD modeling results for maternal body weight gain on GDs 10–15 are presented in Table A-14. All of the constant variance models except the Exponential 5 and Hill models provided adequate fit. The range of BMDLs were <3; thus, the model with the lowest AIC, the Linear model, was selected. The Linear model estimated a BMD_1SD_ and a BMDL_1SD_ of 59.88 and 44.00 mg/kg/day, respectively.

Table A-14 Results from BMD Analysis of Maternal Body Weight Gain on GDs 10–15 in Rats Administered Acrylonitrile on GDs 6–15 (Murray et al. 1978)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Constant Variance
Exponential 2^d^ | 59.49 | 40.94 | 0.846 | 1,112.80 | -0.21 | -0.36
Exponential 3^d^ | 60.96 | 41.77 | 0.900 | 1,114.48 | 0.01 | -0.04
Exponential 4^d^ | 59.49 | 40.94 | 0.846 | 1,112.80 | -0.21 | -0.36
Exponential 5^d^ | | | NA | 1,116.47 | 0.00 | 0.00
Hill^d^ | | | NA | 1,116.47 | 0.00 | 0.00
Polynomial Degree 3^d^ | 61.17 | 44.23 | 0.824 | 1,114.52 | 0.01 | -0.09
Polynomial Degree 2^d^ | 61.17 | 44.23 | 0.824 | 1,114.52 | 0.01 | -0.09
Power^d^ | 61.16 | 44.27 | 0.868 | 1,114.50 | 0.02 | -0.05
Linear ^e^ | 59.88 | 44.00 | 0.926 | 1,112.62 | -0.10 | -0.26

a Values <0.1 fail to meet adequate fit.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Restricted model.

e Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC (Linear model) was selected.

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _05_ = exposure dose associated with a 5% extra risk)

The potential PODs for the maternal and fetal effects are presented in Table A-15.

Table A-15 Potential Points of Departure for the Acute-duration Oral MRL for Acrylonitrile

Endpoint | BMD (mg/kg/day) | BMDL (mg/kg/day)
Increased incidence of litters with fetuses with short tails and litters with missing vertebrae | 23.42 | 13.11
Increased incidence of litters with fetuses with short trunks | 38.56 | 23.88
Increased incidence of litters with malformations | 19.77 | 9.27
Decreased maternal weight gain on GDs 6–9 | 49.15 | 36.45
Decreased maternal weight gain on GDs 10–15 | 59.88 | 44.00

BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD; GD = gestation day

The lowest BMDL is 9.27 mg/kg/day for increased incidence of litters with malformations estimated using Bayesian Model Averaging was selected as the POD for the acute-duration oral MRL. The model average probabilities are illustrated in Figure A-2. The BMDL_05-model average_ of 9.27 mg/kg/day is lower than the NOAEL of 25 mg/kg/day for decreased fetal body weight and forestomach lesions.

Figure A-2 Model Averaging Estimated Probabilities for Incidence of Litters with Fetal Malformations in Rats Administered Acrylonitrile on GDs 6–15

Uncertainty Factors: The BMDL_05-model average_ is divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

MRL = BMDL_05 -model average_ ÷ UFs 9.27 mg / kg / day ÷ ( 10 × 10 ) = 0.0927 mg / kg / day ≈ 0.09 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Developmental toxicity has also been observed in a study conducted by Saillenfait and Sabate (2000), which found abnormal or poor development and allantois, and misdirected trunk and caudal extremities in the embryos of rats administered acrylonitrile via gavage on GD 10. An inhalation study also conducted by Murray et al. (1978) reported an increase in the total number of malformations in fetuses of rats exposed to 80 ppm acrylonitrile 6 hours/day on GDs 6–15.

Agency Contacts (Chemical Managers): Mohammad Shoeb

## Acrylonitrile Intermediate Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.02 mg/kg/day
Critical Effect: | Forestomach hyperplasia
Reference: | Quast 2002
Point of Departure: | BMDL_10_ of 2.48 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 12
Species: | Rat

MRL Summary: An intermediate-duration oral MRL of 0.02 mg/kg/day was derived for acrylonitrile based on an increased incidence of forestomach hyperplasia in male rats exposed to 8.5 mg/kg/day acrylonitrile in drinking water for 1 year (Quast 2002). The MRL is based on a BMDL_10_ of 2.48 mg/kg/day and divided by a total uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

Selection of the Critical Effect: Several effects have been observed in laboratory animals orally exposed to acrylonitrile for an intermediate duration; these are listed in Table A-16 in order of ascending LOAEL values.

Table A-16 Summary of Health Effects Following Intermediate-Duration Oral Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Mouse, 14 weeks, 5 days/week (gavage) | 4.2% decreased hemoglobin level in females | | 5 | NTP 2001
Mouse, 28 days (gavage) | Impaired development of ovarian follicles | | 5 | Luo et al. 2022
Mouse, 28 days (gavage) | Decreased number of pups | | 5 (SLOAEL) | Luo et al. 2022
Rat, 1 year (water) | Squamous cell hyperplasia of the forestomach in males | 3.4 | 8.5 | Quast 2002
Mouse, 60 days (gavage) | Decreased sperm count, degeneration of seminiferous tubules | 1 | 10 | Tandon et al. 1988
Dog, 6 months (water) | Depression, lethargy, death, weight loss, esophageal ulcerations | 10 | 16 (SLOAEL) | Quast et al. 1975
Rat ,48 weeks (water) | Decreased pup viability in F1b generation | | 20 | Friedman and Beliles 2002
Rat, 12 weeks (gavage) | Decreased sperm motility and concentration | | 20 | Dang et al. 2017
Rat, 28 days (gavage) | Increased sperm head and tail alterations | | 46 | Shi et al. 2021
Rat, 12 weeks, 5 days/week (gavage) | Decreased sensory motor conduction velocity, weakness in hindlimbs, inability to rear | 25 | 50 | Gagnaire et al. 1998

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level; SLOAEL = serious lowest-observed-adverse-effect level

The lowest LOAEL is 5 mg/kg/day for hematological, reproductive, and developmental effects. A small decrease in hemoglobin levels was observed in female mice (NTP 2001); a small decrease (4.3%) in hemoglobin levels was also observed in female rats exposed to 10.9 mg/kg/day (NOAEL of 3.7 mg/kg/day) (Johannsen and Levinskas 2002a). The biological relevance of this small magnitude change in hemoglobin levels is uncertain. A 28-day exposure study found alterations in the development of ovarian follicles and decreased number of live pups were observed in mice (Luo et al. 2022). At a slightly higher dose (8.5 mg/kg/day), forestomach lesions were observed in male rats (Quast 2002). Two other studies also reported forestomach lesions (Ghanayem et al. 1997; NTP 2001). Given the uncertainty regarding the relevance of the small change in hemoglobin levels and the lack of supporting data for the reproductive and developmental effects, the forestomach hyperplasia was selected as the critical effect; the NOAEL for this effect was lower than the LOAELs for the hematological, reproductive, and developmental effects.

Selection of the Principal Study: As noted, forestomach lesions have also been observed in two other intermediate-duration studies. Squamous metaplasia of the forestomach was reported by Ghanayem et al. (1997) in rats administered 23 mg/kg/day for 6 weeks; the NOAEL was 12 mg/kg/day. Forestomach inflammation and hyperplasia were observed in female mice administered 40 mg/kg 5 days/week for 14 weeks (NTP 2001). The Quast (2002) study was selected as the principal study because it identified the lowest LOAEL for forestomach lesions.

Summary of the Principal Study:

Quast JF. 2002. Two-year toxicity and oncogenicity study with acrylonitrile incorporated in the drinking water of rats. Toxicol Lett 132:153–196.12044703

Groups of 10 male and 10 female Sprague Dawley rats were exposed to 0, 35, 100, or 300 ppm acrylonitrile in drinking water for 1 year; this is an interim sacrifice in a 2-year study. Using drinking consumption and body weight data, the investigators estimated doses of 0. 3.5, 8.5, and 21.3 mg/kg/day for males and 0. 4.4, 10.8, and 25.0 mg/kg/day for females. The following parameters were used to assess toxicity: daily clinical observations, water and food consumption, monthly body weight measurements, hematology (conducted on 10 rats/sex/group after 45, 87, 180, and 365 days in the controls and 300 ppm groups), urinalysis (in same rats as hematology), clinical chemistry (measured in 10 rats/sex/group in the controls and 300 ppm group after 46 and 365 days and in 10 rats/sex/group in all groups after 88 and 18 days), and ophthalmologic examination, organ weight (brain, heart, liver, kidneys, and testes), and gross necropsy and histopathology of major tissues and organs at 365 days.

A significant increase in mortality was observed in the 25.0 mg/kg/day females after 301 days of exposure; at 360 days, the mortality rate was 29.2% compared to 1.3% in controls. No increases in mortality were observed in males. Decreased weight gain was related to decreased food and water consumption. After 1 year of exposure, the body weight gain decrease was >10% in males at 8.5 (11%) and 21.3 (22%) mg/kg/day and in females at 25 mg/kg/day (18%). Decreased weight gain was related to decreased food and water consumption at all doses. No hematological alterations attributed to acrylonitrile exposure were found. Significant increases in urine specific gravity were observed in male and female rats exposed to 21.3/25.0 mg/kg/day; this correlated with the decreased water intake. Increases in BUN were observed at some time points; the investigators noted the change was not dose related and was within normal range and suggested that it may be secondary to the decreased water intake. No other exposure-related alterations in serum chemistry were found. Squamous cell hyperplasia was observed in males and females in the mid- and high-dose groups. The incidences were 4/10 and 10/10 in the 8.5 and 21.3 mg/kg/day males and 7/10 and 9/10 in the 10.8 and 25.0 mg/kg/day females; the incidence in controls was not reported. Benign forestomach papillomas were observed in 7/10 males and 5/10 females at 21.3/25.0 mg/kg/day. Increases in the incidence of central nervous system tumors, Zymbal gland carcinoma, mammary gland adenocarcinoma, and fibroadenoma were also observed.

Selection of the Point of Departure for the MRL: A BMDL_10_ of 2.48 mg/kg/day for forestomach hyperplasia in male rats was selected as the POD for the MRL.

A BMD approach was used to identify a potential POD for derivation of the intermediate-duration oral MRL for acrylonitrile. The incidence data for forestomach squamous cell hyperplasia in the male rats were amenable to BMD modeling. The incidence data (0/10, 0/10, 4/10, 10/10 for the 0, 3.5, 8.5, and 21.3 mg/kg/day groups, respectively) were fit to all available dichotomous models in EPA’s BMDS, (version 3.2) with extra risk. Adequate model fit was judged by four criteria: goodness-of-fit statistics (p-value >0.1), scaled residual at the data point (except the control) closest to the predefined BMR, BMDL that is not 10 times lower than the lowest non-zero dose, and visual inspection of the dose-response curve. A BMR of 10% extra risk was used.

The results of the BMD modeling are presented in Table A-17. All models except the Weibull model, provided adequate fit to the data. However, the p-values of approximately 1 and scaled residuals of 0.0 suggest that the Dichotomous Hill, Gamma, Log-Logistic, Logistic, Log-Probit, and Probit models are overfit and their BMDLs were not considered for MRL derivation. Of the remaining models, the BMDS recommended the Multistage Degree 1 model because it had the lowest BMDL (BMDLs for models providing adequate fit differed by >3-fold). Although this model met the first three criteria, the visual fit of the dose-response curve was not considered adequate. When the Multistage Degree 1 model was removed from consideration, the BMDLs for the remaining two models with adequate fit differed by <3-fold; thus, the model with the lowest AIC, the Multistage Degree 3 model, was selected; this model met all four fit criteria. The Multistage Degree 3 model estimated a BMD_10_ of 5.15 mg/kg/day and a BMDL_10_ of 2.48 mg/kg/day. The fit of the model to the incidence data is presented in Figure A-3.

Table A-17 Results from BMD Analysis of Incidence of Squamous Cell Hyperplasia in Male Rats Exposed to Acrylonitrile in Drinking Water for 1 Year (Quast 2002)

Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Scaled residuals^c^
Model | BMD_05_^a^ (mg/kg/day) | BMDL_05_^a^ (mg/kg/day) | p-value^b^ | AIC | Dose below BMD^d^ | Dose above BMD^d^
Dichotomous Hill | 7.68 | 4.20 | 1.000 | 17.46 | 0.00 | 0.00
Gamma^d^ | 6.56 | 3.76 | 0.999 | 17.47 | 0.00 | 0.00
Log-Logistic^e^ | 7.69 | 4.20 | 1.000 | 17.46 | 0.00 | 0.00
Multistage Degree 3 ^f^ ^,^ ^g^ | 5.15 | 2.48 | 0.948 | 16.16 | -0.58 | 0.00
Multistage Degree 2^f^ | 3.74 | 2.14 | 0.724 | 17.99 | -0.98 | 0.00
Multistage Degree 1^f^ | 1.35 | 0.86 | 0.123 | 25.42 | 0.00 | 0.00
Weibull^d^ | 6.48 | 3.43 | 0.999 | 15.52 | 0.03 | 0.00
Logistic | 7.63 | 4.14 | 1.000 | 15.46 | 0.00 | 0.00
Log-Probit | 7.44 | 4.06 | 1.000 | 17.46 | 0.00 | 0.00
Probit | 7.28 | 3.82 | 1.000 | 15.46 | 0.00 | 0.00

a BMD and BMDL values for models that provide adequate fit.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Betas restricted to ≥0.

g Recommended model. BMDLs for models providing adequate fit differed by <3-fold; therefore, the model with the lowest AIC and adequate visual fit was selected (Multistage Degree 3).

AIC = Akaike Information Criterion; BMD = maximum likelihood estimate of the exposure dose associated with the selected benchmark response; BMDL = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., _10_ = exposure dose associated with a 10% extra risk)

Figure A-3 Predicted (Multistage Degree 3 Model) and Observed Forestomach Hyperplasia in Male Rats Exposed to Acrylonitrile via Drinking Water

Uncertainty Factors: The BMDL_10_ is divided by a total uncertainty factor (UF) of 100:

- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

MRL = BMDL_10_ ÷ UFs 2.48 mg / kg / day ÷ ( 10 × 10 ) = 0.0248 mg / kg / day ≈ 0.02 mg / kg / day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: None

Agency Contacts (Chemical Managers): Mohammad Shoeb

## Acrylonitrile Chronic Oral

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acrylonitrile
CAS Numbers: | 107-13-1
Date: | April 2025
Profile Status: | Final
Route: | Oral
Duration: | Chronic
MRL: | 0.00009 mg/kg/day (9x10^−5^ mg/kg/day)
Critical Effect: | Increased severity of forestomach hyperplasia
Reference: | Johannsen and Levinskas 2002b
Point of Departure: | LOAEL of 0.09 mg/kg/day
Uncertainty Factor: | 1,000
LSE Graph Key: | 21
Species: | Rat

MRL Summary: A chronic-duration oral MRL of 0.00009 mg/kg/day (9x10^−5^ mg/kg/day) was derived for acrylonitrile based on an increased severity of forestomach hyperplasia in male rats exposed to 0.09 mg/kg/day acrylonitrile in drinking water for 22 months (Johannsen and Levinskas 2002b). The MRL is based on a LOAEL of 0.09 mg/kg/day and divided by a total uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability).

Selection of the Critical Effect: Six chronic-duration studies have evaluated the noncancer toxicity of acrylonitrile in laboratory animals. A summary of the lowest LOAELs for observed effects are listed in Table A-18 in order of ascending LOAEL values. The lowest LOAEL was 0.09 mg/kg/day for an increase in the severity of squamous cell hyperplasia in the forestomach identified in the Johannsen and Levinskas (2002b) 22-month study. Forestomach lesions were selected as the critical effect.

Table A-18 Summary of Health Effects Following Chronic-duration Oral Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Rat, 22 months (water) | Increased severity of squamous cell hyperplasia in forestomach in males | | 0.09 | Johannsen and Levinskas 2002b
Mouse, 2 years (gavage) | Increase in ovarian cysts | | 2.5 | NTP 2001
Rat, 2 years (water) | Gliosis and perivascular cuffing in the brain | | 4.4^a^ | Quast 2002
Rat, 26 months (water) | Epidermal inclusion cysts in males | 2.5 | 8.4 | Johannsen and Levinskas 2002a
Rat, 22 months (water) | Decreased hemoglobin and increased reticulocytes | 0.09 | 8^a^ | Johannsen and Levinskas 2002b
Rat, 20 months (gavage) | Renal transitional cell hyperplasia | 0.1 | 10^a^ | Johannsen and Levinskas 2002b

a Decreased survival reported at this dose.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Selection of the Principal Study: Five studies have reported forestomach lesions in rats and mice. A summary of the results of these studies is presented in Table A-19. The Johannsen and Levinskas (2002b) drinking water study identified the lowest LOAEL for forestomach lesions and was selected as the principal study.

Table A-19 Summary of Forestomach Lesions Following Chronic-Duration Oral Exposure to Acrylonitrile

Species, duration | Effect | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Reference
Rat, 22 months (water) | Increased severity of squamous cell hyperplasia in forestomach | | 0.09 | Johannsen and Levinskas 2002b
Rat, 23-26 months (water) | Hyperplasia and/or hyperkeratosis in forestomach | 0.1 M; 0.1 F | 0.3 M; 0.4 F | Johannsen and Levinskas 2002a
Rat, 2 years (water) | Hyperplasia/hyperkeratosis of forestomach | | 4.4^a^ | Quast 2002
Rat, 20 months (gavage) | Increased severity of squamous cell hyperplasia in forestomach | 0.1 | 10^a^ | Johannsen and Levinskas 2002b
Mouse, 2 years (gavage) | Focal epithelial hyperplasia in the forestomach | 2.5 | 10 | NTP 2001

a Decreased survival reported at this dose.

F = females; LOAEL = lowest-observed-adverse-effect level; M = males; NOAEL = no-observed-adverse-effect level

Summary of the Principal Study:

Johannsen FR and Levinskas GJ. 2002b. Comparative chronic toxicity and carcinogenicity of acrylonitrile by drinking water and oral intubation to Spartan Sprague Dawley rats. Toxicol Lett 132:197–219.12044704

Groups of 100 male and 100 female Spartan Sprague-Dawley rats were administered 0, 1, or 100 ppm acrylonitrile in drinking water for their lifetime. Interim sacrifices of 10 rats/sex/group were done at 6, 12, and 18 months. The investigators reported that the average doses for the 1 and 100 ppm groups were 0.09 and 8.0 mg/kg/day in males, respectively, and 0.15 and 10.7 mg/kg/day for females, respectively. The following parameters were used to assess toxicity: cage-side physical observations, feed and water consumption, body weights (weekly through week 14, biweekly from weeks 16 to 26, and monthly thereafter), hematology (hemoglobin, hematocrit, red blood cell count, reticulocytes, prothrombin time, total and differential white blood cell counts), serum clinical chemistry (ALT, alkaline phosphatase, BUN, fasting glucose), urinalysis (pH, protein specific gravity, glucose, ketones, bilirubin, occult blood), organ weights (brain, pituitary, adrenal, gonads, heart, kidney, liver), and histopathological examination (approximately 40 tissues and organs examined) performed at the interim and terminal sacrifices.

Significant increases in deaths were observed at 8.0/10.7 mg/kg/day after 10 months of exposure. The study was terminated early due to high mortality during month 22 in males and month 19 in females. Slight decreases in body weight were observed in males (10%) and females (8%) in the 8.0/10.7 mg/kg/day group throughout the study. Decreases in hemoglobin levels were observed in males at 8.0 mg/kg/day at all time periods; an increase in reticulocytes and decrease in leucocyte counts were observed at termination. Consistent decreases in hematocrit and erythrocytes were also observed, although they were infrequently statistically significant. No alterations in clinical chemistry or urinalysis parameters were found. Significant alterations in organ weight were limited to decreases in absolute and relative pituitary weights at 8.0/10.7 mg/kg/day at 12 months in males and at termination in females. Non-neoplastic histological alterations were limited to the forestomach, kidney, and uterus. Although no significant increase in the incidence of squamous cell hyperplasia of the forestomach was observed due to the high incidence in controls, significant increases in the incidences of moderate or severe lesions were observed in male rats exposed to 0.09 or 8.0 mg/kg/day and in males and females in the 8.0 and 10.7 mg/kg/day groups that died early or were killed due to morbidity. An increased incidence of transitional cell hyperplasia was observed at 10.7 mg/kg/day in the kidneys of female at termination. After 12 months of exposure, an increase in the incidence of squamous metaplasia was observed in the uterus of rats in the 10.7 mg/kg/day; this was not observed at later time periods. A high incidence of primary tumors was observed in males and females at 8.0/10.7 mg/kg/day. At 8.0/10.7 mg/kg/day, significant increases in the incidence of brain glial cell tumors (females only), spinal cord glial cell tumors (not examined in males), Zymbal’s gland carcinoma, and forestomach squamous cell papilloma/papilloma (females only) were observed.

Selection of the Point of Departure for the MRL: A LOAEL of 0.09 mg/kg/day for increased severity of forestomach hyperplasia in male rats was selected as the POD for the MRL.

A BMD approach was not used to identify a potential POD for derivation of the chronic-duration oral MRL for acrylonitrile because only two non-control groups were used. Thus, a NOAEL/LOAEL approach was used.

Uncertainty Factors: The LOAEL is divided by a total uncertainty factor (UF) of 1,000:

- 10 for the use of a LOAEL
- 10 UF for extrapolation from animals to humans
- 10 UF for human variability

MRL = LOAEL ÷ UFs 0.09 mg / kg / day ÷ ( 10 × 10 × 10 ) = 0.00009 mg / kg / day (9 × 10^− 5^ mg / kg / day)

Other Additional Studies or Pertinent Information that Lend Support to this MRL: None

Agency Contacts (Chemical Managers): Mohammad Shoeb