# 9 REFERENCES

* Not cited in text

Abdelmagid HM, Tabatabai MA. 1982. Decomposition of acrylamide in soils. J Environ Qual 11(4):701–704.
Abernethy DJ, Boreiko CJ. 1987. Acrylonitrile and acrylamide fail to transform C3H/10T1/2 cells. Environ Mutagen 9(Suppl 8):2.
ACGIH. 2011. Acrylamide. In: Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists, 10, 70, 71, 73.
Adinolfi M. 1985. The development of the human blood-CSF-brain barrier. Dev Med Child Neurol 27(4):532–537.4029526
Adler ID. 1990. Clastogenic effects of acrylamide in different germ-cell stages of male mice. In: Allen B, Bridges B, Lyon M, eds. Biology of mammalian germ cell mutagenesis. Cold Spring Harbor, NY: Cold Spring Harbor Laboratory Press, 115–131.
Adler ID, Baumgartner A, Gonda H, 2000. 1-Aminobenzotriazole inhibits acrylamide-induced dominant lethal effects in spermatids of male mice. Mutagenesis 15(2):133–136.10719038
Adler ID, Ingwersen I, Kliesch U, 1988. Clastogenic effects of acrylamide in mouse bone marrow cells. Mutat Res 206(3):379–385.3200258
Adler ID, Reitmeir P, Schmoller R, 1994. Dose response for heritable translocations induced by acrylamide in spermatids of mice. Mutat Res 309(2):285–291.7520986
Adler ID, Zouh R, Schmid E. 1993. Perturbation of cell division by acrylamide in vitro and in vivo. Mutat Res 301(4):249–254.7680759
Adlercreutz H. 1995. Phytoestrogens: Epidemiology and a possible role in cancer protection. Environ Health Perspect Suppl 103(7):103–112.
Agency for Toxic Substances and Disease Registry. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles; Notice. Agency for Toxic Substances and Disease Registry, Division of Toxicology. Fed Regist 54(174):37618–37634.
Ahn JS, Castle L, Clarke DB, 2002. Verification of the findings of acrylamide in heated foods. Food Addit Contam 19(12):1116–1124.12623671
AIHA. 2009. Emergency Response Planning Guidelines (ERPG). Fairfax, VA: American Industrial Hygiene Association. http://www.aiha.org/insideaiha/GuidelineDevelopment/ERPG/Documents/ERPerpglevels.pdf. August 30, 2011.
Allen B, Zeiger E, Lawrence G, 2005. Dose-response modeling of in vivo genotoxicity data for use in risk assessment: Some approaches illustrated by an analysis of acrylamide. Regul Toxicol Pharmacol 41(1):6–27.15649824
Altman PL, Dittmer DS. 1974. In: Biological handbooks: Biology data book. Vol. III. 2nd ed. Bethesda, MD: Federation of American Societies of Experimental Biology, 1987-2008, 2041.
American Cyanamid Company. 1951. Acute eye, dermal and oral toxicity. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211662. OTS206055.
American Cyanamid Company. 1953a. Inhalation toxicity supplement to reports dated May 2, 1951 and August 13, 1952. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA879211664. OTS206055.
American Cyanamid Company. 1953b. Subacute feeding section I-acrylamide section II-acrylamide with metabolic studies supplement to report dated August 13, 1952. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211665. OTS206055.
American Cyanamid Company. 1953c. Chronic oral administration-dogs oral administration and neurohistology-dogs supplement to reports dated August 13, 1952 and May 8, 1953. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211666. OTS206055.
American Cyanamid Company. 1954. Chronic inhalation exposure-acrylamide. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211670. OTS206055.
American Cyanamid Company. 1959. Acrylamide toxicity: Effect of polyvinylpyrrolidone (PVP). Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211673. OTS206055.
American Cyanamid Company. 1973. Range finding studies single oral single dermal (FHSA) single inhalation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211677. OTS206055.
American Cyanamid Company. 1977. Limited release toxicity tests. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211678. OTS206055.
American Cyanamid Company. 1979. A fetal toxicity study of acrylamide in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878211679. OTS206055.
American Cyanamid Company. 1991. 28-Day subchronic dose toxicity study in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS0533854.
Amrein TM, Andres L, Escher F, 2007. Occurrence of acrylamide in selected foods and mitigation options. Food Addit Contam 24(Suppl 1):13–25.17687696
Andersen ME, Krishnan K. 1994. Relating in vitro to in vivo exposures with physiologically based tissue dosimetry and tissue response models. In: Salem H, ed. Animal test alternatives: Refinement, reduction, and replacement. New York: Marcel Dekker Inc., 9–25.
Andersen ME, Clewell HJ, Gargas ML, 1987. Physiologically based pharmacokinetics and the risk assessment process for methylene chloride. Toxicol Appl Pharmacol 87(2):185–205.3824380
Ao L, Liu SX, Yang MS, 2008. Acrylamide-induced molecular mutation spectra at HPRT locus in human promyelocytic leukemia HL-60 and NB4 cell lines. Mutagenesis 23(4):309–315.18407966
Arisseto AP, Toledo MC, Govaert Y, 2007. Determination of acrylamide levels in selected foods in Brazil. Food Addit Contam 24(3):236–241.17364924
Augustsson K, Skog K, Jagerstad M, 1999. Dietary heterocyclic amines and cancer of the colon, rectum, bladder, and kidney: A population-based study. Lancet 353(9154):703–707.10073512
Auld RB, Bedwell SF. 1967. Peripheral neuropathy with sympathetic overactivity from industrial contact with acrylamide. Can Med Assoc J 96:652–654.4289693
Bachmann M, Myers JE, Bezuidenhout BN. 1992. Acrylamide monomer and peripheral neuropathy in chemical workers. Am J Ind Med 21(2):217–222.1311148
Backer LC, Dearfield KL, Erexson GL, 1989. The effects of acrylamide on mouse germ-line and somatic cell chromosomes. Environ Mol Mutagen 13:218–226.2707253
Banerjee S, Segal A. 1986. In vitro transformation of C3H/10T1/2 and NIH/3T3 cells by acrylonitrile and acrylamide. Cancer Lett 32(3):293–304.3768855
Barber DS, LoPachin RM. 2004. Proteomic analysis of acrylamide-protein adduct formation in rat brain synaptosomes. 201:120–136.
Barber DS, Hunt JR, Ehrich MF, 2001a. Metabolism, toxicokinetics and hemoglobin adduct formation in rats following subacute and subchronic acrylamide dosing. Neurotoxicology 22(3):341–353.11456335
*Barber DS, Hunt J, LoPachin RM, 2001b. Determination of acrylamide and glycidamide in rat plasma by reversed-phase high performance liquid chromatography. J Chromatogr B Biomed Sci Appl 758(2):289–293.11486839
Barfknecht TR, Mecca DJ, Naismith RW. 1988. The genotoxic activity of acrylamide. Environ Mol Mutagen 11(Suppl 11):9.
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Batiste-Alentorn M, Xamena N, Creus A, 1991. Genotoxicity studies with the unstable Zeste-White (UZ) System of Drosophila melanogaster: Results with ten carcinogenic compounds. Environ Mol Mutagen 18:120–125.1908775
Berger GS, ed. 1994. Epidemiology of endometriosis. In: Endometriosis: Modern surgical management of endometriosis. New York, NY: Springer-Verlag, 3–7.
Bergmark E. 1997. Hemoglobin adducts of acrylamide and acrylonitrile in laboratory workers, smokers and nonsmokers. Chem Res Toxicol 10(1):78–84.9074806
Bergmark E, Calleman CJ, Costa LG. 1991. Formation of hemoglobin adducts of acrylamide and its epoxide metabolite glycidamide in the rat. Toxicol Appl Pharmacol 111(2):352–363.1957318
Bergmark E, Calleman CJ, He F, 1993. Determination of hemoglobin adducts in humans occupationally exposed to acrylamide. Toxicol Appl Pharmacol 120(1):45–54.8511782
*Besaratinia A, Pfeifer GP. 2004a. Genotoxicity of acrylamide and glycidamide. J Natl Cancer Inst 96(13):1023–1029.15240786
Besaratinia A, Pfeifer GP. 2004b. Genotoxicity of acrylamide in humans and mice: Promutagenic glycidamide-DNA adducts in the human p53 gene and the cII transgene. Proc Am Assoc Cancer Res 45:452. http://www.aacrmeetingabstracts.org/cgi/content/abstract/2004/1/452-b. July 13, 2009.
Besaratinia A, Pfeifer GP. 2007. A review of mechanisms of acrylamide carcinogenicity. Carcinogenesis 28(3):519–528.17234719
*Bjellaas T, Olesen PT, Frandsen H, 2007b. Comparison of estimated dietary intake of acrylamide with hemoglobin adducts of acrylamide and glycidamide. Toxicol Sci 98(1):110–117.17449897
Bjellaas T, Stolen LH, Haugen M, 2007a. Urinary acrylamide metabolites as biomarkers for short-term dietary exposure to acrylamide. Food Chem Toxicol 45(6):1020–1026.17258374
Boettcher MI, Angerer J. 2005. Determination of the major mercapturic acids of acrylamide and glycidamide in human urine by LC-ESI-MS/MS. J Chromatogr B Analyt Technol Biomed Life Sci 824(1-2):283–294.
Boettcher MI, Bolt HM, Angerer J. 2006b. Acrylamide exposure via the diet: Influence of fasting on urinary mercapturic acid metabolite excretion in humans. 80:817–819.
Boettcher MI, Bolt HM, Drexler H, 2006a. Excretion of mercapturic acids of acrylamide and glycidamide in human urine after single oral administration of deuterium-labelled acrylamide. Arch Toxicol 80(2):55–61.16180013
Boettcher MI, Schettgen T, Kutting B, 2005. Mercapturic acids of acrylamide and glycidamide as biomarkers of the internal exposure to acrylamide in the general population. Mutat Res 580(1-2):167–176.15668118
Bolt HM, Roos PH, Their R. 2003. The cytochrome P-450 isoenzyme CYP2E1 in the biological processing of industrial chemicals: Consequences for occupational and environmental medicine. Int Arch Occup Environ Health 76:174–185.12690492
Bowyer JF, Latendresse JR, Delongchamp RR, 2008a. The effects of subchronic acrylamide exposure on gene expression, neurochemistry, hormones, and histopathology in the hypothalamus-pituitary-thyroid axis of male Fischer 344 rats (Erratum in: Toxicol Appl Pharmacol 232:498). Toxicol Appl Pharmacol 230(2):208–215.18430446
Bowyer JF, Latendresse JR, Delongchamp RR, 2009. The mRNA expression and histological integrity in rat forebrain motor and sensory regions are minimally affected by acrylamide exposure through the drinking water. Toxicol Appl Pharmacol 240:401–411.19664650
Brown L, Rhead M. 1979. Liquid chromatographic determination of acrylamide monomer in natural and polluted aqueous environments. Analyst 104:391–399.
Brown RP, Delp MD, Lindstedt SL, 1997 Physiological parameter values for physiologically based pharmacokinetic models. Toxicol Ind Health 13(4):407–484.9249929
Bull RJ, Robinson M, Laurie RD, 1984a. Carcinogenic effects of acrylamide in Sencar and A/J mice. Cancer Res 44(1):107–111.6360343
Bull RJ, Robinson M, Stober JA. 1984b. Carcinogenic activity of acrylamide in the skin and lung of Swiss-ICR mice. Cancer Lett 24(2):209–212.6478447
Burek JD, Albee RR, Beyer JE, 1980. Subchronic toxicity of acrylamide administered to rats in the drinking water followed by up to 144 days of recovery. J Environ Pathol Toxicol 4(5-6):157–182.7217844
Butterworth BE, Eldridge SR, Sprankle CS, 1992. Tissue-specific genotoxic effects of acrylamide and acrylonitrile. Environ Mol Mutagen 20(3):148–155.1396605
Calleman CJ. 1996. The metabolism and pharmacokinetics of acrylamide: Implications for mechanisms of toxicity and human risk estimation. Drug Metab Rev 28(4):527–590.8959391
*Calleman CJ, Bergmark E, He F, 1993a. Determination of hemoglobin adducts and adverse health effects in workers occupationally exposed to acrylamide. J Toxicol Environ Health 40(2-3):447–448.
Calleman CJ, Bergmark E, Stern LG, 1993b. A nonlinear dosimetric model for hemoglobin adduct formation by the neurotoxic agent acrylamide and its genotoxic metabolite glycidamide. Environ Health Perspect 99:221–223.8319628
Calleman CJ, Stern LG, Bergmark E, 1992. Linear versus nonlinear models for hemoglobin adduct formation by acrylamide and its metabolite glycidamide: Implications for risk estimation. Cancer Epidemiol Biomarkers Prev 1(5):361–368.1305468
Calleman CJ, Wu Y, He F, 1994. Relationship between biomarkers of exposure and neurological effects in a group of workers exposed to acrylamide. Toxicol Appl Pharmacol 126(2):361–371.8209389
Cavalli S, Polesello S, Saccani G. 2004. Determination of acrylamide in drinking water by large-volume direct injection and ion-exclusion chromatography-mass spectrometry. J Chromatogr A 1039(1-2):155–159.15250418
Cavanagh JB. 1964. The significance of the "dying back" process in experimental and human neurological disease. Int Rev Exp Pathol 3:219–267 5317971
CDC. 2009. Fourth national report on human exposure to environmental chemicals. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/exposurereport/pdf/FourthReport.pdf. June 1, 2012.
CERI. 1999. Biodegradation database and estimation. Acrylamide. Chemicals Evaluation and Research Institute, Japan. http://qsar.cerij.or.jp/cgi-bin/QSAR/index.cgi?e. June 8, 2009.
Chapin RE, Fail PA, George JD, 1995. The reproductive and neural toxicities of acrylamide and three analogues in Swiss mice, evaluated using the continuous breeding protocol. Fundam Appl Toxicol 27(1):9–24.7589932
Cherry AB, Gabaccia AJ, Senn HW. 1956. The assimilation behavior of certain toxic organic compounds in natural water. Sewage Ind Waste 28(9):1137–1146.
Cihak R, Vontorkova M. 1988. Cytogenetic effects of acrylamide in the bone marrow of mice. Mutat Res 209(1-2):91–94.3173405
Cihak R, Vontorkova M. 1990. Activity of acrylamide in single-, double-, and triple-dose mouse bone marrow micronucleus assays. Mutat Res 234:125–127.2366779
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
CMR. 2008. Chemical profile: Acrylamide. Chem Market Rep July 21-27
Collins BW, Howard DR, Allen JW. 1992. Kinetochore-staining of spermatid micronuclei: Studies of mice treated with X-radiation or acrylamide. Mutat Res 281(4):287–294.1373224
Collins JJ, Swaen GMH, Marsh GM, 1989. Mortality patterns among workers exposed to acrylamide. J Occup Med 31(7):614–617.2769457
Costa LG, Deng H, Calleman CJ, 1995. Evaluation of the neurotoxicity of glycidamide, an epoxide metabolite of acrylamide: Behavioral, neurochemical and morphological studies. Toxicology 98(1-3):151–161.7740544
Crofton KM, Padilla S, Tilson HA, 1996. The impact of dose rate on the neurotoxicity of acrylamide: The interaction of administered dose, target tissue concentrations, tissue damage, and functional effects. Toxicol Appl Pharmacol 139(1):163–176.8685900
Croll BT, Arkell GM, Hodge RP. 1974. Residues of acrylamide in water. Water Res 8(11):989–993.
Currance PL, Clements B, Bronstein AC. 2007. Tri-ortho-cresyl phosphate (TOCP) and related compounds. In: Emergency care for hazardous materials exposure. 3rd ed. St. Louis, MO: MosbyJems, 482–484.
Davenport JG, Farrell DF, Sumi SM. 1976. ’Giant axonal neuropathy’ caused by industrial chemicals: Neurofilamentous axonal masses in man. Neurology 26(10):919–923.183168
Dearfield KL, Douglas GR, Ehling UH, 1995. Acrylamide: A review of its genotoxicity and an assessment of heritable genetic risk. Mutat Res 330(1-2):71–99.7623872
DFG. 2009. Acrylamide. In: Greim H, ed. The MAK-collection for occupational health and safety. Part I: MAK Value Documentations. Vol. 25. Weinheim, Germany: Deutsche Forschungsgemeinschaft. Wiley-VCH Verlag, 1–43.
Dixit R, Husain R, Mukhtar H, 1981. Effect of acrylamide on biogenic amine levels, monoamine oxidase, and cathepsin D activity of rat brain. Environ Res 26(1):168–173.7297529
Dixit R, Seth PK, Mukhtar H. 1982. Metabolism of acrylamide into urinary mercapturic-acid and cysteine conjugates in rats. Drug Metab Dispos 10(2):196–197.6124410
Dobrzynska MM. 2007. Assessment of DNA damage in multiple organs from mice exposed to X-rays or acrylamide or a combination of both using the comet assay. In Vivo 21(4):657–662.17708362
Doerge DR, da Costa GG, McDaniel LP, 2005a. DNA adducts derived from administration of acrylamide and glycidamide to mice and rats. Mutat Res 580(1-2):131–141.15668115
Doerge DR, Twaddle NC, Boettcher MI, 2007. Urinary excretion of acrylamide and metabolites in Fischer 344 rats and B6C3F_1_ mice administered a single dose of acrylamide. Toxicol Lett 169(1):34–42.17224249
Doerge DR, Young JF, McDaniel LP, 2005b. Toxicokinetics of acrylamide and glycidamide in B6C3F1 mice. Toxicol Appl Pharmacol 202(3):258–267.15667831
Doerge DR, Young JF, McDaniel LP, 2005c. Toxicokinetics of acrylamide and glycidamide in Fischer 344 rats. Toxicol Appl Pharmacol 208(3):199–209.16239164
Donovan JW, Pearson T. 1987. Ingestion of acrylamide with severe encephalopathy neurotoxicity and hepatotoxicity. [Abstract]. Vet Hum Toxicol 29(6):462.
Dourson M, Hertzberg R, Allen B, 2008. Evidence-based dose-response assessment for thyroid tumorigenesis from acrylamide. Regul Toxicol Pharmacol 52(3):264–289.18775759
Dow Chemical Company. 1957. Results of toxicological tests on acrylamide with cover letter. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878210955. OTS206135.
Dow Chemical Company. 1981. Effects of acrylamide monomer on sensory thresholds in monkeys Sept. 15, 1979 to Sept. 18, 1981. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878210964. OTS206135.
D’Souza RW, Francis WR, Andersen ME. 1988. Physiological model for tissue glutathione depletion and increased resynthesis after ethylene dichloride exposure. J Pharmacol Exp Ther 245:563–568.3367306
Duck FA. 1990. Physical properties of tissues. In: Physical properties of tissues. San Diego, CA: Academic Press. (Cited in Sweeney et al. 2010).
Dulak LH, Stedham MA, Selwyn MR, 1989. A lifetime oncogenicity study with acrylamide in rats (final report) with cover letter dated 072489. American Cyanamid Company. Submitted to the U.S. Environmental Protection Agency under TSCA, Section 8D. EPA Document No. 86-890001410. OTS0544299.
Dumitru DL. 1989. Occupational intoxication with acrylamide: Discussion of cases with acute and chronic intoxication. Rev Ig Bacteriol Virusol Parazitol Epidemiol Pneumoftiziol Pneumo 38(4):359–364.
Edwards PM. 1975. The distribution and metabolism of acrylamide and its neurotoxic analogues in rats. Biochem Pharmacol 24(20):1277–1282.1148016
Ehling UH, Neuhaeuser-Klaus A. 1992. Reevaluation of the induction of specific-locus mutations in spermatogonia of the mouse by acrylamide. Mutat Res 283(3):185–191.1383787
Environ. 2002. Toxicological review of acrylamide (CAS No. 79-06-01). Ruston, Louisiana: Environ International Corporation.
EPA. 1978. Environmental monitoring near industrial sites acrylamide. Washington, DC: U.S. Environmental Protection Agency. EPA560678001. PB281879.
EPA. 1988. Recommendations for and documentation of biological values for use in risk assessment. Cincinnati, OH: U.S. Environmental Protection Agency. Environmental Criteria and Assessment Office. EPA600687008. PB88179874.
EPA. 1990. Interim methods for development of inhalation reference concentrations. Washington, DC: U.S. Environmental Protection Agency Office of Health and Environmental Assessment, Office of Research and Development, Environmental Criteria and Assessment Office.
EPA. 1997. Special report on environmental endocrine disruption: An effects assessment and analysis. Washington, DC: U.S. Environmental Protection Agency Risk Assessment Forum.
EPA. 1998. Automated Form R for Windows: User’s guide (RY97). Washington, DC: U.S. Environmental Protection Agency Office of Pollution Prevention and Toxics.
EPA. 2000. National air pollutant emission trends, 1900-1998. Research Triangle Park, NC: U. S. Environmental Protection Agency. EPA454R00002. http://www.epa.gov/ttn/chief/trends/trends98/trends98.pdf. June 8, 2009.
EPA. 2003. National primary drinking water regulations. Washington, DC: Office of Ground Water and Drinking Water, U.S. Environmental Protection Agency. http://water.epa.gov/drink/contaminants/index.cfm#Primary. August 3, 2011.
EPA. 2005a. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency.
EPA. 2005b. Supplemental guidance for assessing susceptibility from early life exposure to carcinogens. Risk assessment forum. Washington, DC: U.S. Environmental Protection Agency. EPA630R03003F.
EPA. 2006. National recommended water quality criteria. Washington, DC: Office of Water, Office of Science and Technology, U.S. Environmental Protection Agency. http://www.epa.gov/waterscience/criteria/wqcriteria.html. August 3, 2011.
EPA. 2008. Acute exposure guideline levels (AEGLs). Second AEGL Chemical Priority List. Washington, DC: Office of Pollution Prevention and Toxics, U.S. Environmental Protection Agency. http://www.epa.gov/oppt/aegl/pubs/priority_2.htm. May 19, 2009.
EPA. 2009a. Hazardous air pollutants. Clean Air Act. U.S. Environmental Protection Agency. United States Code. 42 USC 7412. http://www.gpo.gov/fdsys/browse/collectionUScode.action?collectionCode=USCODE. August 3, 2011.
EPA. 2009b. 2005 National emissions inventory data and documentation. National emissions inventory. U.S. Environmental Protection Agency. http://www.epa.gov/ttn/chief/net/2005inventory.html. May 26, 2009.
EPA. 2010. Toxicological review of acrylamide (CAS No.; 79-06-1). In support of summary information on the Integrated Risk Information System (IRIS). U.S. Environmental Protection Agency. EPA635R07009F. http://www.epa.gov/iris/toxreviews/0286tr.pdf. August 3, 2011.
EPA. 2011a. Drinking water standards and health advisories. Washington, DC: Office of Water, U.S. Environmental Protection Agency. http://water.epa.gov/action/advisories/drinking/upload/dwstandards2011.pdf. August 3, 2011.
EPA. 2011b. Designation of hazardous substances. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 302.4. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-sec302-4.pdf. August 3, 2011
EPA. 2011c. The list of extremely hazardous substances and their threshold planning quantities. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 355, Appendix A. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-part355.pdf. August 3, 2011.
EPA. 2011d. Subpart D-Specific toxic chemical listings. 372.65 Chemicals and chemical categories to which this part applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 372.65. http://www.gpo.gov/fdsys/pkg/CFR-2011-title40-vol28/pdf/CFR-2011-title40-vol28-sec372-65.pdf. August 3, 2011.
EPA. 2011e. Part 716. Health and safety data reporting. Substances and listed mixtures to which this subpart applies. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 716.120. http://www.gpo.gov/fdsys/pkg/CFR-2010-title40-vol30/pdf/CFR-2010-title40-vol30-sec716-120.pdf. August 3, 2011.
Eskin TA, Lapham LW, Maurissen JP, 1985. Acrylamide effects on the macaque visual system. II. Retinogeniculate morphology. Invest Ophthalmol Vis Sci 26(3):317–329.3972512
EU. 2002. Opinion of the scientific committee on food on new findings regarding the presence of acrylamide in food. Brussels: European Union. http://europa.eu.int/comm/food/fs/sc/scf/index.en.html. June 3, 2009.
FDA. 2008. Everything added to food in the United States (EAFUS). Washington, DC: U.S. Food and Drug Administration. http://vm.cfsan.fda.gov/~dms/eafus.html. May 19, 2009.
FDA. 2009. Survey data on acrylamide in food: Total diet study results. U.S. Food and Drug Administration. http://www.fda.gov/Food/FoodSafety/FoodContaminantsAdulteration/ChemicalContaminants/Acrylamide/ucm053566.htm. June 8, 2009.
FEDRIP. 2009. Acrylamide. Federal Research in Progress database. Springfield, VA: National Technical Information Service.
Fennell T, Snyder R, Burgess JP, 2004. Metabolism and hemoglobin adducts of [1, 2, 3-^13^C_3_] acrylamide in humans. [Abstract]. Toxicologist 78(1-S):173–174.
Fennell T, Snyder RW, Friedman MA. 2005a. DNA and hemoglobin adducts from oral administration of acrylamide to male Fischer 344 rats. [Abstract]. Toxicol Sci 84(1-S):103.
Fennell T, Snyder RW, Sumner SC, 2006. Kinetics of elimination of urinary metabolites of acrylamide in humans. Toxicol Sci 93(2):256–267.16870689
Fennell TR, Snyder RW, Krol WL, 2003. Comparison of the hemoglobin adducts formed by administration of N-methylolacrylamide and acrylamide to rats. Toxicol Sci 71(2):164–175.12563102
Fennell TR, Sumner SC, Snyder RW, 2005b. Metabolism and hemoglobin adduct formation of acrylamide in humans. Toxicol Sci 85(1):447–459.15625188
Ferguson SA, Garey J, Smith ME, 2010. Preweaning behaviors, developmental landmarks, and acrylamide and glycidamide levels after pre- and postnatal acrylamide treatment in rats. Neurotoxicol Teratol 32:373–382.20117204
Field EA, Price CJ, Sleet RB, 1990. Developmental toxicity evaluation of acrylamide in rats and mice. Fundam Appl Toxicol 14(3):502–512.2340980
Fomon SJ. 1966. Body composition of the infant: Part 1: The male reference infant. In: Faulkner F, ed. Human development. Philadelphia, PA: WB Saunders, 239–246.
Fomon SJ, Haschke F, Ziegler EE, 1982. Body composition of reference children from birth to age 10 years. Am J Clin Nutr 35(Suppl 5):1169–1175.7081099
Friedman MA, Dulak LH, Stedham MA. 1995. A lifetime oncogenicity study in rats with acrylamide. Fundam Appl Toxicol 27(1):95–105.7589934
Friedman MA, Tyl RW, Marr MC, 1999. Effects of lactational administration of acrylamide on rat dams and offspring. Reprod Toxicol 13(6):511–520.10613399
Fuhr U, Boettcher MI, Kinzig-Schippers M, 2006. Toxicokinetics of acrylamide in humans after ingestion of a defined dose in a test meal to improve risk assessment for acrylamide carcinogenicity. Cancer Epidemiol Biomarkers Prev 15(2):266–271.16492914
Fullerton PM. 1969. Electrophysiological and histological observations on peripheral nerves in acrylamide poisoning in man. J Neurol Neurosurg Psychiatry 32:186–192.4307538
Fullerton PM, Barnes JM. 1966. Peripheral neuropathy in rats produced by acrylamide. Br J Ind Med (23):210–221.4287726
Gamboa da Costa G, Churchwell MI, Hamilton LP, 2003. DNA adduct formation from acrylamide via conversion to glycidamide in adult and neonatal mice. Chem Res Toxicol 16(10):1328–1337.14565774
Garey J, Ferguson SA, Paule MG. 2005. Developmental and behavioral effects of acrylamide in Fischer 344 rats. Neurotoxicol Teratol 27:553–563.16087067
Garey J, Paule MG. 2007. Effects of chronic low-dose acrylamide exposure on progressive ratio performance in adolescent rats. Neurotoxicology 28(5):998–1002.17720246
Garey J, Paule MG. 2010. Effects of chronic oral acrylamide exposure on incremental repeated acquisition (learning) task performance in Fischer 344 rats. Neurotoxicol Teratol 32:220–225.19846048
Garland TO, Patterson MWH. 1967. Six cases of acrylamide poisoning. Br Med J 4:134–138.4293302
Generoso WM, Sega GA, Lockhart AM, 1996. Dominant lethal mutations, heritable translocations, and unscheduled DNA synthesis induced in male mouse germ cells by glycidamide, a metabolite of acrylamide. Mutat Res 371(3-4):175–183.9008719
Ghanayem BI, McDaniel LP, Churchwell MI, 2005c. Role of CYP2E1 in the epoxidation of acrylamide to glycidamide and formation of DNA and hemoglobin adducts. Toxicol Sci 88(2):311–318.16141435
Ghanayem BI, Witt KL, El-Hadri L, 2005a. Comparison of germ cell mutagenicity in male CYP2E1- null land wild-type mice treated with acrylamide: Evidence supporting a glycidamide-mediated effect. Biol Reprod 72:157–163.15355880
Ghanayem BJ, Witt KL, Kissling GE, 2005b. Absence of acrylamide-induced genotoxicity in CYP2E1-null mice: Evidence consistent with a glycidamide-mediated effect. Mutat Res 578:284–297.15982677
Gilbert SG, Maurissen JP. 1982. Assessment of the effects of acrylamide, methylmercury and 2,5-hexanedione on motor functions in mice. J Toxicol Environ Health 10(1):31–42.7131587
Giwercman A, Carlsen E, Keiding N, 1993. Evidence for increasing incidence of abnormalities of the human testis: A review. Environmental Health Perspectives Supplement 101(2):65–71.
Gjerløff T, Elsborg H, Bonde JP. 2001. [Severe chronic acrylamide intoxication]. Ugeskr Laeger 163(32):4204–4205.11510240
Goldfrank LR, Flomenbaum NE, Lewin NA, 1998. Goldfrank’s toxicologic emergencies. Stamford, CT: Appleton & Lange, 322-324, 475.
Gorzinski SJ, Morden DC, Albee RR, 1979. Results of papatability (12-day) and tolerance (21-day) studies on acrylamide monomer administered in the drinking water to rats. Dow Chemical Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878210959. OTS206135.
Gutierrez-Espeleta GA, Hughes LA, Piegorsch WW, 1992. Acrylamide: Dermal exposure produces genetic damage in male mouse germ cells. Fundam Appl Toxicol 18(2):189–192.1601219
Guzelian PS, Henry CJ, Olin SS. 1992. In: Similarities and differences between children and adults: Implications for risk assessment. Washington DC: International Life Sciences and Press Institute Press.
Haber LT, Maier A, Kroner OL, 2009. Evaluation of human relevance and mode of action for tunica vaginalis mesotheliomas resulting from oral exposure to acrylamide. Regul Toxicol Pharmacol 53(2):134–149.19166893
Habermann CE. 2002. Acrylamide. In: Kirk-Othmer encylcopedia of chemical technology. John Wiley & Sons, 1–22. http://mrw.interscience.wiley.com/emrw/9780471238966/kirk/article/acryhabe.a01/current/pdf. June 08, 2009.
Hagmar L, Tornvist M, Nordander C, 2001. Health effects of occupational exposure to acrylamide using hemoglobin adducts as biomarkers of internal dose. Scand J Work Environ Health 27(4):219–226.11560335
Hanioka N, Tanaka-Kagawa T, Miyata Y, 2003. Functional characterization of three human cytochrome P450 2E1 variants with amino acid substitutions. Xenobiotica 33(6):575–586.12851035
Harris CH, Gulati AK, Friedman MA, 1994. Toxic neurofilamentous axonopathies and fast axonal transport. V. Reduced bidirectional vesical transport in cultured neurons by acrylamide and glycidamide. J Toxicol Environ Health 42:343–356.7517455
Harry GJ. 1992. Acrylamide-induced alterations in axonal transport. Biochemical and autoradiographic studies. Mol Neurobiol 6(2-3):203–216.1282332
Hashimoto K, Aldridge WN. 1970. Biochemical studies on acrylamide, a neurotoxic agent. Biochem Pharmacol 19:2591–2604.5478284
Hashimoto K, Tanii H. 1985. Mutagenicity of acrylamide and its analogs in Salmonella typhimurium. Mutat Res 158:129–133.3908926
Hashimoto K, Sakamoto J, Tanii H. 1981. Neurotoxicity of acrylamide and related compounds and their effects on male gonads in mice. Arch Toxicol 47:179–189.7271446
HazDat. 2007. Acrylamide. HazDat Database: ATSDR’s Hazardous Substance Release and Health Effects Database. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
He F, Zhang S, Wang H, 1989. Neurological and electroneuromyographic assessment of the adverse effects of acrylamide on occupationally exposed workers. Scand J Work Environ Health 15(2):125–129.2528204
Hersch MI, McLeod JG, Satchell PM, 1989a. Breathing pattern, lung inflation reflex and airway tone in acrylamide neuropathy. Respir Physiol 76(2):257–276.2749028
*Hersch MI, McLeod JG, Sullivan CE. 1989b. Abnormal cough reflex in canine acrylamide neuropathy. Ann Neurol 26(6):738–745.2557793
Heudorf U, Hartmann E, Angerer J. 2009. Acrylamide in children-exposure assessment via urinary acrylamide metabolites as biomarkers. Int J Hyg Environ Health 212:135–14.18555743
Hirvonen T, Kontto J, Jestoi M, 2010. Dietary acrylamide intake and the risk of cancer among Finnish male smokers. Cancer Causes Control 21(12):2223–2229.20859673
Hoel DG, Davis DL, Miller AB, 1992. Trends in cancer mortality in 15 industrialized countries, 1969-1986. J Natl Cancer Inst 84(5):313–320.1738181
Hogervorst JG, Schouten LJ, Konings EJ, 2007. A prospective study of dietary acrylamide intake and the risk of endometrial, ovarian, and breast cancer. Cancer Epidemiol Biomarkers Prev 16(11):2304–2313.18006919
Hogervorst JG, Schouten LJ, Konings EJ, 2008a. Dietary acrylamide intake and the risk of renal cell, bladder, and prostate cancer. Am J Clin Nutr 87(5):1428–1438.18469268
Hogervorst JG, Schouten LJ, Konings EJ, 2008b. Dietary acrylamide intake is not associated with gastrointestinal cancer risk. J Nutr 138(11):2229–2236.18936224
Hogervorst JG, Schouten LJ, Konings EJ, 2009a. Dietary acrylamide intake and brain cancer risk. Cancer Epidemiol Biomarkers Prev 18(5):1663–1666.19383886
Hogervorst JG, Schouten LJ, Konings EJ, 2009b. Lung cancer risk in relation to dietary acrylamide intake. J Natl Cancer Inst 101:651–662.19401552
Hoorn AJW, Custer LI, Myhr BC. 1993. Detection of chemical mutagens using Muta Mouse: A transgenic mouse model. Mutagenesis 8(1):7–10.8450770
Hopkins A. 1970. The effect of acrylamide on the peripheral nervous system of the baboon. J Neurol Neurosurg Psychiatry 33(6):805–816.5497880
HSDB. 2009. Acrylamide. Hazardous Substances Data Bank. National Library of Medicine. http://toxnet.nlm.nih.gov. April 27, 2009.
Huang YF, Chen ML, Liou SH, 2011a. Association of CYP2E1, GST and mEH genetic polymorphisms with urinary acrylamide metabolites in workers exposed to acrylamide. Toxicol Lett 203(2):118–126.21402133
Huang YF, Wu KY, Liou SH, 2011b. Biological monitoring for occupational acrylamide exposure from acrylamide production workers. Int Arch Occup Environ Health 84(3):303–313.20596721
Husain R, Dixit R, Das M, 1987. Neurotoxicity of acrylamide in developing rat brain: Changes in the levels of brain biogenic amines and activities of monoamine oxidase and acetylcholine esterase. Ind Health 25(1):19–28.3583826
IARC. 1994. Acrylamide. In: IARC monographs of some industrial chemicals, summary of data reported and evaluation. Lyon, France: International Agency for Research on Cancer, 389–433.
IARC. 2011. Agents classified by the IARC monographs, Volumes 1-102. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/ClassificationsAlphaOrder.pdf. April 18, 2012.
Igisu H, Matsuoka M. 2002. Acrylamide encephalopathy. J Occup Health 44:63–68.
Igisu H, Goto I, Kawamaura Y, 1975. Acrylamide encephaloneuropathy due to well water pollution. J Neurol Neurosurg Psychiatry 38:581–584.168322
Ikeda GJ, Miller E, Sapienza PP, 1983. Distribution of ^14^C-labelled acrylamide and betaine in fetuses of rats, rabbits, beagle dogs and miniature pigs. Food Chem Toxicol 21:49–58.6681792
Ikeda GJ, Miller E, Sapienza PP, 1985. Maternal-foetal distribution studies in late pregnancy. II. Distribution of [1-^14^C]acrylamide in tissues of beagle dogs and miniature pigs. Food Chem Toxicol 23(8):757–761.3899875
IPCS. 1985. Acrylamide. Environmental Health Criteria 49. International Programme on Chemical Safety. http://www.inchem.org/documents/ehc/ehc/ehc49.htm. June 8, 2009.
IRIS. 2012. Acrylamide. Integrated Risk Information System. Washington, DC: http://www.epa.gov/iris/subst/index.html. May 22, 2012.
Johanson CE. 1980. Permeability and vascularity of the developing brain: Cerebellum vs. cerebral cortex. Brain Res 190(1):3–16.6769537
Johnson KA, Beyer JE, Bell TJ, 1984. Acrylamide: A two-year drinking water chronic toxicity-oncogenicity study in Fischer 344 rats. American Cyanamid Company. Dow Chemical U.S.A. Nalco Chemical Company. The Standard Oil Company. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0507273.
Johnson KA, Beyer JE, Bell TJ, 1985. Acrylamide: A two-year drinking water chronic toxicity-oncogenicity study in Fischer 344 rats. Electron microscopy portion. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878216184. OTS0506849.
Johnson KA, Gorzinski SJ, Bodner KM, 1986. Chronic toxicity and oncogenicity study on acrylamide incorporated in the drinking water of Fischer 344 rats. Toxicol Appl Pharmacol 85(2):154–168.3764902
Johnsrud EK, Kuokouritaki SB, Divakaran K, 2003. Human hepatic CYP2E1 expression during development. J Pharmacol Exp Ther 307(1):402–407. Erratum in: J Pharmacol Exp Ther 309(1):439.14500779
Jung R, Engelhart G, Herbolt B. 1992. Collaborative study of mutagenicity with Salmonella typhimurium TA102. Mutat Res 278:265–270.1373863
Kadry AM, Friedman MA, Abdel-Rahman MS. 1999. Pharmacokinetics of acrylamide after oral administration in male rats. Environ Toxicol Pharmacol 7(2):127–133.21781917
Kaplan ML, Murphy SD, Gilles FH. 1973. Modification of acrylamide neuropathy in rats by selected factors. Toxicol Appl Pharmacol 24:564–579.4713483
Kaster JK, Kamendulls LM, Friedman MA, 1998. Syrian hamsters embryo (SHE) cell transformation by acrylamide and hormones. Toxicol Sci 42(1-S):76.
Kedderis GL, Teo SK, Batra R, 1996. Refinement and verification of the physiologically based dosimetry description for acrylonitrile in rats. Toxicol Appl Pharmacol 140:422–435.8887460
Kermani-Alghoraishi M, Anvari M, Talebi AR, 2010. The effects of acrylamide on sperm parameters and membrane integrity of epididymal spermatozoa in mice. Eur J Obstet Gynecol Reprod Biol 153(1):52–55.20705380
Kesson CM, Baird AW, Lawson DH. 1977. Acrylamide poisoning. Postgrad Med J 53:16–17.195278
Kirman CR, Gargas ML, Deskin R, 2003. A physiologically based pharmacokinetic model for acrylamide and its metabolite, glycidamide, in the rat. J Toxicol Environ Health A 66(3):253–274.12521671
Klaunig JE. 2008. Acrylamide carcinogenicity. J Agric Food Chem 56(15):5984–5988.18624430
Kligerman AD, Atwater AL, Bryant MF, 1991. Cytogenetic studies of ethyl acrylate using C57BL/6 mice. Mutagenesis 6(2):137–141 2056915
Knaap AC, Kramers PN, Voogd CE, 1988. Mutagenic activity of acrylamide in eukaryotic systems but not in bacteria. Mutagenesis 3:263–268.3137422
*Ko MH, Chen WP, Hsieh ST. 2000. Cutaneous nerve degeneration induced by acrylamide in mice. Neurosci Lett 293(3):195–198.11036194
Ko MH, Chen WP, Hsieh ST. 2002. Neuropathology of skin denervation in acrylamide-induced neuropathy. Neurobiol Dis 11(1):155–165.12460555
Ko MH, Chen WP, Lin-Shiau SY, 1999. Age-dependent acrylamide neurotoxicity in mice: Morphology, physiology, and function. Exp Neurol 158(1):37–46.10448416
Komori M, Nishio K, Kitada M, 1990. Fetus-specific expression of a form of cytochrome P-450 in human livers. Biochemistry 29(18):4430–4433.2350547
Koyama N, Yasui M, Kimura A, 2011a. Acrylamide genotoxicity in young versus adult gtp delta male rats. Mutagenesis 26(4):545–549.21441395
Koyama N, Yasui M, Oda Y, 2011b. Genotoxicity of acrylamide in vitro: acrylamide is not metabolically activated in standard in vitro systems. Environ Mol Mutagen 52:12–19.
Krebs O, Favor J. 1997. Somatic and germ cell mutagenesis in lambda lacZ transgenic mice treated with acrylamide or ethylnitrosourea. Mutat Res 388(2-3):239–248.9057886
Krishna G, Theiss C. 1995. Concurrent analysis of cytogenetic damage in vivo: A multiple endpoint-multiple tissue approach. Environ Mol Mutagen 25:314–320.7607186
Krishnan K, Andersen ME. 1994. Physiologically based pharmacokinetic modeling in toxicology. In: Hayes AW, ed. Principles and methods of toxicology. 3rd ed. New York, NY: Raven Press, Ltd., 149–188.
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Lafferty JS, Kamendulis LM, Kaster J, 2004. Subchronic acrylamide treatment induces a tissue-specific increase in DNA synthesis in the rat. Toxicol Lett 154(1-2):95–103.15475183
Lảhdetie J, Suutari A, Sjoblom T. 1994. The spermatid micronucleus test with the dissection technique detects the germ cell mutagenicity of acrylamide in rat meiotic cells. Mutat Res 309(2):255–262.7520983
Lapadula DM, Bowe M, Carrington CD, 1989. In vitro binding of [^14^C]acrylamide to neurofilament and microtubule proteins of rats. Brain Res 481(1):157–161.2495837
Larsson SC, Akesson A, Wolk A. 2009d. Long-term dietary acrylamide intake and breast cancer risk in a prospective cohort of Swedish women. Am J Epidemiol 169(3):376–381.19015201
Larsson SC, Akesson A, Wolk A. 2009b. Long-term dietary acrylamide intake and risk of epithelial ovarian cancer in a prospective cohort of Swedish women. Cancer Epidemiol Biomarkers Prev 18(3):994–997.19223560
Larsson SC, Akesson A, Wolk A. 2009e. Dietary acrylamide intake and prostate cancer risk in a prospective cohort of Swedish men. Cancer Epidemiol Biomarkers Prev 18(6):1939–1941.19505926
Larsson SC, Hakansson N, Akesson A, 2009a. Long-term dietary acrylamide intake and risk of endometrial cancer in a prospective cohort of Swedish women. Int J Cancer 124(5):1196–1199.19048629
Larsson SC, Kesson A, Bergkvist L, 2009c. Dietary acrylamide intake and risk of colorectal cancer in a prospective cohort of men. Eur J Cancer 45:513–516.19121931
Leeder JS, Kearns GL. 1997. Pharmacogenetics in pediatrics: Implications for practice. Pediatr Clin North Am 44(1):55–77.9057784
Leikin JB, Paloucek FP. 2002. Leikin & Paloucek’s poisoning and toxicology handbook. 3^rd^ ed. Poisoning and toxicology handbook. 3rd ed. Hudson, OH: Lexi-Comp, Inc., 193–194.
Leswing RJ, Ribelin WE. 1969. Physiologic and pathologic changes in acrylamide neuropathy. Arch Environ Health 18(1):23–29.4302158
Leung H. 1993. Physiologically-based pharmacokinetic modelling. In: Ballantyne B, Marrs T, Turner P, eds. General and applied toxicology. Vol. 1. New York, NY: Stockton Press, 153–164.
Lewis RJ. 2000. Acrylamide. In: Sax’s dangerous properties of industrial materials. 10th ed. New York, NY: John Wiley & Sons, Inc., 66–67.
Lewis RJ. 2007. Acrylamide. In: Hawley’s condensed chemical dictionary. 15th ed. Hoboken, NJ: John Wiley & Sons, Inc., 19–20.
Lide DR, ed. 2008. CRC handbook of chemistry and physics. 88th ed. New York, NY: CRC Press, 3-8 to 3-9.
Lijinsky W, Andrews AW. 1980. Mutagenicity of vinyl compounds in Salmonella typhimurium. Teratog Carcinog Mutagen 1:259–267.6119816
Lin Y, Lagergren J, Lu Yunxia. 2010. Dietary acrylamide intake and risk of exophageal cancer in a population-based case-control study in Sweden. Int J Cancer 128:676–681.
Livingston AL. 1978. Forage plant estrogens. J Toxicol Environ Health 4(2-3):301–324.351201
LoPachin RM, Barber DS. 2006. Synapticcysteine sulfhydryl groups as targets of electrophilic neurotoxicants. Toxicol Sci 94:240–255.16880199
Lopachin RM, Decaprio AP. 2005. Protein adduct formation as a molecular mechanism in neurotoxicity. Toxicol Sci 86(2):214–225.15901921
Lopachin RM, Gavin T. 2008. Acrylamide-induced nerve terminal damage: Relevance to neurotoxic and neurodegenerative mechanisms. J Agric Food Chem 56(15):5994–6003.18624437
LoPachin RM, Lehning EJ. 1994. Acrylamide-induced distal axon degeneration: A proposed mechanism of action. Neurotoxicology 15(2):247–259.7991213
LoPachin RM, Balaban CD, Ross JF. 2003. Acrylamide axonopathy revisited. Toxicol Appl Pharmacol 188(3):135–153.12729714
LoPachin RM, Barber DS, Gavin T. 2008. Molecular mechanisms of the conjugated alpha, beta-unsaturated carbonyl derivatives: Relevance to neurotoxicity and neurodegenerative diseases. Toxicol Sci 104(2):235–249.18083715
Manjanatha MG, Aidoo A, Shelton SD, 2006. Genotoxicity of acrylamide and its metabolite glycidamide administered in drinking water to male and female Big Blue mice. Environ Mol Mutagen 47(1):6–17.15957192
Mapp C, Mazzotta M, Bartolucci GB, 1977. [La neuropatia da acrilamide: Prime osservazioni in Italia]. (Italian) Med Lav 68(1):1–12.192987
Marchetti F, Lowe X, Bishop J, 1997. Induction of chromosomal aberrations in mouse zygotes by acrylamide treatment of male germ cells and their correlation with dominant lethality and heritable translocations. Environ Mol Mutagen 30(4):410–417.9435882
Marlowe C, Clark MJ, Mast RW, 1986. The distribution of [^14^C]acrylamide in male and pregnant Swiss-Webster mice studied by whole-body autoradiography. Toxicol Appl Pharmacol 86(3):457–465.3787638
Marsh GM, Youk AO, Buchanich JM, 2007. Mortality patterns among workers exposed to acrylamide: Updated follow up. J Occup Environ Med 49(1):82–95.17215717
Martins C, Oliveira NG, Pingarilho M, 2007. Cytogenetic damage induced by acrylamide and glycidamide in mammalian cells: Correlation with specific glycidamide-DNA adducts. Toxicol Sci 95(2):383–390.17088317
Marty JP, Vincent CM. 1998. In vitro percutaneous absorption of acrylamide across human skin. Paris, France, Faculty of Pharmacy, Universite de Paris Sud.
Maurissen JP, Weiss B, Davis HT. 1983. Somatosensory thresholds in monkeys exposed to acrylamide. Toxicol Appl Pharmacol 71(2):266–279.6636191
Mayr U, Butsch A, Schneider S. 1992. Validation of two in vitro test systems for estrogenic activities with zearalenone, phytoestrogens and cereal extracts. Toxicology 74(2-3):135–149.1387742
McCollister DD, Oyen F, Rowe VK. 1964. Toxicology of acrylamide. Toxicol Appl Pharmacol 6:172–181.
Mei N, Hu J, Churchwell MI, 2008b. Genotoxic effects of acrylamide and glycidamide in mouse lymphoma cells. Food Chem Toxicol 46(2):628–636.18029077
Mei N, McDaniel LP, Dobrovolsky VN, 2010. The genotoxicity of acrylamide and glycidamide in Big Blue rats. Toxicol Sci 115(2):412–421.20200216
Merigan WH, Barkdoll E, Maurissen JP, 1985. Acrylamide effects on the macaque visual system. I. Psychophysics and electrophysiology. Invest Ophthalmol Vis Sci 26(3):309–316.3972511
Meylan WM, Howard PH. 1993. Computer estimation of the atmospheric gas-phase reaction rate of organic compounds with hydroxyl radicals and ozone. Chemosphere 26(12):2293–2299.
Michels KB, Rosner BA, Chumlea WC, 2006. Preschool diet and adult risk of breast cancer. Int J Cancer 118(3):749–754.16094624
Miller MJ, Carter DE, Sipes IG. 1982. Pharmacokinetics of acrylamide in Fischer-344 rats. Toxicol Appl Pharmacol 63:36–44.7071872
Moore MM, Amtower A, Doeer C, 1987. Mutagenicity and clastogenicity of acrylamide in l5178y mouse lymphoma cells. Environ Mutagen 9(3):261–267.3569169
Moreno Navarro IM, Rubio Armendariz C, Gutierrez Fernandez AJ, 2007. La acrilamida, contaminante quimico de procesado: Revision. Revista de Toxicologia (Elche, Spain) 24(1):1–9.
Morselli PL, Franco-Morselli R, Bossi L. 1980. Clinical pharmacokinetics in newborns and infants: Age-related differences and therapeutic implications. Clin Pharmacokinet 5(6):485–527.7002417
Mottram DS, Wedzicha BL, Dodson AT. 2002. Acrylamide is formed in the Maillard reaction. Nature 419(6906):448–449.12368844
Mucci LA, Adami HO, Wolk A. 2006. Prospective study of dietary acrylamide and risk of colorectal cancer among women. Int J Cancer 118(1):169–173.16003738
Mucci LA, Dickman PW, Steineck G, 2003. Dietary acrylamide and cancer of the large bowel, kidney, and bladder: Absence of an association in a population-based study in Sweden. Br J Cancer 88(1):84–89.12556964
Mucci LA, Lindblad P, Steineck G, 2004. Dietary acrylamide and risk of renal cell cancer. Int J Cancer 109(5):774–776.14999788
Mucci LA, Sandin S, Balter K, 2005. Acrylamide intake and breast cancer risk in Swedish women. JAMA 293(11):1326–1327.15769965
Müller W, Engelhart G, Herbold B, 1993. Evaluation of mutagenicity testing with Salmonella typhimurium TA102 in three different laboratories. Environ Heath Perspect 101(Suppl 3):33–36.
Mulloy KB. 1996. Two case reports of neurological disease in coal mine preparation plant workers. Am J Ind Med 30(1):56–61.8837683
Muttucumaru N, Elmore JS, Curtis T, 2008. Reducing acrylamide precursors in raw materials derived from wheat and potato. J Agric Food Chem 56(15):6167–6172.18624429
Myers JE, Macun I. 1991. Acrylamide neuropathy in a South African factory: An epidemiologic investigation. Am J Ind Med 19(4):487–493.1852098
Nakagawa-Yagi Y, Choi D, Ogane N, 2001. Discovery of a novel compound insight into mechanisms for acrylamide-induced axonopathy and colchicine-induced apoptotic neuronal cell death. Brain Res 909:8–19.11478917
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC National Academy of Sciences, National Research Council, National Academy Press, 15–35.
NCTR. 2009. National Center for Toxicological Research annual report. Research accomplishments and plans. Department of Health and Human Services, National Center for Toxicological Research, 52, 56, 69. http://www.fda.gov/downloads/AboutFDA/CentersOffices/NCTR/ResearchAccomplishmentsPlans/UCM163319.pdf. July 16, 2009.
Nesterova EV, Durnev AD, Seredenin SB. 1999. Verapamil contributes to the clastogenic effects of acrylamide, cyclophosphamide, and dioxidine on somatic cells of BALB/C and C57BL/6 mice. Mutat Res 440(2):171–179.10209340
Neuhauser-Klaus A, Schmahl W. 1989. Mutagenic and teratogenic effects of acrylamide in the mammalian spot test Mutat Res 226(3):157–162.
NIOSH. 2011. Acrylamide. In: NIOSH pocket guide to chemical hazards. Atlanta, GA: National Institute for Occupational Safety and Health, Centers for Disease Control and Prevention, http://www.cdc.gov/niosh/npg/. August 3, 2011.
NRC. 1993. Pesticides in the diets of infants and children. Washington, DC: National Research Council. National Academy Press.
NTP. 2011a. Report on carcinogens, 12th edition. Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ntp.niehs.nih.gov/ntp/roc/twelfth/roc12.pdf. August 3, 2011.
NTP. 2011b. NTP technical report on the toxicology and carcinogenesis studies of acrylamide (CAS No. 79-06-1) in F344/N rats and B6C3F_1_ mice (drinking water study). Scheduled Peer Review Date: April 5, 2011. National Toxicology Program. National Institutes of Health. Public Health Service. U.S. Department of Health and Human Services. NTP TR 575. http://ntp.niehs.nih.gov/Ntp/About_Ntp/TRPanel/2011/April/DraftTR575.pdf. August 3, 2011.
Ogawa B, Ohishi T, Wang L, 2011. Disruptive neuronal development by acrylamide in the hippocampal dentate hilus after developmental exposure in rats. Arch Toxicol 85:987–994.21120452
Olesen PT, Olsen A, Frandsen H, 2008. Acrylamide exposure and incidence of breast cancer among postmenopausal women in the Danish Diet, Cancer and Health study. Int J Cancer 122(9):2094–2100.18183576
Oliveira NG, Pingarilho M, Martins C, 2009. Cytotoxicity and chromosomal aberrations induced by acrylamide in V79 cells: role of glutathione modulators. Mutat Res 676:87–92.19393333
O’Neil MJ, Heckelman PE, Koch CB, 2006. Acrylamide. In: O’Neil MJ, Heckelman PE, Koch CB, eds. The Merck index. An encyclopedia of chemicals, drugs, and biologicals. 14th ed. Whitehouse Station, NJ: Merck & Co., Inc., 22–23.
OSHA. 2010. Toxic and hazardous substances. Occupational safety and health standards. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000, Table Z-1. http://www.gpo.gov/fdsys/pkg/CFR-2010-title29-vol6/pdf/CFR-2010-title29-vol6-sec1910-1000.pdf. August 26, 2011.
Owen GM, Brozek J. 1966. Influence of age, sex and nutrition on body composition during childhood and adolescence. In: Falkner F, ed. Human development. Philadelphia, PA: WB Saunders, 222–238.
Pacchierotti F, Tiveron C, D’Archivio M, 1994. Acrylamide-induced chromosomal damage in male mouse germ cells detected by cytogenetic analysis of one-cell zygotes. Mutat Res 309(2):273–284.7520985
Padilla S, Atkinson MB, Breuer AC. 1993. Direct measurement of fast axonal organelle transport in the sciatic nerve of rats treated with acrylamide. J Toxicol Environ Health 39(4):429–445.8345531
Palmer RB. 2004. Acrylic acid and derivatives. In: Dart RC, ed. Medical toxicology. 3rd ed. Philadelphia, PA: Lippincott Williams & Wilkins, 1358–1368.
Park J, Kamendulis LM, Friedman MA, 2002. Acrylamide-induced cellular transformation. Toxicol Sci 65(2):177–183.11812921
Paulsson B, Grawe J, Tornqvist M. 2002. Hemoglobin adducts and micronucleus frequencies in mouse and rat after acrylamide or N-methylolacrylamide treatment. Mutat Res 516(1-2):101–111.11943616
Pearson RG, Songstad J. 1967. Application of the principle of hard and soft acids and bases to organic chemistry. J Am Chem Soc 89:1827–1836.
Pelucchi C, Galeone C, Dal Maso L, 2007. Dietary acrylamide and renal cell cancer. Int J Cancer 120(6):1376–1377.17187369
Pelucchi C, Galeone C, Levi F, 2006. Dietary acrylamide and human cancer. Int J Cancer 118(2):467–471.16003724
Pelucchi C, Galeone C, Talamini R, 2011a. Dietary acrylamide and pancreatic cancer risk in an Italian case-control study. Ann Oncol 22:1910–1915.21285136
Pelucchi C, LaVecchia C, Bosetti C, 2011b. Exposure to acrylamide and human cancer-a review and meta-analysis of epidemiologic studies.
Perrault SD. 2003. Distinguishing between fertilization failure and early pregnancy loss when identifying male-mediated adverse pregnancy outcomes. Adv Exp Med Biol 518:189–198.12817687
Petersen DW, Kleinow KM, Kraska RC, 1985. Uptake disposition and elimination of acrylamide in rainbow trout Salmo-gairdneri. Toxicol Appl Pharmacol 80(1):58–65.4024108
Pleasure DE, Mishler KC, Engel WK. 1969. Axonal transport of proteins in experimental neuropathies. Science 166:524–525.4309629
Post EJ, McLeod JG. 1977a. Acrylamide autonomic neuropathy in the cat: 1. Neurophysiological and histological studies. J Neurol Sci 33(3):353–374.915523
Post EJ, McLeod JG. 1977b. Acrylamide autonomic neuropathy in the cat: 2. Effects on mesenteric vascular control. J Neurol Sci 33(3):375–386.915524
Poulin P, Krishnan K. 1995. A biologically-based algorithm for predicting human tissue:blood partition coefficients of organic chemicals. Hum Exp Toxicol 14:273–280.7779458
Poulin P, Krishnan K. 1996a. A mechanistic algorithm for predicting blood:air partition coefficients of organic chemicals with the consideration of reversible binding in hemoglobin. Toxicol Appl Pharmacol 136:131–137.8560466
Poulin P, Krishnan K. 1996. A tissue composition-based algorithm for predicting tissue:air partition coefficients of organic chemicals. Toxicol Appl Pharmacol 136:126–130.8560465
Pratt GC, Palmer K, Wu CY, 2000. An assessment of air toxics in Minnesota. Environ Health Perspect 108(9):815–825.11017885
Ramsey JC, Young JD, Gorzinsky SJ. 1984. Acrylamide: Toxicodynamics in rats. Submitted to the U.S. Environmental Protection Agency under TSCA Section 4. OTS0507270. [Unpublished study for peer review]
Raymer JH, Sparacino CM, Velez GR, 1993. Determination of acrylamide in rat serum and sciatic nerve by gas chromatography-electron-capture detection. J Chromatogr 619:223–234.8263094
Recio L, Hobbs C, Caspary W, 2010. Dose-response assessment of four genotoxic chemicals in a combined mouse and rat micronucleus (MN) and Comet assay protocol. J Toxicol Sci 35(2):149–162.20371966
Rice JM. 2005. The carcinogenicity of acrylamide. Mutat Res 580(1-2):3–20.15668103
Rohm and Haas Company. 1975. Acrylamide and methacrylamide. Subchronic percutaneous toxicity study in new-born rabbits. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. OTS205982.
Russell LB, Hunsicker PR, Cacheiro NA, 1991. Induction of specific-locus mutations in male germ cells of the mouse by acrylamide monomer. Mutat Res 262:101–107.2000095
Russo A, Gabbani G, Simoncini B. 1994. Weak genotoxicity of acrylamide on premeiotic and somatic cells of the mouse. Mutat Res 309(2):263–272.7520984
Sakamoto J, Hashimoto K. 1986. Reproductive toxicity of acrylamide and related compounds in mice: Effects on fertility and sperm morphology. Arch Toxicol 59:201–205.3827588
Sakamoto J, Kurosaka Y, Hashimoto K. 1988. Histological changes of acrylamide-induced testicular lesions in mice. Exp Mol Pathol 48(3):324–334.3371457
Satchell PM, McLeod JG. 1981. Megaoesophagus due to acrylamide neuropathy. J Neurol Neurosurg Psychiatry 44(10):906–913.6273507
Schettgen T, Kutting B, Hornig M, 2004a. Trans-placental exposure of neonates to acrylamide-a pilot study. Int Arch Occup Environ Health 77(3):213–216.14740221
Schettgen T, Müller J, Fromme H, 2010. Simultaneous quantification of haemoglobin adducts of ethylene oxide, propylene oxide, acrylonitrile, acrylamide and glycidamide in human blood by isotope-dilution GC/NCI-MS/MS. J Chromatogr B Analyt Technol Biomed Life Sci 878(27):2467–2473.
*Schettgen T, Rossbach B, Kutting B, 2004b. Determination of haemoglobin adducts of acrylamide and glycidamide in smoking and non-smoking persons of the general population. Int J Hyg Environ Health 207(6):531–539.15729833
Schoeffner DJ, Warren DA, Muralidhara S, 1999. Organ weights and fat volume in rats as a function of stain and age. J Toxicol Environ Health A 56:449–462.10201633
Schouten LJ, Hogervorst JG, Konings EJ, 2009. Dietary acrylamide intake and the risk of head-neck and thyroid cancers: Results from the Netherlands Cohort Study. Am J Epidemiol 170:873–884.19720866
Schulze GE, Boysen BG. 1991. A neurotoxicity screening battery for use in safety evaluation: Effects of acrylamide and 3’,3’-iminodipropionitrile. Fundam Appl Toxicol 16(3):602–615.1842897
Schumacher JN, Green CR, Best FW, 1977. Smoke composition. An extensive investigation of the water-soluble portion of cigarette smoke. J Agric Food Chem 25(2):310–320.838966
Sega GA, Generoso EE. 1990. Measurement of DNA breakage in specific germ-cell stages of male mice exposed to acrylamide, using an alkaline-elution procedure. Mutat Res 242:79–87.2392124
Sega GA, Alcota RP, Tancongco CP, 1989. Acrylamide binding to the DNA and protamine of spermiogenic stages in the mouse and its relationship to genetic damage. Mutat Res 216(4):221–230.2761561
Sega GA, Generoso EE, Brimer PA. 1990. Acrylamide exposure induces a delayed unscheduled DNA synthesis in germ cells of male mice that is correlated with the temporal pattern of adduct formation in testis DNA. Environ Mol Mutagen 16(3):137–142.2209570
Segerback D, Calleman CJ, Schroeder JL, 1995. Formation of N-7-(2-carbamoyl-2-hydroxyethyl)guanine in DNA of the mouse and the rat following intraperitoneal administration of [14C]acrylamide. Carcinogenesis 16(5):1161–1165.7767980
Setchell BP, Waites GMH. 1975. The blood testis barrier. InCreep RO, Astwood EB, Geiger SR, eds. Handbook of physiology: Endocrinology V. Washington, DC: American Physiological Society, 143–172.
Shelby MD, Cain KT, Cornett CV, 1987. Acrylamide: Induction of heritable translocation in male mice. Environ Mutagen 9(4):363–368.3582296
Shi J, Ma Y, Zheng M, 2011. Effect of sub-acute exposure to acrylamide on GABAergic neurons and astrocytes in weaning rat cerebellum. Toxicol Ind Health [Epub ahead of print].
Shipp A, Lawrence G, Gentry R, 2006. Acrylamide: Review of toxicity data and dose-response analyses for cancer and noncancer effects. Crit Rev Toxicol 36(6-7):481–608.16973444
Shiraishi Y. 1978. Chromosome aberrations induced by monomeric acrylamide in bone marrow and germ cells of mice. Mutat Res 57:313–324.672931
Sickles DW. 1991. Toxic neurofilamentous axonopathies and fast anterograde axonal transport. III. Recovery from single injections and multiple dosing effects of acrylamide and 2,5-hexanedione. Toxicol Appl Pharmacol 108(3):390–396.2020966
Sickles DW, Brady ST, Testino A, 1996. Direct effect of the neurotoxicant acrylamide on kinesin-based microtubule motility. J Neurosci Res 46(1):7–17.8892100
Smith MK, Zenick H, Preston RJ, 1986. Dominant lethal effects of subchronic acrylamide administration in the male Long-Evans rat. Mutat Res 173(4):273–277.3951475
Sobel W, Bond GG, Parsons TW, 1986. Acrylamide cohort mortality study. Br J Ind Med 43(11):785–788.3790460
Solomon JJ, Fedyk J, Mukai F, 1985. Direct alkylation of 2’-deoxynucleosides and DNA following in vitro reaction with acrylamide. Cancer Res 45:3465–3470.4016731
Sörgel F, Weissenbacher R, Kinzig-Schippers M, 2002. Acrylamide: Increased concentrations in homemade food and first evidence of its variable absorption from food, variable metabolism and placental and breast milk transfer in humans. Chemotherapy 48(6):267–274.12673101
Spencer PS, Schaumburg HH. 1974. A review of acrylamide neurotoxicity. Part I. Properties, uses and human exposure. Can J Neurol Sci 1(2):143–150.4373158
Spencer PS, Schaumburg HH. 1977. Ultrastructural studies of the dying back process. IV. Differential vulnerability of PNS and CNS fibers in experimental central-peripheral distal axonopathies. J Neuropath Exp Neurol 36:300–320.190358
Spencer PS, Sabri MI, Schaumberg HH, 1979. Does a defect of energy metabolism in the nerve fiber underlie axonal degeneration in polyneuropathies? Ann Neurol 5:501–507.89830
SRI. 2008. Acrylamide. In: 2008 Directory of chemical producers. Menlo Park, CA: SRI Consulting, 410.
Stadler RH, Blank I, Varga N, 2002. Acrylamide from Maillard reaction products. Nature 419(6906):449–450.12368845
Stamler JS, Lamas S, Fang C. 2001. Nitrosylation: the prototypic redox-based signaling mechanism. Cell 106(6):675–683.11572774
Sublet VH, Zenick H, Smith MK. 1989. Factors associated with reduced fertility and implantation rates in females mated to acrylamide-treated rats. Toxicology 55:53–67.2711406
Sumner SC, Fennell TR, Moore TA, 1999. Role of cytochrome P450 2E1 in the metabolism of acrylamide and acrylonitrile in mice. Chem Res Toxicol 12(11):1110–1116.10563837
Sumner SC, Macneela JP, Fennell TR. 1992. Characterization and quantitation of urinary metabolites of (1,2,3-13carbon)acrylamide in rats and mice using 13carbon nuclear magnetic resonance spectroscopy. Chem Res Toxicol 5(1):81–89.1581543
Sumner SC, Williams CC, Snyder RW, 2003. Acrylamide: A comparison of metabolism and hemoglobin adducts in rodents following dermal, intraperitoneal, oral, or inhalation exposure. Toxicol Sci 75(2):260–270.12883088
Suzuki K, Pfaff L. 1973. Acrylamide neuropathy in rats. Acta Neuropathol (Berl) 24(3):197–213.4357171
Svensson K, Abramsson L, Becker W, 2003. Dietary intake of acrylamide in Sweden. Food Chem Toxicol 41(11):1581–1586.12963011
Swaen GM, Haidar S, Burns CJ, 2007. Mortality study update of acrylamide workers. Occup Environ Med 64(6):396–401.17259165
Sweeney LM, Kirman CR, Gargas ML, 2010. Development of a physiologically-based toxicokinetic model of acrylamide and glycidamide in rats and humans. Food Chem Toxicol 48(2):668–685.19948202
Takahashi M, Ohara T, Hashimoto K. 1971. Electrophysiological study of nerve injuries in workers handling acrylamide. Int Arch Arbeitsmed 28(1):1–11.4326044
Takahashi M, Shibutani M, Nakahigashi J, 2009. Limited lactational transfer of acrylamide to rat offspring on maternal oral administration during the gestation and lactation periods. Arch Toxicol [March 21; Epub ahead of print].
Takami S, Imai T, Cho Y- M, 2011. Juvenile rats do not exhibit elevated sensitivity to acrylamide toxicity after oral administration for 12 weeks. J Appl Toxicol [April 29, 2011; Epub ahead of print]
Tanii H, Hashimoto K. 1983. Neurotoxicity of acrylamide and related compounds in rats: Effects on rotarod performance, morphology of nerves and neurotubulin. Arch Toxicol 54(3):203–214.6661030
Tareke E, Rydberg P, Karlsson P, 2002. Analysis of acrylamide, a carcinogen formed in heated foodstuffs. J Agric Food Chem 50(17):4998–5006.12166997
Tareke E, Twaddle NC, McDaniel LP, 2006. Relationships between biomarkers of exposure and toxicokinetics in Fischer 344 rats and B6C3F1 mice administered single doses of acrylamide and glycidamide and multiple doses of acrylamide. Toxicol Appl Pharmacol 217(1):63–75.17007897
Tardiff RG, Gargas ML, Kirman CR, 2010. Estimation of safe dietary intake levels of acrylamide for humans. Food Chem Toxicol 48(2):658–667.19948203
Thomas K, Colborn T. 1992. Organochlorine endocrine disruptors in human tissue. In: Colborn T, Clement C, eds. Chemically induced alterations in sexual and functional development: The wildlife/human connection. Princeton, NJ: Princeton Scientific Publishing, 365–394.
Tilson HA, Cabe PA. 1979. The effects of acrylamide given acutely or in repeated doses on fore- and hindlimb function of rats. Toxicol Appl Pharmacol 47(2):253–260.452021
Tong GC, Cornwell WK, Means GE. 2004. Reactions of acrylamide with glutathione and serum albumin. Toxicol Lett 147:127–131.14757316
TRI 09 2011. 2011. TRI Explorer. Providing access to EPA’s toxics release inventory data. U. S. Environmental Protection Agency. http://www.epa.gov/triexplorer. August 9, 2011.
Tripathy NK, Patnaik KK, Nabi MJ. 1991. Acrylamide is genotoxic to the somatic and germ cells of Drosophila melanogaster. Mutat Res 259(1):21–27.1899131
Tsuda H, Shimizu CS, Taketomi MK, 1993. Acrylamide; induction of DNA damage, chromosomal aberrations and cell transformation without gene mutations. Mutagenesis 8(1):23–29.8450763
Twaddle NC, McDaniel LP, Gamboa da Costa G, 2004. Determination of acrylamide and glycidamide serum toxicokinetics in B6C3F1 mice using LC-ES/MS/MS. Cancer Lett 207(1):9–17.15050729
Tyl RW, Friedman MA. 2003. Effects of acrylamide on rodent reproductive performance. Reprod Toxicol 17(1):1–13.12507653
Tyl RW, Friedman MA, Losco PE, 2000a. Rat two-generation reproduction and dominant lethal study of acrylamide in drinking water. Reprod Toxicol 14(5):385–401.11020651
Tyl RW, Marr MC, Myers CB, 2000b. Relationship between acrylamide reproductive and neurotoxicity in male rats. Reprod Toxicol 14(2):147–157.10825678
Union Carbide Corporation. 1947. Range finding tests on acrylamide with cover letter. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8D. EPA878212200. OTS206058.
Urban M, Kavvadias D, Riedel K, 2006. Urinary mercapturic acids and a hemoglobin adduct for the dosimetry of acrylamide exposure in smokers and nonsmokers. Inhal Toxicol 18(10):831–839.16774873
van Dijk-Looijaard AM, van Genderen J. 2000. Levels of exposure from drinking water. Food Chem Toxicol 38(Suppl. 1):S37–S42.10717369
Vesper HW, Bernert JT, Ospina M, 2007. Assessment of the relation between biomarkers for smoking and biomarkers for acrylamide exposure in humans. Cancer Epidemiol Biomarkers Prev 16:2471–2478.18006939
Vesper HW, Caudill SP, Osterloh JD, 2010. Exposure of the U.S. population to acrylamide in the National Health and Nutrition Examination Survey 2003-2004. Environ Health Perspect 118:278–283.20123601
Vesper HW, Ospina M, Meyers T, 2006. Automated method for measuring globin adducts of acrylamide and glycidamide at optimized Edman reaction conditions. Rapid Commun Mass Spectrom 20:959–964.16479554
Vesper HW, Slimani N, Hallmans G, 2008. Cross-sectional study on acrylamide hemoglobin adducts in subpopulations from the European Prospective Investigation into Cancer and Nutrition (EPIC) study. J Agric Food Chem 56(15):6046–6053.18624432
Vieira I, Sonnier M, Cresteil T. 1996. Developmental expression of CYP2E1 in the human liver: Hypermethylation control of gene expression during the neonatal period. Eur J Biochem 238(2):476–483.8681961
Von Stedingk H, Rydberg P, Törnqvist. 2010. A new modified Edman procedure for analysis of N-terminal valine adducts in hemoglobin by LC-MS/MS. J Chromatog B 878:2483–2490.
Von Tungeln LS, Churchwell MI, Doerge DR, 2009. DNA adduct formation and induction of micronuclei and mutations in B6C3F1/Tk mice treated neonatally with acrylamide or glycidamide. Int J Cancer 124(9):2006–2015.19123476
Walden R, Squibb RE, Schiller CM. 1981. Effects of prenatal and lactational exposure to acrylamide on the development of intestinal enzymes in the rat. Toxicol Appl Pharmacol 58:363–369.7245209
Walker K, Hattis D, Russ A, 2007. Approaches to acrylamide physiologically based toxicokinetic modeling for exploring child-adult dosimetry differences. J Toxicol Environ Health A 70(24):2033–2055.18049993
Wang H, Huang P, Lie T, 2010a. Reproductive toxicity of acrylamide-treated male rats. Repro Toxicol 29:225–230.
Wang R, McDaniel LP, Manjanatha MG, 2010b. Mutagenicity of acrylamide and glycidamide in the testes of Big Blue mice. Toxicol Sci 117(1):72–80.20581126
Warr TJ, Parry JM, Callander RD, 1990. Methyl vinyl sulphone: A new class of Michael-type genotoxin. Mutat Res 245:191–199.2233840
West JR, Smith HW, Chasis H. 1948. Glomerular filtration rate, effective renal blood flow, and maximal tubular excretory capacity in infancy. J Pediatr 32:10–18.18920567
WHO. 2000. Air quality guidelines. 2nd edition. Geneva, Switzerland: World Health Organization. http://www.euro.who.int/air/activities/20050223_4. May 11, 2009.
WHO. 2002. Health implications of acrylamide in food. World Health Organization. http://www.who.int/foodsafety/publications/chem/en/acrylamide_full.pdf. August 3, 2011.
WHO. 2003. Acrylamide in drinking-water. World Health Organization. WHO/SDE/WSH/03.04/71. http://www.who.int/water_sanitation_health/dwq/chemicals/acrylamide.pdf. August 3, 2011.
WHO. 2008. Guidelines for drinking-water quality. 3rd edition. Geneva, Switzerland: World Health Organization. http://www.who.int/water_sanitation_health/dwq/gdwq3/en/. August 3, 2011.
Widdowson EM, Dickerson JWT. 1964. Chemical composition of the body. In: Comar CL, Bronner F, eds. Mineral metabolism: An advance treatise. Volume II: The elements Part A. New York, NY: Academic Press, 1–247.
Wilson KM, Balter K, Adami HO, 2009a. Acrylamide exposure measured by food frequency questionnaire and hemoglobin adduct levels and prostate cancer risk in the cancer of the prostate in Sweden study. Int J Cancer 124(10):2384–2390.19142870
Wilson KM, Mucci LA, Cho E, 2009b. Dietary acrylamide intake and risk of premenopausal breast cancer. Am J Epidemiol 169(8):954–961.19224978
Wilson KM, Mucci LA, Rosner BA, 2010. A prospective study on dietary acrylamide intake and the risk for breast, endometrial, and ovarian cancers. Cancer Epidemiol Biomarkers Prev 19(10):2503–2515.20693310
Wirfält E, Paulsson B, Törnqvist M, 2008. Associations between estimated acrylamide intakes and hemoglobin AA adducts in a sample from the Malmö diet and cancer cohort. Eur J Clin Nutr 62:314–323.17356560
Wise LD, Gordon LR, Soper KA, 1995. Developmental neurotoxicity evaluation of acrylamide in Sprague-Dawley rats. Neurotoxicol Teratol 17(2):189–198.7760778
Working PK, Bentley KS, Hurtt ME, 1987. Dominant lethal assay of acrylonitrile and acrylamide in the male rat. [Abstract]. Environ Mutagen 9(Suppl 8):115.
Xiao Y, Tates AD. 1994. Increased frequencies of micronuclei in early spermatids of rats following exposure of young primary spermatocytes to acrylamide. Mutat Res 309(2):245–253.7520982
Yener Y, Dikmenli M. 2009. Increased micronucleus frequency in rat bone marrow after acrylamide treatment. Food Chem Toxicol 47:2120–2123.19500643
Young JF, Luecke RH, Doerge DR. 2007. Physiologically based pharmacokinetic/pharmacodynamic model for acrylamide and its metabolites in mice, rats, and humans. Chem Res Toxicol 20(3):388–399.17323977
Yuxin M, Jing S, Meige Z, 2011. Toxicological effects of acrylamide on the reproductive system of weaning male rats. Toxicol Ind Health 27(7):617–627.21415092
Zeiger E. Anderson B, Haworth S, 1987. Salmonella mutagenicity tests. III. Results from the testing of 255 chemicals. Environ Mutagen 9(Suppl 9):1–110.
Zeiger E, Recio L, Fennell TR, 2009. Investigation of the low-dose response in the in vivo induction of micronuclei and adducts by acrylamide. Toxicol Sci 107(1):247–257.18931380
Zenick H, Hope E, Smith MK. 1986. Reproductive toxicity associated with acrylamide treatment in male and female rats. J Toxicol Environ Health 17(4):457–472.3959125
Zhang G, Huang G, Xiao L, 2011. Acrylamide formation in almonds (Prunus dulcis): influences of roasting time and temperature, precursors, varietal selection, and storage. J Agric Food Chem 59:8225–8232.21721575
Zhu YJ, Zeng T, Zhu YB, 2008. Effects of acrylamide on the nervous tissue antioxidant system and sciatic nerve electrophysiology in the rat. Neurochem Res 33(11):2310–2317.18470611
Ziegler EE, Edwards BB, Jensen RL, 1978. Absorption and retention of lead by infants. Pediatr Res 12(1):29–34.643372