# PEER REVIEW

A peer review panel was assembled for acrylamide. The panel consisted of the following members:

1. Herman Bolt, M.D., Ph.D., Professor Emeritus, Leibniz Research Centre for Working Environment and Human Factors, Dortmund, Germany
2. Timothy Fennell, Ph.D., Senior Research Chemist, RTI International, Drug Metabolism and Pharmacokinetics Department, Research Triangle Park, NC
3. James Klaunig, Ph.D., Professor of Public Health, Director, Center for Environmental Health, Indiana University School of Medicine, Indianapolis, IN

These experts collectively have knowledge of acrylamide’s physical and chemical properties, toxicokinetics, key health end points, mechanisms of action, human and animal exposure, and quantification of risk to humans. All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.