# 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Acrylamide is an unsaturated amide that is produced mainly for use as an intermediate in the production of polyacrylamide (Abdelmagic 1982; Haberman 2002). Information regarding the chemical identity of acrylamide is located in Table 4-1.

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Acrylamide is a white or colorless, odorless crystalline solid. Information regarding the physical and chemical properties of acrylamide is located in Table 4-2. Acrylamide is stable at room temperature but can violently polymerize at its melting point or under UV light (Lewis 2000, 2007; O’Neil et al. 2006). Acrid fumes, as well as NO_x_, may be released when it is heated to decomposition (Lewis 2000). Acrylamide is soluble in water, alcohol, and acetone, and is insoluble in benzene and heptanes (Lewis 2007).

Table 4-1 Chemical Identity of Acrylamide

Characteristic | Information | Reference
Chemical name | Acrylamide
Synonym(s) | AAM; acrylagel; acrylic acid amide; acrylic amide; akrylamid (Czech); amresco acryl-40; amid kyseliny akrylove; ethylenecarboxamide; optimum; propenamide; 2-propen-amide; propereamide; propenoic acid amide; vinyl amide | HSDB 2009; Lewis 2000
Registered trade name(s) | No data
Chemical formula | C_3_H_5_NO | HSDB 2009; WHO 2003
Chemical structure | [image]
Identification numbers:
CAS registry | 79-06-1
NIOSH RTECS | NIOSH/AS3325000 | NIOSH 2005
EPA hazardous waste | U007 | HSDB 2009; Lewis 2000
OHM/TADS | No data
DOT/UN/NA/IMDG shipping | UN 2074; IMO 6.1 | HSDB 2009; Lewis 2000
HSDB | 191 | HSDB 2009
NCI | No data
STCC | 49 091 83; 49 131 87 | HSDB 2009; HSDB 2009

CAS = Chemical Abstracts Service; DOT/UN/NA/IMDG = Department of Transportation/United Nations/North America/International Maritime Dangerous Goods Code; EPA = Environmental Protection Agency; HSDB = Hazardous Substances Data Bank; NCI = National Cancer Institute; NIOSH = National Institute for Occupational Safety and Health; OHM/TADS = Oil and Hazardous Materials/Technical Assistance Data System; RTECS = Registry of Toxic Effects of Chemical Substances; STCC = Standard Transport Commodity Code

Table 4-2 Physical and Chemical Properties of Acrylamide

Property | Information | Reference
Molecular weight | 71.08 | Haberman 2002; HSDB 2009
Color | White Colorless | HSDB 2009; Lewis 2000 Lewis 2007; WHO 2003
Physical state | Crystalline solid | HSDB 2009; Lewis 2000 Lewis 2007; WHO 2003
Melting point | 84.5 °C | Lewis 2007
Boiling point | 192.6 °C 87 °C (2 mm) 103 °C (5 mm) 125 ºC (25 mm) | Lide 2008 O’Neil et al. 2006 O’Neil et al. 2006 Lewis 2007; O’Neil et al. 2006
Density at 30 °C/4 °C | 1.122 | HSDB 2009; Lewis 2007
Odor | Odorless | Lewis 2007
Odor threshold:
Water | No data
Air | No data
Solubility:
Water at 0 °C | No data
at 20 °C | 3.711×10^5^ mg/L | HSDB 2009
at 30 °C | 4.048×10^5^ mg/L | HSDB 2009
Organic solvents | Soluble in water, alcohol, acetone | Lewis 2007
| Insoluble in benzene and heptanes | Lewis 2007
Partition coefficients:
Log K_ow_ | −0.67 | HSDB 2009
Log K_oc_ | No data
Vapor pressure
at 25 °C | 0.9 Pa (7×10^−3^ mm Hg) | Haberman 2002; HSDB 2009
at 40 °C | 4.4 Pa (3.3×10^−2^ mm Hg) | Haberman 2002
at 50 °C | 9.3 Pa (7.0×10^−2^ mm Hg) | Haberman 2002
Henry’s law constant:
at 25 °C | 1.7×10^−9^ atm-m^3^/mol (estimated) | HSDB 2009
Autoignition temperature | 424 °C | HSDB 2009
Flash point | 138 °C (closed cup) | HSDB 2009
Flammability limits | No data
Conversion factors (25 °C, 1 atm) | 1 mg/m^3^=0.34 ppm 1 ppm=2.95 mg/m^3^ | HSDB 2009