# CHAPTER 8 REFERENCES

Abbondandolo A, Bonatti S, Corsi C, 1980. The use of organic solvents in mutagenicity testing. Mutat Res 79(2):141–150. 10.1016/0165-1218(80)90082-8.7432372
Abe S, Sasaki M. 1982. SCE as an index of mutagenesis and/or carcinogenesis. In: Sister chromatid exchange. New York, NY: Alan R. Liss, Inc., 461–514.
Agnesi R, Valentini F, Mastrangelo G. 1997. Risk of spontaneous abortion and maternal exposure to organic solvents in the shoe industry. Int Arch Occup Environ Health 69(5):311–316. 10.1007/s004200050153.9192214
Aharonson EF, Menkes H, Gurtner G, 1974. Effect of respiratory airflow rate on removal of soluble vapors by the nose. J Appl Physiol 37(5):654–657. 10.1152/jappl.1974.37.5.654.4436189
Ahonen I, Schimberg RW. 1988. 2,5-Hexanedione excretion after occupational exposure to n-hexane. Br J Ind Med 45(2):133–136. 10.1136/oem.45.2.133.3342196
Akagi SK, Yokelson RJ, Wiedinmyer C, 2011. Emission factors for open and domestic biomass burning for use in atmospheric models. Atmos Chem Phys 11(9):4039–4072. 10.5194/acp-11-4039-2011.
Alaves VM, Sleeth DK, Thiese MS, 2013. Characterization of indoor air contaminants in a randomly selected set of commercial nail salons in Salt Lake County, Utah, USA. Int J Environ Health Res 23(5):419–433. 10.1080/09603123.2012.755152.23286453
Albertini S. 1991. Reevaluation of the 9 compounds reported conclusive positive in yeast Saccharomyces cerevisiae aneuploidy test systems by the Gene-Tox Program using strain D61.M of Saccharomyces cerevisiae. Mutat Res 260(2):165–180. 10.1016/0165-1218(91)90005-7.2046697
Albertini S, Friederich U, Holderegger C, 1988. The in vitro porcine brain tubulin assembly assay: effects of a genotoxic carcinogen (aflatoxin B1), eight tumor promoters and nine miscellaneous substances. Mutat Res 201(2):283–292. 10.1002/em.2850110410.3173378
Albertoni P. 1884. [The effect and transformations of chemicals in vivo in relation to the pathogenicity of acetonemia and diabetes]. Arc Exp Pathol Pharmakol 18(3-4):219–241. 10.1007/BF01833844. (German)
Altshuller AP. 1991. The production of carbon monoxide by the homogeneous NO x-induced photooxidation of volatile organic compounds in the troposphere. J Atmos Chem 13(2):155–182. 10.1007/BF00115971.
Altshuller AP, Cohen IR. 1963. Structural effects on the rate of nitrogen dioxide formation in the photo-oxidation of organic compound-nitric oxide mixtures in air. Int J Air Wat Poll 7(8):787–797.
Amacher DE, Paillet SC, Turner GN, 1980. Point mutations at the thymidine kinase locus in L5178Y mouse lymphoma cells II. Test validation and interpretation. Mutat Res 72(3):447–474. 10.1016/0027-5107(80)90118-9.7453708
American Biogenics Corp. 1986. Ninety day gavage study in albino rats using acetone. Research Triangle Park, NC: Research Triangle Institute. Study 410–2313.
Anbar M, Neta P. 1967. A compilation of specific bimolecular rate constants for the reactions of hydrated electrons, hydrogen atoms and hydroxyl radicals with inorganic and organic compounds in aqueous solution. Int J Appl Radiat Isotopes 18(7):493–523. 10.1016/0020-708x(67)90115-9.
Anselme C, N’Guyen K, Bruchet A, 1985. Characterization of low molecular weight products desorbed from polyethylene tubings. Sci Total Environ 47:371–384. 10.1016/0048-9697(85)90343-2.
Arnold F, Knop G, Ziereis H. 1986. Acetone measurements in the upper troposphere and lower stratosphere—implications for hydroxyl radical abundances. Nature 321(6069):505–507. 10.1038/321505a0.
Arnold SR, Chipperfield MP, Blitz MA, 2004. Photodissociation of acetone: Atmospheric implications of temperature-dependent quantum yields. Geophys Res Lett 31(7):L07110. 10.1029/2003GL019099.
Arnts RR, Meeks SA. 1981. Biogenic hydrocarbon contribution to the ambient air of selected areas. Atmos Environ 15(9):1643–1651.
Ashley DL, Bonin MA, Cardinali FL, 1992. Determining volatile organic compounds in human blood from a large sample population by using purge and trap gas chromatography/mass spectrometry. Anal Chem 64(9):1021–1029. 10.1021/ac00033a011.1590585
Ashley DL, Bonin MA, Cardinali FL, 1994. Blood concentrations of volatile organic compounds in a nonoccupationally exposed US population and in groups with suspected exposure. Clin Chem 40(7 Pt 2):1401–1404.8013127
ATSDR. 1988. Health assessment for Vega Alta public supply wells site: Vega Alta, Puerto Rico, Region 2. CERCLIS No. PRS187147. Atlanta, GA: Agency for Toxic Substances and Disease Registry. PB90139213.
ATSDR. 1989. Decision guide for identifying substance-specific data needs related to toxicological profiles. Agency for Toxic Substances and Disease Registry. Fed Regist 54(174):37618–37634.
ATSDR. 2018. Draft guidance for the preparation of toxicological profiles. Agency for Toxic Substances and Disease Registry. https://www.atsdr.cdc.gov/toxprofiles/guidance/profile_development_guidance.pdf. May 6, 2022.
ATSDR. 2019. Full SPL data. Agency for Toxic Substances and Disease Registry. http://www.atsdr.cdc.gov/SPL/resources. November 6, 2019.
Attarchi M, Golabadi M, Labbafinejad Y, 2013. Combined effects of exposure to occupational noise and mixed organic solvents on blood pressure in car manufacturing company workers. Am J Ind Med 56(2):243–251. 10.1002/ajim.22086.22715117
Axelsson G, Lütz C, Rylander R. 1984. Exposure to solvents and outcome of pregnancy in university laboratory employees. Occup Environ Med 41(3):305–312. 10.1136/oem.41.3.305.
Babeu L, Vaishnav DD. 1987. Prediction of biodegradability for selected organic chemicals. J Ind Microbiol 2(2):107–115. 10.1007/bf01569509.
Bánhegyi G, Garzó T, Antoni F, 1988. Accumulation of phenols and catechols in isolated mouse hepatocytes in starvation or after pretreatment with acetone. Biochem Pharmacol 37(21):4157–4162. 10.1016/0006-2952(88)90110-4.3190754
Barnes DG, Dourson M. 1988. Reference dose (RfD): Description and use in health risk assessments. Regul Toxicol Pharmacol 8(4):471–486.3222488
Barnett CR, Petrides L, Wilson J, 1992. Induction of rat hepatic mixed-function oxidases by acetone and other physiological ketones: their role in diabetes-induced changes in cytochrome P450 proteins. Xenobiotica 22(12):1441–1450. 10.3109/00498259209056694.1494889
Barr-Nea L, Wolman M. 1977. Tumors and amyloidosis in mice painted with crude oil found on bathing beaches. Bull Environ Contam Toxicol 18(3):385–391. 10.1007/BF01683437.332261
Bartley JP, Schwede AM. 2002. Production of volatile compounds in ripening kiwi fruit (Actinidia chinensis). J Agric Food Chem 37(4):1023–1025. 10.1021/jf00088a046.
Basler A. 1986. Aneuploidy-inducing chemicals in yeast evaluated by the micronucleus test. Mutat Res 174(1):11–13. 10.1016/0165-7992(86)90070-9.3517637
Beaumont JJ, Swan SH, Hammond SK, 1995. Historical cohort investigation of spontaneous abortion in the Semiconductor Health Study: epidemiologic methods and analyses of risk in fabrication overall and in fabrication work groups. Am J Ind Med 28(6):735–750. 10.1002/ajim.4700280609.8588561
Bedding ND, McIntyre AE, Perry R, 1982. Organic contaminants in the aquatic environment I. Sources and occurrence. Sci Total Environ 25(2):143–167. 10.1016/0048-9697(82)90083-3.
Berardesca E, Andersen PH, Bjerring P, 1992. Erythema induced by organic solvents: In vivo evaluation of oxygenized and deoxygenized haemoglobin by reflectance spectroscopy. Contact Dermatitis 27(1):8–11. 10.1111/j.1600-0536.1992.tb05190.x.1424602
Blount BC, McElprang DO, Chambers DM, 2010. Methodology for collecting, storing, and analyzing human milk for volatile organic compounds. J Environ Monit 12(6):1265–1273. 10.1039/b927022a.20358052
Boggild MD, Peck RW, Tomson CR. 1990. Acetonitrile ingestion: delayed onset of cyanide poisoning due to concurrent ingestion of acetone. Postgrad Med J 66(771):40–41. 10.1136/pgmj.66.771.40.2349164
Bolková A, Čejková J. 1983. Changes in alkaline and acid phosphatases of the rabbit cornea following experimental exposure to ethanol and acetone: A biochemical and histochemical study. Graefe’s Arch Clin Exp Ophthalmol 220(2):96–99. 10.1007/BF02133880.6862191
Bondoc FY, Bao Z, Hu WY, 1999. Acetone catabolism by cytochrome P450 2E1: studies with CYP2E1-null mice. Biochem Pharmacol 58(3):461–463. 10.1016/s0006-2952(99)00111-2.10424765
Boyd AA, Canosa-Mas CE, King AD, 1991. Use of a stopped-flow technique to measure the rate constants at room temperature for reactions between the nitrate radical and various organic species. J Chem Soc Faraday Trans 87(18):2913–2919. 10.1039/ft9918702913.
Brady JF, Li D, Ishizaki H, 1989. Induction of cytochromes P450IIE1 and P450IIB1 by secondary ketones and the role of P450IIE1 in chloroform metabolism. Toxicol Appl Pharmacol 100(2):342–349. 10.1016/0041-008x(89)90320-7.2781561
Bridie´ AL, Wolff CJM, Winter M. 1979. BOD and COD of some petrochemicals. Water Res 13(7):627–630. 10.1016/0043-1354(79)90011-3.
Brondeau MT, Ban M, Bonnet P, 1989. Acetone compared to other ketones in modifying the hepatotoxicity of inhaled 1,2-dichlorobenzene in rats and mice. Toxicol Lett 49(1):69–78. 10.1016/0378-4274(89)90103-3.2554539
Brown EM, Hewitt WR. 1984. Dose-response relationships in ketone-induced potentiation of chloroform hepato-and nephrotoxicity. Toxicol Appl Pharmacol 76(3):437–453. 10.1016/0041-008X(84)90348-X.6506071
Brown KW, Donnelly KC. 1988. An estimation of the risk associated with the organic constituents of hazardous and municipal waste landfill leachates. Haz Waste Haz Mater 5(1):1–30. 10.1089/hwm.1988.5.1.
Brown WD, Setzer JV, Dick RB, 1987. Body burden profiles of single and mixed solvent exposures. J Occup Environ Med 29(11):877–883.
Bruckner JV, Peterson RG. 1981a. Evaluation of toluene and acetone inhalant abuse: I. Pharmacology and pharmacodynamics. Toxicol Appl Pharmacol 61(1):27–38. 10.1016/0041-008X(81)90004-1.7197407
Bruckner JV, Peterson RG. 1981b. Evaluation of toluene and acetone inhalant abuse: II. Model development and toxicology. Toxicol Appl Pharmacol 61(3):302–312. 10.1016/0041-008X(81)90004-1.7330874
Brugnone F, Perbellini L, Grigolini L, 1978. Solvent exposure in a shoe upper factory. Int Arch Occup Environ Health 42(3-4):355–363. 10.1007/BF00377791.
Brugnone F, Perbellini L, Gaffuri E, 1980. Biomonitoring of industrial solvent exposures in workers’ alveolar air. Int Arch Occup Environ Health 47(3):245–261. 10.1007/BF00381682.7461851
Bruss ML. 1989. Ketogenesis and ketosis. In: Kaneko JJ, ed. Clinical biochemistry of domestic animals. 4th ed. Academic Press, 86–105.
Burk T, Zarus G. 2013. Community exposures to chemicals through vapor intrusion: A review of past ATSDR public health evaluations. J Environ Health 75(9):36–41.
Burmaster DE. 2010. The new pollution: Groundwater contamination. Environ Sci Policy Sustain Dev 24(2):6–36. 10.1080/00139157.1982.9932469.
Buron G, Hacquemand R, Pourie G, 2009. Inhalation exposure to acetone induces selective damage on olfactory neuroepithelium in mice. Neurotoxicology 30(1):114–120. 10.1016/j.neuro.2008.11.005.19071159
Cakmak A, Ekici A, Ekici M, 2004. Respiratory findings in gun factory workers exposed to solvents. Respir Med 98(1):52–56. 10.1016/j.rmed.2003.08.006.14959814
Campbell DN, Moore RH. 1979. The quantitative determination of acrylonitrile, acrolein, acetonitrile and acetone in workplace air. Am Ind Hyg Assoc J 40(10):904–909. 10.1080/15298667991430479.525617
Carpenter CP, Smyth HF. 1946. Chemical burns of the rabbit cornea. Am J Ophthalmol 29(11):1363–1372. 10.1016/0002-9394(46)92032-6.20276971
Carriere V, De Waziers I, Courtois YA, 1992. Cytochrome P450 induction and mutagenicity of 2-aminoanthracene (2AA) in rat liver and gut. Mutat Res 268(1):11–20. 10.1016/0165-1161(92)91088-9.1378177
Casazza JP, Felver ME, Veech RL. 1984. The metabolism of acetone in rat. J Biol Chem 259:231–236.6706932
Cavanagh LA, Schadt CF, Robinson E. 1969. Atmospheric hydrocarbon and carbon monoxide measurements at Point Barrow, Alaska. Environ Sci Technol 3(3):251–257. 10.1021/es60026a002.
CDR. 2012. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2012. May 6, 2022.
CDR. 2016. Chemical data reporting. U.S. Environmental Protection Agency. https://www.epa.gov/chemical-data-reporting/access-cdr-data#2016. May 6, 2022.
Ceballos DM, Craig J, Fu X, 2019. Biological and environmental exposure monitoring of volatile organic compounds among nail technicians in the greater Boston area. Indoor Air 29(4):539–550. 10.1111/ina.12564.31112343
Charbonneau M, Tuchweber B, Plaa GL. 1986c. Acetone potentiation of chronic liver injury induced by repetitive administration of carbon tetrachloride. Hepatology 6(4):694–700. 10.1002/hep.1840060426.3733003
Charbonneau M, Couture J, Plaa GL. 1991. Inhalation versus oral administration of acetone: effect of the vehicle on the potentiation of CC14-induced liver injury. Toxicol Lett 57(1):47–54. 10.1016/0378-4274(91)90118-P.2048161
Charbonneau M, Iijima M, Cote MG, 1985. Temporal analysis of rat liver injury following potentiation of carbon tetrachloride hepatotoxicity with ketonic or ketogenic compounds. Toxicology 35(2):95–112. 10.1016/0300-483x(85)90025-3.4002241
Charbonneau M, Brodeur J, du Souich P, 1986a. Correlation between acetone-potentiated CCl4-induced liver injury and blood concentrations after inhalation or oral administration. Toxicol Appl Pharmacol 84(2):286–294. 10.1016/0041-008X(86)90136-5.3715876
Charbonneau M, Oleskevich S, Brodeur J, 1986b. Acetone potentiation of rat liver injury induced by trichloroethylene-carbon tetrachloride mixtures. Fundam Appl Toxicol 6(4):654–661. 10.1093/toxsci/6.4.654.3710035
Charbonneau M, Perreault F, Greselin E, 1988. Assessment of the minimal effective dose of acetone for potentiation of the hepatotoxicity induced by trichloroethylene-carbon tetrachloride mixtures. Fundam Appl Toxicol 10(3):431–438. 10.1016/0272-0590(88)90289-8.3371582
Chatfield RB, Gardner EP, Calvert JG. 1987. Sources and sinks of acetone in the troposphere: Behavior of reactive hydrocarbons and a stable product. J Geophys Res 92(D4):4208–4216. 10.1029/JD092iD04p04208.
Chatterton CC, Elliott RB. 1946. Acute acetone poisoning from leg casts of a synthetic plaster substitute. J Am Med Assoc 130(17):1222–1223. 10.1001/jama.1946.02870170028006b.21022541
Chen T, Kavanagh C, Chang CC, 1984. Inhibition of metabolic cooperation in Chinese hamster V79 cells by various organic solvents and simple compounds. Cell Biol Toxicol 1(1):155–171. 10.1007/BF00125572.6400921
Chen L, Lee M, Hong JY, 1994. Relationship between cytochrome P450 2E1 and acetone catabolism in rats as studied with diallyl sulfide as an inhibitor. Biochem Pharmacol 48(12):2199–2205. 10.1016/0006-2952(94)00435-8.7811301
Chen JK, Wu MS, Yang CW, 2002. Guillain-Barre syndrome associated with minimal change glomerulopathy and tubular dysfunction - related to acetone-based organic solvent? Am J Nephrol 22(5-6):560–565.12381959
Chieli E, Saviozzi M, Puccini P, 1990. Possible role of the acetone-inducible cytochrome P-450IIE1 in the metabolism and hepatotoxicity of thiobenzamide. Arch Toxicol 64(2):122–127. 10.1007/BF01974397.2350230
Chou WL, Speece RE, Siddiqi RH. 1978. Acclimation and degradation of petrochemical wastewater components by methane fermentation. Biotechnol Bioeng Symp 8:391–414.
Christoph GR, Malley LA, Stadler JC. 2003. Subchronic inhalation exposure to acetone vapor and scheduled controlled operant performance in male rats. Inhal Toxicol 15(8):781–798. 10.1080/08958370390217846.12825153
Clewell HJ, Andersen ME. 1985. Risk assessment extrapolations and physiological modeling. Toxicol Ind Health 1(4):111–131.3843496
Clewell HJ, Gentry PR, Gearhart JM, 2001. Development of a physiologically based pharmacokinetic model of isopropanol and its metabolite acetone. Toxicol Sci 63(2):160–172. 10.1093/toxsci/63.2.160.11568359
Coleman DL. 1980. Acetone metabolism in mice: increased activity in mice heterozygous for obesity genes. Proc Natl Acad Sci U S A 77(1):290–293. 10.1073/pnas.77.1.290.6928621
Coleman EC, Ho C, Chang SS. 2002. Isolation and identification of volatile compounds from baked potatoes. J Agric Food Chem 29(1):42–48. 10.1021/jf00103a012.
Coleman WE, Lingg RD, Melton RG, 1976. The occurrence of volatile organics in five drinking water supplies using gas chromatography/mass spectrometry. In: Identification analysis of organic pollutants in water. Ann Arbor, MI: Ann Arbor Science, 305–327.
Cometto-Muniz JE, Cain WS. 1995. Relative sensitivity of the ocular trigeminal, nasal trigeminal and olfactory systems to airborne chemicals. Chem Senses 20(2):191–198. 10.1093/chemse/20.2.191.7583011
Conkle JP, Camp BJ, Welch BE. 1975. Trace composition of human respiratory gas. Arch Environ Health 30(6):290–295. 10.1080/00039896.1975.10666702.1137435
Connecticut Agricultural Experiment Station. 1986. Groundwater contamination: movement of organic pollutants in the Granby landfill. New Haven, CT: Connecticut Agricultural Experiment Station. Bulletin 833. https://portal.ct.gov/-/media/CAES/DOCUMENTS/Publications/Bulletins/B833pdf.pdf. May 6, 2022.
Corwin JF. 1969. Volatile oxygen-containing organic compounds in sea water: determination. Bull Mar Sci 19(3):504–509.
Costa C, Pasquale RD, Silvari V, 2006. In vitro evaluation of oxidative damage from organic solvent vapours on human skin. Toxicol In Vitro 20(3):324–331. 10.1016/j.tiv.2005.08.007.16169704
Counts ME, Morton MJ, Laffoon SW, 2005. Smoke composition and predicting relationships for international commercial cigarettes smoked with three machine-smoking conditions. Regul Toxicol Pharmacol 41(3):185–227. 10.1016/j.yrtph.2004.12.002.15748796
Cox RA, Patrick KF, Chant SA. 1981. Mechanism of atmospheric photooxidation of organic compounds. Reactions of alkoxy radicals in oxidation of n-butane and simple ketones. Environ Sci Technol 15(5):587–592. 10.1021/es00087a011.22283953
Cox RA, Derwent RG, Williams MR. 2002. Atmospheric photooxidation reactions. Rates, reactivity, and mechanism for reaction of organic compounds with hydroxyl radicals. Environ Sci Technol 14(1):57–61. 10.1021/es60161a007.
Cunningham J, Sharkawi M, Plaa GL. 1989. Pharmacological and metabolic interactions between ethanol and methyl n-butyl ketone, methyl isobutyl ketone, methyl ethyl ketone, or acetone in mice. Fundam Appl Toxicol 13(1):102–109. 10.1016/0272-0590(89)90310-2.2767350
Dąbek A, Wojtala M, Pirola L, 2020. Modulation of cellular biochemistry, epigenetics and metabolomics by ketone bodies. Implications of the ketogenic diet in the physiology of the organism and pathological states. Nutrients 12(3):788. 10.3390/nu12030788.32192146
Dalgaard M, Ostergaard G, Lam HR, 2000. Toxicity study of di(2-ethylhexyl)phthalate (DEHP) in combination with acetone in rats. Pharmacol Toxicol 86(2):92–100. 10.1034/j.1600-0773.2000.d01-17.x.10728921
Dalton P, Dilks D, Hummel T. 2006. Effects of long-term exposure to volatile irritants on sensory thresholds, negative mucosal potentials, and event-related potentials. Behav Neurosci 120(1):180–187. 10.1037/0735-7044.120.1.180.16492128
Dalton P, Wysocki CJ, Brody MJ, 1997. Perceived odor, irritation, and health symptoms following short-term exposure to acetone. Am J Ind Med 31(5):558–569. 10.1002/(sici)1097-0274(199705)31:5<558::aid-ajim10>3.0.co;2-y.9099358
Datta RK, Rao KN. 1979. Kinetics of reactions of singlet molecular oxygen (1ΔG) with organic compounds. Indian J Chem 18A:102–105.
Day EA, Anderson DF. 2002. Cheese flavor, gas chromatographic and mass spectral identification of neutral components of aroma faction and blue cheese. J Agric Food Chem 13(1):2–4. 10.1021/jf60137a001.
de Almeida BB, Mathias MG, Portari GV, 2010. Chronic acetonemia alters liver oxidative balance and lipid content in rats. A model of Nash? Exp Clin Endocrinol Diabetes 118(1):61–63. 10.1055/s-0029-1225649.19856260
De Ceaurriz J, Micillino JC, Marignac B, 1984. Quantitative evaluation of sensory irritating and neurobehavioural properties of aliphatic ketones in mice. Food Chem Toxicol 22(7):545–549. 10.1016/0278-6915(84)90225-4.6540229
De Flora S. 1981. Study of 106 organic and inorganic compounds in the Salmonella/microsome test. Carcinogenesis 2(4):283–298. 10.1093/carcin/2.4.283.7023727
De Flora S, Zanacchi P, Camoirano A, 1984. Genotoxic activity and potency of 135 compounds in the Ames reversion test and in a bacterial DNA-repair test. Mutat Res 133(3):161–198. 10.1016/0165-1110(84)90016-2.6374443
De Medinilla J, Espigares M. 1988. Contamination by organic solvents in auto paint shops. Ann Occup Hyg 32(4):509–513.3228264
DeMarini DM, Lawrence BK, Brooks HG, 1991. Compatibility of organic solvents with the Microscreen prophage-induction assay: solvent--mutagen interactions. Mutat Res 263(2):107–113. 10.1016/0165-7992(91)90067-e.1828534
DeMaster EG, Stevens JM. 1988. Acute effects of the aldehyde dehydrogenase inhibitors, disulfiram, pargyline and cyanamide, on circulating ketone body levels in the rat. Biochem Pharmacol 37(2):229–234. 10.1016/0006-2952(88)90722-8.3342079
Denda M, Wood LC, Emami S, 1996. The epidermal hyperplasia associated with repeated barrier disruption by acetone treatment or tape stripping cannot be attributed to increased water loss. Arch Dermatol Res 288(5-6):230–238. 10.1007/BF02530090.8738565
DePass LR, Ballantyne B, Fowler EH, 1989. Dermal oncogenicity studies on two methoxysilanes and two ethoxysilanes in male C3H mice. Fundam Appl Toxicol 12(3):579–583. 10.1016/0272-0590(89)90030-4.2731670
DeWalle FB, Chian ES K. 1981. Detection of trace organics in well water near a solid waste landfill. J Am Water Works Assoc 73(4):206–211. 10.1002/j.1551-8833.1981.tb04681.x.
Dey A, Cederbaum AI. 2007. Induction of cytochrome promotes liver injury in ob/ob mice. Hepatology 45(6):1355–1365. 10.1002/hep.21603.17538970
Dick RB, Setzer JV, Taylor BJ, 1989. Neurobehavioural effects of short duration exposures to acetone and methyl ethyl ketone. Br J Ind Med 46(2):111–121. 10.1136/oem.46.2.111.2923821
Dietz DD, Leininger JR, Rauckman EJ, 1991. Toxicity studies of acetone administered in the drinking water of rodents. Toxicol Sci 17(2):347–360. 10.1093/toxsci/17.2.347.
Dilling WL, Lickly LC, Lickly TD, 1984. Organic photochemistry. 19. Quantum yields for O,O-diethyl O-(3,5,6-trichloro-2-pyridinyl) phosphorothioate (chlorpyrifos) and 3,5,6-trichloro-2-pyridinol in dilute aqueous solutions and their environmental phototransformation rates. Environ Sci Technol 18(7):540–543. 10.1021/es00125a011.
Dimitriades B, Joshi SB. 1977. Application of reactivity criteria in oxidant-related emission control in the USA. In: International conference on photochemical oxidant pollution and its control. Research Triangle Park, NC: U.S. Environmental Protection Agency. 705–711. PB264233. EPA600377001B.
Ding X, Coon MJ. 1990. Induction of cytochrome P-450 isozyme 3a (P-450IIE1) in rabbit olfactory mucosa by ethanol and acetone. Drug Metab Dispos 18(5):742–745.1981730
DiPaolo JA, Donovan P, Nelson R. 1969. Quantitative studies of in vitro transformation by chemical carcinogens. J Natl Cancer Inst 42(5):867–874.4182072
DiVincenzo GD, Yanno FJ, Astill BD. 1973. Exposure of man and dog to low concentrations of acetone vapor. Am Ind Hyg Assoc J 34(8):329–336. 10.1080/0002889738506857.4747727
DOE. 2018a. Table 4: Protective Action Criteria (PAC) Rev. 29 (mg/m3): Based on applicable 60-minute AEGLs, ERPGs, or TEELs (Chemicals listed in alphabetical order). https://edms.energy.gov/pac/docs/Revision_29A_Table4.pdf. January 28, 2022.
DOE. 2018b. Protective action criteria (PAC) with AEGLs, ERPGs, & TEELs: Rev. 29A, June 2018. U.S. Department of Energy. https://edms.energy.gov/pac/. April 12, 2020.
Dowty BJ, Laseter JL, Storer J. 1976. The transplacental migration and accumulation in blood of volatile organic constituents. Pediatr Res 10(7):696–701. 10.1203/00006450-197607000-00013.934736
Drel VR, Mashtalir N, Ilnytska O, 2006. The leptin-deficient (ob/ob) mouse: a new animal model of peripheral neuropathy of type 2 diabetes and obesity. Diabetes 55(12):3335–3343. 10.2337/db06-0885.17130477
Egle JL. 1973. Retention of inhaled acetone and ammonia in the dog. Am Ind Hyg Assoc J 34(12):533.4770675
EHRT. 1987. Screening of priority chemicals for reproductive hazards: Benzethonium chloride (CAS No. 121-54-0); 3-ethoxy-1-propanol (CAS No. 111-35-3); acetone (CAS No. 67-64-1). Cincinnati, OH: National Institute for Occupational Safety and Health. Environmental Health Research & Testing, Inc. PB89139083.
Eisenreich SJ, Looney BB, Thornton JD. 2002. Airborne organic contaminants in the Great Lakes ecosystem. Environ Sci Technol 15(1):30–38. 10.1021/es00083a002.
Elovaara E, Vainio H, Aitio A. 1990. Pulmonary toxicity of inhaled styrene in acetone-, phenobarbital- and 3-methylcholanthrene-treated rats. Arch Toxicol 64(5):365–369. 10.1007/BF01973457.2403287
Elovaara E, Engstrom K, Nakajima T, 1991. Metabolism of inhaled styrene in acetone-, phenobarbital- and 3-methylcholanthrene-pretreated rats: stimulation and stereochemical effects by induction of cytochromes P450IIE1, P450IIB and P450IA. Xenobiotica 21(5):651–661. 10.3109/00498259109039505.1949898
Environment Canada. 2014. Screening assessment: Acetone CAS RN 67-64-1. Environment Canada. Cat. No.: En14-196/2014E-PDF. https://www.ec.gc.ca/ese-ees/CB62CB1D-CBDA-49F2-B617-2FBDE81465FB/FSAR_Acetone_EN.pdf. May 6, 2022.
EPA. 1975. Identification of organic compounds in effluents from industrial sources. U.S. Environmental Protection Agency. EPA560375002.
EPA. 1979. Identification of organic compounds in industrial effluent discharges. Athens, GA: U.S. Environmental Protection Agency. PB294794. EPA600479016. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=9101LV4K.txt. May 6, 2022.
EPA. 1985a. Atmospheric reaction products from hazardous air pollutant degradation. Research Triangle Park: U.S. Environmental Protection Agency. EPA600S385028.
EPA. 1985b. Determination of toxic chemicals in effluent from household septic tanks. Cincinnati, OH: U.S. Environmental Protection Agency.
EPA. 1986. Evaluation of alternatives to toxic organic paint strippers. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S286063.
EPA. 1988a. Prohibitions on land disposal. U.S. Environmental Protection Agency. Code of Federal Regulations. 40 CFR 268.30, 268.40, and 268.41.
EPA. 1988b. Superfund record of decision: Summit National, OH. First remedial action. U.S. Environmental Protection Agency. PB89225908. EPARODR0588068.
EPA. 1989. Compilation and speciation of national emissions factors for consumer/commercial solvent use information compiled to support urban air toxics assessment studies. Research Triangle Park, NC: U.S. Environmental Protection Agency. PB89207203. EPA450289008
EPA. 1990. Project summary: Removal and fate of RCRA and CERCLA toxic organic pollutants in wastewater treatment. Cincinnati, OH: U.S. Environmental Protection Agency. EPA600S289026.
EPA. 1991. Hazardous waste injection restriction. U.S. Environmental Protection Agency. Fed Regist 55:3876.
EPA. 1996. Method 8260B: Volatile organic compounds by gas chromatography/mass spectrometry (GC/MS). U.S. Environmental Protection Agency.
EPA. 1999. Common contaminants found at superfund sites. Washington, DC: U.S. Environmental Protection Agency. PB98963217. OSWER9203117A. EPA540R98008. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=10002AYA.txt. May 6, 2022.
EPA. 2003. Chemical assessment summary: Acetone; CASRN 67-64-1. Integrated Risk Information System. U.S. Environmental Protection Agency.
EPA. 2005. Toxic chemical release inventory reporting forms and instructions: Revised 2004 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA260B05001.
EPA. 2009. National primary drinking water regulations. U.S. Environmental Protection Agency. EPA816F09004.
EPA. 2011. Background indoor air concentrations of volatile organic compounds in North American residences (1990-2005): A compilation of statistics for assessing vapor intrusion. Washington, DC: U.S. Environmental Protection Agency. EPA530R10001. https://nepis.epa.gov/Exe/ZyPURL.cgi?Dockey=P100GL6W.txt. May 6, 2022.
EPA. 2018a. 2018 Edition of the drinking water standards and health advisories tables. U.S. Environmental Protection Agency. EPA822F18001. https://semspub.epa.gov/work/HQ/100002014.pdf. May 6, 2022.
EPA. 2018b. Acetone results - AEGL Program. U.S. Environmental Protection Agency. https://www.epa.gov/aegl/acetone-results-aegl-program. April 4, 2019.
EPA. 2018c. About acute exposure guideline levels (AEGLs). U.S. Environmental Protection Agency. https://www.epa.gov/aegl/about-acute-exposure-guideline-levels-aegls. July 26, 2018.
EPA. 2020. Toxic chemical release inventory reporting forms and instructions: Revised 2019 version. Section 313 of the Emergency Planning and Community Right-to-Know Act (Title III of the Superfund Amendments and Reauthorization Act of 1986). U.S. Environmental Protection Agency. EPA740B19037. https://ordspub.epa.gov/ords/guideme_ext/guideme_ext/guideme/file/ry_2019_rfi.pdf. May 6, 2022.
EPA. 2021. Air quality system (AQS): Acetone. U.S. Environmental Protection Agency. https://www.epa.gov/aqs. January 10, 2021.
Ernstgard L, Gullstrand E, Johanson G, 1999. Toxicokinetic interactions between orally ingested chlorzoxazone and inhaled acetone or toluene in male volunteers. Toxicol Sci 48(2):189–196. 10.1093/toxsci/48.2.189. 8/12/2020.10353310
Ernstgard L, Sjogren B, Warholm M, 2003. Sex differences in the toxicokinetics of inhaled solvent vapors in humans 2. 2-propanol. Toxicol Appl Pharmacol 193(2):158–167. 10.1016/j.taap.2003.08.005.14644618
Ettinger MB. 1956. Biochemical oxidation characteristics of stream-pollutant organics. Indus Eng Chem 48(2):256–259. 10.1021/ie50554a030.
Fastlich E. 1976. Detection of volatile solvents in gastric contents by gas phase infrared spectrophotometry. J Assoc Off Anal Chem 59(1):130–133.1249026
FDA. 2019. Substances added to food (formerly EAFUS). U.S. Food and Drug Administration. https://www.accessdata.fda.gov/scripts/fdcc/?set=FoodSubstances&id=ACETONE&sort=Sortterm&order=ASC&startrow=1&type=basic&search=acetone. May 9, 2019.
FDA. 2022. Substances added to food. U.S. Food and Drug Administration. https://www.cfsanappsexternal.fda.gov/scripts/fdcc/?set=FoodSubstances. January 24, 2022.
Fischer EV, Jacob DJ, Millet DB, 2012. The role of the ocean in the global atmospheric budget of acetone. Geophys Res Lett 39(1):L01807. 10.1029/2011gl050086.
Fiserova-Bergerova V, Diaz ML. 1986. Determination and prediction of tissue-gas partition coefficients. Int Arch Occup Environ Health 58(1):75–87. 10.1007/BF00378543.3721592
Fitzpatrick LJ, Claire DC. 1947. Acute acetone poisoning (resulting from synthetic plaster substitute in spica cast). Curr Res Anesth Analg 26(2):86. 10.1213/00000539-194701000-00022.20292327
Folland DS, Schaffner W, Ginn HE, 1976. Carbon tetrachloride toxicity potentiated by isopropyl alcohol. Investigation of an industrial outbreak. JAMA 236(16):1853–1856. 10.1001/jama.236.16.1853.989535
Frantik E, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66(2):173–185. 10.1006/enrs.1994.1053.8055839
Frantik E, Vodickova L, Hornychova M, 1996. Pattern of inhalation exposure: blood levels and acute subnarcotic effects of toluene and acetone in rats. Cent Eur J Public Health 4(4):226–232.8997530
Freeman JJ, Hayes EP. 1985. Acetone potentiation of acute acetonitrile toxicity in rats. J Toxicol Environ Health A 15(5):609–621. 10.1080/15287398509530690.
Freeman JJ, Hayes EP. 1988. Microsomal metabolism of acetonitrile to cyanide. Effects of acetone and other compounds. Biochem Pharmacol 37(6):1153–1159. 10.1016/0006-2952(88)90524-2.3355589
Freeman AE, Weisburger EK, Weisburger JH, 1973. Transformation of cell cultures as an indication of the carcinogenic potential of chemicals. J Natl Cancer Inst 51(3):799–808. 10.1093/jnci/51.3.799.4200596
Fujiki M. 1978. Simulation studies of degradation of the chemicals in the environment. Chemical Research Report. Office of Health Studies, Environment Agency, Japan. Vol. 1. Chemical Research Report No. 1/1978.
Fujino A, Satoh T, Takebayashi T, 1992. Biological monitoring of workers exposed to acetone in acetate fibre plants. Occup Environ Med 49(9):654–657. 10.1136/oem.49.9.654.
Fukabori S., Nakaaki K., Tada O. 1979. On the cutaneous absorption of acetone. J Sci Labour 55(10):525–532.
Furner RL, Neville ED, Talarico KS, 1972. A common modality of action of simulated space stresses on the oxidative metabolism of ethylmorphine, aniline and p-nitroanisole by male rat liver. Toxicol Appl Pharmacol 21(4):569–581. 10.1016/0041-008X(72)90013-0.4403048
Futamura M, Goto S, Kimura R, 2009. Differential effects of topically applied formalin and aromatic compounds on neurogenic-mediated microvascular leakage in rat skin. Toxicology 255(1):100–106. 10.1016/j.tox.2008.10.012.19014991
Gamis AZ, Wasserman GS. 1988. Acute acetone intoxication in a pediatric patient. Pediatr Emerg Care 4:24–26. 10.1097/00006565-198803000-00008.3362729
Gaudy AF, Turner BG, Pusztaszeri S. 1963. Biological treatment of volatile waste components. J Water Pollut Control Fed 35(1):75–93.
Gavino VC, Vinet B, David F, 1986. Determination of the concentration and specific activity of acetone in biological fluids. Anal Biochem 152(2):256–261. 10.1016/0003-2697(86)90407-0.3963362
Gavino VC, Somma J, Philbert L, 1987. Production of acetone and conversion of acetone to acetate in the perfused rat liver. J Biol Chem 262(14):6735–6740.3571284
Ge S, Xu Y, Jia L. 2017. Effects of inorganic seeds on secondary organic aerosol formation from photochemical oxidation of acetone in a chamber. Atmos Environ 170:205–215. 10.1016/j.atmosenv.2017.09.036.
Geiss O, Giannopoulos G, Tirendi S, 2011. The AIRMEX study-VOC measurements in public buildings and schools/kindergartens in eleven European cities: Statistical analysis of the data. Atmos Environ 45(22):3676–3684.
Geller I, Gause E, Kaplan H, 1979a. Effects of acetone, methyl ethyl ketone and methyl isobutyl ketone on a match-to-sample task in the baboon. Pharmacol Biochem Behav 11(4):401–406. 10.1016/0091-3057(79)90115-1.118468
Geller I, Hartmann RJ, Randle SR, 1979b. Effects of acetone and toluene vapors on multiple schedule performance of rats. Pharmacol Biochem Behav 11(4):395–399. 10.1016/0091-3057(79)90114-X.523498
Gentry PR, Covington TR, Andersen ME, 2002. Application of a physiologically based pharmacokinetic model for isopropanol in the derivation of a reference dose and reference concentration. Regul Toxicol Pharmacol 36(1):51–68. 10.1006/rtph.2002.1540.12383718
Gentry PR, Covington TR, Clewell HJ, 2003. Application of a physiologically based pharmacokinetic model for reference dose and reference concentration estimation for acetone. J Toxicol Environ Health A 66(23):2209–2225. 10.1080/713853996.14612334
Gerasimov MR, Ferrieri RA, Pareto D, 2005. Synthesis and evaluation of inhaled [11C]butane and intravenously injected [11C]acetone as potential radiotracers for studying inhalant abuse. Nucl Med Biol 32(2):201–208. 10.1016/j.nucmedbio.2004.11.002.15721766
Gerhold RM, Malaney GW. 1966. Structural determinants in the oxidation of aliphatic compounds by activated sludge. J Water Pollut Control Fed 38(4):562–579.
Ghittori S, Imbriani M, Pezzagno G, 1987. The urinary concentration of solvents as a biological indicator of exposure: Proposal for the biological equivalent exposure limit for nine solvents. Am Ind Hyg Assoc J 48(9):786–790. 10.1080/15298668791385570.3687738
Gichner T, Velemínský J. 1987. The organic solvents acetone, ethanol and dimethylformamide potentiate the mutagenic activity of N-methyl-N′-nitro-N-nitrosoguanidine, but have no effect on the mutagenic potential of N-methyl-N-nitrosourea. Mutat Res Lett 192(1):31–35. 10.1016/0165-7992(87)90122-9.
Girman JR, Hadwen GE, Burton LE, 1999. Individual volatile organic compound prevalence and concentrations in 56 buildings of the building assessment survey and evaluation (BASE) study. Indoor Air 99:460–465.
Giroux D, Lapointe G, Baril M. 1992. Toxicological index and the presence in the workplace of chemical hazards for workers who breast-feed infants. Am Ind Hyg Assoc J 53(7):471–474. 10.1080/15298669291359960.1496936
Gitelson S, Werczberger A, Herman JB. 1966. Coma and hyperglycemia following drinking of acetone. Diabetes 15(11):810–811. 10.2337/diab.15.11.810.5924615
Gjolstad M, Thorud S, Molander P. 2006. Occupational exposure to airborne solvents during nail sculpturing. J Environ Monit 8(5):537–542. 10.1039/b601917j.16688355
Glatt H, de Balle L, Oesch F. 1981. Ethanol- or acetone-pretreatment of mice strongly enhances the bacterial mutagenicity of dimethylnitrosamine in assays mediated by liver subcellular fraction, but not in host-mediated assays. Carcinogenesis 2(10):1057–1061. 10.1093/carcin/2.10.1057.7028306
Glowa JR, Dews PB. 1987. Behavioral toxicology of volatile organic solvents. IV. Comparisons of the rate-decreasing effects of acetone, ethyl acetate, methyl ethyl ketone, toluene, and carbon disulfide on schedule-controlled behavior of mice. J Am Coll Toxicol 6(4):461–469. 10.3109/10915818709075691.
Goldberg ME, Johnson HE, Pozzani UC, 1964. Effect of repeated inhalation of vapors of industrial solvents on animal behavior I. Evaluation of nine solvent vapors on pole-climb performance in rats. Am Ind Hyg Assoc Jl 25(4):369–375. 10.1080/00028896409342606.
Gordon A, Gordon M. 1981. Analysis of volatile organic compounds in a textile finishing plant effluent. Trans KY Acad Sci 42:149–157.
Goss KU. 2002. Effects of temperature and relative humidity on the sorption of organic vapors on quartz sand. Environ Sci Technol 26(11):2287–2294. 10.1021/es00035a030.
Gould JP, Ramsey RE, Giabbai M, 1983. Formation of volatile haloorganic compounds in the chlorination of municipal landfill leachates. Water Chlorin Environ Impact Health Eff 4:525–539.
Graedel T. 1978. Carbonyl compounds. In: Chemical compounds in the atmosphere. Vol. 7. New York, NY: Academic Press, 182. 10.1016/B978-0-12-294480-2.50008-4.
Graedel TE, Hawkins DT, Claxton LD. 1986. Alkanic ketones. In: Atmospheric chemical compounds: sources, occurrence and bioassay. New York, NY: Academic Press, Inc, 263.
Green WJ, Lee GF, Jones RA, 2002. Interaction of clay soils with water and organic solvents: implications for the disposal of hazardous wastes. Environ Sci Technol 17(5):278–282. 10.1021/es00111a007.
Grégoire M, Pineau A, Bretonnière C, 2018. Difference between plasma and red blood cell acetone distribution during the first 60 h of a massive intoxication. Clin Toxicol (Phila) 56(12):1207–1208. 10.1080/15563650.2018.1480025.29893588
Grey TC, Shrimpton DH. 1967. Volatile components of raw chicken breast muscle. Br Poult Sci 8(1):23–33. 10.1080/00071666708415646.
Grosjean D, Wright B. 1983. Carbonyls in urban fog, ice fog, cloudwater and rainwater. Atmos Environ 17(10):2093–2096. 10.1016/0004-6981(83)90368-2.
Gummin DD, Mowry JB, Spyker DA, 2018. 2017 Annual report of the American Association of Poison Control Centers’ National Poison Data System (NPDS): 35th annual report. Clin Toxicol (Phila) 56(12):1213–1415. 10.1080/15563650.2018.1533727.30576252
Haff AC, Reichard GA. 1977. A method for estimation of acetone radioactivity and concentration in blood and urine. Biochem Med 18(3):308–314. 10.1016/0006-2944(77)90065-5.597280
Haggard HW, Greenberg LA, Turner JM. 1944. The physiological principles governing the action of acetone, together with determination of toxicity. J Ind Hyg Toxicol 26(5):133–151.
Hall LW, Scott Hall W, Bushong SJ, 1987. In situ striped bass (Morone saxatilis) contaminant and water quality studies in the Potomac River. Aquat Toxicol 10(2-3):73–99. 10.1016/0166-445x(87)90016-6.
Hallbourg RR, Delfino JJ, Miller WL. 1992. Organic priority pollutants in groundwater and surface water at three landfills in north central Florida. Water Air Soil Pollut 65(3-4):307–322. 10.1007/bf00479894.
Hallier E, Filser JG, Bolt HM. 1981. Inhalation pharmacokinetics based on gas uptake studies. II. Pharmacokinetics of acetone in rats. Arch Toxicol 47(4):293–304. 10.1007/BF00332395.7271455
Hanst PL, Gay BW. 1983. Atmospheric oxidation of hydrocarbons: Formation of hydroperoxides and peroxyacids. Atmos Environ 17(11):2259–2265. 10.1016/0004-6981(83)90223-8.
Hard GC, Khan KN. 2004. A contemporary overview of chronic progressive nephropathy in the laboratory rat, and its significance for human risk assessment. Toxicol Pathol 32(2):171–180. 10.1080/01926230490422574.15200155
Hard GC, Johnson KJ, Cohen SM. 2009. A comparison of rat chronic progressive nephropathy with human renal disease-implications for human risk assessment. Crit Rev Toxicol 39(4):332–346. 10.1080/10408440802368642.19514917
Harris LC, Jackson RH. 1952. Acute acetone poisoning caused by setting fluid for immobilizing casts. Br Med J 2(4792):1024–1026. 10.1136/bmj.2.4792.1024.12987731
Hatfield R. 1957. Biological oxidation of some organic compounds. Ind Eng Chem 49(2):192–196. 10.1021/ie50566a027.
Hawthorne SB, Sievers RE. 1984. Emission of organic air pollutants from shale oil wastewaters. Environ Sci Technol 18(6):483–490. 10.1021/es00124a016.22247953
Haynes WM, Lide DR, Bruno TJ. 2015. Acetone. In: CRC handbook of chemistry and physics: A ready-reference book of chemical and physical data. 95^th^ ed. Boca Raton, FL: CRC Press, 3-4, 3-5, 5–196, 6-132, 16-20.
Hazelton Laboratories. 1994. Initial submission: Letter from [] to USEPA regarding acute irritation and oral toxicity studies of two paint strippers with attachments dated 052094 (sanitized). Submitted to the U.S. Environmental Protection Agency under section 8E. OTS0556242. 88-940000284S. 8EHQ-0594-13042S.
Heaton T, Hurst LK, Amiri A, 2019. Laboratory estimation of occupational exposures to volatile organic compounds during nail polish application. Workplace Health Saf 67(6):288–293. 10.1177/2165079918821701.30614420
Heavner DL, Morgan WT, Ogden M. 1996. Determination of volatile organic compounds and respirable suspended particulate matter in New Jersey and Pennsylvania homes and workplaces. Environ Int 22(2):159–183.
Herberger S, Herold M, Ulmer H, 2010. Detection of human effluents by a MOS gas sensor in correlation to VOC quantification by GC/MS. Building and Environment 45(11):2430–2439. 10.1016/j.buildenv.2010.05.005.
Herman MI, Glass T, Howard SC. 1997. Case records of the LeBonheur Children’s Medical Center: a 17-month-old girl with abdominal distension and portal vein gas. Pediatr Emerg Care 13(3):237–242. 10.1097/00006565-199706000-00018.9220518
Hetenyi G, Ferrarotto C. 1985. Gluconeogenesis from acetone in starved rats. Biochem J 231(1):151–155. 10.1042/bj2310151.2998338
Hétu C, Joly J-G. 1988. Effects of chronic acetone administration on ethanol-inducible monooxygenase activities in the rat. Biochem Pharmacol 37(3):421–426. 10.1016/0006-2952(88)90209-2.3122762
Heukelekian H, Rand MC. 1955. Biochemical oxygen demand of pure organic compounds: a report of the research committee, FSIWA. J Water Pollut Contr Assoc 29:1040–1053.
Heuser VD, de Andrade VM, da Silva J, 2005. Comparison of genetic damage in Brazilian footwear-workers exposed to solvent-based or water-based adhesive. Mutat Res 583(1):85–94. 10.1016/j.mrgentox.2005.03.002.15866469
Hewitt WR, Plaa GL. 1983. Dose-dependent modification of 1,1-dichloroethylene toxicity by acetone. Toxicol Lett 16(1-2):145–152. 10.1016/0378-4274(83)90023-1.6836608
Hewitt WR, Brown EM, Plaa GL. 1983. Acetone-induced potentiation of trihalomethane toxicity in male rats. Toxicol Lett 16(3-4):285–296. 10.1016/0378-4274(83)90189-3.6857724
Hewitt LA, Valiquette C, Plaa GL. 1987. The role of biotransformation–detoxication in acetone-, 2-butanone-, and 2-hexanone-potentiated chloroform-induced hepatotoxicity. Can J Physiol Pharmacol 65(11):2313–2318. 10.1139/y87-367.3449191
Hewitt WR, Miyajima H, Cote MG, 1980. Acute alteration of chloroform-induced hepato- and nephrotoxicity by n-hexane, methyl n-butyl ketone, and 2,5-hexanedione. Toxicol Appl Pharmacol 53(2):230–248. 10.1016/0041-008x(80)90423-8.7394766
HHS. 2010. How tobacco smoke causes disease: The biology and behavioral basis for smoking-attributable disease: A report of the surgeon general. Atlanta, GA: U.S. Department of Health and Human Services.
Hift W, Patel PL. 1961. Acute acetone poisoning due to a synthetic plaster cast. S Afr Med J 35(3):246–250.13714180
Hites R, Lopez-Avila V. 1980. Sedimentary accumulation of industrial organic compounds discharged into a river system. In: Baker RA, ed. Contaminants and sediments. Ann Arbor, MI: Ann Arbor Science Publishers, 53–66.
Hodgkin JH, Galbraith MN, Chong YK. 2006. Combustion products from burning polyethylene. J Macromolec Sci A Chem 17(1):35–44. 10.1080/00222338208056463.
Hodgson AT, Wooley JD, Daisey JM. 1993. Emissions of volatile organic compounds from new carpets measured in a large-scale environmental chamber. Air Waste 43(3):316–324. 10.1080/1073161x.1993.10467136.8457318
Hong J, Yang CS. 1985. The nature of microsomal N-nitrosodimethylamine demethylase and its role in carcinogen activation. Carcinogenesis 6(12):1805–1809. 10.1093/carcin/6.12.1805.3933847
Hong J, Pan J, Dong Z, 1987. Regulation of N-nitrosodimethylamine demethylase in rat liver and kidney. Cancer Res 47(22):5948–5953.3664497
Huizer D, Oldenkamp R, Ragas AM, 2012. Separating uncertainty and physiological variability in human PBPK modelling: The example of 2-propanol and its metabolite acetone. Toxicol Lett 214(2):154–165. 10.1016/j.toxlet.2012.08.016.22955064
Hwang H, Hodson RE, Lewis DL. 1989. Microbial degradation kinetics of toxic organic chemicals over a wide range of concentrations in natural aquatic systems. Environ Toxicol Chem 8(1):65–74. 10.1002/etc.5620080108.
IARC. 2021. Agents classified by the IARC monographs, volumes 1-128. International Agency for Research on Cancer. https://monographs.iarc.fr/list-of-classifications. February 3, 2021.
Iba MM, Bennett S, Storch A, 1993. Synergistic induction of rat microsomal CYP1A1 and CYP1A2 by acetone in combination with pyridine. Cancer Lett 74(1-2):69–74. 10.1016/0304-3835(93)90046-c.8287374
ICIS. 2017. Chemical profile: US Acetone. Independent Commodity Intelligence Services. https://www.icis.com/explore/resources/news/2017/01/06/10068037/chemical-profile-us-acetone/. January 6, 2017.
Ikeda M, Hirayama T. 1978. Possible metabolic interaction of styrene with organic solvents. Scand J Work Environ Health 4(Suppl 2):41–46. 10.5271/sjweh.2737.734415
Imai H, Nakamoto Y, Asakura K, 1985. Spontaneous glomerular IgA deposition in ddY mice: An animal model of IgA nephritis. Kidney Int 27(5):756–761. 10.1038/ki.1985.76.4021309
Inomata S, Tanimoto H, Fujitani Y, 2013. On-line measurements of gaseous nitro-organic compounds in diesel vehicle exhaust by proton-transfer-reaction mass spectrometry. Atmos Environ 73:195–203. 10.1016/j.atmosenv.2013.03.035.
Ishidate M, Sofuni T, Yoshikawa K, 1984. Primary mutagenicity screening of food additives currently used in Japan. Food Chem Toxicol 22(8):623–636. 10.1016/0278-6915(84)90271-0.6381265
Isidorov VA, Zenkevich IG, Ioffe BV. 1985. Volatile organic compounds in the atmosphere of forests. Atmos Environ 19(1):1–8. 10.1016/0004-6981(85)90131-3.
Isidorov V, Zenkevich I, Ioffe B. 1990. Volatile organic compounds in solfataric gases. J Atmos Chem 10(3):329–340. 10.1007/BF00053867.
Iversen OH, Paulsen JE, Schjolberg A. 1981. The time needed for normalization of hairless mouse epidermis after treatment with twice weekly topical skin applications of 10 nmol 12-O-tetradecanoylphorbol-13-acetate in acetone, or acetone alone, for 18 weeks. A morphologic and cell kinetic study. Carcinogenesis 2(12):1353–1358. 10.1093/carcin/2.12.1353.7326834
Iversen O, Ljunggren S, Olsen W. 1988. The early effects of a single application of acetone and various doses of 7, 12-dimethylbenz (alpha) anthracene on CD-1 and hairless mouse epidermis. A cell kinetic study of so-called initiation and complete carcinogenesis (initiation plus promotion) in chemical skin tumor induction. APMIS Supplementum 2:7–80.3140844
Jacob DJ, Field BD, Jin EM, 2002. Atmospheric budget of acetone. J Geophys Res Atmos 107(D10):ACH 5-1-ACH 5-17. 10.1029/2001jd000694.
Jaeger RJ, Conolly RB, Reynolds ES, 1975. Biochemical toxicology of unsaturated halogenated monomers. Environ Health Perspect 11:121–128. 10.1289/ehp.7511121.1175549
Jakubowski M, Wieczorek H. 1988. The effects of physical effort on pulmonary uptake of selected organic compound vapours. Pol J Occup Med Environ Health 1(1):62–71.
Jansson B, Larsson B. 1969. Analysis of organic compounds in human breath by gas chromatography-mass spectrometry. J Lab Clin Med 74(6):961–966.5359667
Jarke FH, Dravnieks A, Gordon SM. 1981. Organic contaminants in indoor air and their relation to outdoor contaminants. In: ASHRAE Research Project. Final report. 153–166.
Jeffery EH, Arndt K, Haschek W. 1991. The role of cytochrome P450IIE1 in bioactivation of acetaminophen in diabetic and acetone-treated mice. In: Biological reactive intermediates IV: Molecular and cellular effects and their impact on human health. New York: Plenum Press, 249–251. 10.1007/978-1-4684-5877-0_25.
Jelnes JE. 1988. Semen quality in workers producing reinforced plastic. Reprod Toxicol 2(3-4):209–212.2980348
Jenney EH, Pfeiffer CC. 1958. The convulsant effect of hydrazides and the antidotal effect of anticonvulsants and metabolites. J Pharmacol Exp Ther 122(1):110–123.13502836
Johanson G. 1991. Modelling of respiratory exchange of polar solvents. Ann Occup Hyg 35(3):323–339. 10.1093/annhyg/35.3.323. 8/12/2020.1888103
Johanson G. 2012. Acetone. In: Bingham E, Cohrssen B, eds. Patty’s Toxicology. 6th Edition ed. Hoboken, NJ: John Wiley & Sons, 739–752.
Johansson I, Ingelman-Sundberg M. 1988. Benzene metabolism by ethanol-, acetone-, and benzene-inducible cytochrome P-450 (IIE1) in rat and rabbit liver microsomes. Cancer Res 48(19):5387–5390.3416296
Johansson I, Eliasson E, Norsten C, 1986. Hydroxylation of acetone by ethanol-and acetone-inducible cytochrome P-450 in liver microsomes and reconstituted membranes. FEBS Lett 196(1):59–64. 10.1016/0014-5793(86)80214-9.3943633
Johansson I, Ekstroem G, Scholte B, 1988. Ethanol-, fasting-, and acetone-inducible cytochromes P-450 in rat liver: regulation and characteristics of enzymes belonging to the IIB and IIE gene subfamilies. Biochemistry 27(6):1925–1934.3378038
Jones AW. 1987. Breath-acetone concentrations in fasting healthy men: response of infrared breath-alcohol analyzers. J Anal Toxicol 11(2):67–69. 10.1093/jat/11.2.67.3573727
Jones AW. 1988. Breath acetone concentrations in fasting male volunteers: further studies and effect of alcohol administration. J Anal Toxicol 12(2):75–79. 10.1093/jat/12.2.75.3379925
Jones KR, Brautbar N. 1997. Reactive airway disease in patients with prolonged exposure to industrial solvents. Toxicol Ind Health 13(6):743–750. 10.1177/074823379701300604.9399419
Jones AW, Sagarduy A, Ericsson E, 1993. Concentrations of acetone in venous blood samples from drunk drivers, type-I diabetic outpatients, and healthy blood donors. J Anal Toxicol 17(3):182–185.8336493
Jungclaus G, Avila V, Hites R. 2002. Organic compounds in an industrial Wastewater: a case study of their environmental impact. Environ Sci Technol 12(1):88–96. 10.1021/es60137a015.
Jüttner F. 1986. Analysis of organic compounds (VOC) in the forest air of the Southern Black Forest. Chemosphere 15(8):985–992. 10.1016/0045-6535(86)90551-5.
Kallenberg K, Behrens A, Strik H, 2008. MR imaging-based evidence of vasogenic brain edema in a case of acute acetone intoxication. AJNR Am J Neuroradiol 29(4):e16. 10.3174/ajnr.A0913.18202235
Kanada M, Miyagawa M, Sato M, 1994. Neurochemical profile of effects of 28 neurotoxic chemicals on the central nervous system in rats: 1. Effects of oral administration on brain contents of biogenic amines and metabolites. Ind Health 32(3):145–164. 10.2486/indhealth.32.145.7698903
Kane LE, Dombroske R, Alarie Y. 1980. Evaluation of sensory irritation from some common industrial solvents. Am Ind Hyg Assoc J 41(6):451–455. 10.1080/15298668091425022.7395760
Kasprowska-Liskiewicz D, Liskiewicz AD, Nowacka-Chmielewska MM, 2017. The ketogenic diet affects the social behavior of young male rats. Physiological Behavior 179:168–177. 10.1016/j.physbeh.2017.06.007.
Kawachi T, Yahagi T, Kada T, 1980. Cooperative programme on short-term assays for carcinogenicity in Japan. IARC Sci Publ 27:323–330.
Kawai T, Yasugi T, Uchida Y, 1990a. Urinary excretion of unmetabolized acetone as an indicator of occupational exposure to acetone. Int Arch Occup Environ Health 62(2):165–169. 10.1007/BF00383593.2323834
Kawai T, Yasugi T, Horiguchi Si, 1990b. Biological monitoring of occupational exposure to isopropyl alcohol vapor by urinalysis for acetone. Int Arch Occup Environ Health 62(5):409–413. 10.1007/BF00381373.2228263
Kawai T, Yasugi T, Mizunuma K, 1992. Curvi-linear relation between acetone in breathing zone air and acetone in urine among workers exposed to acetone vapor. Toxicol Lett 62(1):85–91. 10.1016/0378-4274(92)90081-T.1509510
Keith LH GA, Allen FR, 1976. Identification of organic compounds in drinking water for thirteen U.S. cities. In: Keith LH, ed. Identification and analysis of organic pollutants in water. Ann Arbor Press, 329–373.
Kenner SJ, Bender DA, Zogorski JS, 2014. The atmosphere can be a source of certain water soluble volatile organic compounds in urban streams. J Am Water Resour Assoc 50(5):1124–1137. 10.1111/jawr.12181.
Kenyon EM, Seaton MJ, Himmelstein MW, 1998. Influence of gender and acetone pretreatment on benzene metabolism in mice exposed by nose-only inhalation. J Toxicol Environ Health A 55(6):421–443. 10.1080/009841098158340.9833972
Kerr MA, Nasca PC, Mundt KA. 2000. Parental occupational exposures and risk of neuroblastoma: a case-control study (United States). Cancer Causes Control 11(7):635–643. 10.1023/a:1008951632482.10977108
Khalil MA K, Rasmussen RA. 1992. Forest hydrocarbon emissions: Relationships between fluxes and ambient concentrations. J Air Waste Manag Assoc 42(6):810–813. 10.1080/10473289.1992.10467033.
Kieber RJ, Mopper K. 1990. Determination of picomolar concentrations of carbonyl compounds in natural waters, including seawater, by liquid chromatography. Environ Sci Technol 24(10):1477–1481. 10.1021/es00080a003.
Kiesswetter E, Seeber A. 1995. Modification of shiftwork effects by chemical workplace exposure. Work & Stress 9(2-3):351–359. 10.1080/02678379508256572.
Kiesswetter E, Blaszkewicz M, Vangala RR, 1994. Acute exposure to acetone in a factory and ratings of well-being. Neurotoxicology 15(3):597–601.7854593
Kim SR, Halden RU, Buckley TJ. 2007. Volatile organic compounds in human milk: methods and measurements. Environ Sci Technol 41(5):1662–1667. 10.1021/es062362y.17396657
Kim SG, Shehin SE, States JC, 1990. Evidence for increased translational efficiency in the induction of P450IIE1 by solvents: analysis of P450IIE1 mRNA polyribosomal distribution. Biochem Biophys Res Commun 172(2):767–774. 10.1016/0006-291x(90)90740-e.2241968
Kimura ET, Ebert DM, Dodge PW. 1971. Acute toxicity and limits of solvent residue for sixteen organic solvents. Toxicol Appl Pharmacol 19(4):699–704. 10.1016/0041-008x(71)90301-2.5132037
Kimura M, Shimosawa M, Kobayashi K, 1986. Acetoacetate decarboxylase activity of plasma components. Nihon Rinsho 15(1):37–43.
Kinlin TE, Muralidhara R, Pittet AO, 1972. Volatile components of roasted filberts. J Agric Food Chem 20(5):1021–1028. 10.1021/jf60183a013.
Kleindienst TE, Shepson PB, Edney EO, 1986. Wood smoke: measurement of the mutagenic activities of its gas-and particulate-phase photooxidation products. Environ Sci Technol 20(5):493–501. 10.1021/es00147a009.19994934
Knöppel H, Schauenburg H. 1989. Screening of household products for the emission of volatile organic compounds. Environ Int 15(1-6):413–418. 10.1016/0160-4120(89)90056-1.
Ko IY, Park SS, Song BJ, 1987. Monoclonal antibodies to ethanol-induced rat liver cytochrome P-450 that metabolizes aniline and nitrosamines. Cancer Res 47(12):3101–3109.3107803
Kobayashi K, Okada M, Yasuda Y, 1983. A gas chromatographic method for the determination of acetone and acetoacetic acid in urine. Clin Chim Acta 133(2):223–226. 10.1016/0009-8981(83)90408-4.6627684
Kobusch AB, Plaa GL, Du Souich P. 1989. Effects of acetone and methyl n-butyl ketone on hepatic mixed-function oxidase. Biochem Pharmacol 38(20):3461–3467. 10.1016/0006-2952(89)90115-9.2818637
Koeslag J, Noakes T, Sloan A. 1980. Post‐exercise ketosis. J Physiol 301(1):79–90. 10.1113/jphysiol.1980.sp013190.6997456
Kohli R, Kishor K, Dua P, 1967. Anticonvulsant activity of some carbonyl containing compounds. Indian J Med Res 55(11):1221–1225.5582789
Koop D, Casazza J. 1985. Identification of ethanol-inducible P-450 isozyme 3a as the acetone and acetol monooxygenase of rabbit microsomes. J Biol Chem 260(25):13607–13612.4055750
Koorevaar G, Van Stekelenburg GJ. 1976. Mammalian acetoacetate decarboxylase activity: its distribution in subfractions of human albumin and occurrence in various tissues of the rat. Clin Chim Acta 71(2):173–183. 10.1016/0009-8981(76)90528-3.963888
Kostusiak V, Bekkal R, Mateu P. 2003. Survival after drinking lethal dose of acetone. Intensive Care Med 29(2):339. 10.1007/s00134-002-1575-0.12594602
Kosugi K, Chandramouli V, Kumaran K, 1986a. Determinants in the pathways followed by the carbons of acetone in their conversion to glucose. J Biol Chem 261(28):13179–13181.3759956
Kosugi K, Scofield RF, Chandramouli V, 1986b. Pathways of acetone’s metabolism in the rat. J Biol Chem 261(9):3952–3957.3081512
Krishnan K, Anderson ME, Clewell HJ, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures. Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Krotoszynski BK, Bruneau GM, O’Neill HJ. 1979. Measurement of chemical inhalation exposure in urban population in the presence of endogenous effluents. J Anal Toxicol 3(6):225–234. 10.1093/jat/3.6.225.
Krotoszynski B, Gabriel G, O’Neill H, 1977. Characterization of human expired air: a promising investigative and diagnostic technique. J Chromatogr Sci 15(7):239–244. 10.1093/chromsci/15.7.239.893644
Kubinski H, Gutzke G, Kubinski Z. 1981. DNA-cell-binding (DCB) assay for suspected carcinogens and mutagens. Mutat Res 89(2):95–136. 10.1016/0165-1218(81)90118-X.7290095
Kumagai S, Matsunaga I. 1995. Physiologically based pharmacokinetic model for acetone. Occup Environ Med 52(5):344–352. 10.1136/oem.52.5.344.7795758
Kumarvel V, Da Fonseca J. 2007. Acetone poisoning--a diagnostic dilemma. Eur J Anaesthesiol 24(9):805–806. 10.1017/S0265021507000245.17924476
Kundu SK, Bruzek JA, Nair R, 1993. Breath acetone analyzer: diagnostic tool to monitor dietary fat loss. Clin Chem 39(1):87–92.8419065
Kupferschmid LL, Perkins JL. 1986. Organic solvent recycling plant exposure levels. Appl Ind Hyg 1(3):122–131. 10.1080/08828032.1986.10390494.
Ladefoged O, Perbellini L. 1986. Acetone-induced changes in the toxicokinetics of 2,5-hexanedione in rabbits. Scand J Work Environ Health 12:627–629. 10.5271/sjweh.2092.3823813
Ladefoged O, Hass U, Simonsen L. 1989. Neurophysiological and behavioural effects of combined exposure to 2, 5‐hexanedione and acetone or ethanol in rats. J Toxicol Pharmacol 65(5):372–375. 10.1111/j.1600-0773.1989.tb01191.x.
Ladefoged O, Roswall K, Larsen JJ. 1994. Acetone potentiation and influence on the reversibility of 2,5-hexanedione-induced neurotoxicity studied with behavioural and morphometric methods in rats. J Toxicol Pharmacol 74(4-5):294–299. 10.1111/j.1600-0773.1994.tb01114.x.
Lagrone F. 1991. Potential community exposure to toxic chemicals. Environ Sci Technol 25:366–368.
Lake RS, Kropko ML, Pezzutti MR, 1978. Chemical induction of unscheduled DNA synthesis in human skin epithelial cell cultures. Cancer Res 38(7):2091–2098.657142
Lam HR, Larsen J-J, Ladefoged O, 1991. Effects of 2,5-hexanedione alone and in combination with acetone on radial arm maze behavior, the “brain-swelling” reaction and synaptosomal functions. Neurotoxicol Teratol 13(4):407–412. 10.1016/0892-0362(91)90089-F.1921920
Lamb CB, Jenkins GF. 1952. BOD of synthetic organic chemicals. In: Proceedings of the 7th Purdue Industrial Waste Conference. Purdue University, 326–339.
Lamplugh A, Harries M, Xiang F, 2019. Occupational exposure to volatile organic compounds and health risks in Colorado nail salons. Environ Pollut 249:518–526. 10.1016/j.envpol.2019.03.086.30933751
Landahl H, Herrmann R. 1950. Retention of vapors and gases in the human nose and lung. Arch Ind Hyg Occup Med 1(1):36–45.15419854
LaRegina J, Bozzelli JW, Harkov R, 1986. Volatile organic compounds at hazardous waste sites and a sanitary landfill in New Jersey. Environ Prog 5(1):18–27. 10.1002/ep.670050109.
Larsen J, Lykkegaard M, Ladefoged O. 1991. Infertility in rats induced by 2, 5-hexanedione in combination with acetone. J Toxicol Pharmacol 69(1):43–46. 10.1111/j.1600-0773.1991.tb00407.x.
Larson PS, Finnegan JK, Haag HB. 1956. Observations on the effect of chemical configuration on the edema-producing potency of acids, aldehydes, ketones and alcohols. J Pharmacol Exp Ther 116(1):119–122.13296026
Le Baron FN. 1982. Lipid metabolism 1: Utilization and storage of energy in lipid form. In: Devlin TM, ed. Textbook of biochemistry with clinical correlations. New York, NY: John Wiley and Sons, 464-479, 1243–1265.
Lee JH, Timmons RB. 1977. Kinetics and mechanism of the gas-phase reaction of O (3P) atoms with acetone. Int J Chem Kinet 9(1):133–139. 10.1002/kin.550090112.
Lee DE, Pai J, Mullapudui U, 2008. The effects of inhaled acetone on place conditioning in adolescent rats. Pharmacol Biochem Behav 89(1):101–105. 10.1016/j.pbb.2007.11.006.18096214
Lee EG, Harper M, Bowen RB, 2009. Evaluation of COSHH essentials: methylene chloride, isopropanol, and acetone exposures in a small printing plant. Ann Occup Hyg 53(5):463–474.19435980
Lehninger A. 1970. Biochemistry: the molecular basis of cell structure and function. New York, NY: Worth Publishers, Inc., 316, 338.
Leung H-W, Paustenbach DJ. 1988. Application of pharmacokinetics to derive biological exposure indexes from threshold limit values. Am Ind Hyg Assoc J 49(9):445–450. 10.1080/15298668891380051.3177223
Levey S, Balchum OJ, Medrano V, 1964. Studies of metabolic products in expired air. II. Acetone. J Lab Clin Med 63(4):574–584.14155446
Levsen K, Behnert S, Prieß B, 1990. Organic compounds in precipitation. Chemosphere 21(9):1037–1061. 10.1016/0045-6535(90)90127-f.
Levy LJ, Duga J, Girgis M, 1973. Ketoacidosis associated with alcoholism in nondiabetic subjects. Ann Intern Med 78(2):213–219. 10.7326/0003-4819-78-2-213.4683750
Lewinsohn E, Sitrit Y, Bar E, 2005. Carotenoid pigmentation affects the volatile composition of tomato and watermelon fruits, as revealed by comparative genetic analyses. J Agric Food Chem 53(8):3142–3148. 10.1021/jf047927t.15826071
Lewis SB, Wallin JD, Kane JP, 1977. Effect of diet composition on metabolic adaptations to hypocaloric nutrition: comparison of high carbohydrate and high fat isocaloric diets. Am J Clin Nutr 30(2):160–170. 10.1093/ajcn/30.2.160.835502
Lewis GD, Laufman AK, McAnalley BH, 1984. Metabolism of acetone to isopropyl alcohol in rats and humans. J Forensic Sci 29(2):541–549. 10.1520/JFS11702J.6726158
Li M, Li Q, Nantz MH, 2018. Analysis of carbonyl compounds in ambient air by a microreactor approach. ACS Omega 3(6):6764–6769. 10.1021/acsomega.8b00503.29978147
Line DE, Wu J, Arnold J, 1997. Water quality of first flush runoff from 20 industrial sites. Water Environ Res 69(3):305–310.
Lipari F, Dasch JM, Scruggs WF. 1984. Aldehyde emissions from wood-burning fireplaces. Environ Sci Technol 18(5):326–330. 10.1021/es00123a007.22280078
Liu J, Sato C, Marumo F. 1991. Characterization of the acetaminophen-glutathione conjugation reaction by liver microsomes: species difference in the effects of acetone. Toxicol Lett 56(3):269–274. 10.1016/0378-4274(91)90155-Y.2035174
Liu W, Zhang J, Zhang L, 2006. Estimating contributions of indoor and outdoor sources to indoor carbonyl concentrations in three urban areas of the United States. Atmos Environ 40(12):2202–2214. 10.1016/j.atmosenv.2005.12.005.
Lo HH, Teets VJ, Yang DJ, 1987. Acetone effects on N-(3,5-dichlorophenyl)succinimide-induced nephrotoxicity. Toxicol Lett 38(1-2):1610168. 10.1016/0378-4274(87)90124-x.
López-Soriano F, Argilés J. 1985. Simultaneous determination of ketone bodies in biological samples by gas chromatographic headspace analysis. J Chromatogr Sci 23(3):120–123. 10.1093/chromsci/23.3.120.3980662
López-Soriano F, Alemany M, Argilés J. 1985. Rat acetoacetic acid decarboxylase inhibition by acetone. Int J Biochem 17(11):1271–1273. 10.1016/0020-711X(85)90019-9.4076528
Lorr NA, Miller KW, Chung HR, 1984. Potentiation of the hepatotoxicity of N-nitrosodimethylamine by fasting, diabetes, acetone, and isopropanol. Toxicol Appl Pharmacol 73(3):423–431. 10.1016/0041-008X(84)90095-4.6719461
Lovegren NV, Fisher GS, Legendre MG, 1979. Volatile constituents of dried legumes. J Agric Food Chem 27(4):851–853. 10.1021/jf60224a055.
Lupulescu AP, Birmingham DJ. 1975. Effect of lipid solvents on protein, DNA, and collagen synthesis in human skin: an electron microscopic autoradiographic study. J Invest Dermatol 65(5):419–422. 10.1111/1523-1747.ep12607986.1194707
Lupulescu AP, Birmingham DJ. 1976. Effect of protective agent against lipid-solvent-induced damages: ultrastructural and scanning electron microscopical study of human epidermis. Arch Environ Health 31(1):33–35. 10.1080/00039896.1976.10667186.128331
Lupulescu AP, Pinkus H, Birmingham DJ. 1972. Effect of acetone and kerosene on skin ultrastructure. Proceedings of the Annual Meeting of the Electron Microscopy Society of America 30:92–93.
Lupulescu AP, Birmingham DI, Pinkus H. 1973. An electron microscopic study of human epidermis after acetone and kerosene administration. J Invest Dermatol 60(1):33–45. 10.1111/1523-1747.ep13069780.4684159
Lyman W. 1982. Adsorption coefficient for soils and sediments. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation methods. New York: McGraw-Hill Book Company, 4–9.
Ma GX, Wei Z, Husni R, 2019. Characterizing occupational health risks and chemical exposures among Asian nail salon workers on the east coast of the United States. J Community Health 44(6):1168–1179. 10.1007/s10900-019-00702-0.31297649
MacDonald JR, Gandolfi AJ, Sipes IG. 1982a. Acetone potentiation of 1,1,2-trichloroethane hepatotoxicity. Toxicol Lett 13(1-2):57–69. 10.1016/0378-4274(82)90139-4.7179309
MacDonald JR, Gandolfi AJ, Sipes IG. 1982b. Covalent binding of 14C-1,1,2-trichloroethane to hepatic proteins following acetone pretreatment. Drug Chem Toxicol 5(3):233–247. 10.3109/01480548209041055.7151718
Manning D, Maskarinec M, Jenkins R, 1983. High performance liquid chromatographic determination of selected gas phase carbonyls in tobacco smoke. J Assoc Off Anal Chem 66(1):8–12.
Marandino CA, De Bruyn WJ, Miller SD, 2005. Oceanic uptake and the global atmospheric acetone budget. Geophys Res Lett 32(15) 10.1029/2005GL023285.
Marchand A, Ménard J, Brochu P, 2021. Impact of heat on biological concentrations of toluene and acetone resulting from exposure by inhalation: A pilot study. Environ Toxicol Pharmacol 88:103737. 10.1016/j.etap.2021.103737.34481063
Marefat P, Shklar G. 1977. Experimental production of lingual leukoplakia and carcinoma. Oral Surg Oral Med Oral Pathol 44(4):578–586. 10.1016/0030-4220(77)90301-2.409973
Marhuenda D, Prieto MJ, Periago JF, 1997. Biological monitoring of styrene exposure and possible interference of acetone co-exposure. Int Arch Occup Environ Health 69(6):455–460. 10.1007/s004200050174.9215933
Martinez RD, Buitrago AA, Howell NW, 1992. The near UV absorption spectra of several aliphatic aldehydes and ketones at 300 K. Atmos Environ Part A 26(5):785–792. 10.1016/0960-1686(92)90238-G.
Mashbitz L, Sklianskaya R, Urieva F. 1936. The relative toxicity of acetone, methylalcohol and their mixtures: II. Their action on white mice. J Ind Hyg Toxicol 18:117–122.
Masood W, Annamaraju P, Uppaluri KR. 2020. Ketogenic diet. In: StatPearls. Treasure Island, FL: StatPearls Publishing. https://www.ncbi.nlm.nih.gov/books/NBK499830/?report=printable. April 8, 2021.
Mathias MG, Almeida BB, Bueno JE, 2010. Lipid peroxidation and antioxidant system in rats acutely treated with acetone. Exp Clin Endocrinol Diabetes 118(6):368–370. 10.1055/s-0029-1224122.20213598
Matsushita T, Goshima E, Miyagaki H, 1969a. Experimental studies for determining the mac value of acetone: 1. Biological reactions in the" one-day exposure" to acetone. Sangyo Igaku 11(9):477–484. 10.1539/joh1959.11.477.
Matsushita T, Goshima E, Miyagaki H, 1969b. Experimental studies for determining the mac value of acetone: 2. Biological reactions in the" six-day exposure" to acetone. Sangyo Igaku 11(10):507–515. 10.1539/joh1959.11.507.
Mattheis JP, Fellman JK, Chen PM, 1991. Changes in headspace volatiles during physiological development of Bisbee Delicious apple fruits. J Agric Food Chem 39(11):1902–1906. 10.1021/jf00011a002.
Matthews EJ, Spalding JW, Tennant RW. 1993. Transformation of BALB/c-3T3 cells: V. Transformation responses of 168 chemicals compared with mutagenicity in Salmonella and carcinogenicity in rodent bioassays. Environ Health Perspect 2:347–482. 10.1289/ehp.93101s2347.
Maurer JK, Molai A, Parker RD, 2001. Pathology of ocular irritation with acetone, cyclohexanol, parafluoroaniline, and formaldehyde in the rabbit low-volume eye test. Toxicol Pathol 29(2):187–199. 10.1080/019262301317052468.11421486
McCann J, Choi E, Yamasaki E, 1975. Detection of carcinogens as mutagens in the Salmonella/microsome test: assay of 300 chemicals. Proceedings of the National Academy of Sciences 72(12):5135–5139. 10.1073/pnas.72.12.5135.
Menck CF, Cabral-Neto JB, Faljoni-Alário A, 1986. Damages induced in λ phage DNA by enzyme-generated triplet acetone. Mutat Res 165(1):9–14. 10.1016/0167-8817(86)90003-9.2934629
Menicagli S, Puccini P, Longo V, 1990. Effect of acetone administration on renal, pulmonary and hepatic monooxygenase activities in hamster. Toxicology 64(2):141–153. 10.1016/0300-483X(90)90131-Y.2219136
Meyrahn H, Pauly J, Schneider W, 1986. Quantum yields for the photodissociation of acetone in air and an estimate for the life time of acetone in the lower troposphere. J Atmos Chem 4(2):277–291. 10.1007/BF00052006.
Mikalsen A, Alexander J, Andersen RA, 1991. Effect of in vivo chromate, acetone and combined treatment on rat liver in vitro microsomal chromium (VI) reductive activity and on cytochrome P450 expression. J Toxicol Pharmacol 68(6):456–463. 10.1111/j.1600-0773.1991.tb01270.x.
Militana LM, Mauch SC. 1989. Statistical modeling of ambient air toxics impact during remedial investigation at a landfill site. In: Proceedings of the 10th National Conference. The Hazardous Materials Control Research Institute, 157–162.
Mill T, Mabey W. 1985. Photochemical transformations. In: Neely WB, Blau GE, eds. Environmental exposure from chemistry Vol. 1. Boca Raton, FL: CRC Press, Inc., 175–216.
Miller KW, Yang CS. 1984. Studies on the mechanisms of induction of N-nitrosodimethylamine demethylase by fasting, acetone, and ethanol. Arch Biochem Biophys 229(1):483–491. 10.1016/0003-9861(84)90179-6.6703708
Mishra NK, Wilson CM, Pant KJ, 1978. Simultaneous determination of cellular mutagenesis and transformation by chemical carcinogens in Fischer rat embryo cells. J Toxicol Environ Health 4(1):79–91. 10.1080/15287397809529646.633413
Mitran E, Callender T, Orha B, 1997. Neurotoxicity associated with occupational exposure to acetone, methyl ethyl ketone, and cyclohexanone. Environ Res 73(1-2):181–188. 10.1006/enrs.1997.3703.9311545
Mizunuma K, Yasugi T, Kawai T, 1993. Exposure-excretion relationship of styrene and acetone in factory workers: a comparison of a lipophilic solvent and a hydrophilic solvent. Arch Environ Contam Toxicol 25(1):129–133. 10.1007/BF00230723.8346972
Mohr DH, King CJ. 1985. Identification of polar organic compounds in coal-gasification condensate water by gas chromatography-mass spectrometry analysis of high-performance liquid chromatography fractions. Environ Sci Technol 19(10):929–935. 10.1021/es00140a007.
Moldéus P, Gergely V. 1980. Effect of acetone on the activation of acetaminophen. Toxicol Appl Pharmacol 53(1):8–13. 10.1016/0041-008X(80)90374-9.7385240
Monder C. 1967. α-Keto aldehyde dehydrogenase, an enzyme that catalyzes the enzymic oxidation of methylglyoxal to pyruvate. J Biol Chem 242(20):4603–4609.4383524
Mopper K, Stahovec WL. 1986. Sources and sinks of low molecular weight organic carbonyl compounds in seawater. Mar Chem 19(4):305–321. 10.1016/0304-4203(86)90052-6.
Morgan ET, Koop DR, Coon MJ. 1983. Comparison of six rabbit liver cytochrome P-450 isozymes in formation of a reactive metabolite of acetaminophen. Biochem Biophys Res Commun 112(1):8–13. 10.1016/0006-291x(83)91789-8.6838622
Mori Y, Yamazaki H, Toyoshi K, 1985. Inhibitory effect of organic solvents on the mutagenicity of N-nitrosodialkylamines in Salmonella. Mutat Res 142(4):153–158. 10.1016/0165-7992(85)90015-6.3885018
Mork AK, Johanson G. 2006. A human physiological model describing acetone kinetics in blood and breath during various levels of physical exercise. Toxicol Lett 164(1):6–15. 10.1016/j.toxlet.2005.11.005.16364574
Mork A, Johanson G. 2010. Chemical-specific adjustment factors for intraspecies variability of acetone toxicokinetics using a probabilistic approach. Toxicol Sci 116(1):336–348. 10.1093/toxsci/kfq116.20400482
Mork AK, Jonsson F, Johanson G. 2009. Bayesian population analysis of a washin-washout physiologically based pharmacokinetic model for acetone. Toxicol Appl Pharmacol 240(3):423–432. 10.1016/j.taap.2009.07.033.19660484
Morris JB. 1991. Deposition of acetone vapor in the upper respiratory tract of the B6C3F1 mouse. Toxicol Lett 56(1-2):187–196. 10.1016/0378-4274(91)90106-G.2017777
Morris JB, Cavanagh DG. 1986. Deposition of ethanol and acetone vapors in the upper respiratory tract of the rat. Fundam Appl Toxicol 6(1):78–88. 10.1093/toxsci/6.1.78.3710031
Morris JB, Cavanagh DG. 1987. Metabolism and deposition of propanol and acetone vapors in the upper respiratory tract of the hamster. Toxicol Sci 9(1):34–40. 10.1093/toxsci/9.1.34.
Morris JB, Clay RJ, Cavanagh DG. 1986. Species differences in upper respiratory tract deposition of acetone and ethanol vapors. Fundam Appl Toxicol 7(4):671–680. 10.1093/toxsci/7.4.671.3803762
Morris JB, Clay RJ, Trela BA, 1991. Deposition of dibasic esters in the upper respiratory tract of the male and female Sprague-Dawley rat. Toxicol Appl Pharmacol 108(3):538–546. 10.1016/0041-008X(91)90100-S.2020975
Moshonas MG, Shaw PE. 1990. Flavor evaluation of concentrated aqueous orange essences. J Agric Food Chem 38(12):2181–2184. 10.1021/jf00102a016.
Mourkides GA, Hobbs DC, Koeppe RE. 1959. The metabolism of acetone-2-C14 by intact rats. J Biol Chem 234:27–30.13610886
Muller WJ, Black MS. 1995. Sensory irritation in mice exposed to emissions from indoor products. Am Ind Hyg Assoc J 56(8):794–803. 10.1080/15428119591016629.7653434
Muttray A, Martus P, Schachtrup S, 2005. Acute effects of an organic solvent mixture on the human central nervous system. Eur J Pharm Med Res 10(9):381–388.
NAS. 1976. Vapor-phase organic pollutants: Volatile hydrocarbons and oxidation products. Washington, DC: National Academy of Sciences. 10.17226/19963.
NAS/NRC. 1989. Report of the oversight committee. In: Biologic markers in reproductive toxicology. Washington, DC: National Academy of Sciences, National Research Council, National Academy Press, 15–35.
Neiman J, Jones AW, Numminen H, 1987. Combined effect of a small dose of ethanol and 36 hr fasting on blood-glucose response, breath-acetone profiles and platelet function in healthy men. Alcohol 22(3):265–270.
Nelson K, Ege J, Ross M, 1943. Sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 25(7):282–285.
NIOSH. 1989. National occupational exposure survey as of 03/22/89. National Institute for Occupational Safety and Health.
NIOSH. 2017. NIOSH manual of analytical methods (NMAM). National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/nmam/pdfs/NMAM_5thEd_EBook.pdf. May 6, 2022.
NIOSH. 2019a. Evaluation of ergonomics, chemical exposures, and ventilation at four nail salons. Health hazard evaluation report. Cincinnati, OH: National Institute for Occupational Safety and Health. https://stacks.cdc.gov/view/cdc/77120. May 6, 2022.
NIOSH. 2019b. Acetone. NIOSH pocket guide to chemical hazards. National Institute for Occupational Safety and Health. https://www.cdc.gov/niosh/npg/npgd0631.html. January 27, 2022.
Nizyaeva IV. 1982. The hygienic evaluation of acetone. Gig Tr Prof Zabol 6:24–28.
Nomiyama K, Nomiyama H. 1974a. Respiratory retention, uptake and excretion of organic solvents in man. Int Arch Arbeitsmed 32(1):75–83. 10.1007/BF00539097.4813696
Nomiyama K, Nomiyama H. 1974b. Respiratory elimination of organic solvents in man. Int Arch Occup Environ Health 32(1):85–91.
NTP. 1988. Inhalation developmental toxicology studies: Teratology study of acetone in mice and rats. National Toxicology Program. DE89005671. PNL-6768.
NTP. 1991. Toxicity studies of acetone in F344/N rats and B6C3F1 mice (drinking water studies). National Toxicology Program. NIH Publication No. 91-3122. NTP TOX 3.
NTP. 2021. CASRN index. Report on carcinogens. National Toxicology Program. https://ntp.niehs.nih.gov/pubhealth/roc/index-1.html#P. January 10, 2022.
NYSDOH. 2005. Study of volatile organic chemicals in air of fuel oil heated homes. New York State Department of Health. www.health.ny.gov/environmental/indoors/air/docs/fuel_oil.pdf. May 6, 2022.
Orellana BM, Guajardo V, Araya J, 2001. Oxidative stress, microsomal and peroxisomal fatty acid oxidation in the liver of rats treated with acetone. Comp Biochem Physiol C Toxicol Pharmacol 128(4):503–509.11301292
OSHA. 2018a. Occupational safety and health standards. Subpart Z - Toxic and hazardous substances. Air contaminants. Table Z-1: Limits for air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1910.1000.
OSHA. 2018b. Occupational safety and health standards for shipyard employment. Subpart Z - Toxic and hazardous substances. Air contaminants. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1915.1000.
OSHA. 2018c. Safety and health regulations for construction. Subpart D - Occupational health and environment controls. Gases, vapors, fumes, dusts, and mists. Occupational Safety and Health Administration. Code of Federal Regulations. 29 CFR 1926.55 Appendix A.
OTA. 1990. Neurotoxicity: Identifying and controlling poisons of the nervous system. Washington, DC: Office of Technology Assessment. OTA-BA-438.
Ott MG, Skory LK, Holder B, 1983a. Health evaluation of employees occupationally exposed to methylene chloride: General Study design and environmental considerations. Scand J Work Environ Health 9(Suppl 1):1–7.
Ott MG, Skory LK, Holder B, 1983b. Health evaluation of employees occupationally exposed to methylene chloride: Mortality. Scand J Work Environ Health 9(Suppl 1):8–16.
Ott MG, Skory LK, Holder B, 1983c. Health evaluation of employees occupationally exposed to methylene chloride: Clinical laboratory evaluation. Scand J Work Environ Health 9(Suppl 1):17–25.
Owen O, Trapp V, Skutches C, 1982. Acetone metabolism during diabetic ketoacidosis. Diabetes 31(3):242–248. 10.2337/diabetes.31.3.242.6818074
Palo V, Ilkova H. 1970. Direct gas chromatographic estimation of lower alcohols, acetaldehyde, acetone and diacetyl in milk products. J Chromatogr 53:363–367. 10.1016/S0021-9673(01)98477-8.5498849
Pankow D, Hoffmann P. 1989. Dichloromethane metabolism to carbon monoxide can be induced by isoniazid, acetone and fasting. Arch Toxicol Suppl 13:302–303. 10.1007/978-3-642-74117-3_55.2774950
Pankow JF, Asher WE, Zogorski JS. 2006. Source apportionment modeling of volatile organic compounds in streams. Environ Toxicol Chem 25(4):921–932. 10.1897/05-205R1.1.16629131
Pasanen M. 1999. The expression and regulation of drug metabolism in human placenta. Adv Drug Deliv Rev 38(1):81–97. 10.1016/s0169-409x(99)00008-3.10837748
Paterson S, Mackay D. 1989. Correlation of tissue, blood, and air partition coefficients of volatile organic chemicals. Occup Environ Med 46(5):321–328. 10.1136/oem.46.5.321.
Paterson P, Sheath J, Taft P, 1967. Maternal and foetal ketone concentrations in plasma and urine. The Lancet 289(7495):862–865. 10.1016/S0140-6736(67)91426-2.
Patsner B. 1993. Topical acetone for control of life-threatening vaginal hemorrhage from recurrent gynecologic cancer. Eur J Gynaecol Oncol 14(1):33–35.8472728
Patten CJ, Ning SM, Lu AY, 1986. Acetone-inducible cytochrome P-450: purification, catalytic activity, and interaction with cytochrome b5. Arch Biochem Biophys 251(2):629–638. 10.1016/0003-9861(86)90373-5.3800390
Peden VH. 1964. Determination of individual serum “ketone bodies,” with normal values in infants and children. J Lab Clin Med 63(2):332–343.14125122
Pe’er J, Folberg R, Massicotte SJ, 1992. Clinicopathologic spectrum of primary uveal melanocytic lesions in an animal model. Ophthalmology 99(6):977–986. 10.1016/S0161-6420(92)31868-8.1630787
Peinado J, Lopez-Soriano FJ, Argiles JM. 1986. The metabolism of acetone in the pregnant rat. Biosci Rep 6(11):983–989. 10.1007/BF01114975.3580522
Pellizzari ED, Castillo NP, Willis S, 1979. Identification of organic components in aqueous effluents from energy-related processes. In: Van Hall CE, ed. Measurement of organic pollutants in water and wastewater. American Society for Testing and Materials, 256–274.
Pellizzari ED, Hartwell TD, Harris BS, 1982. Purgeable organic compounds in mother’s milk. Bull Environ Contam Toxicol 28(3):322–328. 10.1007/BF01608515.7082873
Pezzagno G, Imbriani M, Ghittori S, 1986. Urinary elimination of acetone in experimental and occupational exposure. Scand J Work Environ Health 12(6):603–608. 10.5271/sjweh.2096.3823809
Phillips M, Greenberg J. 1987. Detection of endogenous acetone in normal human breath. J Chromatogr 422:235–238. 10.1016/0378-4347(87)80456-5.3437008
Phillips M, Greenberg J, Martinez V. 1989. Elevated concentrations of acetone and unidentified compounds in the breath of alcohol abusers. Alcohol Clin Exp Res 13(4):523–526. 10.1111/j.1530-0277.1989.tb00371.x.2679209
Phillips M, Herrera J, Krishnan S, 1999. Variation in volatile organic compounds in the breath of normal humans. J Chromatogr 729(1-2):75–88. 10.1016/S0378-4347(99)00127-9.
Piatkowski A, Groger A, Bozkurt A, 2007. Acetone associated inhalation injury and rhabdomyolysis. Burns 33(7):932–934. 10.1016/j.burns.2006.08.033.17498882
Pienta RJ. 1980. Transformation of Syrian hamster embryo cells by diverse chemicals and correlation with their reported carcinogenic and mutagenic activities. In: de Serres FJ, Hollaender A, eds. Chemical mutagens. Boston, MA: Springer, 175–202. 10.1007/978-1-4613-3072-1_7.
Pitarque M, Vaglenov A, Nosko M, 1999. Evaluation of DNA damage by the Comet assay in shoe workers exposed to toluene and other organic solvents. Mutat Res 441(1):115–127. 10.1016/S1383-5718(99)00042-X.10224328
Plaa GL, Traiger GJ. 1972. Mechanism of potentiation of CCl4-induced hepatotoxicity. In: Loomis T, ed. Pharmacology and the future of man. Vol. 2. New York, NY: Karger, 101-113. 10.1093/toxsci/10.4.563.
Plaa GL, Traiger GJ, Hanasono GK. 1973. Effect of alcohols on various forms of chemically induced liver injury. In: Khanna JM, Isreal Y, Kalant H, eds. Alcoholic liver pathology. Toronto, Ontario: Alcoholism and Drug Addiction Research Foundation of Ontario, 225–244.
Plaa GL, Hewitt WR, du Souich P, 1982. Isopropanol and acetone potentiation of carbon tetrachloride‐induced hepatotoxic1ty: Single versus repetitive pretreatments in rats. J Toxicol Environ Health A 9(2):235–250. 10.1080/15287398209530158.
Polzin GM, Kosa-Maines RE, Ashley DL, 2007. Analysis of volatile organic compounds in mainstream cigarette smoke. Environ Sci Technol 41(4):1297–1302. 10.1021/es060609l.17593733
Pomerantz RB. 1950. Acute acetone poisoning from castex. Am J Surg 80(1):117–118. 10.1016/0002-9610(50)90572-1.15419373
Porter TD, Khani S, Coon MJ. 1989. Induction and tissue-specific expression of rabbit cytochrome P450IIE1 and IIE2 genes. Mol Pharmacol 36(1):61–65.2747631
Pozzani U, Weil C, Carpenter C. 1959. The toxicological basis of threshold limit values: 5. The experimental inhalation of vapor mixtures by rats, with notes upon the relationship between single dose inhalation and single dose oral data. Am Ind Hyg Assoc J 20(5):364–369. 10.1080/00028895909343733.14434607
Pozzer A, Pollmann J, Taraborrelli D, 2010. Observed and simulated global distribution and budget of atmospheric C2-C5 alkanes. Atmos Chem Phys 10(9):4403–4422. 10.5194/acp-10-4403-2010.
Prabhakar A, Quach A, Zhang H, 2015. Acetone as biomarker for ketosis buildup capability--a study in healthy individuals under combined high fat and starvation diets. Nutr J 14(1):41. 10.1186/s12937-015-0028-x.25897953
Price TD, Rittenberg D. 1950. The metabolism of acetone. J Biol Chem 185:449.15436518
Price VF, Jollow DJ. 1983. Mechanism of ketone-induced protection from acetaminophen hepatotoxicity in the rat. Drug Metab Dispos 11(5):451–457.6138230
Price KS, Waggy GT, Conway RA. 1974. Brine shrimp bioassay and seawater BOD of petrochemicals. J Water Pollut Control Fed 46(1):63–77.4812499
PubChem. 2021. Compound summary: Acetone. National Library of Medicine. https://pubchem.ncbi.nlm.nih.gov/compound/Acetone. June 29, 2021.
Puccini P, Fiorio R, Longo V, 1990. Effects of acetone administration on drug-metabolizing enzymes in mice: presence of a high-affinity diethylnitrosamine de-ethylase. Toxicol Lett 54(2-3):143–150. 10.1016/0378-4274(90)90177-N.2260112
Puccini P, Menicagli S, Longo V, 1992. Purification and characterization of an acetone-inducible cytochrome P-450 from hamster liver microsomes. Biochem J 287:863–870. 10.1042/bj2870863.1445245
Quach T, Gunier R, Tran A, 2011. Characterizing workplace exposures in Vietnamese women working in California nail salons. Am J Public Health 101(Suppl 1):S271–276. 10.2105/ajph.2010.300099.21551383
Quarles JM, Sega MW, Schenley CK, 1979a. Transformation of hamster fetal cells by nitrosated pesticides in a transplacental assay. Cancer Res 39(11):4525–4533.498084
Quarles JM, Sega MW, Schenley CK, 1979b. Rapid screening for chemical carcinogens: transforming activity of selected nitroso compounds detected in a transplacental host-mediated culture system. Natl Cancer Inst Monogr (51):257–263.481579
Racker E. 1951. The mechanism of action of glyoxalase. J Biol Chem 190:685–696.14841219
Rahim S, Bashir W. 1981. Microdetermination of acetone in aqueous solution. Microchemical Journal 26(3):329–333. 10.1016/0026-265X(81)90107-7.
Rahn R, Landry L, Carrier W. 1974. Formation of chain breaks and thymine dimers in DNA upon photosensitization at 313 nm with acetophenone, acetone, or benzophenone. Photochem Photobiol 19(1):75–78. 10.1111/j.1751-1097.1974.tb06476.x.4590519
Raleigh R, McGee W. 1972. Effects of short, high-concentration exposures to acetone as determined by observation in the work area. J Occup Environ Med 14(8):607–610.
Ramu A, Rosenbaum J, Blaschke T. 1978. Disposition of acetone following acute acetone intoxication. West J Med 129(5):429.726426
Rathbun RE, Tai DY. 1987. Vapor pressures and gas-film coefficients for ketones. Chemosphere 16(1):69–78. 10.1016/0045-6535(87)90110-x.
Rathbun RE, Stephens DW, Tai DY. 1991. Fate of acetone in an outdoor model stream with a nitrate supplement, southern Mississippi, U.S.A. J Hydrol 123(3-4):225–242. 10.1016/0022-1694(91)90092-v.
Rathbun RE, Stephens DW, Tai DY. 1993. Bacterial degradation of acetone in an outdoor model stream. Environ Pollut 79(2):153–162. 10.1016/0269-7491(93)90065-v.15091900
Rathbun RE, Stephens DW, Schultz DJ, 1982. Fate of acetone in water. Chemosphere 11:1097–1114. 10.1016/0045-6535(82)90114-X.
Rathbun RE, Stephens DW, Shultz DJ, 1988. Fate of acetone in an outdoor model stream in southern Mississippi, U.S.A. J Hydrol 104(1-4):181–209. 10.1016/0022-1694(88)90165-5.
Raucy JL, Lasker JM, Lieber CS, 1989. Acetaminophen activation by human liver cytochromes P450IIE1 and P450IA2. Arch Biochem Biophys 271(2):270–283. 10.1016/0003-9861(89)90278-6.2729995
Ravi K, Singh M, Julka DB. 1995. Properties of rapidly adapting receptors of the airways in monkeys (Macaca mulatta). Respir Physiol 99(1):51–62. 10.1016/0034-5687(94)00072-8.7740212
Raymond P, Plaa GL. 1996. Ketone potentiation of haloalkane-induced hepatotoxicity: CCl4 and ketone treatment on hepatic membrane integrity. J Toxicol Environ Health 49(3):285–300. 10.1080/00984108.1996.11667602.8876655
Reichard GA, Haff AC, Skutches CL, 1979. Plasma acetone metabolism in the fasting human. J Clin Invest 63(4):619–626. 10.1172/JCI109344.438326
Reichard GA, Skutches CL, Hoeldtke RD, 1986. Acetone metabolism in humans during diabetic ketoacidosis. Diabetes 35(6):668–674. 10.2337/diab.35.6.668.3086164
Reifferscheid G, Heil J. 1996. Validation of the SOS/umu test using test results of 486 chemicals and comparison with the Ames test and carcinogenicity data. Mutat Res Genet Toxicol 369(3-4):129–145. 10.1016/s0165-1218(96)90021-x.
Reilly SM, Goel R, Bitzer Z, 2018a. Little cigars, filtered cigars, and their carbonyl delivery relative to cigarettes. Nicotine Tob Res 20(Suppl 1):S99–S106. 10.1093/ntr/ntx274.30125018
Reilly SM, Goel R, Bitzer Z, 2018b. Supplemental material: Little cigars, filtered cigars, and their carbonyl delivery relative to cigarettes. Nicotine Tob Res 20 10.1093/ntr/ntx274.
Reilly SM, Bitzer ZT, Goel R, 2019. Free Radical, Carbonyl, and Nicotine Levels Produced by Juul Electronic Cigarettes. Nicotine Tob Res 21(9):1274–1278. 10.1093/ntr/nty221.30346584
Rengstorff RH, Khafagy HI. 1985. Cutaneous acetone depresses aqueous humor ascorbate in guinea pigs. Arch Toxicol 58(1):64–66. 10.1007/BF00292620.4074132
Rengstorff RH, Petrali JP, Sim VM. 1972. Cataracts induced in guinea pigs by acetone, cyclohexanone, and dimethyl sulfoxide. Am J Optom Arch Am Acad Optom 49(4):308–319. 10.1097/00006324-197204000-00003.4503502
Rengstorff R, Petrali J, Sim V. 1976. Attempt to induce cataracts in rabbits by cutaneous application of acetone. Am J Optom Physiol Opt 53(1):41–42. 10.1097/00006324-197601000-00007.937472
Renshaw P, Mitchell R. 1956. Acetone poisoning following the application of a lightweight cast. BMJ 1(4967):615-615. 10.1136/bmj.1.4967.615.13293404
RePORTER. 2021. Acetone. Research Portfolio Online Reporting Tools. National Institute of Health. https://reporter.nih.gov/. January 25, 2022.
Rhim JS, Park DK, Weisburger EK, 1974. Evaluation of an in vitro assay system for carcinogens based on prior infection of rodent cells with nontransforming RNA tumor virus. J Natl Cancer Inst 52(4):1167–1173. 10.1093/jnci/52.4.1167.4363703
Roe F, Carter R, Mitchley B, 1972. On the persistence of tumour initiation and the acceleration of tumour progression in mouse skin tumorigenesis. Int J Cancer 9(2):264–273. 10.1002/ijc.2910090204.5041607
Ronis M, Ingelman-Sundberg M. 1989. Acetone-dependent regulation of cytochrome P-450j (IIE1) and P-450b (IIB1) in rat liver. Xenobiotica 19(10):1161–1165. 10.3109/00498258909043168.2815820
Ronis MJ, Johansson I, Hultenby K, 1991. Acetone-regulated synthesis and degradation of cytochrome P450El and cytochrome P4502Bl in rat liver. Eur J Biochem 198:383–389. 10.1111/j.1432-1033.1991.tb16026.x.2040300
Rooth G. 1967. Insulin action measured by acetone disappearance. Preliminary report. Acta Med Scand 182(2):271–272. 10.1111/j.0954-6820.1967.tb11522.x.6039045
Rooth G, Ostenson S. 1966. Acetone in alveolar air, and the control of diabetes. Lancet 2(7473):1102–1105. 10.1016/s0140-6736(66)92194-5.4162529
Rooth G, Carlstrom S. 1970. Therapeutic fasting. Acta Med Scand 187(6):455–463. 10.1111/j.0954-6820.1970.tb02970.x.5458176
Ross DS. 1973. Acute acetone intoxication involving eight male workers. Ann Occup Hyg 16(1):73–75. 10.1016/0165-1218(91)90021-D.4775391
Ross AD, Varghese G, Oporto B, 1995. Effect of propylthiouracil treatment on NADPH-cytochrome P450 reductase levels, oxygen consumption and hydroxyl radical formation in liver microsomes from rats fed ethanol or acetone chronically. Biochem Pharmacol 49(7):979–989. 10.1016/0006-2952(95)00007-M.7741770
Rossman TG, Molina M, Meyer L, 1991. Performance of 133 compounds in the lambda prophage induction endpoint of the Microscreen assay and a comparison with S. typhimurium mutagenicity and rodent carcinogenicity assays. Mutat Res 260(4):349–367. 10.1016/0165-1218(91)90021-d.1831244
Roudabush RL, Terhaar C, Fassett DW, 1965. Comparative acute effects of some chemicals on the skin of rabbits and guinea pigs. Toxicol Appl Pharmacol 7(4):559–565. 10.1016/0041-008X(65)90041-4.5839391
Ruddick JA. 1972. Toxicology, metabolism, and biochemistry of 1,2-propanediol. Toxicol Appl Pharmacol 21(1):102–111. 10.1016/0041-008x(72)90032-4.4553872
Rudney H. 1954. Propanediol phosphate as a possible intermediate in the metabolism of acetone. J Biol Chem 210(1):361–371.13201598
Rustung E, Frithjof K, Foyen A. 1931. The uptake and distribution of acetone in the coldblooded organism. Biochem Z 242:366–376.
Sack TM, Steele DH, Hammerstrom K, 1992. A survey of household products for volatile organic compounds. Atmos Environ Part A 26(6):1063–1070. 10.1016/0960-1686(92)90038-m.
Sakai A, Sato M. 1989. Improvement of carcinogen identification in BALB/3T3 cell transformation by application of a 2-stage method. Mutat Res 214(2):285–296. 10.1016/0027-5107(89)90172-3.2797027
Sakami W. 1950. Formation of formate and labile methyl groups from acetone in the intact rat. J Biol Chem 187(1):369–378.14794722
Sakami W, Lafaye JM. 1951. The metabolism of acetone in the intact rat. J Biol Chem 193:199–203.14907706
Sakata M, Kikuchi J, Haga M, 1989. Disposition of acetone, methyl ethyl ketone and cyclohexanone in acute poisoning. J Toxicol Clin Toxicol 27(1-2):67–77. 10.3109/15563658909038570.2769822
Sallee ED, Sappington CO. 1949. American Conference of Governmental Industrial Hygienists eleventh annual meeting; American Industrial Hygiene Association tenth annual meeting, April 2-7, 1949, Detroit, MI. Am Ind Hyg Assoc Q 10:36-44. 10.1080/00968204909344276.
Sammett D, Lee EW, Kocsis JJ, 1979. Partial hepatectomy reduces both metabolism and toxicity of benzene. J Toxicol Environ Health 5(5):785–792. 10.1080/15287397909529789.513147
Sato A, Nakajima T. 1979. Partition coefficients of some aromatic hydrocarbons and ketones in water, blood and oil. Br J Ind Med 36(3):231–234. 10.1136/oem.36.3.231.500783
Satoh T, Omae K, Takebayashi T, 1995. Acetone excretion into urine of workers exposed to acetone in acetate fiber plants. Int Arch Occup Environ Health 67(2):131–134. 10.1007/BF00572237.7672857
Satoh T, Omae K, Nakashima H, 1996. Relationship between acetone exposure concentration and health effects in acetate fiber plant workers. Int Arch Occup Environ Health 68(3):147–153. 10.1007/BF00381623.8919841
Schaper M, Brost MA. 1991. Respiratory effects of trimellitic anhydride aerosols in mice. Arch Toxicol 65(8):671–677. 10.1007/BF02098035.1747068
Schenk L, Rauma M, Fransson MN, 2018. Percutaneous absorption of thirty-eight organic solvents in vitro using pig skin. PLoS ONE 13(10):e0205458. 10.1371/journal.pone.0205458.30379962
Schnier GG, Laethem CL, Koop DR. 1989. Identification and induction of cytochromes P450, P450IIE1 and P450IA1 in rabbit bone marrow. J Pharmacol Exp Ther 251(2):790–796.2509684
Scholl HR, Iba MM. 1997. Pharmacokinetics of and CYP1A induction by pyridine and acetone in the rat: interactions and effects of route of exposure. Xenobiotica 27(3):265–277. 10.1080/004982597240596.9141234
Schrikker A, De Vries W, Zwart A, 1985. Uptake of highly soluble gases in the epithelium of the conducting airways. Pflugers Arch 405(4):389–394. 10.1007/BF00595693.4080516
Schrikker A, de Vries W, Zwart A, 1989. The excretion of highly soluble gases by the lung in man. Pflugers Arch 415(2):214–219. 10.1007/BF00370595.2556686
Seeber A, Kiesswetter E. 1991. Exposure to mixtures of organic solvents: Subjective symptoms as valid adverse effects? In: Fletcher LD, ed. Proceeding of the 4th international conference on the combined effects of environmental factors. Baltimore, MD: Johns Hopkins University, 1–74.
Seeber A, Kiesswetter E, Blaszkewicz M. 1992. Correlations between subjective disturbances due to acute exposure to organic solvents and internal dose. Neurotoxicology 13(1):265–269.1508428
Shah JJ, Singh HB. 1988. Distribution of volatile organic chemicals in outdoor and indoor air: a national VOCs data base. Environ Sci Technol 22(12):1381–1388. 10.1021/es00177a001.22200458
Shahidi F, Rubin LJ, D’Souza LA. 1986. Meat flavor volatiles: a review of the composition, techniques of analysis, and sensory evaluation. Crit Rev Food Sci Nutr 24(2):141–243. 10.1080/10408398609527435.3527563
Shepson PB, Hastie DR, Schiff HI, 1991. Atmospheric concentrations and temporal variations of C1-C3 carbonyl compounds at two rural sites in central Ontario. Atmos Environ 25A(9):2001–2015. 10.1016/0960-1686(91)90280-k.
Siller H, Rainey FA, Stackebrandt E, 1996. Isolation and characterization of a new gram-negative, acetone-degrading, nitrate-reducing bacterium from soil, Paracoccus solventivorans sp. nov. Int J Syst Bacteriol 46(4):1125–1130. 10.1099/00207713-46-4-1125.8863446
Simamora N, Soemarko DS, Yunus F. 2018. Analysis of obstruction of lung function in workers exposed to organic solvents at shoe factory. J Phy Conf Ser 1073:042019. 10.1088/1742-6596/1073/4/042019.
Singh HB, Hanst PL. 1981. Peroxyacetyl nitrate (PAN) in the unpolluted atmosphere: An important reservoir for nitrogen oxides. Geophys Res Lett 8(8):941–944. 10.1029/GL008i008p00941.
Singh HB, O’Hara D, Herlth D, 1994. Acetone in the atmosphere: Distribution, sources, and sinks. J Geophys Res 99(D1):1805–1819. 10.1029/93jd00764.
Singh KP, Yoon HL, Ratner S, 1996. Modulation of the development of humoral immunity by topically applied acetone, ethanol, and 12-O-tetradecanoylphorbol-13-acetate. Fundam Appl Toxicol 33(1):129–139. 10.1006/faat.1996.0150.8812255
Sipes IG, Slocumb ML, Holtzman G. 1978. Stimulation of microsomal dimethylnitrosamine-N-demethylase by pretreatment of mice with acetone. Chem Biol Interact 21(2-3):155–166. 10.1016/0009-2797(78)90016-9.679394
Sipes IG, Stripp B, Krishna G, 1973. Enhanced hepatic microsomal activity by pretreatment of rats with acetone or isopropanol. Proc Soc Exp Biol Med 142(1):237–240. 10.3181/00379727-142-36996.4405141
Sippel H, Penttilä KE, Lindros KO. 1991. Regioselective induction of liver glutathione transferase by ethanol and acetone. J Toxicol Pharmacol 68(5):391–393. 10.1111/j.1600-0773.1991.tb01258.x.
Skutches CL, Owen OE, Reichard GA. 1990. Acetone and acetol inhibition of insulin-stimulated glucose oxidation in adipose tissue and isolated adipocytes. Diabetes 39(4):450–455. 10.2337/diab.39.4.450.2180756
Slutzman JE, Curley DP, Macias-Konstantopoulos W, 2015. Altered mental status and tachycardia. J Emerg Med 48(5):597–602. 10.1016/j.jemermed.2014.12.021.25656429
Smith R, Fuller DJ, Wedge JH, 1975. Initial effect of injury on ketone bodies and other blood metabolites. Lancet 1(7897):1–3. 10.1016/s0140-6736(75)92369-7.46334
Smyth HF, Carpenter CP, Well CS, 1962. Range-finding toxicity data: List VI. Am Ind Hyg Assoc J 23(2):95–107. 10.1080/00028896209343211.13914538
Snider JR, Dawson GA. 1985. Tropospheric light alcohols, carbonyls, and acetonitrile: Concentrations in the southwestern United States and Henry’s law data. J Geophys Res Atmos 90(D2):3797–3805. 10.1029/JD090iD02p03797.
Snyder R, Kocsis JJ, Drew R. 1975. Current concepts of chronic benzene toxicity. CRC Crit Rev Toxicol 3(3):265–288. 10.3109/10408447509079860.1097190
Socie EM, Gromen KD, Migliozzi AA, 1997. Work-related skin disease in the plastics industry. Am J Ind Med 31(5):545–550. 10.1002/(sici)1097-0274(199705)31:5<545::aid-ajim7>3.0.co;2-s.9099355
Song B, Gelboin HV, Park S, 1986. Complementary DNA and protein sequences of ethanol-inducible rat and human cytochrome P-450s. Transcriptional and post-transcriptional regulation of the rat enzyme. J Biol Chem 261(35):16689–16697.3782137
Song B, Veech RL, Park SS, 1989. Induction of rat hepatic N-nitrosodimethylamine demethylase by acetone is due to protein stabilization. J Biol Chem 264(6):3568–3572.2914964
Song C, Zhao Z, Lv G, 2010. Carbonyl compound emissions from a heavy-duty diesel engine fueled with diesel fuel and ethanol-diesel blend. Chemosphere 79(11):1033–1039. 10.1016/j.chemosphere.2010.03.061.20416922
Specht H, Miller JW, Valaer PJ, 1939. Acute response of guinea pigs to the inhalation of ketone vapors. Public Health Rep 54:944–954.
Spencer PS, Bischoff MC, Schaumburg HH. 1978. On the specific molecular configuration of neurotoxic aliphatic hexacarbon compounds causing central-peripheral distal axonopathy. Toxicol Appl Pharmacol 44(1):17–28. 10.1016/0041-008X(78)90280-6.675688
Stadler K, Bonini MG, Dallas S, 2008. Direct evidence of iNOS-mediated in vivo free radical production and protein oxidation in acetone-induced ketosis. Am J Physiol Endocrinol Metab 295(2):E456–462. 10.1152/ajpendo.00015.2008.18559982
Stafford W, Northup HJ. 1955. The BOD of textile chemicals. Am Dyestuff Rep 11:355–359.
Steelman B, Ecker R. 1984. Organics contamination of groundwater: an open literature review. In: 5th DOE environment protection meeting. Richland, WA: U.S. Department of Energy, 1–12.
Steinberg SM, Kreamer DK. 2002. Evaluation of the sorption of volatile organic compounds by unsaturated calcareous soil from Southern Nevada using inverse gas chromatography. Environ Sci Technol 27(5):883–888. 10.1021/es00042a010.
Stewart R, Hake C, Wu A, 1975. Acetone: Development of a biologic standard for the industrial worker by breath analysis. Milwaukee, MI: National Institute of Occupational Safety and Health. PB82172917.
Stonebraker RD, Smith AJ. 1980. Containment and treatment of a mixed chemical discharge from “The Valley of the Drums” near Louisville, Kentucky. In: Control of hazardous material spills: Proceedings of the 1980 National Conference of Control Hazardous Material Spills, May 13-15, 1980, Louisville, Kentucky. Nashville, TN: Vanderbilt University, 1–10.
Stowell A, Hillborn M, Salaspuro M, 1980. Low acetaldehyde levels in blood, breath and cerebrospinal fluid of intoxicated humans as assayed by improved methods. In: Thurman RG, ed. Alcohol and aldehyde metabolizing systems-IV. Boston, MA: Springer, 635–645.
Strange P, Møller A, Ladefoged O, 1991. Total number and mean cell volume of neocortical neurons in rats exposed to 2,5-hexanedione with and without acetone. Neurotoxicol Teratol 13(4):401–406. 10.1016/0892-0362(91)90088-e.1921919
Striegel JA, Carpenter CP. 1961. Progress report for the month ending August 31, 1961. Union Carbide Corporation. Submitted to the U.S. Environmental Protection Agency under TSCA Section 8(e). OTS0536615. 88-920003273. 8EHQ-0692-4631.
Strong G. 1944. Acute acetone poisoning. CMAJ 51(4):359.20323234
Swan SH, Beaumont JJ, Hammond SK, 1995. Historical cohort study of spontaneous abortion among fabrication workers in the Semiconductor Health Study: agent-level analysis. Am J Ind Med 28(6):751–769. 10.1002/ajim.4700280610.8588562
Takemoto S, Kuge Y, Nakamoto M. 1981. The measurement of BOD in sea water. Suishitsu Odaku Kenkyu 4(2):80–90. 10.2965/jswe1978.4.80.
Takeoka GR, Flath RA, Guentert M, 1988. Nectarine volatiles: vacuum steam distillation versus headspace sampling. J Agric Food Chem 36(3):553–560. 10.1021/jf00081a037.
Tanii H. 1996. Anesthetic activity of monoketones in mice: Relationship to hydrophobicity and in vivo effects on Na++-ATPase activity and membrane fluidity. Toxicol Lett 85(1):41–47. 10.1016/0378-4274(96)03635-1.8619259
Tanii H, Tsuji H, Hashimoto K. 1986. Structure-toxicity relationship of monoketones. Toxicol Lett 30(1):13–17. 10.1016/0378-4274(86)90173-6.3952768
Tates A, Kriek E. 1981. Induction of chromosomal aberrations and sister-chromatid exchanges in Chinese hamster cells in vitro by some proximate and ultimate carcinogenic arylamide derivatives. Mutat Res 88:397–410. 10.1016/0165-1218(81)90031-8.7195981
Taylor A, Smith DE, Palmer VJ, 1993. Relationships between acetone, cataracts, and ascorbate in hairless guinea pigs. Ophthalmic Res 25(1):30–35. 10.1159/000267218.8446366
Thom NS, Agg AR. 1975. The breakdown of synthetic organic compounds in biological processes. Proc R Soc Lond B Biol Sci 189(1096):347–357. 10.1098/rspb.1975.0061.238201
Thomas RG. 1990. Volatilization from water. In: Lyman WJ, Reehl WF, Rosenblatt DH, eds. Handbook of chemical property estimation: Environmental behavior of organic compounds. New York, NY: McGraw-Hill Book Company, 15-18 to 15-21.
Thornalley PJ. 1990. The glyoxalase system: new developments towards functional characterization of a metabolic pathway fundamental to biological life. Biochem J 269(1):1–11. 10.1042/bj2690001.2198020
Tichenor BA, Mason MA. 1988. Organic emissions from consumer products and building materials to the indoor environment. JAPCA 38(3):264–268. 10.1080/08940630.1988.10466376.3379453
Tindberg N, Ingelman-Sundberg M. 1989. Cytochrome P-450 and oxygen toxicity. Oxygen-dependent induction of ethanol-inducible cytochrome P-450 (IIE1) in rat liver and lung. Biochemistry 28(10):4499–4504. 10.1021/bi00436a056.2765498
Tomei F, Giuntoli P, Biagi M, 1999. Liver damage among shoe repairers. Am J Ind Med 36(5):541–547. 10.1002/(sici)1097-0274(199911)36:5<541::aid-ajim6>3.0.co;2-4.10506736
Tosti A, Bardazzi F, Ghetti P. 1988. Unusual complication of sensitizing therapy for alopecia areata. Contact Dermatitis 18(5):322-322. 10.1111/j.1600-0536.1988.tb02857.x.3416602
Traiger GJ, Plaa GL. 1973. Effect of aminotriazole on isopropanol- and acetone-induced potentiation of CCl 4 hepatotoxicity. Can J Physiol Pharmacol 51(4):291–296. 10.1139/y73-043.4701720
Traiger GJ, Plaa GL. 1974. Chlorinated hydrocarbon toxicity. Arch Environ Health 28(5):276–278. 10.1080/00039896.1974.10666486.4821771
Trotter MD, Sulway MJ, Trotter E. 1971. The rapid determination of acetone in breath and plasma. Clin Chim Acta 35(1):137–143. 10.1016/0009-8981(71)90304-4.5126988
Tsukamoto S, Kanegae T, Saito M, 1991. Concentrations of blood and urine ethanol, acetaldehyde, acetate and acetone during experimental hangover in volunteers. Arukoru kenkyu to yakubutsu izon 26(6):500–510.1785958
Tu YY, Peng R, Chang Z-FaY, Chung S. 1983. Induction of a high affinity nitrosamine demethylase in rat liver microsomes by acetone and isopropanol. Chem Biol Interact 44(3):247–260. 10.1016/0009-2797(83)90053-4.6409434
Turner CE, Elsohly MA, Boeren EG. 1980. Constituents of Cannabis sativa L. XVII. A review of the natural constituents. J Nat Prod 43(2):169–234. 10.1021/np50008a001.6991645
Turner C, Walton C, Hoashi S, 2009. Breath acetone concentration decreases with blood glucose concentration in type I diabetes mellitus patients during hypoglycaemic clamps. J Breath Res 3(4):046004. 10.1088/1752-7155/3/4/046004.21386197
U.S. Census Bureau. 2018. Trade definitions. U.S. Census Bureau. https://www.census.gov/foreign-trade/reference/definitions/index.html#general_imports. May 2, 2019.
Ueng T-H, Tsai J-N, Ju M, 1991. Effects of acetone administration on cytochrome P-450-dependent monooxygenases in hamster liver, kidney, and lung. Arch Toxicol 65(1):45–51. 10.1007/BF01973502.2043050
Unlu I, Kesici GG, Basturk A, 2014. A comparison of the effects of solvent and noise exposure on hearing, together and separately. Noise Health 16(73):410–415. 10.4103/1463-1741.144422.25387537
Urano K, Kato Z. 1986a. A method to classify biodegradabilities of organic compounds. J Hazard Mater 13(2):135–145. 10.1016/0304-3894(86)80014-0.
Urano K, Kato Z. 1986b. Evaluation of biodegradation ranks of priority organic compounds. J Hazard Mater 13(2):147–159. 10.1016/0304-3894(86)80015-2.
USGS. 1997. Spatial variability of volatile organic compounds in streams on Long Island, New York, and in New Jersey. U.S. Geological Survey. Fact Sheet FS-194-97. https://pubs.er.usgs.gov/publication/fs19497. May 6, 2022.
USGS. 2001. Ground-water levels and water-quality data for wells in the Spring Creek area near Arnold Air Force Base, Tennessee, April and May 2000. Nashville, TN: U.S. Geological Survey. Open-File Report 01-150. https://pubs.usgs.gov/of/2001/ofr01-150/pdf/ofr01-150.book_new.pdf. May 6, 2022.
USGS. 2007. Concentration data for anthropogenic organic compounds in ground water, surface water, and finished water of selected community water systems in the United States 2002-05. U.S. Geological Survey. Data series 268. 10.3133/ds268
USGS. 2009. Factors affecting water quality in selected carbonate aquifers in the United States,1993-2005. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2008-5240. 10.3133/sir20085240.
USGS. 2020. Groundwater quality in relation to drinking water health standards and geochemical characteristics for 54 domestic wells in Clinton County, Pennsylvania, 2017. Reston, VA: U.S. Geological Survey. Scientific Investigations Report 2020-5022. 10.3133/sir20205022.
USITC. 2019. USITC DataWeb. United States International Trade Commission. https://dataweb.usitc.gov/trade/search. May 21, 2019.
Vainio H, Zitting A. 1978. Interaction of styrene and acetone with drug biotransformation enzymes in rat liver. Scand J Work Environ Health 4(Suppl 2):47–52. 10.1016/0378-4274(81)90038-2.
Valentovic M, Ball JG, Anestis D. 1992. Contribution of acetone and osmotic-diuresis by streptozotocin-induced diabetes in attenuation of cephaloridine nephrotoxicity. Toxicology 71(3):245–255. 10.1016/0300-483X(92)90027-C.1736416
Van Duuren BL, Sivak A, Katz C, 1971. Cigarette smoke carcinogenesis: importance of tumor promoters. J Natl Cancer Inst 47(1):235–240. 10.1093/jnci/47.1.235.5570117
Van Duuren BL, Loewengart G, Seidman I, 1978. Mouse skin carcinogenicity tests of the flame retardants tris(2,3-dibromopropyl) phosphate, tetrakis(hydroxymethyl)phosphonium chloride, and polyvinyl bromide. Cancer Res 38(10):3236–3240.688215
Van Stekelenburg GJ, Koorevaar G. 1972. Evidence for the existence of mammalian acetoacetate decarboxylase: with special reference to human blood serum. Clin Chim Acta 39(1):191–199.4624981
Vance DE. 1984. Metabolism of fatty acids and triacylglycerols. In: Zubay G, ed. Biochemistry. Reading, MA: Addison-Wesley Publishing Company, 471–503.
Vangala RR, Blaszkewicz M, Bolt HM, 1991. Acute experimental exposures to acetone and ethyl acetate. Arch Toxicol Suppl 14:259–262. 10.1007/978-3-642-74936-0_54.1805744
Vasavada HA, Padayatty JD. 1981. Rapid transfection assay for screening mutagens and carcinogens. Mutat Res 91(1):9–14. 10.1016/0165-7992(81)90062-2.7010154
Vodickova L, Frantik E, Vodickova A. 1995. Neutrotropic effects and blood levels of solvents at combined exposures: binary mixtures of toluene, o-xylene and acetone in rats and mice. Cent Eur J Public Health 3(2):57–64.
Walton DC, Kehr EF, Loevenhart AS. 1928. A comparison of the pharmacological action of diacetone alcohol and acetone. J Pharmacol Exp Ther 33(2):175–183.
Wang A, Luca A, Edelenbos M. 2019. Emission of volatile organic compounds from yellow onion (Allium cepa L.) bulbs during storage. J Food Sci Technol 56(6):2940–2948. 10.1007/s13197-019-03764-z.31205349
Wang G, Maranelli G, Perbellini L, 1994. Blood acetone concentration in "normal people" and in exposed workers 16 h after the end of the workshift. Int Arch Occup Environ Health 65(5):285–289. 10.1007/BF00405690.
Wang M, Li S, Zhu R, 2020. On-road tailpipe emission characteristics and ozone formation potentials of VOCs from gasoline, diesel and liquefied petroleum gas fueled vehicles. Atmos Environ 223:117294. 10.1016/j.atmosenv.2020.117294.
Weisel CP, Alimokhtari S, Sanders PF. 2008. Indoor air VOC concentrations in suburban and rural New Jersey. Environ Sci Technol 42(22):8231–8238. 10.1021/es8005223.19068799
Weiss HS, O’connell JF, Hakaim AGaJ, William T. 1986. Inhibitory effect of toluene on tumor promotion in mouse skin. Proc Soc Exp Biol Mede 181(2):199–204. 10.3181/00379727-181-42240.
WHO. 2010. WHO guidelines for indoor air quality: Selected pollutants. World Health Organization. https://www.euro.who.int/__data/assets/pdf_file/0009/128169/e94535.pdf. May 6, 2022.
WHO. 2017. Guidelines for drinking-water quality. World Health Organization. https://www.who.int/publications/i/item/9789241549950. May 6, 2022.
Widmark EM P. 1919. Studies in the concentration of indifferent narcotics in blood and tissues. Acta Med Scand 52(1):87–164. 10.1111/j.0954-6820.1919.tb08277.
Wigaeus E, Holm S, Astrand I. 1981. Exposure to acetone. Uptake and elimination in man. Scand J Work Environ Health 7(2):84–94. 10.5271/sjweh.2561.
Wigaeus E, Lof A, Nordqvist M. 1982. Distribution and elimination of 2-[14C]-acetone in mice after inhalation exposure. Scand J Work Environ Health 8(2):121–128. 10.5271/sjweh.2486.7134929
Wigaeus E, Löf A, Nordqvist MB. 1984. Uptake, distribution, metabolism, and elimination of styrene in man. A comparison between single exposure and co-exposure with acetone. Occup Environ Med 41(4):539–546. 10.1136/oem.41.4.539.
Wildenhoff K. 1972. Diurnal variations in the concentrations of blood acetoacetate, 3-hydroxybutyrate and glucose in normal persons. Acta Med Scand 191(4):303.5032673
Williamson D, Whitelaw E. 1978. Physiological aspects of the regulation of ketogenesis. In: Biochemical society symposium. Biochemical Society, 137–161.
Woolhiser MR, Houtman CE, Waechter JM. 2006. Acetone in drinking water does not modulate humoral immunity in mice as measured by the antibody, plaque-forming cell assay. Int J Toxicol 25(5):333–339. 10.1080/10915810600840826.16940005
WQP. 2021. Water quality portal data: Acetone. National Water Quality Monitoring Council. https://www.waterqualitydata.us/portal/. April 7, 2021.
Wysocki CJ, Dalton P, Brody MJ, 1997. Acetone odor and irritation thresholds obtained from acetone-exposed factory workers and from control (occupationally unexposed) subjects. Am Ind Hyg Assoc J 58(10):704–712. 10.1080/15428119791012342.9342830
Yamaguchi T. 1985. Stimulating effects of organic solvents on the mutagenicities of sugar-degradation compounds. Agric Biol Chem 49(12):3363–3368. 10.1080/00021369.1985.10867291.
Yanagihara S, Shimada I, Shinoyama E, 1977. Photochemical reactivities of hydrocarbons. In: Proceedings of the fourth International Clean Air Congress, held at Tokyo, Japan, May 16-20, 1977. Tokyo, Japan: Japanese Union of Air Pollution Prevention Associations, 472–477.
Yi J, Duling MG, Bowers LN, 2019. Particle and organic vapor emissions from children’s 3-D pen and 3-D printer toys. Inhal Toxicol 31(13-14):432–445. 10.1080/08958378.2019.1705441.31874579
Yoo J-SH, Yang CS. 1985. Enzyme specificity in the metabolic activation of N-nitrosodimethylamine to a mutagen for Chinese hamster V79 cells. Cancer Res 45(11 Part 1):5569–5574.4053031
Yoo JS, Ishizaki H, Yang CS. 1990. Roles of cytochrome P450IIE1 in the dealkylation and denitrosation of N-nitrosodimethylamine and N-nitrosodiethylamine in rat liver microsomes. Carcinogenesis 11(12):2239–2243. 10.1093/carcin/11.12.2239.2265475
Zakoshansky VM, Griaznov AK. 1995. Acid cleavage of cumene hydroperoxide to phenol, acetone and alpha-methylstyrene. European Patent Office. Patent No. EP0670296B1. https://patents.google.com/patent/EP0670296A1/en. May 6, 2022.
Zarani F, Papazafiri P, Kappas A. 1999. Induction of micronuclei in human lymphocytes by organic solvents in vitro. J Environ Pathol Toxicol Oncol 18(1):21–28.9951836
Zeiger E, Anderson B, Haworth S, 1992. Salmonella mutagenicity tests: V. Results from the testing of 311 chemicals. Environ Mol Mutagen 21(Suppl 21):2–141. 10.1002/em.2850190603.
Zhang Y, Yue D, Liu J, 2012. Release of non-methane organic compounds during simulated landfilling of aerobically pretreated municipal solid waste. J Environ Manage 101:54–58. 10.1016/j.jenvman.2011.10.018.22406844
Zhong L, Batterman S, Milando CW. 2019a. VOC sources and exposures in nail salons: a pilot study in Michigan, USA. Int Arch Occup Environ Health 92(1):141–153. 10.1007/s00420-018-1353-0.30276513
Zhong L, Batterman S, Milando CW. 2019b. Supplemental material: VOC sources and exposures in nail salons: a pilot study in Michigan, USA. Int Arch Occup Environ Health 92 10.1007/s00420-018-1353-0.
Zhou X, Mopper K. 1993. Carbonyl compounds in the lower marine troposphere over the Caribbean Sea and Bahamas. J Geophys Res Oceans 98(C2):2385–2392. 10.1029/92JC02772.
Zhu J, Newhook R, Marro L, 2005. Selected volatile organic compounds in residential air in the city of Ottawa, Canada. Environ Sci Technol 39(11):3964–3971.15984771
Zimmermann FK. 1983. Mutagenicity screening with fungal systems. Ann N Y Acad Sci 407(1):186–196. 10.1111/j.1749-6632.1983.tb47824.x.6349475
Zimmermann FK, Mayer VW, Scheel I. 1984. Induction of aneuploidy by oncodazole (nocodazole), an anti-tubulin agent, and acetone. Mutat Res 141(1):15–18. 10.1016/0165-7992(84)90030-7.6384770
Zimmermann FK, Mayer VW, Scheel I, 1985. Acetone, methyl ethyl ketone, ethyl acetate, acetonitrile and other polar aprotic solvents are strong inducers of aneuploidy in Saccharomyces cerevisiae. Mutat Res 149(3):339–351. 10.1016/0027-5107(85)90150-2.3887145