# CONTRIBUTORS & REVIEWERS

## CHEMICAL MANAGER TEAM

- Obaid Faroon, D.V.M., Ph.D. (Lead)
  Mike Fay, Ph.D.
- ATSDR, Office of Innovation and Analytics, Toxicology Section, Atlanta, GA
- Ryan Klein, Ph.D.
  Rebecca Gray, M.P.H.
  Andrea Chiger, M.P.H.
  Kaley Beins, M.P.H.
  Hannah Derrick, B.S.
  Kerry Diskin, Ph.D.
  Mary Juergens, M.P.H.
- Abt Associates, Rockville, MD
- Julie M. Klotzbach, Ph.D.
  Ramsey D. Hanna
- SRC, Inc., North Syracuse, NY

## REVIEWERS

Interagency Minimal Risk Level Workgroup:

Includes ATSDR; National Center for Environmental Health (NCEH); National Institute for Occupational Safety and Health (NIOSH); U.S. Environmental Protection Agency (EPA); National Toxicology Program (NTP).

Additional reviews for science and/or policy:

ATSDR, Office of Community Health and Hazard Assessment; ATSDR, Office of Capacity Development and Applied Prevention Science; ATSDR, Office of Science; NCEH, Division of Laboratory Science; NCEH, Division of Environmental Health Science and Practice; EPA.

## PEER REVIEWERS

1. Leena Nylander-French, Ph.D.; Professor, Department of Environmental Sciences and Engineering; Director, NC Occupational Safety and Health Education and Research Center; Director, Occupational Exposure Science and Industrial Hygiene Program; University of North Carolina at Chapel Hill Gillings School of Global Public Health; Chapel Hill, North Carolina
2. Gunnar Johanson, Ph.D.; Professor of Occupational Toxicology and Risk Assessment; Institute of Environmental Medicine; Karolinska Institutet; Stockholm, Sweden
3. Andrew Patterson, Ph.D.; Tombros Early Career Professor; Professor of Molecular Toxicology; Professor of Biochemistry & Molecular Biology; Center for Molecular Toxicology and Carcinogenesis, Department of Veterinary and Biomedical Sciences; Pennsylvania State University; University Park, Pennsylvania

These experts collectively have knowledge of toxicology, chemistry, and/or health effects. All reviewers were selected in conformity with Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

ATSDR scientists review peer reviewers’ comments and determine whether changes will be made to the profile based on comments. The peer reviewers’ comments and responses to these comments are part of the administrative record for this compound.

The listing of peer reviewers should not be understood to imply their approval of the profile’s final content. The responsibility for the content of this profile lies with ATSDR.