# CHAPTER 4 CHEMICAL AND PHYSICAL INFORMATION

## 4.1 CHEMICAL IDENTITY

Table 4-1 lists common synonyms, trade names, and other pertinent identification information for acetone.

Table 4-1 Chemical Identity of Acetone

Characteristic | Information | Reference
Chemical name | Acetone | PubChem 2021
Synonym(s) and registered trade name(s) | Dimethyl ketone; 2-propanone; propan-2-one; beta-ketopropane | PubChem 2021
Chemical formula | C_3_H_6_O | Haynes et al. 2015
Chemical structure | Chemical structure of Acetone | Haynes et al. 2015
CAS Registry Number | 67-64-1 | Haynes et al. 2015

CAS = Chemical Abstracts Service

## 4.2 PHYSICAL AND CHEMICAL PROPERTIES

Acetone is a colorless volatile liquid with a fruity odor and pungent, sweetish taste. It dissolves completely in water and is expected to volatilize from soil and water. Table 4-2 lists important physical and chemical properties of acetone.

Table 4-2 Physical and Chemical Properties of Acetone

Property | Information | Reference
Molecular weight | 58.079 | Haynes et al. 2015
Color | Colorless | PubChem 2021
Physical state | Liquid | Haynes et al. 2015
Melting point | −94.9°C | Haynes et al. 2015
Boiling point | 56.08°C | Haynes et al. 2015
Critical temperature and pressure | 508.1 K and 4.7 MPa | Haynes et al. 2015
Density at 20°C | 0.7845 g/cm^3^ at 25°C | Haynes et al. 2015
Taste | Pungent, sweetish | PubChem 2021
Odor | Fruity odor | PubChem 2021
Odor threshold: | | PubChem 2021
Water | 20 ppm, w/v
Air | 13 ppm, v/v
Solubility:
Water at 20°C | Miscible with water | Haynes et al. 2015
Organic solvents | Miscible with ethanol, diethyl ether, acetone, benzene, chloroform
Partition coefficients:
Log K_ow_ | −0.24 | Haynes et al. 2015
Log K_oc_ | 0.73 (estimated)^a^ | Lyman 1982
Vapor pressure at 20°C | | Haynes et al. 2015
Henry's law constant at 25°C | | PubChem 2021
Degradation half-life in air via reaction with OH radicals | 1.80×10^−13^ cm^3^/molecule-second at 25°C | PubChem 2021
Dissociation constant | pKa 20 | PubChem 2021
Heat of vaporization | 30.99 kJ/mol at 25°C | Haynes et al. 2015
Autoignition temperature | 465°C | Haynes et al. 2015
Flashpoint | −20°C | Haynes et al. 2015
Flammability limits in air (percent by volume) | 2.5–12.8% | Haynes et al. 2015
Conversion factors | 1 ppm = 2.38 mg/m^3^; 1 mg/m^3^ = 0.42 ppm
Incompatibilities and reactivity | Acetone and chloroform is a potentially explosive combination in the presences of a base; incompatible with nitric and sulfuric acid mixtures and hydrogen peroxide | Haynes et al. 2015

a Estimated by regression equation 4–13 in Lyman (1982).