# APPENDIX A ATSDR MINIMAL RISK LEVEL WORKSHEETS

MRLs are derived when reliable and sufficient data exist to identify the target organ(s) of effect or the most sensitive health effect(s) for a specific duration for a given route of exposure. An MRL is an estimate of the daily human exposure to a hazardous substance that is likely to be without appreciable risk of adverse noncancer health effects over a specified route and duration of exposure. MRLs are based on noncancer health effects only; cancer effects are not considered. These substance-specific estimates, which are intended to serve as screening levels, are used by ATSDR health assessors to identify contaminants and potential health effects that may be of concern at hazardous waste sites. It is important to note that MRLs are not intended to define clean-up or action levels.

MRLs are derived for hazardous substances using the NOAEL/uncertainty factor approach. They are below levels that might cause adverse health effects in the people most sensitive to such chemical-induced effects. MRLs are derived for acute (1-14 days), intermediate (15-364 days), and chronic (≥365 days) durations and for the oral and inhalation routes of exposure. Currently, MRLs for the dermal route of exposure are not derived because ATSDR has not yet identified a method suitable for this route of exposure. MRLs are generally based on the most sensitive substance-induced endpoint considered to be of relevance to humans. Serious health effects (such as irreparable damage to the liver or kidneys, or birth defects) are not used as a basis for establishing MRLs. Exposure to a level above the MRL does not mean that adverse health effects will occur.

MRLs are intended only to serve as a screening tool to help public health professionals decide where to look more closely. They may also be viewed as a mechanism to identify those hazardous waste sites that are not expected to cause adverse health effects. Most MRLs contain a degree of uncertainty because of the lack of precise toxicological information on the people who might be most sensitive (e.g., infants, elderly, nutritionally or immunologically compromised) to the effects of hazardous substances. ATSDR uses a conservative (i.e., protective) approach to address this uncertainty consistent with the public health principle of prevention. Although human data are preferred, MRLs often must be based on animal studies because relevant human studies are lacking. In the absence of evidence to the contrary, ATSDR assumes that humans are more sensitive to the effects of hazardous substance than animals and that certain persons may be particularly sensitive. Thus, the resulting MRL may be as much as 100-fold below levels that have been shown to be nontoxic in laboratory animals.

Proposed MRLs undergo a rigorous review process: Health Effects/MRL Workgroup reviews within the Office of Innovation and Analytics, Toxicology Section, expert panel peer reviews, and agency-wide MRL Workgroup reviews, with participation from other federal agencies and comments from the public. They are subject to change as new information becomes available concomitant with updating the toxicological profiles. Thus, MRLs in the most recent toxicological profiles supersede previously published MRLs. For additional information regarding MRLs, please contact the Office of Innovation and Analytics, Toxicology Section, Agency for Toxic Substances and Disease Registry, 1600 Clifton Road NE, Mailstop S102-1, Atlanta, Georgia 30329-4027.

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Acute
MRL: | 8 ppm
Critical Effect: | Altered auditory tone discrimination and neurobehavioral effects
Reference: | Dick et al. 1989
Point of Departure: | Minimal LOAEL of 237 ppm
Uncertainty Factor: | 30
LSE Graph Key: | 1
Species: | Human

MRL Summary: The acute-duration inhalation MRL of 8 ppm is based on a minimal LOAEL of 237 ppm for neurobehavioral effects (altered auditory tone discrimination and neurobehavioral effects) in humans exposed for 4 hours (Dick et al. 1989). An uncertainty factor of 30 (3 for use of a minimal LOAEL and 10 for human variability) was applied.

Selection of the Critical Effect: Numerous studies have evaluated the neurological effects of acetone. Neurological effects in humans exposed to acetone range from dizziness and headaches (Pomerantz 1950; Raleigh and McGee 1972) to dulling of reflexes (Chen et al. 2002; Haggard et al. 1944) and unconsciousness (Ross 1973). Narcotic effects were found in animals exposed to high doses of acetone (NTP 1988; Specht et al. 1939). These effects are found after both inhalation and oral exposures of varying durations. Table A-1 summarizes relevant NOAEL and LOAEL values following acute inhalation exposures to acetone.

Table A-1 Summary of Relevant NOAEL and LOAEL Values Following Acute Duration Inhalation Exposure to Acetone

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Neurological effects
Human | 4 hours | None | 237 | Altered auditory tone discrimination; increases in anger and hostility | Dick et al. 1989
Human | 4.5 hours | 247 | None | Tests of reaction time and vigilance | Muttray et al. 2005
Human | Two 3-hour sessions with 45-minute interval break | 100 | 250 | Self-reports of weakness, tension, lack of energy | Matsushita et al. 1969a
Human | 6 hours/day; 6 days | None | 250 | Decreased reaction time; self- reports of weakness, tension, lack of energy | Matsushita et al. 1969b
Respiratory irritation
Human | Two 3-hour sessions with 45-minute interval break | None | 100 | Self-report of irritation of the mucous membrane (nose, throat and trachea) | Matsushita et al. 1969a
Human | 6 hours/day; 6 days | 250 | 500 | Self-report of irritation of the mucous membrane (nose, throat, and trachea) | Matsushita et al. 1969b
Human | 3–5 minutes | 200 | 500 | Irritation in the majority of subjects (n≈10) | Nelson et al. 1943

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Neurobehavioral effects were observed in humans exposed to acetone at 237 ppm for 4 hours (Dick et al. 1989). Similar effects have also been observed in humans exposed to 250 ppm acetone for 6 hours or repeatedly for 6 hours/day for 6 days (Matsushita et al. 1969a, 1969b). Effects included lack of energy, general weakness, delayed visual reaction time, and headache. Although irritation of the nose, throat, and trachea was reported in one of five subjects exposed to 100 ppm for two 3-hour exposures (with 45-minute interval break) (Matsushita et al. 1969a), other studies in humans reported respiratory irritation only at higher levels (>250 ppm) for longer durations (Matsushita et al. 1969b; Nelson et al. 1943; Raleigh and McGee 1972; Ross 1973). Furthermore, the reporting of these irritating effects was subjective, and only five volunteers were exposed to 100 ppm (Matsushita et al. 1969a). Therefore, neurological effects were preferentially selected as the critical effect.

Selection of the Principal Study: Matsushita et al. (1969a) reported a NOAEL of 100 ppm and in a subsequent study, Matsushita et al. (1969b) observed neurological effects including lack of energy, weakness, headache, and delayed reaction times after exposure in volunteers to 250 ppm of acetone for 6 hours/day for 6 days. The effects observed in Dick et al. (1989) occurred at a slightly lower concentration of acetone (237 ppm) with a shorter exposure duration of 4 hours. Another study by Muttray et al. (2005) examined the neurological effects of acetone exposures in male volunteers at 247 ppm for 4.5 hours. However, this study involved co-exposure to toluene at 25 ppm. Due to study quality (i.e., small sample size) of Matsushita et al. (1969a) and given the other relevant acute inhalation studies under consideration, Dick et al. (1989) was selected as the key study for its sensitive endpoint (i.e., minimal LOAEL).

Summary of the Principal Study: Dick RB, Setzer JV, Taylor BJ, et al. 1989. Neurobehavioural effects of short duration exposures to acetone and methyl ethyl ketone. Occup Environ Med 46(2):111-121.

Dick et al. (1989) exposed 11 male and 11 female volunteers to a concentration of 237 ppm of acetone (note: the target concentration for participants was 250 ppm acetone, but monitoring of acetone concentrations during the 4-hour exposures indicated a mean concentration of 237 ppm). Additional participants were exposed to either methyl ethyl ketone (MEK) at a target concentration of 200 ppm, a combination of acetone at 125 ppm and MEK at 100 ppm, or ethanol solution. Two control groups were also examined. Participants were aged 18-32 years old and did not have pre-existing medical conditions or substance use disorders. Neurobehavioral testing occurred during six test sessions: one session on the day before the exposures occurred, four sessions on the day of exposure, and one final session on the day after exposure. Psychomotor, sensorimotor, and psychological tests were administered to participants to assess a variety of neurobehavioral tasks.

Participants exposed to acetone at a mean concentration of 237 ppm showed significant differences on two neurobehavioral tasks as compared to controls. Acetone-exposed participants showed significant increases in response time (p <0.05) and significantly greater false alarm percentages (p <0.005) on the auditory tone discrimination task compared to controls. The changes in performance on this task were persistent and mirrored the measured blood concentrations of acetone, indicating that tolerance to acetone did not occur. In addition, significant increases in measures of anger and hostility were observed in males, but not females, exposed to acetone (p <0.001). However, the study authors noted that this finding may be due to chance, given the small sample size and absence of any other significant changes in tests of mood.

Selection of the Point of Departure for the MRL: The MRL was derived from the minimal LOAEL of 237 ppm for neurological effects (auditory tone discrimination task and neurobehavioral effects) in humans exposed to acetone for 4 hours (Dick et al. 1989). Benchmark dose (BMD) modeling could not be performed as only one dose of exposure to acetone alone was examined.

Adjustment for Intermittent Exposure: Because acetone is evenly distributed in blood after absorption, an adjustment for intermittent to continuous exposure was deemed not necessary. Henry’s law indicates that acetone has a high blood to air partition coefficient and will therefore dissolve in blood upon pulmonary gas exchange.

Adjustments for Animal to Human Exposure: Not applicable.

Uncertainty Factor (UF): The LOAEL of 237 was divided by a total uncertainty factor of 30.

- 3 for use of a minimal LOAEL
- 10 for human variability

- MRL = LOAEL ÷ UF = 237 ppm ÷ 30 = 8 ppm

Other Additional Studies or Pertinent Information that Lend Support: A second minimal LOAEL of 250 ppm for neurobehavioral effects (Matsushita et al. 1969b) was considered for derivation of an acute inhalation MRL. Using an uncertainty factor of 30 (3 for use of a minimal LOAEL and 10 for human variability), the resulting MRL would be 8 ppm, which is equivalent to the proposed MRL.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Intermediate

MRL Summary: There are insufficient data for derivation of an intermediate-duration inhalation MRL due to extremely high exposure levels and limitations in study design. Table A-2 indicates the breadth of the data available.

Table A-2 Summary of Relevant NOAEL and LOAEL Values Following Intermediate Duration Inhalation Exposure to Acetone

Species | Duration | NOAEL (ppm) | LOAEL (ppm) | Effect | Reference
Neurological effects
Human | 1, 3, or 7.5 hours/day, 4 days/week, 6 weeks | 1,000 | 1,250 | Significantly increased amplitude of the visual evoked response | Stewart et al. 1975
Rat (Sprague- Dawley) | 3 hours/day, 5 days/week, 8 weeks | None | 19,000 | Significant decreases in brain weight | Bruckner and Peterson 1981b
Rat (Crl:CD BR) | 6 hours/day, 5 days/week, 13 weeks | 4,000 | None | Schedule-controlled operant conditioning | Christoph et al. 2003

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

Rationale for Not Deriving an MRL: Bruckner and Peterson (1981b) only examined high-dose acetone exposure (19,000 ppm). This exposure level resulted in a serious LOAEL for significant decreases in brain weights of rats; therefore, it is not appropriate for derivation of an MRL. Christoph et al. (2003) observed that exposure of male rats to acetone vapor concentrations as high as 4,000 ppm for 6 hours/day, 5 days/week for 13 weeks did not cause lasting effects on schedule-controlled operant performance. The study authors noted that their study design was not intended to investigate the operant processes that have been associated with occupational exposures to acetone in humans (e.g., decreased digit-span retention); conclusions of the study only “serve to increase confidence that prolonged exposures within specified limits are unlikely to have enduring effects on the expression of previously well-learned behaviors” (p. 797). Therefore, other unmeasured neurological effects may have occurred at the concentrations examined and the study is not appropriate for derivation of the MRL. Stewart et al. (1975) examined adults exposed to varying durations of acetone at concentrations of 0, 200, 1,000, and 1,250 ppm. No significant neurological effects were observed, apart from increases in visual evoked response in two of four males exposed to 1,250 ppm. However, multiple studies of acute exposure suggest that acetone causes neurological effects in humans at levels around 250 ppm (Dick et al. 1989; Matsushita et al. 1969a, 1969b). Additionally, the Stewart et al. (1975) study only examined a maximum of four participants per dosage and contains poor reporting of methodology and results; it was not considered to be of sufficient quality for derivation of an MRL.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Inhalation
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic inhalation MRL.

Rationale for Not Deriving an MRL: A chronic-duration inhalation MRL was not derived for acetone because a suitable NOAEL or LOAEL for a sensitive endpoint was not sufficiently characterized. The only studies located were three epidemiological studies. Ott et al. (1983a, 1983c) observed no hematological or hepatic effects in workers exposed 5 days/week, 8 hours/day to up to 1,070 ppm for months to years. However, the study did not monitor all endpoints that are known to be sensitive endpoints of acetone exposure, such as neurological effects; other endpoints may have been affected at this exposure level. Additionally, this study has significant limitations: there was no true reference group for the acetone-exposed workers and high potential for misclassification of exposure. Two occupational studies found evidence of neurological and behavioral effects (lack of energy, general weakness, delayed visual reaction time, and headache) associated with exposures to acetone (Mitran et al. 1997; Satoh et al. 1996). Mitran et al. (1997) examined 71 workers at a coin printing factory who were exposed to TWA concentrations of acetone ranging from 416 to 980 ppm for a mean duration of 14 years. Acetone-exposed workers showed significant decreases in measures of attention and delays in tests of nerve conduction velocity and visual reaction time relative to controls. In addition to neurological effects, the workers self-reported a higher prevalence of respiratory irritation, eye irritation, and gastrointestinal symptoms relative to matched controls. Satoh et al. (1996) reported symptoms of heavy, vague, or faint feelings in the head, along with impaired neurobehavioral responses, in a group of 110 male workers at an acetate fiber manufacturing plant where acetone was used for production. Controls consisted of 67 unexposed workers at the same facility. Acetone levels at the end of the work shift measured 5-1,212 ppm in the breathing zone (mean of 361.4 ppm). It is difficult to establish a NOAEL and LOAEL for effects observed in the occupational studies by Mitran et al. (1997) and Satoh et al. (1996), as the occupational exposures observed varied widely in concentration and duration. Therefore, these studies were deemed inappropriate for derivation of an MRL for chronic inhalation exposures to acetone.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Acute

MRL Summary: There are insufficient data for derivation of an acute-duration oral MRL.

Rationale for Not Deriving an MRL: An acute-duration oral MRL was not derived for acetone because a suitable NOAEL or LOAEL for a sensitive endpoint was not sufficiently characterized. Brown and Hewitt (1984) found a renal LOAEL of 871 mg/kg/day in rats; however, this study was a one-time gavage exposure and is therefore not considered to be applicable to human exposure scenarios. Additionally, other studies failed to find renal effects in rats following 2 days of gavage exposure to 1,766 mg/kg/day acetone (Valentovic et al. 1992) or 14 days of drinking water exposure at concentrations of 8,560 mg/kg/day (Dietz et al. 1991; NTP 1991). Mice also tolerated doses up to 12,725 mg/kg/day without renal effect (Dietz et al. 1991; NTP 1991). Similarly, Ross et al. (1995) found increased liver weights in eight rats administered 90 mg/kg/day of acetone in drinking water for 14 days. However, other studies have only observed these effects at higher levels of exposure. Moreover, available evidence from epidemiological and human controlled studies suggests that acetone is not associated with hepatic endpoints in humans.

The other acute studies located showed effects above 2,241 mg/kg/day, which is a serious effect level for neurological and metabolic effects for human exposures (Gitelson et al. 1966). Therefore, these studies cannot be used as they would not be the most sensitive endpoint nor species in the current dataset.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Intermediate
MRL: | 0.6 mg/kg/day
Critical Effect: | Anemia with decreased reticulocyte count
Reference: | Dietz et al. (1991); NTP (1991)
Point of Departure: | BMDL_1SD_ of 57.0 mg/kg/day
Uncertainty Factor: | 100
LSE Graph Key: | 22
Species: | Rat

MRL Summary: The intermediate-duration oral MRL of 0.6 mg/kg/day is based on a BMDL_1SD_ of 57.0 mg/kg/day for anemia with decreased reticulocyte count in rats treated with acetone in the drinking water for 13 weeks (Dietz et al. 1991; NTP 1991). An uncertainty factor of 100 (10 for interspecies extrapolation and 10 for human variability) was applied.

Selection of the Critical Effect: Table A-3 summarizes relevant NOAEL and LOAEL values following intermediate oral exposures to acetone. The available data indicate that hematological effects are the most sensitive endpoint associated with intermediate duration oral exposure to acetone. Additionally, there is evidence of the hematological effects of acetone from human and animal studies. Hematological effects have been observed in humans exposed by inhalation to acetone (Matsushita et al. 1969a, 1969b), in rats exposed to 200 mg/kg/day in the drinking water for 14 days (Dietz et al. 1991; NTP 1991), and in rats treated by gavage with 2,500 mg/kg/day for 93-95 days (American Biogenics Corp. 1986).

Table A-3 Summary of Relevant NOAEL and LOAEL Values Following Intermediate Duration Oral Exposure to Acetone

Species | Duration | NOAEL (mg/kg/day) | LOAEL (mg/kg/day) | Effect | Reference
Neurological effects
Rat | 6 weeks | None | 650 | Decreased motor nerve conduction velocity | Ladefoged et al. 1989
Hematological effects
Rat (F344/N) | 13 weeks | 200 | 400 | Anemia with decreased reticulocyte counts | Dietz et al. 1991; NTP 1991
Rat (Crl:CD BR) | 93–95 days, 1 time/day | 500 | 2,500 | Increased hemoglobin, hematocrit, mean cell hemoglobin, mean cell volume, decreased platelets | American Biogenics Corp. 1986
Reproductive effects
Rat (F344/N) | 13 weeks | 200 | 3,400 | 11.7% decreased sperm motility | Dietz et al. 1991; NTP 1991^a^

a Dietz et al. (1991) and NTP (1991) refer to the same study.

LOAEL = lowest-observed-adverse-effect level; NOAEL = no-observed-adverse-effect level

The critical hematological effect observed by Dietz et al. (1991) and NTP (1991) is anemia with decreased reticulocyte count (Table A-3). Reticulocytes are necessary for bone marrow to regenerate in response to anemia. The absence of reticulocytes in an anemic subject indicates that the bone marrow is not regenerating in response to the anemia, a condition known as non-regenerative anemia. Dietz et al. (1991) and NTP (1991) also observed statistically significantly increased relative kidney weight in female rats, along with decreased sperm motility and increased mean corpuscular hemoglobin in male rats. However, each of these results was not consistent as doses increased. Further, Dietz et al. (1991) and NTP (1991) observed kidney nephropathy in male rats exposed to doses as low as 200 mg/kg/day, with increasing incidence and severity as doses increased up to 3,400 mg/kg/day; however, the male control group developed minimal and mild severity kidney nephropathy similar to the 200 mg/kg/day dose group, and no similar kidney nephropathy effects were observed in the female rats. American Biogenics Corp. (1986) also observed severe kidney nephropathy in male rats at doses of 500 and 2,500 mg/kg/day via oral gavage, in addition to an accentuation of hyaline droplet accumulation, with no observed kidney effects in female rats. It is widely known that male rats have a high likelihood of developing chronic progressive kidney nephropathy as a part of their natural aging process, which often confounds intermediate and chronic studies of kidney nephropathy in these animals (Hard and Khan 2004; Hard et al. 2009). The accentuation of hyaline droplet accumulation observed in the American Biogenics Corp. (1986) study is often a biomarker of one mechanism of this kidney nephropathy that is not considered relevant for extrapolation to humans, specifically pointing to α2-μglobulin induced renal pathology (ATSDR 2018). Additionally, chronic progressive nephropathy that only occurs in male rats and not female rats, as was the case in Dietz et al. (1991) and NTP (1991), is generally considered to be age-related, even if the test chemical is shown to potentially exacerbate this age-related effect (ATSDR 2018). ATSDR does not use lesions of chronic progressive nephropathy where there was no concurrent enhancement in females as endpoints in MRL derivation (ATSDR 2018).

Selection of the Principal Study: Hematological effects are considered to be a sensitive endpoint associated with acetone exposure. Of the two intermediate-duration studies identified (American Biogenics Corp. 1986; Dietz et al. 1991; NTP 1991), the study published by Dietz et al. (1991) and NTP (1991) had the lowest NOAEL and LOAEL identified.

Summary of the Principal Study:

Dietz DD, Leininger JR, Rauckman EJ, et al. 1991. Toxicity studies of acetone administered in the drinking water of rodents. Toxicol Sci 17(2):347-360. https://doi.org/10.1093/toxsci/17.2.34.

NTP. 1991. National Toxicology Program - technical report no. 3. Toxicity studies of acetone in F344/N rats and B6C3F, mice (drinking water studies). U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. NIH publication no. 91-3122.

Dietz et al. (1991) and NTP (1991) examined exposures to acetone in the drinking water of F344/N rats and B6C3F1 mice (10 males and 10 females per dose per species). In the 13-week study, rats and female mice were continuously exposed to acetone in drinking water at 0, 2,500, 5,000, 10,000, 20,000 or 50,000 ppm. Concentrations examined in male mice were 0, 1,250, 2,500, 5,000, 10,000 or 20,000 ppm of acetone. The authors calculated TWA doses (mg/kg/day) associated with each concentration.

Clinical examinations of exposed animals occurred twice daily throughout the 13-week exposure period. At the end of the exposure period, animals were sacrificed, and histopathological and hematological examinations were conducted.

No hematological effects or histologically observable lesions in hematopoietic tissues were found in male or female mice (Dietz et al. 1991; NTP 1991). In contrast to the mouse data, Dietz et al. (1991) and NTP (1991) found evidence of macrocytic anemia in male, but not female, rats exposed to acetone in drinking water for 13 weeks. This evidence consisted of significantly (p<0.05 or p<0.01) decreased hemoglobin concentration, increased mean corpuscular hemoglobin and mean corpuscular volume, decreased erythrocyte counts, decreased reticulocyte counts and platelets, and splenic hemosiderosis. The LOAEL for these effects was 400 mg/kg/day, and the NOAEL was 200 mg/kg/day. The number of affected parameters increased as the dose increased. Table A-4 displays results for the most sensitive hematological effect observed: decreased reticulocyte counts in male rats. The data were amenable to BMD modeling and were fit to the continuous models in EPA’s Benchmark Dose Modeling Software (BMDS; version 3.1.2).

Table A-4 Reticulocyte Counts in Male Rats Administered Acetone via Drinking Water for 13 Weeks (Dietz et al. 1991; NTP 1991)

Dose (mg/kg/day) | Reticulocyte count mean (10^6^/μL) | Reticulocyte count standard deviation
0 | 225 | 34.8
200 | 195 | 46.5
400 | 171a | 47.1
900 | 179b | 47.4
1,700 | 168a | 34.8
3,400 | 152a | 29.4

a p ≤0.01.

b p ≤0.05.

Selection of the Point of Departure for the MRL: BMD modeling was conducted to identify a point of departure (POD) using the data from Dietz et al. (1991) and NTP (1991) displayed in Table A-4. The data were fit to all available continuous models in EPA’s BMDS (version 3.1.2) using a benchmark response (BMR) of 10% extra risk and the default settings for the application of restrictions. Adequate model fit was judged by four criteria: chi-square goodness-of-fit p-value (p≥0.1), visual inspection of the dose-response curve, BMDL <10 times the lowest non-zero dose, and scaled residual (>-2 and <+2) at the data point (except the control) closest to the predefined BMR. Among models providing adequate fit to the data, the lowest BMDL1SD was selected as the POD when the difference between the BMDLs estimated from these models was >3 fold; otherwise, the BMDL_1SD_ from the model with the lowest Akaike’s Information Criterion (AIC) was chosen. Table A-5 presents only those BMD/BMDL values considered for MRL derivation. The MRL was based on a BMDL_1SD_ of 57.0 mg/kg/day for a decrease in reticulocytes in rats treated with acetone in the drinking water for 13 weeks (Dietz et al. 1991; NTP 1991).

Table A-5 Results from BMD Analysis of Decreased Reticulocyte Counts in Sprague-Dawley Rats After Intermediate Oral Exposure via Drinking Water for 13 Weeks (Dietz et al. 1991; NTP 1991)

Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | P Value^b^ | AIC | Scaled residuals^c^
Model | BMD_1SD_^a^ (mg/kg/day) | BMDL_1SD_^a^ (mg/kg/day) | P Value^b^ | AIC | Dose below BMD | Dose above BMD
Exponential (2-degree)^d^ | 2,422.23 | 1,495.34 | 0.12 | 621.93 | −0.20 | 1.90
Exponential (3-degree)^d^ | 2,419.46 | 1,495.34 | 0.12 | 621.93 | −0.20 | 1.90
Exponential (5-degree)^d^ | 281.18 | 119.84 | 0.48 | 619.01 | 0.16 | 0.01
Hill ^e^ ^,^ ^f^ | 263.80 | 57.02 | 0.60 | 618.41 | 0.11 | −0.21

a BMDLs <10 times the lowest non-zero dose and their corresponding BMDs are not included in this table.

b Values <0.1 fail to meet conventional χ^2^ goodness-of-fit criteria.

c Scaled residuals at doses immediately below and above the BMD; also the largest residual at any dose.

d Power restricted to ≥1.

e Slope restricted to ≥1.

f Selected model. The exponential and Hill models provided adequate fit to the data. BMDLs for models providing adequate fit differed by >3-fold; therefore, the model with the lowest BMDL1SD was selected (Hill).

AIC = Akaike Information Criterion; BMD = benchmark dose (maximum likelihood estimate of the dose associated with the selected benchmark response); BMDL1SD = 95% lower confidence limit on the BMD (subscripts denote benchmark response: i.e., 1SD = dose associated with 1 standard deviation from the mean); DF = degree of freedom

Adjustment for Intermittent Exposure: Because acetone is evenly distributed in blood after absorption, an adjustment for intermittent to continuous exposure was deemed not necessary. Henry’s law indicates that acetone has a high blood to air partition coefficient and therefore will dissolve in blood upon pulmonary gas exchange.

Uncertainty Factor (UF): The BMDL_1SD_ of 57.0 mg/kg/day was divided by a total uncertainty factor of 100.

- 10 for interspecies extrapolation
- 10 for human variability
  - MRL = BMDL_1SD_ ÷ UF = 57.0 mg/kg/day ÷ 100 = 0.6 mg/kg/day

Other Additional Studies or Pertinent Information that Lend Support to this MRL: Not applicable.

Agency Contacts (Chemical Managers): Obaid Faroon

MINIMAL RISK LEVEL (MRL) WORKSHEET

Chemical Name: | Acetone
CAS Numbers: | 67-64-1
Date: | June 2022
Profile Status: | Final
Route: | Oral
Duration: | Chronic

MRL Summary: There are insufficient data for derivation of a chronic-duration oral MRL.

Rationale for Not Deriving an MRL: A chronic-duration oral MRL was not derived for acetone because no chronic-duration oral exposure studies were identified.

Agency Contacts (Chemical Managers): Obaid Faroon